# Appendix B Literature Flow Diagram

Appendix B Figure 1 Literature Flow Diagram

* Articles may appear under more than one Key Question

Appendix B, Figure 1 shows the literature flow diagram for the systematic review