# Appendix A Detailed Methods

## Literature search strategies for primary literature

Key:

- / = MeSH subject heading
- * = truncation
- ab = word in abstract
- adj# = adjacent within # number of words
- ae = adverse effects
- bt = word in book title
- co = complications
- di = diagnosis
- fs = floating subheading
- kf = keyword heading word
- kw= keyword
- MH = MeSH Heading
- MW = floating subheading
- N# = adjacent within # number of words
- near/# = adjacent within × number of words
- NEXT = immediately adjacent
- PT = Publication type
- ti = word in title

Cochrane Central Register of Controlled Clinical Trials (CENTRAL)

Issue 8 of 12, August 2019

#1 "blood pressure":ti 12378
#2 "blood pressures":ti 100
#3 "arterial pressure":ti 350
#4 "arterial pressures":ti 6
#5 "systolic pressure":ti 48
#6 "systolic pressures":ti 1
#7 "diastolic pressure":ti 20
#8 "diastolic pressures":ti 1
#9 hypertensi*:ti 26580
#10 prehypertensi*:ti 295
#11 pre NEXT hypertensi*:ti 68
#12 sphygmomanomet*:ti 56
#13 aobp:ti 0
#14 mobp:ti 0
#15 obpm:ti 0
#16 hbpm:ti 3
#17 abpm:ti 72
#18 {#1-`#17 35871
#19 screen*:ti,ab,kw 63475
#20 monitor*:ti,ab,kw 84917
#21 diagnos*:ti,ab,kw 215515
#22 measur*:ti,ab,kw 410731
#23 determin*:ti,ab,kw 229847
#24 surveil*:ti,ab,kw 8011
#25 confirm*:ti,ab,kw 79820
#26 {or #19-#25} 749079
#27 #18 and #26 18198
#28 home:ti,ab,kw 36669
#29 office:ti,ab,kw 7125
#30 ambulatory:ti,ab,kw 19896
#31 ausculta*:ti,ab,kw 800
#32 oscillometr*:ti,ab,kw 708
#33 korotkoff:ti,ab,kw 67
#34 {or #28-#33} 61055
#35 #18 and #34 5598
#36 #27 or #35 with Publication Year from 2014 to 2019, with Cochrane Library publication date Between Jul 2018 and Dec 2019, in Trials 1987

OVID MEDLINE Indexed

Database: Ovid MEDLINE(R) <1946 to July Week 5 2019>, Ovid MEDLINE(R) Daily Update <August 07, 2019>

Search Strategy:

KQ1 Screening Trials

1. Hypertension/ (227235)
2. Essential Hypertension/ (2145)
3. Masked Hypertension/ (254)
4. White Coat Hypertension/ (374)
5. Prehypertension/ (873)
6. Blood Pressure/ (268434)
7. Arterial Pressure/ (4823)
8. hypertensi*.ti,bt. (175473)
9. prehypertensi*.ti,bt. (861)
10. arterial pressure*.ti,bt. (5335)
11. (systolic pressure* or diastolic pressure*).ti,ab,kf. (24759)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 (488330)
13. Mass Screening/ (98464)
14. screen*.ti,ab,kf. (602589)
15. 13 or 14 (630045)
16. Hypertension/di (18926)
17. Prehypertension/di (178)
18. Essential Hypertension/di (42)
19. Masked Hypertension/di (138)
20. White Coat Hypertension/di (200)
21. 16 or 17 or 18 or 19 or 20 (19223)
22. hypertensi*.ti,ab,kf. (377802)
23. prehypertensi*.ti,ab,kf. (2171)
24. pre hypertensi*.ti,ab,kf. (590)
25. arterial pressure*.ti,ab,kf. (56533)
26. blood pressure.ti,ab,kf. (265756)
27. (systolic pressure* or diastolic pressure*).ti,ab,kf. (24759)
28. 22 or 23 or 24 or 25 or 26 or 27 (586814)
29. screen*.ti,ab,kf. (602589)
30. 28 and 29 (17927)
31. limit 30 to ("in data review" or in process or “pubmed not medline”) (0)
32. 12 and 15 (10927)
33. 21 or 31 or 32 (28369)
34. Blood Pressure Determination/ (26875)
35. Sphygmomanometers/ (869)
36. Blood Pressure Monitors/ (2223)
37. ((office or clinic*) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (11817)
38. (home adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (2226)
39. ((blood pressure* or BP or hypertensi*) adj3 kiosk*).ti,ab,kf. (12)
40. ((manual or automated) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (784)
41. ((ausculta* or oscillomet* or korotkoff) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (991)
42. ((blood pressure* or BP or hypertensi*) adj1 (monitor* or measur* or surveil*)).ti,ab,kf. (21373)
43. ((blood pressure* or BP or hypertensi*) adj3 confirm*).ti,ab,kf. (1370)
44. (((hypertensi* or blood pressure* or BP) adj3 screen*) and (instrument* or method* or technique*)).ti,ab,kf. (930)
45. aobp.ti,ab,kf. (47)
46. mobp.ti,ab,kf. (89)
47. obpm.ti,ab,kf. (30)
48. hbpm.ti,ab,kf. (203)
49. Sphygmomanomet*.ti,ab,kf. (2837)
50. Blood Pressure Monitoring, Ambulatory/ (9294)
51. abpm.ti,ab,kf. (2326)
52. (ambulat* and (blood pressure* or BP or hypertensi*)).ti,ab,kf. (14367)
53. 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 (62391)
54. 33 or 53 (81694)
55. (clinical trial or controlled clinical trial or randomized controlled trial or adaptive clinical trial orequivalence trial or pragmatic clinical trial or meta analysis).pt. (914388)
56. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or adaptive clinical trials as topic/ or equivalence trials as topic/ or pragmatic clinical trials as topic/ (314705)
57. Meta-Analysis as Topic/ (17134)
58. Random allocation/ (99937)
59. control groups/ or double-blind method/ or single-blind method/ (180418)
60. clinical trial*.ti,ab,kf. (292255)
61. (control* adj3 (study or studies or trial*)).ti,ab,kf. (425239)
62. random*.ti,ab,kf. (905774)
63. 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 (1871409)
64. 54 and 63 (15136)
65. limit 64 to “all adult (19 plus years)” (11398)
66. limit 64 to “all child (0 to 18 years)” (1969)
67. 66 not 65 (585)
68. 64 not 67 (14551)
69. animals/ not (humans/ and animals/) (4573928)
70. 68 not 69 (14228)
71. limit 70 to english language (12959)
72. limit 71 to yr="2014 -Current" (3314)
73. remove duplicates from 72 (3308)
74. (201808* or 201809* or 201810* or 201811* or 201812* or 2019*).ed. (947729)
75. 73 and 74 (607)

KQ2 and KQ3 Screening Diagnostic Accuracy

1. Hypertension/ (227235)
2. Essential Hypertension/ (2145)
3. Masked Hypertension/ (254)
4. White Coat Hypertension/ (374)
5. Prehypertension/ (873)
6. Blood Pressure/ (268434)
7. Arterial Pressure/ (4823)
8. hypertensi*.ti,bt. (175473)
9. prehypertensi*.ti,bt. (861)
10. arterial pressure*.ti,bt. (5335)
11. (systolic pressure* or diastolic pressure*).ti,ab,kf. (24759)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 (488330)
13. Mass Screening/ (98464)
14. screen*.ti,ab,kf. (602589)
15. 13 or 14 (630045)
16. Hypertension/di (18926)
17. Prehypertension/di (178)
18. Essential Hypertension/di (42)
19. Masked Hypertension/di (138)
20. White Coat Hypertension/di (200)
21. 16 or 17 or 18 or 19 or 20 (19223)
22. hypertensi*.ti,ab,kf. (377802)
23. prehypertensi*.ti,ab,kf. (2171)
24. pre hypertensi*.ti,ab,kf. (590)
25. arterial pressure*.ti,ab,kf. (56533)
26. blood pressure.ti,ab,kf. (265756)
27. (systolic pressure* or diastolic pressure*).ti,ab,kf. (24759)
28. 22 or 23 or 24 or 25 or 26 or 27 (586814)
29. screen*.ti,ab,kf. (602589)
30. 28 and 29 (17927)
31. limit 30 to ("in data review" or in process or “pubmed not medline”) (0)
32. 12 and 15 (10927)
33. 21 or 31 or 32 (28369)
34. Blood Pressure Determination/ (26875)
35. Sphygmomanometers/ (869)
36. Blood Pressure Monitors/ (2223)
37. ((office or clinic*) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (11817)
38. (home adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (2226)
39. ((blood pressure* or BP or hypertensi*) adj3 kiosk*).ti,ab,kf. (12)
40. ((manual or automated) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (784)
41. ((ausculta* or oscillomet* or korotkoff) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (991)
42. ((blood pressure* or BP or hypertensi*) adj1 (monitor* or measur* or surveil*)).ti,ab,kf. (21373)
43. ((blood pressure* or BP or hypertensi*) adj3 confirm*).ti,ab,kf. (1370)
44. (((hypertensi* or blood pressure* or BP) adj3 screen*) and (instrument* or method* or technique*)).ti,ab,kf. (930)
45. aobp.ti,ab,kf. (47)
46. mobp.ti,ab,kf. (89)
47. obpm.ti,ab,kf. (30)
48. hbpm.ti,ab,kf. (203)
49. Sphygmomanomet*.ti,ab,kf. (2837)
50. 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 (55272)
51. 33 or 50 (75330)
52. Blood Pressure Monitoring, Ambulatory/ (9294)
53. abpm.ti,ab,kf. (2326)
54. (ambulat* and (blood pressure* or BP or hypertensi*)).ti,ab,kf. (14367)
55. 52 or 53 or 54 (17720)
56. "Sensitivity and Specificity"/ (337969)
57. "Predictive Value of Tests"/ (193080)
58. ROC Curve/ (53126)
59. False Negative Reactions/ (17444)
60. False Positive Reactions/ (27151)
61. Diagnostic Errors/ (36643)
62. "Reproducibility of Results"/ (379982)
63. Reference Values/ (157427)
64. Reference Standards/ (41087)
65. Observer Variation/ (40998)
66. Prevalence/ (272713)
67. Receiver operat*.ti,ab,kf. (59412)
68. ROC curve*.ti,ab,kf. (24460)
69. sensitivit*.ti,ab,kf. (668322)
70. specificit*.ti,ab,kf. (419213)
71. predictive value.ti,ab,kf. (75452)
72. accuracy.ti,ab,kf. (295343)
73. false positive*.ti,ab,kf. (50776)
74. false negative*.ti,ab,kf. (28903)
75. miss rate*.ti,ab,kf. (382)
76. error rate*.ti,ab,kf. (10497)
77. prevalence.ti,ab,kf. (501046)
78. 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 (2443663)
79. 51 and 55 and 78 (3544)
80. limit 79 to “all adult (19 plus years)” (2600)
81. limit 79 to “all child (0 to 18 years)” (572)
82. 81 not 80 (224)
83. 79 not 82 (3320)
84. animals/ not (humans/ and animals/) (4573928)
85. 83 not 84 (3309)
86. limit 85 to english language (2951)
87. limit 86 to yr="2014 -Current" (761)
88. remove duplicates from 87 (761)
89. (201808* or 201809* or 201810* or 201811* or 201812* or 2019*).ed. (947729)
90. 88 and 89 (117)

KQ4 Screening Harms

1. Hypertension/ (227235)
2. Essential Hypertension/ (2145)
3. Masked Hypertension/ (254)
4. White Coat Hypertension/ (374)
5. Prehypertension/ (873)
6. Blood Pressure/ (268434)
7. Arterial Pressure/ (4823)
8. hypertensi*.ti,bt. (175473)
9. prehypertensi*.ti,bt. (861)
10. arterial pressure*.ti,bt. (5335)
11. (systolic pressure* or diastolic pressure*).ti,ab,kf. (24759)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 (488330)
13. Mass Screening/ (98464)
14. screen*.ti,ab,kf. (602589)
15. 13 or 14 (630045)
16. Hypertension/di (18926)
17. Prehypertension/di (178)
18. Essential Hypertension/di (42)
19. Masked Hypertension/di (138)
20. White Coat Hypertension/di (200)
21. 16 or 17 or 18 or 19 or 20 (19223)
22. hypertensi*.ti,ab,kf. (377802)
23. prehypertensi*.ti,ab,kf. (2171)
24. pre hypertensi*.ti,ab,kf. (590)
25. arterial pressure*.ti,ab,kf. (56533)
26. blood pressure.ti,ab,kf. (265756)
27. (systolic pressure* or diastolic pressure*).ti,ab,kf. (24759)
28. 22 or 23 or 24 or 25 or 26 or 27 (586814)
29. screen*.ti,ab,kf. (602589)
30. 28 and 29 (17927)
31. limit 30 to ("in data review" or in process or “pubmed not medline”) (0)
32. 12 and 15 (10927)
33. 21 or 31 or 32 (28369)
34. Blood Pressure Determination/ (26875)
35. Sphygmomanometers/ (869)
36. Blood Pressure Monitors/ (2223)
37. ((office or clinic*) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (11817)
38. (home adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (2226)
39. ((blood pressure* or BP or hypertensi*) adj3 kiosk*).ti,ab,kf. (12)
40. ((manual or automated) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (784)
41. ((ausculta* or oscillometr* or korotkoff) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (987)
42. ((blood pressure* or BP or hypertensi*) adj1 (monitor* or measur* or surveil*)).ti,ab,kf. (21373)
43. ((blood pressure* or BP or hypertensi*) adj3 confirm*).ti,ab,kf. (1370)
44. (((hypertensi* or blood pressure* or BP) adj3 screen*) and (instrument* or method* or technique*)).ti,ab,kf. (930)
45. aobp.ti,ab,kf. (47)
46. mobp.ti,ab,kf. (89)
47. obpm.ti,ab,kf. (30)
48. hbpm.ti,ab,kf. (203)
49. Sphygmomanometer.ti,ab,kf. (1981)
50. Blood Pressure Monitoring, Ambulatory/ (9294)
51. abpm.ti,ab,kf. (2326)
52. (ambulat* and (blood pressure* or BP or hypertensi*)).ti,ab,kf. (14367)
53. 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 (62121)
54. "Quality of Life"/ (179329)
55. ABSENTEEISM/ (8783)
56. Sick Leave/ (5529)|
57. Sick Role/ (11307)
58. Illness Behavior/ (981)
59. ANXIETY/ (75777)
60. DEPRESSION/ (110709)
61. quality of life.ti,ab,kf. (214204)
62. self rated health.ti,ab,kf. (5570)
63. (psychological adj (distress or effect* or impact)).ti,ab,kf. (19979)
64. anxiet*.ti,ab,kf. (152104)
65. (depression or depressed or depressive).ti,ab,kf. (361412)
66. absenteeism.ti,ab,kf. (4889)
67. ((disability or sick) adj3 day*).ti,ab,kf. (1981)
68. ae.fs. (1663413)
69. (harm or harms or harmful or harmed).ti,ab,kf. (88494)
70. (adverse adj (effect* or event* or outcome* or reaction*)).ti,ab,kf. (284811)
71. complication*.ti,ab,kf. (811196)
72. 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 (3105948)
73. (33 or 53) and 72 (13382)
74. (label* adj5 (hypertensi* or prehypertensi* or “blood pressure” or “arterial pressure”)).ti,ab,kf. (373)
75. 73 or 74 (13703)
76. limit 75 to “all adult (19 plus years)” (9373)
77. limit 75 to “all child (0 to 18 years)” (2097)
78. 77 not 76 (748)
79. 75 not 78 (12955)
80. animals/ not (humans/ and animals/) (4573928)
81. 79 not 80 (12489)
82. limit 81 to english language (10794)
83. limit 82 to yr="2014 -Current" (3042)
84. remove duplicates from 83 (3039)
85. (201808* or 201809* or 201810* or 201811* or 201812* or 2019*).ed. (947729)
86. 84 and 85 (649)

MEDLINE Non Indexed

Database: Ovid MEDLINE(R) Epub Ahead of Print <August 08, 2019>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <1946 to August 07, 2019>

Search Strategy:

KQ1 Screening Trials

1. Hypertension/ (0)
2. Essential Hypertension/ (0)
3. Masked Hypertension/ (0)
4. White Coat Hypertension/ (0)
5. Prehypertension/ (0)
6. Blood Pressure/ (0)
7. Arterial Pressure/ (0)
8. hypertensi*.ti,bt. (13979)
9. prehypertensi*.ti,bt. (99)
10. arterial pressure*.ti,bt. (189)
11. (systolic pressure* or diastolic pressure*).ti,ab,kf. (1384)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 (15258)
13. Mass Screening/ (0)
14. screen*.ti,ab,kf. (97400)
15. 13 or 14 (97400)
16. Hypertension/di (0)
17. Prehypertension/di (0)
18. Essential Hypertension/di (0)
19. Masked Hypertension/di (0)
20. White Coat Hypertension/di (0)
21. 16 or 17 or 18 or 19 or 20 (0)
22. hypertensi*.ti,ab,kf. (40693)
23. prehypertensi*.ti,ab,kf. (304)
24. pre hypertensi*.ti,ab,kf. (138
25. arterial pressure*.ti,ab,kf. (3664)
26. blood pressure.ti,ab,kf. (26043)
27. (systolic pressure* or diastolic pressure*).ti,ab,kf. (1384)
28. 22 or 23 or 24 or 25 or 26 or 27 (59241)
29. screen*.ti,ab,kf. (97400)
30. 28 and 29 (3110)
31. limit 30 to ("in data review" or in process or “pubmed not medline”) (2707)
32. 12 and 15 (695)
33. 21 or 31 or 32 (2787)
34. Blood Pressure Determination/ (0)
35. Sphygmomanometers/ (0)
36. Blood Pressure Monitors/ (0)
37. ((office or clinic*) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (1560)
38. (home adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (352)
39. ((blood pressure* or BP or hypertensi*) adj3 kiosk*).ti,ab,kf. (3)
40. ((manual or automated) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (142)
41. ((ausculta* or oscillomet* or korotkoff) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (107)
42. ((blood pressure* or BP or hypertensi*) adj1 (monitor* or measur* or surveil*)).ti,ab,kf. (2569)
43. ((blood pressure* or BP or hypertensi*) adj3 confirm*).ti,ab,kf. (167)
44. (((hypertensi* or blood pressure* or BP) adj3 screen*) and (instrument* or method* or technique*)).ti,ab,kf. (182)
45. aobp.ti,ab,kf. (22)
46. mobp.ti,ab,kf. (11)
47. obpm.ti,ab,kf. (9)
48. hbpm.ti,ab,kf. (49)
49. Sphygmomanomet*.ti,ab,kf. (279)
50. Blood Pressure Monitoring, Ambulatory/ (0)
51. abpm.ti,ab,kf. (340)
52. (ambulat* and (blood pressure* or BP or hypertensi*)).ti,ab,kf. (1541)
53. 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 (4753)
54. 33 or 53 (7094)
55. (clinical trial or controlled clinical trial or randomized controlled trial or adaptive clinical trial or equivalence trial or pragmatic clinical trial or meta analysis).pt. (413)
56. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or adaptive clinical trials as topic/ or equivalence trials as topic/ or pragmatic clinical trials as topic/ (0)
57. Meta-Analysis as Topic/ (0)
58. Random allocation/ (0)
59. control groups/ or double-blind method/ or single-blind method/ (0)
60. clinical trial*.ti,ab,kf. (53205)
61. (control* adj3 (study or studies or trial*)).ti,ab,kf. (68672)
62. random*.ti,ab,kf. (161593)
63. 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 (217224)
64. 54 and 63 (1440)
65. limit 64 to “all adult (19 plus years)” (0)
66. limit 64 to “all child (0 to 18 years)” (0)
67. 66 not 65 (0)
68. 64 not 67 (1440)
69. animals/ not (humans/ and animals/) (0)
70. 68 not 69 (1440)
71. limit 70 to english language (1426)
72. limit 71 to yr="2014 -Current" (1071)
73. remove duplicates from 72 (1065)

KQ2 and KQ3 Screening Diagnostic Accuracy

1. Hypertension/ (0)
2. Essential Hypertension/ (0)
3. Masked Hypertension/ (0)
4. White Coat Hypertension/ (0)
5. Prehypertension/ (0)
6. Blood Pressure/ (0)
7. Arterial Pressure/ (0)
8. hypertensi*.ti,bt. (13979)
9. prehypertensi*.ti,bt. (99)
10. arterial pressure*.ti,bt. (189)
11. (systolic pressure* or diastolic pressure*).ti,ab,kf. (1384)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 (15258)
13. Mass Screening/ (0)
14. screen*.ti,ab,kf. (97400)
15. 13 or 14 (97400)
16. Hypertension/di (0)
17. Prehypertension/di (0)
18. Essential Hypertension/di (0)
19. Masked Hypertension/di (0)
20. White Coat Hypertension/di (0)
21. 16 or 17 or 18 or 19 or 20 (0)
22. hypertensi*.ti,ab,kf. (40693)
23. prehypertensi*.ti,ab,kf. (304)
24. pre hypertensi*.ti,ab,kf. (138)
25. arterial pressure*.ti,ab,kf. (3664)
26. blood pressure.ti,ab,kf. (26043)
27. (systolic pressure* or diastolic pressure*).ti,ab,kf. (1384)
28. 22 or 23 or 24 or 25 or 26 or 27 (59241)
29. screen*.ti,ab,kf. (97400)
30. 28 and 29 (3110)
31. limit 30 to ("in data review" or in process or “pubmed not medline”) (2707)
32. 12 and 15 (695)
33. 21 or 31 or 32 (2787)
34. Blood Pressure Determination/ (0)
35. Sphygmomanometers/ (0)
36. Blood Pressure Monitors/ (0)
37. ((office or clinic*) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (1560)
38. (home adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (352)
39. ((blood pressure* or BP or hypertensi*) adj3 kiosk*).ti,ab,kf. (3)
40. ((manual or automated) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (142)
41. ((ausculta* or oscillomet* or korotkoff) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (107)
42. ((blood pressure* or BP or hypertensi*) adj1 (monitor* or measur* or surveil*)).ti,ab,kf. (2569)
43. ((blood pressure* or BP or hypertensi*) adj3 confirm*).ti,ab,kf. (167)
44. (((hypertensi* or blood pressure* or BP) adj3 screen*) and (instrument* or method* or technique*)).ti,ab,kf. (182)
45. aobp.ti,ab,kf. (22)
46. mobp.ti,ab,kf. (11)
47. obpm.ti,ab,kf. (9)
48. hbpm.ti,ab,kf. (49)
49. Sphygmomanomet*.ti,ab,kf. (279)
50. 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 (4186)
51. 33 or 50 (6551)]
52. Blood Pressure Monitoring, Ambulatory/ (0)
53. abpm.ti,ab,kf. (340)
54. (ambulat* and (blood pressure* or BP or hypertensi*)).ti,ab,kf. (1541)
55. 52 or 53 or 54 (1578)
56. "Sensitivity and Specificity"/ (0)
57. "Predictive Value of Tests"/ (0)
58. ROC Curve/ (0)
59. False Negative Reactions/ (0)
60. False Positive Reactions/ (0)
61. Diagnostic Errors/ (0)
62. "Reproducibility of Results"/ (0)
63. Reference Values/ (0)
64. Reference Standards/ (0)
65. Observer Variation/ (0)
66. Prevalence/ (0)
67. Receiver operat*.ti,ab,kf. (12876)
68. ROC curve*.ti,ab,kf. (5325)
69. sensitivit*.ti,ab,kf. (103359)
70. specificit*.ti,ab,kf. (44604)
71. predictive value.ti,ab,kf. (10286)
72. accuracy.ti,ab,kf. (73665)
73. false positive*.ti,ab,kf. (5512)
74. false negative*.ti,ab,kf. (2794)
75. miss rate*.ti,ab,kf. (83)
76. error rate*.ti,ab,kf. (3020)
77. prevalence.ti,ab,kf. (79505)
78. 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 (274346)
79. 51 and 55 and 78 (255)
80. limit 79 to “all adult (19 plus years)” (0)
81. limit 79 to “all child (0 to 18 years)” (0)
82. 81 not 80 (0)
83. 79 not 82 (255)
84. animals/ not (humans/ and animals/) (0)
85. 83 not 84 (255)
86. limit 85 to english language (251)
87. limit 86 to yr="2014 -Current" (199)
88. remove duplicates from 87 (198)

KQ4 Screening Harms

1. Hypertension/ (0)
2. Essential Hypertension/ (0)
3. Masked Hypertension/ (0)
4. White Coat Hypertension/ (0)
5. Prehypertension/ (0)
6. Blood Pressure/ (0)
7. Arterial Pressure/ (0)
8. hypertensi*.ti,bt. (13979)
9. prehypertensi*.ti,bt. (99)
10. arterial pressure*.ti,bt. (189)
11. (systolic pressure* or diastolic pressure*).ti,ab,kf. (1384)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 (15258)
13. Mass Screening/ (0)
14. screen*.ti,ab,kf. (97400)
15. 13 or 14 (97400)
16. Hypertension/di (0)
17. Prehypertension/di (0)
18. Essential Hypertension/di (0)
19. Masked Hypertension/di (0)
20. White Coat Hypertension/di (0)
21. 16 or 17 or 18 or 19 or 20 (0)
22. hypertensi*.ti,ab,kf. (40693)
23. prehypertensi*.ti,ab,kf. (304)
24. pre hypertensi*.ti,ab,kf. (138)
25. arterial pressure*.ti,ab,kf. (3664)
26. blood pressure.ti,ab,kf. (26043)
27. (systolic pressure* or diastolic pressure*).ti,ab,kf. (1384)
28. 22 or 23 or 24 or 25 or 26 or 27 (59241)
29. screen*.ti,ab,kf. (97400)
30. 28 and 29 (3110)
31. limit 30 to ("in data review" or in process or “pubmed not medline”) (2707)
32. 12 and 15 (695)
33. 21 or 31 or 32 (2787)
34. Blood Pressure Determination/ (0)
35. Sphygmomanometers/ (0)
36. Blood Pressure Monitors/ (0)
37. ((office or clinic*) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (1560)
38. (home adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (352)
39. ((blood pressure* or BP or hypertensi*) adj3 kiosk*).ti,ab,kf. (3)
40. ((manual or automated) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (142)
41. ((ausculta* or oscillometr* or korotkoff) adj3 (blood pressure* or BP or hypertensi*)).ti,ab,kf. (107)
42. ((blood pressure* or BP or hypertensi*) adj1 (monitor* or measur* or surveil*)).ti,ab,kf. (2569)
43. ((blood pressure* or BP or hypertensi*) adj3 confirm*).ti,ab,kf. (167)
44. (((hypertensi* or blood pressure* or BP) adj3 screen*) and (instrument* or method* or technique*)).ti,ab,kf. (182)
45. aobp.ti,ab,kf. (22)
46. mobp.ti,ab,kf. (11)
47. obpm.ti,ab,kf. (9)
48. hbpm.ti,ab,kf. (49)
49. Sphygmomanometer.ti,ab,kf. (224)
50. Blood Pressure Monitoring, Ambulatory/ (0)
51. abpm.ti,ab,kf. (340)
52. (ambulat* and (blood pressure* or BP or hypertensi*)).ti,ab,kf. (1541)
53. 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 (4721)
54. "Quality of Life"/ (0)
55. ABSENTEEISM/ (0)
56. Sick Leave/ (0)
57. Sick Role/ (0)
58. Illness Behavior/ (0)
59. ANXIETY/ (0)
60. DEPRESSION/ (0)
61. quality of life.ti,ab,kf. (42992)
62. self rated health.ti,ab,kf. (997)
63. (psychological adj (distress or effect* or impact)).ti,ab,kf. (3661)
64. anxiet*.ti,ab,kf. (26684)
65. (depression or depressed or depressive).ti,ab,kf. (50781)
66. absenteeism.ti,ab,kf. (668)
67. ((disability or sick) adj3 day*).ti,ab,kf. (227)
68. ae.fs. (0)
69. (harm or harms or harmful or harmed).ti,ab,kf. (18069)
70. (adverse adj (effect* or event* or outcome* or reaction*)).ti,ab,kf. (49108)
71. complication*.ti,ab,kf. (112421)
72. 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 (264381)
73. (33 or 53) and 72 (1319)
74. (label* adj5 (hypertensi* or prehypertensi* or “blood pressure” or “arterial pressure”)).ti,ab,kf. (47)
75. 73 or 74 (1361)
76. limit 75 to “all adult (19 plus years)” (0)
77. limit 75 to “all child (0 to 18 years)” (0)
78. 77 not 76 (0)
79. 75 not 78 (1361)
80. animals/ not (humans/ and animals/) (0)
81. 79 not 80 (1361)
82. limit 81 to english language (1336)
83. limit 82 to yr="2014 -Current" (1002)
84. remove duplicates from 83 (999)

CINAHL

KQ1 Screening Trials

# | Query | Results
S81 | S77 AND S80 | 320
S80 | S78 OR S79 | 334,171
S79 | EM 2019- | 189,166
S78 | EM 201808* OR EM 201809* OR EM 201810* OR EM 201811* OR EM 201812* | 145,005
S77 | S74 AND S75 (2014-2019) Limits | 2,300
S76 | S74 AND S75 | 5,340
S75 | (MH “Meta Analysis”) OR (MH “Control Group”) OR (MH “Single-Blind Studies”) OR (MH “Double-Blind Studies”) OR (MH “Triple-Blind Studies”) OR (MH “Randomized Controlled Trials”) OR (MH “Clinical Trials”) OR (MH “Random Assignment”) OR (AB clinical n1 trial*) OR (AB controlled n1 trial*) OR (TI clinical n1 trial*) OR (TI controlled n1 trial*) OR (PT Clinical trial) OR (PT randomized controlled trial) | 411,569
S74 | S39 OR S73 | 31,555
S73 | (S40 OR S41 OR S42 OR S43 OR S44 OR S45 OR S46 OR S47 OR S48 OR S49 OR S50 OR S51 OR S52 OR S53 OR S54 OR S55 OR S56 OR S57 OR S58 OR S59 OR S60 OR S61 OR S62 OR S63 OR S64 OR S65 OR S66 OR S67 OR S68 OR S69 OR S70 OR S71 OR S72) | 23,603
S72 | AB (ambulat*) AND (blood pressure* or BP or hypertensi*) | 3,931
S71 | TI (ambulat*) AND (blood pressure* or BP or hypertensi*) | 1,622
S70 | AB abpm | 567
S69 | TI abpm | 27
S68 | (MH “Blood Pressure Monitoring, Ambulatory”) | 3,023
S67 | AB sphygmomanometer* | 603
S66 | TI sphygmomanometer* | 142
S65 | AB hbpm | 81
S64 | TI hbpm | 0
S63 | AB obpm | 12
S62 | TI obpm | 0
S61 | AB mobp | 7
S60 | TI mobp | 2
S59 | AB aobp | 25
S58 | TI aobp | 1
S57 | AB (confirm*) N3 (blood pressure* or BP or hypertensi*) | 338
S56 | TI (confirm*) N3 (blood pressure* or BP or hypertensi*) | 20
S55 | AB (monitor* or measur* or surveil*) N3 (blood pressure* or BP or hypertensi*) | 10,131
S54 | TI (monitor* or measur* or surveil*) N3 (blood pressure* or BP or hypertensi*) | 2,444
S53 | AB (ausculta* or oscillomet* or korotkoff) N3 (blood pressure* or BP or hypertensi*) | 318
S52 | TI (ausculta* or oscillomet* or korotkoff) N3 (blood pressure* or BP or hypertensi*) | 143
S51 | AB (manual or automated) N3 (blood pressure* or BP or hypertensi*) | 327
S50 | TI (manual or automated) N3 (blood pressure* or BP or hypertensi*) | 158
S49 | AB kiosk* N3 (blood pressure* or BP or hypertensi*) | 7
S48 | TI kiosk* N3 (blood pressure* or BP or hypertensi*) | 5
S47 | AB home N3 (blood pressure* or BP or hypertensi*) | 821
S46 | TI home N3 (blood pressure* or BP or hypertensi*) | 602
S45 | AB (office or clinic*) N3 (blood pressure* or BP or hypertensi*) | 3,712
S44 | TI (office or clinic*) N3 (blood pressure* or BP or hypertensi*) | 1,008
S43 | (MH “Blood Pressure Cuffs”) | 240
S42 | (MH “Blood Pressure Devices”) | 708
S41 | (MH “Sphygmomanometers”) | 539
S40 | (MH “Blood Pressure Determination”) | 8,737
S39 | S30 OR S38 | 11,286
S38 | (S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37) | 5,278
S37 | (MH “Prehypertension/DI”) | 48
S36 | (MH “Hypertension, Malignant/DI”) | 43
S35 | (MH “Hypertension, Isolated Systolic/DI”) | 7
S34 | (MH “Hypertension, Refractory/DI”) | 25
S33 | (MH “Masked Hypertension/DI”) | 45
S32 | (MH “Hypertension, White Coat/DI”) | 57
S31 | (MH “Hypertension/DI”) | 5,123
S30 | S24 AND S29 | 6,567
S29 | (S25 OR S26 OR S27 OR S28) | 158,344
S28 | AB screen* | 116,458
S27 | TI screen* | 54,032
S26 | (MH “Rescreening”) | 164
S25 | (MH “Health Screening”) | 39,820
S24 | (S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23) | 142,878
S23 | AB “diastolic pressur*” | 1,251
S22 | TI “diastolic pressur*” | 119
S21 | AB “systolic pressur*” | 1,619
S20 | TI “systolic pressur*” | 127
S19 | AB “arterial pressur*” | 6,674
S18 | TI “arterial pressur*” | 566
S17 | AB “blood pressur*” | 49,183
S16 | TI “blood pressur*” | 16,343
S15 | AB prehypertensi* OR “pre hypertensi*” | 985
S14 | TI prehypertensi* OR “pre hypertensi*” | 745
S13 | AB hypertensi* | 59,036
S12 | TI hypertensi* | 33,537
S11 | (MH “Diastolic Pressure”) | 2,154
S10 | (MH “Systolic Pressure”) | 3,242
S9 | (MH “Arterial Pressure”) | 2,588
S8 | (MH “Blood Pressure”) | 35,137
S7 | (MH “Prehypertension”) | 277
S6 | (MH “Hypertension, Malignant”) | 164
S5 | (MH “Hypertension, Isolated Systolic”) | 67
S4 | (MH “Hypertension, Refractory”) | 120
S3 | (MH “Masked Hypertension”) | 99
S2 | (MH “Hypertension, White Coat”) | 163
S1 | (MH “Hypertension”) | 48,394

KQ2 and KQ3 Screening Diagnostic Accuracy

# | Query | Results
S113 | S109 AND S112 | 49
S112 | S110 OR S111 | 334,171
S111 | EM 2019- | 189,166
S110 | EM 201808* OR EM 201809* OR EM 201810* OR EM 201811* OR EM 201812* | 145,005
S109 | S69 AND S75 AND S107 (2014-2019) Date Limits | 329
S108 | S69 AND S75 AND S107 | 814
S107 | S76 OR S77 OR S78 OR S79 OR S80 OR S81 OR S82 OR S83 OR S84 OR S85 OR S86 OR S87 OR S88 OR S89 OR S90 OR S91 OR S92 OR S93 OR S94 OR S95 OR S96 OR S97 OR S98 OR S99 OR S100 OR S101 OR S102 OR S103 OR S104 OR S105 OR S106 | 393,737
S106 | TI prevalence* | 39,219
S105 | AB “error rate*” | 1,992
S104 | TI “error rate*” | 172
S103 | AB “miss rate*” | 116
S102 | TI “miss rate*” | 37
S101 | AB “false negative*” | 3,673
S100 | TI “false negative*” | 312
S99 | AB “false positive*” | 6,927
S98 | TI “false positive*” | 937
S97 | AB accuracy | 54,807
S96 | TI accuracy | 13,448
S95 | AB “predictive value” | 17,145
S94 | TI “predictive value” | 1,948
S93 | AB specificit* | 46,490
S92 | TI specificit* | 2,215
S91 | AB sensitivit* | 88,475
S90 | TI sensitivit* | 11,791
S89 | AB “ROC curve* | 6,436
S88 | TI “ROC curve* | 117
S87 | AB “receiver operat*” | 19,418
S86 | TI “receiver operat*” | 207
S85 | (MH “Prevalence”) | 80,071
S84 | (MH “Observer Bias”) | 8,364
S83 | (MH “Reference Values”) | 20,067
S82 | (MH “Reproducibility of Results”) | 56,528
S81 | (MH “Diagnostic Errors”) | 10,025
S80 | (MH “False Positive Results”) | 5,023
S79 | (MH “False Negative Results”) | 2,780
S78 | (MH “ROC Curve”) | 23,125
S77 | (MH “Predictive Value of Tests”) | 44,521
S76 | (MH “Sensitivity and Specificity”) | 74,503
S75 | (S70 OR S71 OR S72 OR S73 OR S74) | 5,897
S74 | AB (ambulat*) AND (blood pressure* or BP or hypertensi*) | 3,931
S73 | TI (ambulat*) AND (blood pressure* or BP or hypertensi*) | 1,622
S72 | AB abpm | 567
S71 | TI abpm | 27
S70 | (MH “Blood Pressure Monitoring, Ambulatory”) | 3,023
S69 | S39 OR S68 | 29,304
S68 | S40 OR S41 OR S42 OR S43 OR S44 OR S45 OR S46 OR S47 OR S48 OR S49 OR S50 OR S51 OR S52 OR S53 OR S54 OR S55 OR S56 OR S57 OR S58 OR S59 OR S60 OR S61 OR S62 OR S63 OR S64 OR S65 OR S66 OR S67 | 21,113
S67 | AB sphygmomanometer* | 603
S66 | TI sphygmomanometer* | 142
S65 | AB hbpm | 81
S64 | TI hbpm | 0
S63 | AB obpm | 12
S62 | TI obpm | 0
S61 | AB mobp | 7
S60 | TI mobp | 2
S59 | AB aobp | 25
S58 | TI aobp | 1
S57 | AB (confirm*) N3 (blood pressure* or BP or hypertensi*) | 338
S56 | TI (confirm*) N3 (blood pressure* or BP or hypertensi*) | 20
S55 | AB (monitor* or measur* or surveil*) N3 (blood pressure* or BP or hypertensi*) | 10,131
S54 | TI (monitor* or measur* or surveil*) N3 (blood pressure* or BP or hypertensi*) | 2,444
S53 | AB (ausculta* or oscillomet* or korotkoff) N3 (blood pressure* or BP or hypertensi*) | 318
S52 | TI (ausculta* or oscillomet* or korotkoff) N3 (blood pressure* or BP or hypertensi*) | 143
S51 | AB (manual or automated) N3 (blood pressure* or BP or hypertensi*) | 327
S50 | TI (manual or automated) N3 (blood pressure* or BP or hypertensi*) | 158
S49 | AB kiosk* N3 (blood pressure* or BP or hypertensi*) | 7
S48 | TI kiosk* N3 (blood pressure* or BP or hypertensi*) | 5
S47 | AB home N3 (blood pressure* or BP or hypertensi*) | 821
S46 | TI home N3 (blood pressure* or BP or hypertensi*) | 602
S45 | AB (office or clinic*) N3 (blood pressure* or BP or hypertensi*) | 3,712
S44 | TI (office or clinic*) N3 (blood pressure* or BP or hypertensi*) | 1,008
S43 | (MH “Blood Pressure Cuffs”) | 240
S42 | (MH “Blood Pressure Devices”) | 708
S41 | (MH “Sphygmomanometers”) | 539
S40 | (MH “Blood Pressure Determination”) | 8,737
S39 | S30 OR S38 | 11,286
S38 | (S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37) | 5,278
S37 | (MH “Prehypertension/DI”) | 48
S36 | (MH “Hypertension, Malignant/DI”) | 43
S35 | (MH “Hypertension, Isolated Systolic/DI”) | 7
S34 | (MH “Hypertension, Refractory/DI”) | 25
S33 | (MH “Masked Hypertension/DI”) | 45
S32 | (MH “Hypertension, White Coat/DI”) | 57
S31 | (MH “Hypertension/DI”) | 5,123
S30 | S24 AND S29 | 6,567
S29 | (S25 OR S26 OR S27 OR S28) | 158,344
S28 | AB screen* | 116,458
S27 | TI screen* | 54,032
S26 | (MH “Rescreening”) | 164
S25 | (MH “Health Screening”) | 39,820
S24 | (S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23) | 142,878
S23 | AB “diastolic pressur*” | 1,251
S22 | TI “diastolic pressur*” | 119
S21 | AB “systolic pressur*” | 1,619
S20 | TI “systolic pressur*” | 127
S19 | AB “arterial pressur*” | 6,674
S18 | TI “arterial pressur*” | 566
S17 | AB “blood pressur*” | 49,183
S16 | TI “blood pressur*” | 16,343
S15 | AB prehypertensi* OR “pre hypertensi*” | 985
S14 | TI prehypertensi* OR “pre hypertensi*” | 745
S13 | AB hypertensi* | 59,036
S12 | TI hypertensi* | 33,537
S11 | (MH “Diastolic Pressure”) | 2,154
S10 | (MH “Systolic Pressure”) | 3,242
S9 | (MH “Arterial Pressure”) | 2,588
S8 | (MH “Blood Pressure”) | 35,137
S7 | (MH “Prehypertension”) | 277
S6 | (MH “Hypertension, Malignant”) | 164
S5 | (MH “Hypertension, Isolated Systolic”) | 67
S4 | (MH “Hypertension, Refractory”) | 120
S3 | (MH “Masked Hypertension”) | 99
S2 | (MH “Hypertension, White Coat”) | 163
S1 | (MH “Hypertension”) | 48,394

KQ4 Screening Harms

# | Query | Results
S113 | S109 AND S112 | 655
S112 | S110 OR S111 | 334,171
S111 | EM 2019- | 189,166
S110 | EM 201808* OR EM 201809* OR EM 201810* OR EM 201811* OR EM 201812* | 145,005
S109 | S104 OR S107 (2014-2019) Date Limits | 4,116
S108 | S104 OR S107 | 9,941
S107 | S105 OR S106 | 124
S106 | AB label* N5 (hypertensi* or prehypertensi* or “blood pressure*” or arterial pressure*) | 87
S105 | TI label* N5 (hypertensi* or prehypertensi* or “blood pressure*” or arterial pressure*) | 47
S104 | S74 AND S103 | 9,842
S103 | S75 OR S76 OR S77 OR S78 OR S79 OR S80 OR S81 OR S82 OR S83 OR S84 OR S85 OR S86 OR S87 OR S88 OR S89 OR S90 OR S91 OR S92 OR S93 OR S94 OR S95 OR S96 OR S97 OR S98 OR S99 OR S100 OR S101 OR S102 | 1,149,243
S102 | MW “co” | 366,860
S101 | MW “ae” | 388,056
S100 | AB complication* | 141,245
S99 | TI complication* | 26,848
S98 | AB adverse N1 (effect* or event* or outcome* or reaction*) | 94,680
S97 | TI adverse N1 (effect* or event* or outcome* or reaction*) | 14,220
S96 | AB harm or harms or harmful or harmed | 30,895
S95 | TI harm or harms or harmful or harmed | 8,617
S94 | AB (disability or sick) N3 day* | 942
S93 | TI (disability or sick) N3 day* | 149
S92 | AB absenteeism | 2,057
S91 | TI absenteeism | 652
S90 | AB depression or depressed or depressive | 102,422
S89 | TI depression or depressed or depressive | 53,992
S88 | AB anxiet* | 57,813
S87 | TI anxiet* | 19,688
S86 | AB psychological* N2 (distress* or effect* or impact*) | 13,224
S85 | TI psychological* N2 (distress* or effect* or impact*) | 4,087
S84 | AB “self rated health” | 3,413
S83 | TI “self rated health” | 1,331
S82 | AB “quality of life” | 89,814
S81 | TI “quality of life” | 34,317
S80 | (MH “Depression”) | 93,775
S79 | (MH “Anxiety”) | 36,604
S78 | (MH “Sick Role”) | 1,255
S77 | (MH “Sick Leave”) | 4,363
S76 | (MH “Absenteeism”) | 4,140
S75 | (MH “Quality of Life”) | 96,318
S74 | S39 OR S73 | 31,555
S73 | (S40 OR S41 OR S42 OR S43 OR S44 OR S45 OR S46 OR S47 OR S48 OR S49 OR S50 OR S51 OR S52 OR S53 OR S54 OR S55 OR S56 OR S57 OR S58 OR S59 OR S60 OR S61 OR S62 OR S63 OR S64 OR S65 OR S66 OR S67 OR S68 OR S69 OR S70 OR S71 OR S72) | 23,603
S72 | AB (ambulat*) AND (blood pressure* or BP or hypertensi*) | 3,931
S71 | TI (ambulat*) AND (blood pressure* or BP or hypertensi*) | 1,622
S70 | AB abpm | 567
S69 | TI abpm | 27
S68 | (MH “Blood Pressure Monitoring, Ambulatory”) | 3,023
S67 | AB sphygmomanometer* | 603
S66 | TI sphygmomanometer* | 142
S65 | AB hbpm | 81
S64 | TI hbpm | 0
S63 | AB obpm | 12
S62 | TI obpm | 0
S61 | AB mobp | 7
S60 | TI mobp | 2
S59 | AB aobp | 25
S58 | TI aobp | 1
S57 | AB (confirm*) N3 (blood pressure* or BP or hypertensi*) | 338
S56 | TI (confirm*) N3 (blood pressure* or BP or hypertensi*) | 20
S55 | AB (monitor* or measur* or surveil*) N3 (blood pressure* or BP or hypertensi*) | 10,131
S54 | TI (monitor* or measur* or surveil*) N3 (blood pressure* or BP or hypertensi*) | 2,444
S53 | AB (ausculta* or oscillomet* or korotkoff) N3 (blood pressure* or BP or hypertensi*) | 318
S52 | TI (ausculta* or oscillomet* or korotkoff) N3 (blood pressure* or BP or hypertensi*) | 143
S51 | AB (manual or automated) N3 (blood pressure* or BP or hypertensi*) | 327
S50 | TI (manual or automated) N3 (blood pressure* or BP or hypertensi*) | 158
S49 | AB kiosk* N3 (blood pressure* or BP or hypertensi*) | 7
S48 | TI kiosk* N3 (blood pressure* or BP or hypertensi*) | 5
S47 | AB home N3 (blood pressure* or BP or hypertensi*) | 821
S46 | TI home N3 (blood pressure* or BP or hypertensi*) | 602
S45 | AB (office or clinic*) N3 (blood pressure* or BP or hypertensi*) | 3,712
S44 | TI (office or clinic*) N3 (blood pressure* or BP or hypertensi*) | 1,008
S43 | (MH “Blood Pressure Cuffs”) | 240
S42 | (MH “Blood Pressure Devices”) | 708
S41 | (MH “Sphygmomanometers”) | 539
S40 | (MH “Blood Pressure Determination”) | 8,737
S39 | S30 OR S38 | 11,286
S38 | (S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37) | 5,278
S37 | (MH “Prehypertension/DI”) | 48
S36 | (MH “Hypertension, Malignant/DI”) | 43
S35 | (MH “Hypertension, Isolated Systolic/DI”) | 7
S34 | (MH “Hypertension, Refractory/DI”) | 25
S33 | (MH “Masked Hypertension/DI”) | 45
S32 | (MH “Hypertension, White Coat/DI”) | 57
S31 | (MH “Hypertension/DI”) | 5,123
S30 | S24 AND S29 | 6,567
S29 | (S25 OR S26 OR S27 OR S28) | 158,344
S28 | AB screen* | 116,458
S27 | TI screen* | 54,032
S26 | (MH “Rescreening”) | 164
S25 | (MH “Health Screening”) | 39,820
S24 | (S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23) | 142,878
S23 | AB “diastolic pressur*” | 1,251
S22 | TI “diastolic pressur*” | 119
S21 | AB “systolic pressur*” | 1,619
S20 | TI “systolic pressur*” | 127
S19 | AB “arterial pressur*” | 6,674
S18 | TI “arterial pressur*” | 566
S17 | AB “blood pressur*” | 49,183
S16 | TI “blood pressur*” | 16,343
S15 | AB prehypertensi* OR “pre hypertensi*” | 985
S14 | TI prehypertensi* OR “pre hypertensi*” | 745
S13 | AB hypertensi* | 59,036
S12 | TI hypertensi* | 33,537
S11 | (MH “Diastolic Pressure”) | 2,154
S10 | (MH “Systolic Pressure”) | 3,242
S9 | (MH “Arterial Pressure”) | 2,588
S8 | (MH “Blood Pressure”) | 35,137
S7 | (MH “Prehypertension”) | 277
S6 | (MH “Hypertension, Malignant”) | 164
S5 | (MH “Hypertension, Isolated Systolic”) | 67
S4 | (MH “Hypertension, Refractory”) | 120
S3 | (MH “Masked Hypertension”) | 99
S2 | (MH “Hypertension, White Coat”) | 163
S1 | (MH “Hypertension”) | 48,394

PUBMED, publisher-supplied

Search | Query
[underlined: #12] | Search #10 AND #11
[underlined: #11] | Search (“2014”[Date - Publication] : “3000”[Date - Publication])
[underlined: #10] | Search #8 AND #9
[underlined: #9] | Search English [Language]
[underlined: #8] | Search #6 AND #7
[underlined: #7] | Search publisher[sb]
[underlined: #6] | Search #3 OR #5
[underlined: #5] | Search #1 AND #4
[underlined: #4] | Search home[tiab] OR office[tiab] OR ambulatory[tiab] OR clinic[tiab] OR ausculta*[tiab] OR oscillometr*[tiab] OR korotkoff[tiab] OR sphygmomanomet*[tiab] OR aobp[tiab] OR mobp[tiab] OR obpm[tiab] OR hbpm[tiab] OR abpm[tiab]
[underlined: #3] | Search #1 AND #2
[underlined: #2] | Search screen*[tiab] OR monitor*[tiab] OR diagnos*[tiab] OR measur*[tiab] OR determin*[tiab] or surveil*[tiab]
[underlined: #1] | Search “blood pressure”[ti] OR “blood pressures”[ti] OR “arterial pressure”[ti] “arterial pressures”[ti] OR “systolic pressure”[ti] OR “systolic pressures”[ti] OR hypertensi*[ti] OR prehypertens*[ti] OR “pre hypertension”[ti] OR “pre hypertensive”[ti] OR “pre-hypertensive”[ti]

## Targeted search of previous bibliographic database for diabetes

Field | Parameter(s) | Results
Title, Abstract OR Keyword | *Diabet | 3459

* Asterisk indicates truncation of search term

## Methods for quality assessment

For studies of test accuracy, good-quality studies had a low risk of bias on all four domains for critical appraisal which are further described below: patient selection, conduct or interpretation of the index text, conduct or interpretation of the reference standard, and patient flow and timing. Fair-quality studies did not meet these criteria but did not have serious threats to their internal validity related to the design, execution, or reporting of the study. Studies rated as poor quality had several important limitations across domains or one fatal flaw and were excluded from this review.

- Patient selection domain: Low risk of bias for patient selection was characterized by population-based, consecutive, or random selection of participants, the avoidance of inappropriate exclusions, and study designs that did not involve a volunteer subset from a larger trial. We recognize that studies may exclude patients with high clinic BPs (e.g., SBPs of >160 mm Hg or >170 mm Hg) because of safety concerns. Although it is unlikely that these patients would go through a confirmation step prior to treatment based on current practice guidelines, patient selection that limits inclusion based on high blood pressure will understate diagnostic accuracy. We established a priori that such studies have at least a medium risk of bias for the patient selection domain. Studies involving volunteer subsets where only those accepting ABPM from a larger study were not considered a fatal flaw but were rated as high risk of bias in the patient selection domain because of uncertainty around whether populations accepting versus declining ABPM may have differed.
- Conduct or interpretation of index test: Screening tests with a low risk of bias had well described protocols that were applied universally. Ideally, studies reported that the blood pressure measurement devices met validation criteria and were calibrated but this was not a requirement for a low risk of bias rating. Studies with unclear or sparse reporting of index test protocols were downgraded to medium or high risk of bias.
- Conduct or interpretation of the reference standard: We established a priori that generally, the ABPM reference test will have low risk of bias because it is automated with a computer algorithm. However, for KQ2, we considered it a fatal flaw if the ABPM reference standard was not independent of OBPM (e.g., an ABPM diagnostic threshold based upon on the upper 95% confidence interval for OBPM). For KQ3 where the comparison might be partial versus full 24-h ABPM and the index test and reference standard are part of the same test, low risk of bias could be achieved if the partial test was defined a priori and applied universally. This domain was down-graded to medium or high risk of bias based on issues of no reported criteria for completeness of ABPM, or unclear or problematic fidelity of reference standard conduct.
- Patient flow and timing: Per inclusion criteria, all participants had the same reference standard. Ideally, the screening test and reference standard were conducted on the same day, but an interval of less than 3 months was still considered low risk of bias. An interval of 3-6 months was considered reasonable with the biggest changes that can happen during this period likely being new chronic medications and weight changes. If the interval between tests was not explicitly reported, this was not considered a fatal flaw. Studies were downgraded on this domain for unknown or problematic exclusions for incomplete ABPM readings.

Appendix A Table 1 Search Terms Used in Title, Abstract, or Keyword Fields of Endnote for Prescreening

Search Terms in Title, Abstract or Keyword Fields
Animal; Braz^*^; Chin *; India^*^; Iran^*^; Mexic^*^; Turk^*^; Adoles *; Child *; Infant^*^; Mice^*^; Rats; Neonat^*^; Preg *; Rheum^*^; Arthrit^*^; Cancer^*^; Hepati^*^; HIV^*^; Infect^*^; Transplant *; Dialysis; Niger^*^; Peru^*^; Russ^*^; South Africa^*^; Allele; Polymorphism

* Asterisk indicates truncation of search term

Appendix A Table 2 Inclusion and Exclusion Criteria

Category | Included | Excluded
Aim | KQs 1, 2, 4: Screening for hypertension in a primary care setting; KQ 3: Measuring blood pressure to confirm diagnosis of hypertension | Studies measuring blood pressure for reasons other than screening or confirmation of a hypertension diagnosis; mathematical transformation of blood pressure results (e.g., pulse pressure, variability) or diurnal variations (e.g., morning surge, dipping) for use as additional diagnostic criteria, predicting risk, or both
Population | KQs 1, 2, 4: Adults age ≥18 years; KQ 3: Adults age ≥18 years with at least one elevated blood pressure measurement (as defined by study) identified by clinic-based screening | - Pregnant women, children (age <18 years), inpatients, persons in institutions, patients with secondary hypertension, and highly selected groups of patients (e.g., those with chronic kidney disease or renal transplant) who do not represent a primary screening population; - Patients treated for hypertension with medication
Intervention | KQs 1, 2, 4: Clinic-based, noninvasive brachial blood pressure measurement (manual or automated) using any common device or screening protocol during a single encounter; KQ 3: Any clinic-based or out-of-office noninvasive blood pressure measurement used to confirm an initial elevated blood pressure result (i.e., manual or automated office-based blood pressure, home blood pressure, or kiosk blood pressure measurement); KQ 3a: ABPM screening protocol that differs from the comparator ABPM protocol (e.g., 12- vs. 24-hour ABPM, daytime vs. nighttime ABPM) | Blood pressure measurement with wrist and finger monitors, forearm cuffs, or ankle and toe measures; any method not commonly used in routine blood pressure screening (e.g., invasive methods, noninvasive method of central blood pressure measurement); Osler’s maneuver
Comparator | KQs 1, 4: No blood pressure measurement; KQs 2, 3: ABPM (any protocol) | KQs 2, 3: Within-class comparative effectiveness of devices (e.g., automated vs. automated; random zero vs. standard sphygmomanometer) with identical screening protocols; validation and accuracy studies of devices compared with standards or using specific protocols (e.g., British Hypertension Society, Association for the Advancement of Medical Instrumentation)
Outcomes | KQ 1:; - Mortality (all-cause and cardiovascular); - Cardiovascular disease events, including: myocardial infarction, sudden cardiac death, stroke, heart failure, and hospitalization for coronary heart disease; - End-stage renal disease (i.e., kidney disease requiring dialysis); - Quality of life; KQs 2, 3: Sensitivity, specificity, and positive and negative predictive values; KQ 4: Harms of screening (e.g., labeling, absenteeism, quality of life measures, tolerability of ABPM devices) | KQs 1, 3: Cardiovascular symptoms (e.g., palpitations), angina pectoris (chest pain), revascularization, carotid intima-media thickness, left ventricular hypertrophy, or patient satisfaction; KQs 2, 3: Studies that do not provide enough data to create 2×2 tables or to calculate sensitivity and specificity; studies designed to assess specific devices vs. blood pressure measurement standards
Timing of outcome assessment | No restrictions | No restrictions
Setting | KQs 1, 2, 4: Eligible primary care settings must have personnel trained in blood pressure measurement, established blood pressure measurement protocols, and ongoing documentation procedures; KQ 3: Primary care settings (see above for definition) and out-of-office settings (e.g., home, pharmacy, kiosks in other settings) | All KQs: Inpatient/residential facilities; KQs 1, 2, 4: Settings not generalizable to primary care
Study design | KQ 1: RCTs and CCTs; KQs 2, 3: Diagnostic accuracy studies, RCTs, and CCTs; KQ 4: RCTs, CCTs, and cohort studies | All KQs: Before-after studies, time series, case series, case reports, case-control studies, and simulation studies; KQ 3: Studies with a sample size <100; KQ 4: Cross-sectional studies
Country | Studies conducted in countries categorized as “very high” on the 2015 Human Development Index (as defined by the United Nations Development Programme) | Studies conducted in countries not categorized as “very high” on the 2015 Human Development Index
Language | English | Other languages than English
Study quality | Fair or good | Poor, according to design-specific USPSTF criteria

Abbreviations: ABPM = ambulatory blood pressure measurement; CCT = controlled clinical trial; RCT = randomized, controlled trial; vs = versus

Appendix A Table 3 Study-Design Quality Rating Criteria

Study Design | Adapted Quality Criteria
Cohort studies, adapted from Newcastle-Ottawa Scale^76^ | Bias arising in randomization process or due to confounding; - Balance in baseline characteristics; - No baseline confounding; - No time-varying confounding; Bias in selecting participants into the study; - No evidence of biased selection of sample; - Start of followup and start of intervention coincide; Bias due to departures form intended interventions; - Participant intervention status is clearly and explicitly defined and measured; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome; Bias in classifying interventions; - Fidelity to intervention protocol; - Participants were analyzed as originally allocated; Bias from missing data; - Outcome data are reasonably complete and comparable between groups; - Confounding variables that are controlled for in analysis are reasonably complete; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported
Diagnostic accuracy studies, adapted from the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) I^77^ and II^78^ instrument | Patient Selection; - Was a consecutive or random sample of patients enrolled?; - Did the study avoid inappropriate exclusions?; Index Test; - Were the index test results interpreted without knowledge of the reference standard results?; - If a threshold was used, was it prespecified or was a range of values presented?; Reference Standard; - Is the reference standard likely to correctly classify the target condition?; - Were the reference standard results interpreted without knowledge of the index test?; - Were staff trained in the use of the reference standard?; - Was fidelity of the reference standard monitored or reported?; Flow and Timing; - Was there an appropriate interval between the index test and reference standard?; - Did all patients receive a reference standard?; - Did all patients receive the same reference standard?; ○ Were all patients included in the analysis?
Randomized clinical trials adapted from U.S. Preventive Services Task Force Manual^75^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.

Appendix A Table 4 Determination of Pooling Boundaries for Diagnostic Thresholds Within 0.5 Standard Deviation

Modality | Mean | SD | 0.5 SD | Preferred Threshold, mm Hg | Preferred Threshold - 0.5 SD | Preferred Threshold + 0.5 SD
OBPM SBP | 128.8 | 21.6 | 10.8 | 140 | 129.2 | 150.8
OBPM DBP | 78.6 | 11.3 | 5.65 | 90 | 84.35 | 95.65
24-h ABPM SBP | 122.1 | 13.6 | 6.8 | 130 | 123.2 | 136.8
24-h ABPM DBP | 73.1 | 8.2 | 4.1 | 80 | 75.9 | 84.1
Daytime ABPM SBP | 128.5 | 14.5 | 7.25 | 135 | 127.75 | 142.25
Daytime ABPM DBP | 78.3 | 8.9 | 4.45 | 85 | 80.55 | 89.45

Abbreviations: ABPM = ambulatory blood pressure monitoring; DBP = diastolic blood pressure; OBPM = office-based blood pressure measurement; SBP = systolic blood pressure; SD = standard deviation