# References

1 Siu AL, US Preventive Services Task Force. Behavioral and pharmacotherapy interventions for tobacco smoking cessation in adults, including pregnant women: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2015;163(8):622–34. PMID: 26389730. 10.7326/M15-2023 26389730
2 U.S. Food and Drug Administration. FDA’s Deeming Regulations for E-Cigarettes, Cigars, and All Other Tobacco Products. https://www.fda.gov/tobacco-products/rules-regulations-and-guidance/fdas-deeming-regulations-e-cigarettes-cigars-and-all-other-tobacco-products#rule. Accessed: 2019.
3 U.S. Food and Drug Administration. Final Rule: Deeming Tobacco Products To Be Subject to the Federal Food, Drug, and Cosmetic Act, as Amended by the Family Smoking Prevention and Tobacco Control Act; Restrictions on the Sale and Distribution of Tobacco Products and Required Warning Statements for Tobacco Products. Silver Srping, MD: Office of Regulations, Center for Tobacco Products, Food and Drug Administration, HHS; 2016.
4 Goniewicz ML, Kuma T, Gawron M, . Nicotine levels in electronic cigarettes. Nicotine Tob Res. 2013;15(1):158–66. PMID: 22529223. 10.1093/ntr/nts103 22529223
5 National Academies of Sciences, Engineering, and Medicine. Public Health Consequences of E-Cigarettes. Washington, DC: The National Academies Press; 2018.
6 Cohen G, Mehoudar P, Carbonara C, . Acute use of nicotine salt-based ends and combusted cigarettes. Presented at: 24th Annual Society for Research on Nicotine and Tobacco (SRNT). February 24, 2018; Baltimore, MD. 2018.
7 Jackler RK, Ramamurthi D. Nicotine arms race: JUUL and the high-nicotine product market. Tob Control. 2019;28(6):623–628. PMID: 30733312. 10.1136/tobaccocontrol-2018-054796 30733312
8 Huang J, Duan Z, Kwok J, . Vaping versus JUULing: how the extraordinary growth and marketing of JUUL transformed the US retail e-cigarette market. Tob Control. 2019;28(2):146–151. PMID: 29853561. 10.1136/tobaccocontrol-2018-054382 29853561
9 Etter JF, Bullen C, Flouris AD, . Electronic nicotine delivery systems: a research agenda. Tob Control. 2011;20(3):243–8. PMID: 21415064. 10.1136/tc.2010.042168 21415064
10 Cameron JM, Howell DN, White JR, . Variable and potentially fatal amounts of nicotine in e-cigarette nicotine solutions. Tob Control. 2014;23(1):77–8. PMID: 23407110. 10.1136/tobaccocontrol-2012-050604 23407110
11 Trehy ML, Ye W, Hadwiger ME, . Analysis of electronic cigarette cartridges, refill solutions, and smoke for nicotine and nicotine related impurities. J Liquid Chromatogr Rel Technol. 2011;34(14):1442–58. 10.1080/10826076.2011.572213
12 Davis B, Dang M, Kim J, . Nicotine concentrations in electronic cigarette refill and do-it-yourself fluids. Nicotine Tob Res. 2015;17(2):134–41. PMID: 24862971. 10.1093/ntr/ntu080 24862971
13 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Fifth Edition (DSM-5). Arlington, VA: American Psychiatric Association; 2013.
14 U.S. Department of Health and Human Services. Smoking Cessation: A Report of the Surgeon General. Atlanta, GA: Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health; 2020.
15 U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, . The Health Consequences of Smoking: 50 Years of Progress. A Report of the Surgeon General. Atlanta, GA: 2014.
16 Office on Smoking and Health. Women and Smoking: A Report of the Surgeon General. Atlanta, GA: 2001.
17 Office on Smoking and Health. How Tobacco Smoke Causes Disease: The Biology and Behavioral Basis for Smoking-Attributable Disease: A Report of the Surgeon General. Atlanta, GA: 2010.
18 World Health Organization. WHO Recommendations for the prevention and management of tobacco use and second-hand smoke exposure in pregnancy. Geneva, Switzerland: 2013.
19 Cornelius ME, Wang TW, Jamal A, . Tobacco product use among adults - United States, 2019. MMWR Morb Mortal Wkly Rep. 2020;69(46):1736–42. PMID: 33211681. 10.15585/mmwr.mm6946a4 33211681
20 Obisesan OH, Osei AD, Uddin SMI, . Trends in e-cigarette use in adults in the United States, 2016–2018. JAMA Intern Med. 2020;180(10):1394–8. PMID: 32897288. 10.1001/jamainternmed.2020.2817 32897288
21 Cullen KA, Ambrose BK, Gentzke AS, . Notes from the field: use of electronic cigarettes and any tobacco product among middle and high school students - United States, 2011–2018. MMWR Morb Mortal Wkly Rep. 2018;67(45):1276–7. PMID: 30439875. 10.15585/mmwr.mm6745a5 30439875
22 Dai H, Leventhal A. Prevalence of e-cigarette use among adults in the United States, 2014–2018. JAMA. 2019;322(18):1824–7. PMID: 31524940. 10.1001/jama.2019.15331 31524940
23 Drake P, Driscoll AK, Mathews TJ. Cigarette smoking during pregnancy: United States, 2016. NCHS Data Brief. 2018(305):1–8. PMID: 29528282.29528282
24 Liu B, Xu G, Rong S, . National estimates of e-cigarette use among pregnant and nonpregnant women of reproductive age in the United States, 2014–2017. JAMA Pediatr. 2019;173(6):600–602. PMID: 31034001. 10.1001/jamapediatrics.2019.0658 31034001
25 Obisesan OH, Osei AD, Uddin SMI, . E-cigarette use patterns and high-risk behaviors in pregnancy: Behavioral Risk Factor Surveillance System, 2016–2018. Am J Prev Med. 2020;59(2):187–195. PMID: 32362509. 10.1016/j.amepre.2020.02.015 32362509
26 DiFranza JR, Savageau JA, Rigotti NA, . Development of symptoms of tobacco dependence in youths: 30 month follow up data from the DANDY study. Tob Control. 2002;11(3):228–35. PMID: 12198274. 10.1136/tc.11.3.228 12198274
27 Colby SM, Tiffany ST, Shiffman S, . Are adolescent smokers dependent on nicotine? A review of the evidence. Drug Alcohol Depend. 2000;59 Suppl 1:S83–95. PMID: 10773439. 10.1016/s0376-8716(99)00166-0 10773439
28 Fiore MC, Jaen CR, Baker TB. Treating Tobacco Use and Dependence: 2008 Update (Clinical Practice Guideline). Respir Care. 2008;53(9):1217–22.18807274
29 Babb S, Malarcher A, Schauer G, . Quitting smoking among adults - United States, 2000–2015. MMWR Morb Mortal Wkly Rep. 2017;65(52):1457–64. PMID: 28056007. 10.15585/mmwr.mm6552a1 28056007
30 Hughes JR, Solomon LJ, Naud S, . Natural history of attempts to stop smoking. Nicotine Tob Res. 2014;16(9):1190–8. PMID: 24719491. 10.1093/ntr/ntu052 24719491
31 Garcia-Rodriguez O, Secades-Villa R, Florez-Salamanca L, . Probability and predictors of relapse to smoking: results of the National Epidemiologic Survey on Alcohol and Related Conditions (NESARC). Drug Alcohol Depend. 2013;132(3):479–85. PMID: 23570817. 10.1016/j.drugalcdep.2013.03.008 23570817
32 U.S. Food and Drug Administration. Smoking Cessation Products to Help You Quit. U S Department of Health and Human Services [serial on the Internet].
33 Herman AI, Sofuoglu M. Comparison of available treatments for tobacco addiction. Curr Psychiatry Rep. 2010;12(5):433–40. PMID: 20623259. 10.1007/s11920-010-0134-6 20623259
34 Tutka P, Zatonski W. Cytisine for the treatment of nicotine addiction: from a molecule to therapeutic efficacy. Pharmacol Rep. 2006;58(6):777–98. PMID: 17220536.17220536
35 Prochaska JJ, Das S, Benowitz NL. Cytisine, the world’s oldest smoking cessation aid. BMJ. 2013;347:f5198. PMID: 23974638. 10.1136/bmj.f5198 23974638
36 World Health Organization. Marketers of electronic cigarettes should halt unproved therapy claims. http://www.who.int/mediacentre/news/releases/2008/pr34/en/.
37 Caponnetto P, Russo C, Bruno CM, . Electronic cigarette: a possible substitute for cigarette dependence. Monaldi Arch Chest Dis. 2013;79(1):12–9. PMID: 23741941. 10.4081/monaldi.2013.104 23741941
38 Wagener TL, Siegel M, Borrelli B. Electronic cigarettes: achieving a balanced perspective. Addiction. 2012;107(9):1545–8. PMID: 22471757. 10.1111/j.1360-0443.2012.03826.x 22471757
39 Abrams DB. Promise and peril of e-cigarettes: can disruptive technology make cigarettes obsolete? JAMA. 2014;311(2):135–6. PMID: 24399548. 10.1001/jama.2013.285347 24399548
40 Callahan-Lyon P. Electronic cigarettes: human health effects. Tob Control. 2014;23 Suppl 2:ii36–ii40. PMID: 24732161. 10.1136/tobaccocontrol-2013-051470 24732161
41 Chen IL, Husten CG. Introduction to tobacco control supplement. Tob Control. 2014;23 Suppl 2:ii1–ii3. PMID: 24732156. 10.1136/tobaccocontrol-2013-051504 24732156
42 Goniewicz ML, Knysak J, Gawron M, . Levels of selected carcinogens and toxicants in vapour from electronic cigarettes. Tob Control. 2014;23(2):133–9. PMID: 23467656. 10.1136/tobaccocontrol-2012-050859 23467656
43 Bhatnagar A, Whitsel LP, Ribisl KM, . Electronic cigarettes: a policy statement from the American Heart Association. Circulation. 2014;130(16):1418–36. PMID: 25156991. 10.1161/CIR.0000000000000107 25156991
44 Tibuakuu M, Okunrintemi V, Jirru E, . National trends in cessation counseling, prescription medication use, and associated costs among US adult cigarette smokers. JAMA Network Open. 2019;2(5):e194585. PMID: 31125108. 10.1001/jamanetworkopen.2019.4585 31125108
45 Jamal A, Dube SR, Malarcher AM, . Tobacco use screening and counseling during physician office visits among adults-National Ambulatory Medical Care Survey and National Health Interview Survey, United States, 2005–2009. MMWR Morb Mortal Wkly Rep. 2012;61 Suppl:38–45. PMID: 22695462.22695462
46 Messer K, Trinidad DR, Al-Delaimy WK, . Smoking cessation rates in the United States: a comparison of young adult and older smokers. Am J Public Health. 2008;98(2):317–22. PMID: 18172143. 10.2105/AJPH.2007.112060 18172143
47 Kandra KL, Ranney LM, Lee JG, . Physicians’ attitudes and use of e-cigarettes as cessation devices, North Carolina, 2013. PLoS One. 2014;9(7):e103462. PMID: 25072466. 10.1371/journal.pone.0103462 25072466
48 Ofei-Dodoo S, Kellerman R, Nilsen K, . Family physicians’ perceptions of electronic cigarettes in tobacco use counseling. J Am Board Fam Med. 2017;30(4):448–59. PMID: 28720626. 10.3122/jabfm.2017.04.170084 28720626
49 Nickels AS, Warner DO, Jenkins SM, . Beliefs, practices, and self-efficacy of US physicians regarding smoking cessation and electronic cigarettes: a national survey. Nicotine Tob Res. 2017;19(2):197–207. PMID: 27613879. 10.1093/ntr/ntw194 27613879
50 England L, Anderson B, Tong V, . Screening practices and attitudes of obstetricians-gynecologists toward new and emerging tobacco products. Am J Obstet Gynecol. 2014;211(6):695.e1–7. PMID: 24881828. 10.1016/j.ajog.2014.05.041 24881828
51 Pepper J, Gilkey M, Brewer N. Physicians’ counseling of adolescents regarding e-cigarette use. J Adolesc Health. 2015;57(6):580–6. PMID: 26297135. 10.1016/j.jadohealth.2015.06.017 26297135
52 Keith DR, Stanton CA, Gaalema DE, . Disparities in US healthcare provider screening and advice for cessation across chronic medical conditions and tobacco products. J Gen Intern Med. 2017;32(9):974–80. PMID: 28470547. 10.1007/s11606-017-4062-6 28470547
53 Clinical Practice Guideline Treating Tobacco Use and Dependence 2008 Update Panel. A clinical practice guideline for treating tobacco use and dependence: 2008 update. A U.S. Public Health Service report (Clinical Summary). Am J Prev Med. 2008;35(2):158–76. PMID: 18617085 10.1016/j.amepre.2008.04.009 18617085
54 American Medical Association. American Medical Association guidelines for the diagnosis and treatment of nicotine dependence: how to help patients stop smoking. Washington, DC: American Medical Association; 1994.
55 Patel MS, Steinberg MB. In the Clinic. Smoking Cessation. Ann Intern Med. 2016;164(5):Itc33–itc48. PMID: 26926702. 10.7326/aitc201603010 26926702
56 Larzelere MM, Williams DE. Promoting smoking cessation. Am Fam Physician. 2012;85(6):591–8. PMID: 22534270.22534270
57 American Dental Association. Policy and Recommendations on Tobacco Use. Chicago, IL: American Dental Association; 2016.
58 Guide to Community Preventive Services. Tobacco use and secondhand smoke exposure. https://www.thecommunityguide.org/content/2017-annual-report-congress. Accessed: Jan 5, 2017.
59 [No authors listed]. Tobacco and Nicotine Cessation During Pregnancy: ACOG Committee Opinion, Number 807. Obstet Gynecol. 2020;135(5):e221–e9. PMID: 32332417. 10.1097/aog.0000000000003822 32332417
60 American Academy of Family Physicians. Electronic Nicotine Delivery Systems (ENDS). https://www.aafp.org/about/policies/all/e-cigarettes.html. Accessed: Jan 20, 2020.
61 American College of Obstetricians and Gynecologists. Practice Advisory: Lung Injury Associated with E-cigarettes (“Vaping”). https://www.acog.org/Clinical-Guidance-and-Publications/Practice-Advisories/Lung-Injury-Associated-with-E-cigarettes-Vaping?IsMobileSet=false. Accessed: Jan 20, 2020.
62 American Cancer Society. American Cancer Society Position Statement on Electronic Cigarettes. https://www.cancer.org/healthy/stay-away-from-tobacco/e-cigarette-position-statement.html. Accessed: Jan 20, 2020.
63 Livingston CJ, Freeman RJ, Costales VC, . Electronic nicotine delivery systems or e-cigarettes: American College of Preventive Medicine’s practice statement. Am J Prev Med. 2019;56(1):167–78. PMID: 30573147. 10.1016/j.amepre.2018.09.010 30573147
64 National Institute for Health and Care Excellence, Public Health Internal Guideline Development Team. Smoking cessation interventions and services: [C] Evidence reviews for advice on e-cigarettes and general sale. NICE guideline NG92. London, UK: National Institute for Health and Care Excellence; 2018.
65 Brandon TH, Goniewicz ML, Hanna NH, . Electronic Nicotine Delivery Systems: A Policy Statement From the American Association for Cancer Research and the American Society of Clinical Oncology. J Clin Oncol. 2015;33(8):952–63. PMID: 22572671. 10.1200/JCO.2014.59.4465 25572671
66 U.S. Department of Health and Human Services. Surgeon General’s Advisory on E-cigarette Use Among Youth. https://e-cigarettes.surgeongeneral.gov/. Accessed: 6/17/2019, 2019.
67 U.S. Department of Health and Human Services, Centers for Diesease Control and Prevention. 2016 Surgeon General’s Report: E-Cigarette Use Among Youth and Young Adults. https://www.cdc.gov/tobacco/data_statistics/sgr/e-cigarettes/index.htm. Accessed: 6/17/2019, 2019.
68 U.S. Preventive Services Task Force. Counseling and interventions to prevent tobacco use and tobacco-caused disease in adults and pregnant women: U.S. Preventive Services Task Force reaffirmation recommendation statement. Ann Intern Med. 2009;150(8):551–5. PMID: 19380855. 10.7326/0003-4819-150-8-200904210-00009 19380855
69 Fiore MC. A clinical practice guideline for treating tobacco use and dependence: a US Public Health Service report. The Tobacco Use and Dependence Clinical Practice Guideline Panel, Staff, and Consortium Representatives. JAMA. 2000;283(24):3244–54. PMID: 10866874. 10.1001/jama.283.24.3244 10866874
70 Patnode CD, Henderson JT, Thompson JH, . Behavioral counseling and pharmacotherapy interventions for tobacco cessation in adults, including pregnant women: a review of reviews for the U.S. Preventive Services Task Force. Ann Intern Med. 2015;163(8):608–21. PMID: 26389650. 10.7326/m15-0171 26389650
71 Patnode CD, Henderson JT, Thompson JH, . Behavioral Counseling and Pharmacotherapy Interventions for Tobacco Cessation in Adults, Including Pregnant Women: A Review of Reviews for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2015.
72 Coleman T, Chamberlain C, Davey MA, . Pharmacological interventions for promoting smoking cessation during pregnancy. Cochrane Database Syst Rev. 2015(12):CD010078. PMID: 26690977. 10.1002/14651858.CD010078.pub2 26690977
73 Shea BJ, Reeves B, Wells G, . AMSTAR 2: a critical appraisal tool for systematic reviews that include randomised or non-randomised studies of healthcare interventions, or both. BMJ. 2017;358:j4008. PMID: 28935701. 10.1136/bmj.j4008 28935701
74 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. https://www.uspreventiveservicestaskforce.org/uspstf/procedure-manual. Accessed: May 22, 2019.
75 West R, Hajek P, Stead L, . Outcome criteria in smoking cessation trials: proposal for a common standard. Addiction. 2005;100(3):299–303. PMID: 15733243. 10.1111/j.1360-0443.2004.00995.x.15733243
76 Claire R, Chamberlain C, Davey MA, . Pharmacological interventions for promoting smoking cessation during pregnancy. Cochrane Database Syst Rev. 2020;3:CD010078. PMID: 32129504. 10.1002/14651858.CD010078.pub3 32129504
77 Brockwell SE, Gordon IR. A comparison of statistical methods for meta-analysis. Stat Med. 2001;20(6):825–40. PMID: 11252006. 10.1002/sim.650 11252006
78 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: 2440462724404627.
79 Agboola SA, Coleman T, McNeill A, . Abstinence and relapse among smokers who use varenicline in a quit attempt-a pooled analysis of randomized controlled trials. Addiction. 2015;110(7):1182–93. PMID: 25846123. 10.1111/add.12941 25846123
80 Ahmed S, Virani S, Kotapati VP, . Efficacy and safety of varenicline for smoking cessation in schizophrenia: a meta-analysis. Front Psychiatry. 2018;9:428. PMID: 30283363. 10.3389/fpsyt.2018.00428 30283363
81 Apollonio D, Philipps R, Bero L. Interventions for tobacco use cessation in people in treatment for or recovery from substance use disorders. Cochrane Database Syst Rev. 2016(11):CD010274. PMID: 27878808. 10.1002/14651858.CD010274.pub2 27878808
82 Barnes J, McRobbie H, Dong CY, . Hypnotherapy for smoking cessation. Cochrane Database Syst Rev. 2019;6:CD001008. PMID: 31198991. 10.1002/14651858.CD001008.pub3 31198991
83 Boland VC, Stockings EA, Mattick RP, . The methodological quality and effectiveness of technology-based smoking cessation interventions for disadvantaged groups: a systematic review and meta-analysis. Nicotine Tob Res. 2016;20(3):276–85. PMID: 28034998. 10.1093/ntr/ntw391 28034998
84 Boyle R, Solberg L, Fiore M. Use of electronic health records to support smoking cessation. Cochrane Database Syst Rev. 2014(12):CD008743. PMID: 25547090. 10.1002/14651858.CD008743.pub3 25547090
85 Cahill K, Lindson-Hawley N, Thomas KH, . Nicotine receptor partial agonists for smoking cessation. Cochrane Database Syst Rev. 2016(5):CD006103. PMID: 27158893. 10.1002/14651858.CD006103.pub7 27158893
86 Carson KV, Brinn MP, Peters M, . Interventions for smoking cessation in Indigenous populations. Cochrane Database Syst Rev. 2012(1):CD009046. PMID: 22258998. 10.1002/14651858.CD009046.pub2 22258998
87 Chang PH, Chiang CH, Ho WC, . Combination therapy of varenicline with nicotine replacement therapy is better than varenicline alone: a systematic review and meta-analysis of randomized controlled trials. BMC Public Health. 2015;15:689. PMID: 26198192. 10.1186/s12889-015-2055-0 26198192
88 Clair C, Mueller Y, Livingstone-Banks J, . Biomedical risk assessment as an aid for smoking cessation. Cochrane Database Syst Rev. 2019(3):CD004705. PMID: 30912847. 10.1002/14651858.CD004705.pub5 30912847
89 Danielsson AK, Eriksson AK, Allebeck P. Technology-based support via telephone or web: a systematic review of the effects on smoking, alcohol use and gambling. Addict Behav. 2014;39(12):1846–68. PMID: 25128637. 10.1016/j.addbeh.2014.06.007 25128637
90 Denison E, Underland V, Mosdol A, . Cognitive Therapies for Smoking Cessation: A Systematic Review. Oslo, Norway: Knowledge Centre for the Health Services at The Norwegian Institute of Public Health (NIPH); 2017.
91 Do HP, Tran BX, Le Pham Q, . Which eHealth interventions are most effective for smoking cessation? A systematic review. Patient Prefer Adherence. 2018;12:2065–84. PMID: 30349201. 10.2147/ppa.S169397 30349201
92 Ebbert JO, Elrashidi MY, Stead LF. Interventions for smokeless tobacco use cessation. Cochrane Database Syst Rev. 2015(10):CD004306. PMID: 26501380. 10.1002/14651858.CD004306.pub5 26501380
93 Giles E, Robalino S, McColl E, . The effectiveness of financial incentives for health behaviour change: systematic review and meta-analysis (Structured abstract). Plos One. 2014;9(3):e90347. PMID: 24618584. 10.1371/journal.pone.0090347 24618584
94 Graham AL, Carpenter KM, Cha S, . Systematic review and meta-analysis of internet interventions for smoking cessation among adults. Subst Abuse Rehabil. 2016;7:55–69. PMID: 27274333. 10.2147/sar.s101660 27274333
95 Hartmann-Boyce J, Hong B, Livingstone-Banks J, . Additional behavioural support as an adjunct to pharmacotherapy for smoking cessation. Cochrane Database Syst Rev. 2019(6):CD009670. PMID: 31166007. 10.1002/14651858.CD009670.pub4 31166007
96 Hartmann-Boyce J, Chepkin SC, Ye W, . Nicotine replacement therapy versus control for smoking cessation. Cochrane Database Syst Rev. 2018(5):CD000146. PMID: 29852054. 10.1002/14651858.CD000146.pub5 29852054
97 Hollands GJ, Naughton F, Farley A, . Interventions to increase adherence to medications for tobacco dependence. Cochrane Database Syst Rev. 2019(8):CD009164. PMID: 31425618. 10.1002/14651858.CD009164.pub3 31425618
98 Howes S, Hartmann-Boyce J, Livingstone-Banks J, . Antidepressants for smoking cessation. Cochrane Database Syst Rev. 2020(4):CD000031. PMID: 32319681. 10.1002/14651858.CD000031.pub5 32319681
99 Johnston V, Westphal DW, Glover M, . Reducing smoking among indigenous populations: new evidence from a review of trials. Nicotine Tob Res. 2013;15(8):1329–38. PMID: 23519776. 10.1093/ntr/ntt022 23519776
100 Khanna P, Clifton AV, Banks D, . Smoking cessation advice for people with serious mental illness. Cochrane Database Syst Rev. 2016(1):CD009704. PMID: 26816385. 10.1002/14651858.CD009704.pub2 26816385
101 Kishi T, Iwata N. Varenicline for smoking cessation in people with schizophrenia: systematic review and meta-analysis. Eur Arch Psychiatry Clin Neurosci. 2015;265(3):259–68. PMID: 25283510. 10.1007/s00406-014-0551-3 25283510
102 Klinsophon T, Thaveeratitham P, Sitthipornvorakul E, . Effect of exercise type on smoking cessation: a meta-analysis of randomized controlled trials. BMC Res Notes. 2017;10(1):442. PMID: 28874175. 10.1186/s13104-017-2762-y 28874175
103 Lancaster T, Stead LF. Individual behavioural counselling for smoking cessation. Cochrane Database Syst Rev. 2017(3):CD001292. PMID: 28361496. 10.1002/14651858.CD001292.pub3 28361496
104 Lindson N, Chepkin S, Ye W, . Different doses, durations and modes of delivery of nicotine replacement therapy for smoking cessation. Cochrane Database Syst Rev. 2019(4):CD013308. 10.1002/14651858.CD013308 30997928
105 Lindson N, Klemperer E, Hong B, . Smoking reduction interventions for smoking cessation. Cochrane Database Syst Rev. 2019(9):CD013183. PMID: 31565800. 10.1002/14651858.CD013183.pub2 31565800
106 Lindson N, Thompson TP, Ferrey A, . Motivational interviewing for smoking cessation. Cochrane Database Syst Rev. 2019(7):CD006936. PMID: 31425622. 10.1002/14651858.CD006936.pub4 31425622
107 Liu JJ, Wabnitz C, Davidson E, . Smoking cessation interventions for ethnic minority groups: a systematic review of adapted interventions. Prev Med. 2013;57(6):765–75. PMID: 24076130. 10.1016/j.ypmed.2013.09.014 24076130
108 Livingstone-Banks J, Norris E, Hartmann-Boyce J, . Relapse prevention interventions for smoking cessation. Cochrane Database Syst Rev. 2019(2):CD003999. PMID: 30758045. 10.1002/14651858.CD003999.pub5 30758045
109 Livingstone-Banks J, Ordonez-Mena JM, Hartmann-Boyce J. Print-based self-help interventions for smoking cessation. Cochrane Database Syst Rev. 2019(1):CD001118. PMID: 30623970. 10.1002/14651858.CD001118.pub4 30623970
110 Matkin W, Ordonez-Mena JM, Hartmann-Boyce J. Telephone counselling for smoking cessation. Cochrane Database Syst Rev. 2019(5):CD002850. PMID: 31045250. 10.1002/14651858.CD002850.pub4 31045250
111 McCrabb S, Baker AL, Attia J, . Internet-based programs incorporating behavior change techniques are associated with increased smoking cessation in the general population: a systematic review and meta-analysis. Ann Behav Med. 2019;53(2):180–95. PMID: 29750240. 10.1093/abm/kay026 29750240
112 McKee SA, Smith PH, Kaufman M, . Sex differences in varenicline efficacy for smoking cessation: a meta-analysis. Nicotine Tob Res. 2016;18(5):1002–11. PMID: 26446070. 10.1093/ntr/ntv207 26446070
113 Mills EJ, Thorlund K, Eapen S, . Cardiovascular events associated with smoking cessation pharmacotherapies: a network meta-analysis. Circulation. 2014;129(1):28–41. PMID: 24323793. 10.1161/CIRCULATIONAHA.113.003961 24323793
114 Mills EJ, Wu P, Lockhart I, . Adverse events associated with nicotine replacement therapy (NRT) for smoking cessation. A systematic review and meta-analysis of one hundred and twenty studies involving 177,390 individuals. Tob Induc Dis. 2010;8:8. PMID: 20626883. 10.1186/1617-9625-8-8 20626883
115 Moyo F, Archibald E, Slyer JT. Effectiveness of decision aids for smoking cessation in adults: a quantitative systematic review. JBI Database System Rev Implement Rep. 2018;16(9):1791–822. PMID: 30204670. 10.11124/jbisrir-2017-003698 30204670
116 Notley C, Gentry S, Livingstone-Banks J, . Incentives for smoking cessation. Cochrane Database Syst Rev. 2019(7):CD004307. PMID: 31313293. 10.1002/14651858.CD004307.pub6 31313293
117 Palmer M, Sutherland J, Barnard S, . The effectiveness of smoking cessation, physical activity/diet and alcohol reduction interventions delivered by mobile phones for the prevention of non-communicable diseases: a systematic review of randomised controlled trials. PLoS One. 2018;13(1):e0189801. PMID: 29304148. 10.1371/journal.pone.0189801 29304148
118 Peckham E, Brabyn S, Cook L, . Smoking cessation in severe mental ill health: what works? An updated systematic review and meta-analysis. BMC Psychiatry. 2017;17(1):252. PMID: 28705244. 10.1186/s12888-017-1419-7 28705244
119 Rice VH, Heath L, Livingstone-Banks J, . Nursing interventions for smoking cessation. Cochrane Database Syst Rev. 2017(12):CD00118. PMID: 29243221. 10.1002/14651858.CD001188.pub5 29243221
120 Roberts E, Evins A, McNeill A, . Efficacy and tolerability of pharmacotherapy for smoking cessation in adults with serious mental illness: a systematic review and network meta-analysis. Addiction. 2016;111(4):599–612. PMID: 26594837. 10.1111/add.13236 26594837
121 Rosen LJ, Galili T, Kott J, . Diminishing benefit of smoking cessation medications during the first year: a meta-analysis of randomized controlled trials. Addiction. 2018;113(5):805–16. PMID: 29377409. 10.1111/add.14134 29377409
122 Schuit E, Panagiotou OA, Munafo MR, . Pharmacotherapy for smoking cessation: effects by subgroup defined by genetically informed biomarkers. Cochrane Database Syst Rev. 2017(9):CD011823. PMID: 28884473. 10.1002/14651858.CD011823.pub2 28884473
123 Schwartz J, Fadahunsi O, Hingorani R, . Use of varenicline in smokeless tobacco cessation: a systematic review and meta-analysis. Nicotine Tob Res. 2016;18(1):10–6. PMID: 25646351. 10.1093/ntr/ntv010 25646351
124 Smith PH, Weinberger AH, Zhang J, . Sex differences in smoking cessation pharmacotherapy comparative efficacy: a network meta-analysis. Nicotine Tob Res. 2016;19(3):273–81. 10.1093/ntr/ntw144
125 Stead LF, Buitrago D, Preciado N, . Physician advice for smoking cessation. Cochrane Database Syst Rev. 2013(5):CD000165. PMID: 23728631. 10.1002/14651858.CD000165.pub4 23728631
126 Stead LF, Carroll AJ, Lancaster T. Group behaviour therapy programmes for smoking cessation. Cochrane Database Syst Rev. 2017(3):CD00107. PMID: 28361497. 10.1002/14651858.CD001007.pub3 28361497
127 Stead LF, Koilpillai P, Fanshawe TR, . Combined pharmacotherapy and behavioural interventions for smoking cessation. Cochrane Database Syst Rev. 2016(3):CD008286. PMID: 27009521. 10.1002/14651858.CD008286.pub3 27009521
128 Sterling LH, Windle SB, Filion KB, . Varenicline and adverse cardiovascular events: a systematic review and meta-analysis of randomized controlled trials. J Am Heart Assoc. 2016;5(2):e002849. PMID: 26903004. 10.1161/jaha.115.002849 26903004
129 Taylor GM, Dalili MN, Semwal M, . Internet-based interventions for smoking cessation. Cochrane Database Syst Rev. 2017(9):CD007078. PMID: 28869775. 10.1002/14651858.CD007078.pub5 28869775
130 Thomas D, Abramson MJ, Bonevski B, . System change interventions for smoking cessation. Cochrane Database Syst Rev. 2017(2):CD010742. PMID: 28185257. 10.1002/14651858.CD010742.pub2 28185257
131 Thomas KH, Martin RM, Knipe DW, . Risk of neuropsychiatric adverse events associated with varenicline: systematic review and meta-analysis. BMJ. 2015;350:h1109. PMID: 25767129. 10.1136/bmj.h1109 25767129
132 Thurgood SL, McNeill A, Clark-Carter D, . A systematic review of smoking cessation interventions for adults in substance abuse treatment or recovery. Nicotine Tob Res. 2016;18(5):993–1001. PMID: 26069036. 10.1093/ntr/ntv127 26069036
133 Tsoi DT, Porwal M, Webster AC. Interventions for smoking cessation and reduction in individuals with schizophrenia. Cochrane Database Syst Rev. 2013(2):CD007253. PMID: 23450574. 10.1002/14651858.CD007253.pub3 23450574
134 Tzelepis F, Paul CL, Williams CM, . Real-time video counselling for smoking cessation. Cochrane Database Syst Rev. 2019(10):CD012659. PMID: 31684699. 10.1002/14651858.CD012659.pub2 31684699
135 Ussher MH, Faulkner GE, Angus K, . Exercise interventions for smoking cessation. Cochrane Database Syst Rev. 2019(10):CD002295. PMID: 31684691. 10.1002/14651858.CD002295.pub6 31684691
136 van der Meer RM, Willemsen MC, Smit F, . Smoking cessation interventions for smokers with current or past depression. Cochrane Database Syst Rev. 2013(8):CD006102. PMID: 23963776. 10.1002/14651858.CD006102.pub2 23963776
137 White AR, Rampes H, Liu JP, . Acupuncture and related interventions for smoking cessation. Cochrane Database Syst Rev. 2014(1):CD000009. PMID: 24459016. 10.1002/14651858.CD000009.pub4 24459016
138 Whittaker R, McRobbie H, Bullen C, . Mobile phone text messaging and app-based interventions for smoking cessation. Cochrane Database Syst Rev. 2019(10):CD006611. PMID: 31638271. 10.1002/14651858.CD006611.pub5 31638271
139 Wilson A, Guillaumier A, George J, . A systematic narrative review of the effectiveness of behavioural smoking cessation interventions in selected disadvantaged groups (2010–2017). Expert Rev Respir Med. 2017;11(8):617–30. PMID: 28608758. 10.1080/17476348.2017.1340836 28608758
140 Windle SB, Filion KB, Mancini JG, . Combination therapies for smoking cessation: a hierarchical Bayesian meta-analysis. Am J Prev Med. 2016;51(6):1060–71. PMID: 27617367. 10.1016/j.amepre.2016.07.011 27617367
141 Wu L, Sun S, He Y, . Effect of smoking reduction therapy on smoking cessation for smokers without an intention to quit: an updated systematic review and meta-analysis of randomized controlled trial. Int J Environ Res Public Health. 2015;12(9):10235–53. PMID: 26308034. 10.3390/ijerph120910235 26308034
142 Wu Q, Gilbody S, Peckham E, . Varenicline for smoking cessation and reduction in people with severe mental illnesses: systematic review and meta-analysis. Addiction. 2016;111(9):1554–67. PMID: 27043328. 10.1111/add.13415 27043328
143 Bullen C, Williman J, Howe C, . Study protocol for a randomised controlled trial of electronic cigarettes versus nicotine patch for smoking cessation. BMC Public Health. 2013;13:210. PMID: 23496861. 10.1186/1471-2458-13-210 23496861
144 Bullen C, Howe C, Laugesen M, . Electronic cigarettes for smoking cessation: a randomised controlled trial. Lancet. 2013;382(9905):1629–37. PMID: 24029165. 10.1016/S0140-6736(13)61842-5 24029165
145 Caponnetto P, Campagna D, Cibella F, . EffiCiency and Safety of an eLectronic cigAreTte (ECLAT) as tobacco cigarettes substitute: a prospective 12-month randomized control design study. PLoS One. 2013;8(6):e66317. PMID: 23826093. 10.1371/journal.pone.0066317 23826093
146 Masiero M, Lucchiari C, Mazzocco K, . E-cigarettes may support smokers with high smoking-related risk awareness to stop smoking in the short run: preliminary results by randomized controlled trial. Nicotine Tob Res. 2019;21(1):119–26. PMID: 29660034. 10.1093/ntr/nty047 29660034
147 Carpenter MJ, Heckman BW, Wahlquist AE, . A naturalistic, randomized pilot trial of e-cigarettes: uptake, exposure, and behavioral effects. Cancer Epidemiol Biomarkers Prev. 2017;26(12):1795–803. PMID: 29127080. 10.1158/1055-9965.epi-17-0460 29127080
148 Cravo AS, Bush J, Sharma G, . A randomised, parallel group study to evaluate the safety profile of an electronic vapour product over 12 weeks. Regul Toxicol Pharmacol. 2016;81(Suppl 1):S1–s14. PMID: 27769828. 10.1016/j.yrtph.2016.10.003 27769828
149 Lucchiari C, Masiero M, Veronesi G, . Benefits of e-cigarettes among heavy smokers undergoing a lung cancer screening program: randomized controlled trial protocol. JMIR Res Protocols. 2016;5(1):e21. PMID: 26842790. 10.2196/resprot.4805 26842790
150 Tseng TY, Ostroff JS, Campo A, . A randomized trial comparing the effect of nicotine versus placebo electronic cigarettes on smoking reduction among young adult smokers. Nicotine Tob Res. 2016;18(10):1937–43. PMID: 26783292. 10.1093/ntr/ntw017 26783292
151 O’Brien B, Knight-West O, Walker N, . E-cigarettes versus NRT for smoking reduction or cessation in people with mental illness: secondary analysis of data from the ASCEND trial. Tob Induc Dis. 2015;13(1):5. PMID: 25814920. 10.1186/s12971-015-0030-2 25814920
152 Bullen C, Howe C, Laugesen M. Electronic cigarettes for smoking cessation: a randomised controlled trial. J Vasc Surg. 2014;59(3):872. 10.1016/j.jvs.2014.01.028
153 Caponnetto P, Campagna D, Cibella F, . Erratum: EffiCiency and Safety of an eLectronic cigAreTte (ECLAT) as tobacco cigarettes substitute: a prospective 12-month randomized control design study. PLoS One. 2014;9(1). 10.1371/annotation/e12c22d3-a42b-455d-9100-6c7ee45d58d0
154 Hajek P, Phillips-Waller A, Przulji D, . A randomized trial of e-cigarettes versus nicotine-replacement therapy. N Engl J Med. 2019;380(629–37). PMID: 30699054. 10.1056/NEJMoa1808779 30699054
155 Walker N, Parag V, Verbiest M, . Nicotine patches used in combination with e-cigarettes (with and without nicotine) for smoking cessation: a pragmatic, randomised trial. Lancet Respir Med. 2020;8(1):54–64. PMID: 31515173. 10.1016/S2213-2600(19)30269-3 31515173
156 Hajek P, Phillips-Waller A, Przulj D, . E-cigarettes compared with nicotine replacement therapy within the UK Stop Smoking Services: the TEC RCT. Health Technol Assess. 2019;23(43):1–82. PMID: 31434605. 10.3310/hta23430 31434605
157 Lee SH, Ahn SH, Cheong YS. Effect of electronic cigarettes on smoking reduction and cessation in Korean male smokers: a randomized controlled study. J Am Board Fam Med. 2019;32(4):567–74. PMID: 31300577. 10.3122/jabfm.2019.04.180384 31300577
158 Masiero M, Lucchiari C, Mazzocco K, . Corrigendum: e-cigarettes may support smokers with high smoking-related risk awareness to stop smoking in the short run: preliminary results by randomized controlled trial. Nicotine Tob Res. 2020;22(4):594–5. 10.1093/ntr/nty175 30239904
159 Rose G, Hamilton PJ. A randomised controlled trial of the effect on middle-aged men of advice to stop smoking. J Epidemiol Community Health. 1978;32(4):275–81. PMID: 370171. 10.1136/jech.32.4.275 370171
160 Rose G, Colwell L. Randomised controlled trial of anti-smoking advice: final (20 year) results. J Epidemiol Community Health. 1992;46(1):75–7. PMID: 1573365. 10.1016/j.amepre.2007.05.006 1573365
161 Anthenelli RM, Benowitz NL, West R, . Neuropsychiatric safety and efficacy of varenicline, bupropion, and nicotine patch in smokers with and without psychiatric disorders (EAGLES): a double-blind, randomised, placebo-controlled clinical trial. Lancet. 2016;387(10037):2507–20. PMID: 27116918. 10.1016/S0140-6736(16)30272-0 27116918
162 Miller W, Rollnick S. Motivational Interviewing: Preparing People for Change. New York: Guildfort Press; 2002.
163 American Lung Association. Freedom from Smoking. http://www.freedomfromsmoking.org/. Accessed: 5/17/2019, 2019.
164 Benowitz NL, Pipe A, West R, . Cardiovascular safety of varenicline, bupropion, and nicotine patch in smokers: a randomized clinical trial. JAMA Intern Med. 2018;178(5):622–31. PMID: 29630702. 10.1001/jamainternmed.2018.0397 29630702
165 Evins AE, Benowitz NL, West R, . Neuropsychiatric safety and efficacy of varenicline, bupropion, and nicotine patch in smokers with psychotic, anxiety, and mood disorders in the EAGLES trial. J Clin Psychopharmacol. 2019;39(2):108–16. PMID: 30811371. 10.1097/JCP.0000000000001015 30811371
166 Cahill K, Hartmann-Boyce J, Perera R. Incentives for smoking cessation. Cochrane Database Syst Rev. 2015(5):CD004307. PMID: 25983287. 10.1002/14651858.CD004307.pub5 25983287
167 Berlin I, Grange G, Jacob N, . Nicotine patches in pregnant smokers: randomised, placebo controlled, multicentre trial of efficacy. BMJ. 2014;348:g1622. PMID: 24627552. 10.1136/bmj.g1622 24627552
168 Coleman T, Cooper S, Thornton JG, . A randomized trial of nicotine-replacement therapy patches in pregnancy. New Engl J Med. 2012;366(9):808–18. PMID: 22375972. 10.1056/NEJMoa1109582 22375972
169 Cooper S, Lewis S, Thornton JG, . The SNAP trial: a randomised placebo-controlled trial of nicotine replacement therapy in pregnancy-clinical effectiveness and safety until 2 years after delivery, with economic evaluation. Health Technol Assess. 2014;18(54):1–128. PMID: 25158081. 10.3310/hta18540 25158081
170 Cooper S, Taggar J, Lewis S, . Effect of nicotine patches in pregnancy on infant and maternal outcomes at 2 years: follow-up from the randomised, double-blind, placebo-controlled SNAP trial. Lancet Respir Med. 2014(9):728–37. PMID: 25127405. 10.1016/S2213-2600(14)70157-2 25127405
171 El-Mohandes AA, Windsor R, Tan S, . A randomized clinical trial of trans-dermal nicotine replacement in pregnant African-American smokers. Matern Child Health J. 2013;17(5):897–906. PMID: 22761006. 10.1007/s10995-012-1069-9 22761006
172 Essex HN, Parrott S, Wu Q, . Cost-effectiveness of nicotine patches for smoking cessation in pregnancy: a placebo randomized controlled trial (SNAP). Nicotine Tob Res. 2015;17(6):636–42. PMID: 25481916. 10.1093/ntr/ntu258 25481916
173 Iyen B, Vaz LR, Taggar J, . Is the apparently protective effect of maternal nicotine replacement therapy (NRT) used in pregnancy on infant development explained by smoking cessation?: secondary analyses of a randomised controlled trial. BMJ Open. 2019;9(7):e024923. PMID: 31300493. 10.1136/bmjopen-2018-024923 31300493
174 Oncken C, Dornelas E, Greene J, . Nicotine gum for pregnant smokers: a randomized controlled trial. Obstet Gynecol. 2008;112(4):859–67. PMID: 18827129. 10.1097/AOG.0b013e318187e1ec 18827129
175 Oncken C, Dornelas EA, Kuo CL, . Randomized trial of nicotine inhaler for pregnant smokers. Am J Obstet Gynecol MFM. 2019;1(1):10–8. PMID: 31380506. 10.1016/j.ajogmf.2019.03.006 31380506
176 Pollak KI, Oncken CA, Lipkus IM, . Nicotine replacement and behavioral therapy for smoking cessation in pregnancy. Am J Prev Med. 2007;33(4):297–305. PMID: 17888856. 10.1016/j.amepre.2007.05.006 17888856
177 Vaz LR, Coleman T, Cooper S, . The Nicotine metabolite ratio in pregnancy measured by trans-3’-hydroxycotinine to cotinine ratio: characteristics and relationship with smoking cessation. Nicotine Tob Res. 2015;17(11):1318–23. PMID: 25589677. 10.1093/ntr/ntu342 25589677
178 Wisborg K, Henriksen TB, Jespersen LB, . Nicotine patches for pregnant smokers: a randomized controlled study. Obstet Gynecol. 2000;96(6):967–71. PMID: 11084187. 10.1016/s0029-7844(00)01071-1 11084187
179 Berard A, Zhao JP, Sheehy O. Success of smoking cessation interventions during pregnancy. Am J Obstet Gynecol. 2016;215(5):611.e1–.e8. PMID: 27402053. 10.1016/j.ajog.2016.06.059 27402053
180 Dhalwani NN, Szatkowski L, Coleman T, . Nicotine replacement therapy in pregnancy and major congenital anomalies in offspring. Pediatrics. 2015;135(5):859–67. PMID: 25847803. 10.1542/peds.2014-2560 25847803
181 Dhalwani NN, Szatkowski L, Coleman T, . Stillbirth among women prescribed nicotine replacement therapy in pregnancy: analysis of a large UK pregnancy cohort. Nicotine Tob Res. 2018;21(4):409–15. PMID: 29394405. 10.1093/ntr/nty019 29394405
182 Pedersen L, Petronis KR, Norgaard M, . Risk of adverse birth outcomes after maternal varenicline use: a population-based observational study in Denmark and Sweden. Pharmacoepidemiol Drug Saf. 2020;29(1):94–102. PMID: 31713302. 10.1002/pds.4894 31713302
183 Tran DT, Preen DB, Einarsdottir K, . Use of smoking cessation pharmacotherapies during pregnancy is not associated with increased risk of adverse pregnancy outcomes: a population-based cohort study. BMC Medicine. 2020;18(1):15. PMID: 32019533. 10.1186/s12916-019-1472-9 32019533
184 Zhu JL, Olsen J, Liew Z, . Parental smoking during pregnancy and ADHD in children: the Danish national birth cohort. Pediatrics. 2014;134(2):e382–8. PMID: 25049343. 10.1542/peds.2014-0213 25049343
185 Chamberlain C, O’Mara-Eves A, Porter J, . Psychosocial interventions for supporting women to stop smoking in pregnancy. Cochrane Database Syst Rev. 2017(2):CD00105. PMID: 28196405. 10.1002/14651858.CD001055.pub5 28196405
186 Griffiths SE, Parsons J, Naughton F, . Are digital interventions for smoking cessation in pregnancy effective? A systematic review and meta-analysis. Health Psychol Rev. 2018;12(4):333–56. PMID: 29912621. 10.1080/17437199.2018.1488602 29912621
187 Wilson SM, Newins AR, Medenblik AM, . Contingency management versus psychotherapy for prenatal smoking cessation: a meta-analysis of randomized controlled trials. Womens Health Issues. 2018;28(6):514–23. PMID: 30061033. 10.1016/j.whi.2018.05.002 30061033
188 Leas EC, Pierce JP, Benmarhnia T, . Effectiveness of pharmaceutical smoking cessation aids in a nationally representative cohort of American smokers. J Natl Cancer Inst. 2018;110(6):581–7. PMID: 29281040. 10.1093/jnci/djx240 29281040
189 Brown J, Beard E, Kotz D, . Real-world effectiveness of e-cigarettes when used to aid smoking cessation: a cross-sectional population study. Addiction. 2014;109(9):1531–40. 10.1111/add.12623 24846453
190 Krishnasamy VP, Hallowell BD, Ko JY, . Update: characteristics of a nationwide outbreak of e-cigarette, or vaping, product use-associated lung injury - United States, August 2019–January 2020. MMWR Morb Mortal Wkly Rep. 2020;69(3):90–4. PMID: 31971931. 10.15585/mmwr.mm6903e2 31971931
191 Moritz ED, Zapata LB, Lekiachvili A, . Update: characteristics of patients in a national outbreak of e-cigarette, or vaping, product use-associated lung injuries - United States, October 2019. MMWR Morb Mortal Wkly Rep. 2019;68(43):985–9. PMID: 31671085. 10.15585/mmwr.mm6843e1 31671085
192 Blount BC, Karwowski MP, Shields PG, . Vitamin E acetate in bronchoalveolar-lavage fluid associated with EVALI. N Engl J Med. 2019;382(8):697–705. PMID: 31860793. 10.1056/NEJMoa1916433 31860793
193 Office on Smoking and Health. Outbreak of Lung Injury Associated with E-Cigarette Use, or Vaping. https://www.cdc.gov/tobacco/basic_information/e-cigarettes/severe-lung-disease.html.
194 Jatlaoui TC, Wiltz JL, Kabbani S, . Update: interim guidance for health care providers for managing patients with suspected e-cigarette, or vaping, product use-associated lung injury - United States, November 2019. MMWR Morb Mortal Wkly Rep. 2019;68(46):1081–6. PMID: 31751322. 10.15585/mmwr.mm6846e2 31751322
195 Evans ME, Twentyman E, Click ES, . Update: interim guidance for health care professionals evaluating and caring for patients with suspected e-cigarette, or vaping, product use-associated lung injury and for reducing the risk for rehospitalization and death following hospital discharge - United States, December 2019. MMWR Morb Mortal Wkly Rep. 2020;68(5152):1189–94. PMID: 31895915. 10.15585/mmwr.mm685152e2 31895915
196 Kamboj A, Spiller HA, Casavant MJ, . Pediatric exposure to e-cigarettes, nicotine, and tobacco products in the United States. Pediatrics. 2016;137(6). PMID: 27244861. 10.1542/peds.2016-0041 27244861
197 Gentzke AS, Creamer M, Cullen KA, . Vital Signs: tobacco product use among middle and high school students - United States, 2011–2018. MMWR Morb Mortal Wkly Rep. 2019;68(6):157–64. PMID: 30763302. 10.15585/mmwr.mm6806e1 30763302
198 Centers for Disease Control and Prevention. QuickStats: Cigarette Smoking Status* Among Current Adult E-cigarette Users,(dagger) by Age Group - National Health Interview Survey,( section sign) United States, 2015. MMWR Morb Mortal Wkly Rep. 2016;65(42):1177. PMID: 27787495. 10.15585/mmwr.mm6542a7 27787495
199 Patel D, Davis KC, Cox S, . Reasons for current E-cigarette use among U.S. adults. Prev Med. 2016;93:14–20. PMID: 27612572. 10.1016/j.ypmed.2016.09.011 27612572
200 Zhuang YL, Cummins SE, Sun JY, . Long-term e-cigarette use and smoking cessation: a longitudinal study with US population. Tob Control. 2016;25(Suppl 1):i90–i5. PMID: 27697953. 10.1136/tobaccocontrol-2016-053096 27697953
201 [No authors listed]. QuickStats: Cigarette Smoking Status* Among Current Adult E-cigarette Users,(†) by Age Group - National Health Interview Survey,(§) United States, 2015. MMWR Morb Mortal Wkly Rep. 2016;65(42):1177. PMID: 27787495. 10.15585/mmwr.mm6542a7 27787495
202 Cochrane Tobacco Addiction Group. Cochrane Tobacco Addiction Group’s website. https://tobacco.cochrane.org/. Accessed: May 20, 2019, 2019.
203 Klemperer EM, Hughes JR, Naud S. Study characteristics influence the efficacy of substance abuse treatments: a meta-analysis of medications for smoking cessation. Nicotine Tob Res. 2020;22(3):317–323. PMID: 30380134. 10.1093/ntr/nty225 30380134
204 Etter JF, Burri M, Stapleton J. The impact of pharmaceutical company funding on results of randomized trials of nicotine replacement therapy for smoking cessation: a meta-analysis. Addiction. 2007;102(5):815–22. PMID: 17493109. 10.1111/j.1360-0443.2007.01822.x 17493109
205 Tutka P, Vinnikov D, Courtney RJ, . Cytisine for nicotine addiction treatment: a review of pharmacology, therapeutics and an update of clinical trial evidence for smoking cessation. Addiction. 2019;[Epub ahead of print]. PMID: 31240783. 10.1111/add.14721 31240783
206 Haskins BL, Lesperance D, Gibbons P, . A systematic review of smartphone applications for smoking cessation. Transl Behav Med. 2017;7(2):292–9. PMID: 28527027. 10.1007/s13142-017-0492-2 28527027
207 National Institute on Drug Abuse. Supplemental Information for NIDA e-cig. https://www.drugabuse.gov/funding/nida-funding-opportunities/supplemental-information-nida-e-cig. Accessed: Jul 24, 2020.
208 Food and Drug Administration. FDA Authorizes Marketing of IQOS Tobacco Heating System with “Reduced Exposure” Information. Food and Drug Administration; 2020.
209 Hickson C, Lewis S, Campbell KA, . Comparison of nicotine exposure during pregnancy when smoking and abstinent with nicotine replacement therapy: systematic review and meta-analysis. Addiction. 2019;114(3):406–24. PMID: 30315598. 10.1111/add.14473 30315598
210 Coleman T, Chamberlain C, Davey MA, . Pharmacological interventions for promoting smoking cessation during pregnancy. Cochrane Database Syst Rev. 2012(9):CD010078. PMID: 22972148. 10.1002/14651858.CD010078 22972148
211 Hughes JR, Stead LF, Hartmann BJ, . Antidepressants for smoking cessation. Cochrane Database Syst Rev. 2014(1):CD000031. PMID: 24402784. 10.1002/14651858.CD000031.pub4 24402784
212 Wells G, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed: December 3, 2018.
213 Lindson-Hawley N, Thompson TP, Begh R. Motivational interviewing for smoking cessation. Cochrane Database Syst Rev. 2015;3:CD006936. PMID: 25726920. 10.1002/14651858.CD006936.pub3 25726920