# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tina Fan, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Brian King, PhD, MPH, Janet Wright, MD, Nicola Lindson, BSc, MSc, CPsychol, PhD, Stephen Fortmann, MD, Nancy Rigotti, MD, and Michele Levine, PhD, who provided expert review of the draft report; Brandy Peaker, MD, MPH, on behalf of the Office of Smoking Health, Division of Reproductive Health, and the National Institute for Occupational Safety and Health at the Centers for Disease Control and Prevention, A. Gretchen Buckler, MD, MPH, and Elena Gorodetsky, MD, PhD, with the Office of Research on Women’s Health at the National Institutes of Health, Kevin Walton, PhD, with the National Institute on Drug Abuse, and Holly Nicastro, PhD, MPH, with the National Heart, Lung, and Blood Institute for providing federal review of our draft report, and Corinne Husten, Md, MPH, with the Food and Drug Administration, Center for Tobacco Products; and Todd Hannon, MLS, and Katherine Essick, BS, at the Kaiser Permanente Center for Health Research for technical and editorial assistance.