# Chapter 4 Discussion

## Summary of Evidence

We conducted an overview of reviews to update the evidence on the benefits and harms of tobacco cessation interventions among the general adult population and pregnant adults. This approach allowed us to summarize the evidence on health outcomes, cessation outcomes, and harms of pharmacotherapy (NRT in various forms, bupropion, and varenicline), a variety of primary care-applicable behavioral interventions, and various combinations of pharmacotherapy and behavioral intervention approaches from 67 relevant systematic reviews, with more than 1500 RCTs and observational studies represented. We supplemented the overview of reviews approach with a primary search for studies evaluating the use of e-cigarettes for smoking cessation, given the more recent emergence of this technology and the existing USPSTF determination of insufficient evidence for this approach.^1^ Similarly, we conducted a primary search for literature to locate all recent studies related to the use of bupropion among adults given no updated review on the subject and of all pharmacotherapy among pregnant women, given the small evidence base we previously identified and potential harms related to these medications among this population.

The results of our review are consistent with the conclusions of the 2020 Surgeon General’s report on Smoking Cessation.^14^

### General Adult Population

Available evidence on the impact of tobacco cessation interventions on health outcomes (KQ 1) from systematic reviews among general adults represented a single behavioral intervention (physician advice) with no pharmacological treatment (Table 13). Our ratings of “low” and “insufficient” for this key question reflect the lack of evidence on health outcomes presented in the included reviews, not a lack of confidence in the beneficial association between quitting smoking and improved health outcomes. The research field has largely moved past the question of whether tobacco cessation interventions improve health outcomes, given that the health benefits of quitting smoking are already firmly established. Within the included reviews, most included studies reported smoking cessation as the primary outcome and emphasized improved validity through biochemical verification of use or more stringent definitions of abstinence.

Table 13 Summary of Evidence for the General Adult Population

Key question | Intervention | Number of included studies and participants^*^ | Summary of findings | Consistency and precision | Other limitations | Strength of evidence^†^ | Applicability
1: Health outcomes | Combined pharm and behavioral | 0 | NA | NA | NA | Insufficient | NA
1: Health outcomes | Pharm | 0 | NA | NA | NA | Insufficient | NA
1: Health outcomes | Behavioral | 1 review (1 RCT, n=1445) | One trial found favorable effects on all-cause and coronary disease mortality and lung cancer incidence and mortality 20 years following an intensive behavioral intervention, although results were not statistically significant. | NA | Only one review reported the results of one intervention in men. Within that trial, the rate of smoking among control group participants declined steadily over the followup period, narrowing the intervention effect. | Low evidence of potential benefit | One trial conducted among civil servant men aged 40–59 years in the UK with high risk of cardiorespiratory disease.; Intervention took place in the 1970’s.
1: Health outcomes | Electronic cigarettes | 0 RCTs | NA | NA | NA | Insufficient | NA
2: Cessation outcomes | Combined pharm and behavioral | 1 review (53 RCTs, n=25,375) | Combined pharmacotherapy and behavioral interventions increased smoking quit rates by 68–98% compared with no or minimal treatment (RR 1.83 [95% CI, 1.68 to 1.98]) at 6 months or more followup. | Reasonably consistent; Reasonably precise | May be risk of bias due to lack of blinding of participants. | High evidence of benefit^‡^ | Treatment effects appear to be comparable in a range of populations, settings and types of interventions and in smokers with and without other co-morbidities.; The literature almost exclusively addressed treatment for cigarette smoking, as opposed to the use of other forms of tobacco, so results may not be generalizable to all forms of tobacco.
2: Cessation outcomes | Pharm | 5 reviews (336 RCTs, n>159,000) | NRT, bupropion, and varenicline significantly increased the chances of quitting smoking compared with placebo or no medication. Reviews suggested that NRT might increase smoking abstinence at 6 months or longer by 49–61% (RR 1.55 [95% CI, 1.49 to 1.61]); bupropion by 49–76% (RR 1.62 [95% CI, 1.49 to 1.76]); and varenicline by 106–143% (RR 2.24 [95% CI, 2.06 to 2.43]).; Absolute quit differences averaged 6.4% for NRT; 8.2% for bupropion, and 14.5% for varenicline.; Using a combination of NRT products increased quitting more than the use of a single NRT product (RR 1.25 [95% CI, 1.15 to 1.36]).; Direct comparisons between drugs suggested that varenicline may be superior to NRT and bupropion in achieving smoking abstinence at 6 months or longer.^‖^ | Reasonably consistent; Reasonably precise | Possibility of publication bias but unlikely that the presence of additional studies with lower relative risks would alter the findings given large number of studies and consistency in findings for each type of drug. | High evidence of benefit^§^ | Treatment effects appear to be comparable in a range of populations, settings and types of interventions and in smokers with and without other co-morbidities.; The literature almost exclusively addressed treatment for cigarette smoking, as opposed to the use of other forms of tobacco, so results may not be generalizable to all forms of tobacco.
2: Cessation outcomes | Behavioral | 20 reviews (830 RCTs, n>500,000) | Health provider advice and counseling, individual counseling, group-based interventions, telephone counseling, mobile phone-based interventions, tailored and interactive internet-based interventions, and incentives showed significant increased smoking cessation at 6 or more months relative to controls (15% to 88%). For example, for physician advice versus minimal controls or usual care: RR 1.76 (95% CI, 1.58 to 1.96).; Providing more intense adjunctive behavioral support to smokers receiving pharmacotherapy may increase cessation by 8–22% (RR 1.15 [95% CI, 1.08 to 1.22]).; Evidence on the use of motivational interviewing, decision aids, print-based, nontailored self-help materials, real-time video counseling, biomedical risk assessment, exercise, complementary and alternative therapies, and system-level interventions was limited and not definitive in the effects on cessation. | Reasonably consistent; Reasonably precise | Individual trials may be represented in more than one review and/or meta-analysis.; Indication of possible publication bias for evidence related to motivational interviewing and acupuncture.; Fixed-effects models were used in nearly all meta-analyses. | Moderate to High evidence of benefit^¶^ | Treatment effects appear to be comparable in a range of populations, settings and types of interventions and in smokers with and without other co-morbidities.; The literature almost exclusively addressed treatment for cigarette smoking, as opposed to the use of other forms of tobacco, so results may not be generalizable to all forms of tobacco.
2: Cessation outcomes | Relapse prevention | 1 review (77 RCTs, n=67,285) | Analyses of behavioral interventions among abstainers did not detect an effect in both studies of assisted abstainers (RR 0.99 [95% CI, 0.87 to 1.13]; I^2^=56%; k=10; n=5408) and unaided abstainers (RR 1.06 [95% CI, 0.96 to 1.16]; I^2^=1%; k=5; n=3561) from the general population.; There was some evidence that extending varenicline could be beneficial in preventing relapse, but it was only reported by two studies. NRT was found to help in unassisted abstainers, but no difference was seen among those who achieved abstinence with NRT. None of the six studies that examined the use of bupropion to prevent relapse found a statistically significant effect. | Inconsistent; Imprecise | Highly variable study designs and included interventions. | Moderate evidence of no benefit of behavioral interventions on relapse prevention; Moderate evidence of benefit of varenicline on relapse prevention; low evidence of no benefit of bupropion or NRT on relapse prevention | Studies were highly heterogenous and may not be applicable to the general adult population.
2: Cessation outcomes | Electronic cigarettes | 5 RCTs (n=3117) | Two trials (n=2008) found statistically significantly greater rates of smoking abstinence in those using e-cigarettes containing nicotine (with or without the co-use of NRT) compared with NRT alone or NRT plus non-nicotine e-cigarettes at 6- to 12-months followup, although continued use of e-cigs remained high after the treatment phase. Another trial (n=300) found a borderline statistically significant higher quit rate among those receiving nicotine-containing e-cigs (11%) vs no nicotine e-cigs (4%) at 12 months (p=0.04), but 27 percent of those who quit smoking continued to use e-cigarettes at 1 year. The remaining two trials found no statistically significant difference in biochemically verified abstinence at 6 months between those receiving e-cigs vs nicotine patch or placebo e-cig (n=807). | Inconsistent; Imprecise | Limited statistical power to detect differences and differential loss to followup in all five trials (22–50%).; Wide variance of nicotine concentrations in e-cig interventions (7.8mg vs. 18mg) | Insufficient | All five trials took place outside of the US, Korea, in New Zealand, Italy, and the UK.; Two trials used older models of e-cigs of which is no longer available.; One trial conducted among smokers not wanting to quit.
3: Harms | Combined pharm and behavioral | 0 reviews^#^ | NA | NA | NA | Moderate evidence of no harms | NA
3: Harms | Pharm | 15 reviews^#^ | NRT, bupropion, and varenicline were not associated with an increased risk in major CV or neuropsychiatric adverse events. NRT was associated with a higher rate of any CV adverse events largely driven by low-risk events, typically bradycardia and arrhythmia. There was no evidence of a difference in harms associated with medications for those with versus without severe mental illness. | Reasonably consistent; Reasonably precise | Many trials that report cessation effectiveness do no report AEs, particularly CV- or neuropsychiatric-specific AEs.; AEs typically measured through passive reporting and therefore susceptible to underreporting. | Moderate evidence of no serious harms | Findings appear applicable across populations and settings, including among patients with severe mental illness.
3: Harms | Behavioral | 3 reviews^#^ | There was no evidence that behavioral tobacco cessation interventions are associated with serious adverse events. | NA | Very few reviews assessed AEs related to behavioral interventions. | Moderate evidence of no harms^**^ | Limited evidence on harms limits applicability.
3: Harms | Electronic cigarettes | 9 RCTs (n=3942) | No trials reported serious AEs in either the intervention or control groups related to product use and no significant differences in the frequency of AEs among study groups. Coughing, nausea, throat irritation and sleep disruption were the most commonly reported side effects of e-cig use. | Reasonably consistent; Imprecise | Limited statistical power to detect differences and differential loss to followup in all three trials (22–39%).; One study did not report methods for AEs reporting. | Insufficient | The two US trials had the lowest enrollment (<100 participants).; Two trials used older models of e-cigs, one of which is no longer available, one trial used an e-cig that is not available in US markets, and one trial used a prototype.

* Number of included studies reflects the number of systematic reviews designated as primary evidence for that body of evidence as well as the summed total number of included studies and observations from each review.

† For our review-of-reviews method, we adopted the strength of the overall body of evidence assigned within the primary systematic review. In most cases, these grades were based on the Grading of Recommendations Assessment, Development and Evaluation (GRADE) working group definitions which consider study limitations, consistency of effect, imprecision, indirectness and publication bias. Where strength of evidence grades were not available, we adapted the EPC approach to assign an overall strength of evidence grade based on consensus discussions involving at least two reviewers.^78^

‡ Some evidence of asymmetry in a funnel plot; excess of small trials detecting larger effects. However, in a sensitivity analysis, removing smaller studies did not markedly decrease the pooled estimate.

§ Sensitivity analysis including only those studies judged to be a low risk of bis did not impact the pooled results for any comparison; for NRT and bupropion, the funnel plots showed some evidence of asymmetry. However, given the large number of trials in these reviews, this does not suggest the results would be altered significantly were smaller studies with lower RRs included.

‖ Evidence from existing systematic reviews as well as the EAGLES trial indicate that adult smokers randomized to varenicline have a statistically significant higher likelihood of quitting smoking at 6 months compared with those randomized to NRT or bupropion. In the EAGLES trial (n=8144) 21.8% of smokers randomized to varenicline quit smoking at 6 months compared with 15.7% randomized to NRT (OR 1.52 [95% 1.29 to 1.78]) and 16.2% randomized to bupropion (OR 1.45 [95% CI, 1.24 to 1.70]).^161^

¶ Quality of the evidence differs for each specific type of intervention, but generally reflects moderate to high certainty grades. Most common reasons for downgraded the quality of evidence were unexplained statistical heterogeneity, several studies with high or unclear risk of bias, or inconsistency in the evidence base.

# Total number of studies and observations not estimated

** Despite the relatively limited number of reviews that reported harms related to interventions, we are moderately confident that there are no serious harms related to combined pharmacotherapy and behavioral counseling interventions or behavioral counseling alone for tobacco cessation.

Abbreviations: AE = adverse event; CI = confidence interval; CV = cardiovascular; e-cig = electronic cigarette; mg = milligrams; NA = not applicable; NRT = nicotine replacement therapy; pharm = pharmacotherapy; RCT = randomized controlled trial; RR = risk ratio; UK = United Kingdom; US = United States

We have moderate to high confidence that all seven FDA-approved medications for tobacco cessation, a variety of behavioral support and counseling approaches, and the combination of pharmacotherapy plus behavioral support—all interventions that may be readily available to primary care patients and clinicians—can significantly increase the rate of smoking cessation at 6 months and longer compared with usual care or brief self-help materials (KQ 2) (Table 13). Treatment effects appear to be comparable in a range of populations, settings, and types of behavioral support. Furthermore, despite adding nearly 5 more years of research, the effect estimates for each pooled comparison have been remarkably stable for at least the past three decades (i.e., the time period in which these reviews have been completed and updated). Analyses of combined pharmacotherapy and behavioral counseling interventions suggested an increase in smoking cessation by 68 to 98 percent (RR 1.83) compared with usual care or brief cessation advice or self-help. Likewise, there was clear evidence of effectiveness of pharmacotherapy on smoking abstinence. Based on research involving almost 65,000 smokers, nicotine replacement therapy in any form was effective in increasing relative quit rates by 49 to 61 percent (RR 1.55) compared with placebo or no NRT. A smaller yet still robust body of evidence (27 trials representing over 12,000 smokers) comparing varenicline with placebo found relatively larger effects on smoking cessation (RR 2.24 [95% CI, 2.06 to 2.43]) (defined stringently as 100% biochemically verified continuous abstinence). The absolute differences in mean cessation rates between the medication and control arms was 6.4 percent (16.9% vs. 10.5%), 8.2 percent (19.7% vs. 11.5%), and 14.5 percent (25.6% vs. 11.1%), for NRT, bupropion, and varenicline, respectively. Certain combinations of these medications (e.g., long-term NRT patch plus NRT gum, NRT patch plus bupropion) may also increase quit rates compared with no intervention or a single medication; but fewer trials have tested each combination. Direct comparisons of these drugs, including those with the EAGLES trial,^161^ consistently showed that 12 weeks of treatment with varenicline produced higher statistically significant absolute and relative effects on rates of smoking cessation versus NRT and bupropion. No differences have been found between the relative effectiveness of NRT and bupropion in direct or indirect comparisons.

Although often reported as “pharmacotherapy” interventions in our report for brevity, we note that these interventions almost always include some level of behavioral support that is offered to both medication and placebo arms. In trials, the level of behavioral support is often more intense than what is seen in real world settings where most smokers who use cessation medications do not access any type of behavioral support.^29^ Robust observational studies have found no relationship between the use of medications and smoking abstinence, especially when not paired with brief advice or behavioral support.^188,^ ^189^ The incremental effect of adding additional behavioral support to pharmacotherapy versus pharmacotherapy alone or with minimal behavioral support was found to be small but statistically significant (RR, 1.15 [95% CI, 1.08 to 1.22]). In these trials, both arms on medication achieved high rates of quitting (mean quit rates in intervention vs. control, 19.5% vs. 17.1%), and the incremental difference in intensity of the behavioral support between arms was quite modest, about a 0.5 to 5 hours difference in intervention contact time.

Research on behavioral support interventions spans a broad range of approaches, including in-person advice and support from health care clinicians or tobacco cessation counselors to a plethora of non-face-to-face formats (tailored and nontailored self-help materials, quitlines, outreach or “proactive” telephone counseling, mobile phone-based interventions, and internet interventions). Compared with various controls, these behavioral interventions produced modest increases in relative smoking cessation at 6 months or more (15% to 88%). Physician or nurse advice, even brief, resulted in a significant relative increase in smoking cessation compared with usual care or self-help materials (RR 1.76 [95% CI, 1.58 to 1.96] and RR 1.29 [95% CI, 1.21 to 1.38], for physician and nurse advice, respectively). These results suggest that there are many effective approaches to aid cessation, and that because of the wide array of options, smokers – with their clinicians – can choose an option that works best for them.

Within and between reviews, there was no strong evidence that specific study, population, or intervention characteristics predicted larger effects or that certain types of behavioral support were more effective than others. The direct evidence on such comparisons was synthesized in many of the reviews but is based on far fewer trials. Furthermore, very few reviews presented direct comparisons of the effects of tobacco cessation interventions between specific subgroups of adults (e.g., those at high risk vs. not at high risk for cardiovascular disease, men vs. women, those with vs. without severe mental illness). Twenty-one reviews summarized the effectiveness of pharmacotherapy and/or behavioral interventions for specific subpopulations of adults (e.g., studies limited to smokeless tobacco users, indigenous populations, those with schizophrenia). None of these reviews suggested findings that differed in direction or magnitude of effects on smoking cessation.

The mean quit rates in the control groups across all the reviews was highly variable, ranging from approximately 5 percent (in trials among smokers receiving usual care in primary care) to approximately 11 to 15 percent (in trials including minimal tobacco cessation behavioral support to control groups). However, the relative effects of the interventions were much less variable and the general absence of substantial heterogeneity between trials within given bodies of evidence makes for reliable estimate of relative effects. If we assume an unassisted quit rate of 5 percent at 12 months in a population of adults attending primary care and use the confidence intervals of interventions using physician advice, 1.58 to 1.96, the result is a number needed to treat (NNT) of 21–34 for additional benefit. If we use the pooled estimate from nurse advice versus usual care, we would decrease the lower confidence interval (1.21) and increase the upper estimate of the NNT to 95. If we assumed a higher quit rate in the usual care control groups (e.g., 10%), less smokers would be needed to treat to see an additional benefit of more intensive advice and/or medications (<20).

There was no evidence of an increased risk of serious AEs, including major cardiovascular AEs and serious neuropsychiatric AEs, among the general adult population associated with NRT, bupropion, or varenicline (KQ 3) (Table 13). NRT was associated with a higher rate of any cardiovascular event, although this was largely driven by low-risk events, typically tachycardia (a well-known risk). Reviews that included AEs related to medication use among individuals with severe mental illness found no difference between study groups in the rates of AEs, including a worsening of psychiatric symptoms or serious psychiatric events (suicide or suicidal ideation).

In contrast to the robust evidence on pharmacotherapy and behavioral interventions for smoking cessation, our review identified only four RCTs that provide data on the use of e-cigarettes versus placebo e-cigarettes or NRT for quitting conventional smoking at 6 or more months’ followup (Table 13). We did not identify any primary evidence on the use of e-cigarettes as tobacco cessation interventions that reported health outcomes. In two of the five trials (n=2008), smokers randomized to e-cigarettes containing nicotine (with or without the co-use of NRT) were found to have statistically significantly greater rates of abstinence than those randomized to NRT alone or NRT plus non-nicotine e-cigarettes at 6- to 12-months followup. In both trials, continued use of e-cigarettes was high at 6- and 12-months followup (~3–9 months after the treatment phase) with 45 to 80 percent of participants still using nicotine-based e-cigarettes as opposed to only 9 to 40 percent of participants still using NRT. Another trial compared the use of e-cigarettes (two arms using different nicotine concentrations) with placebo at 12 months and found 11 percent abstinence in the nicotine containing e-cigarette groups compared to 4 percent abstinence in the placebo group (p=0.04) but 27 percent of those who quit smoking continued to use e-cigarettes at 1 year. The remaining trial reported no clear difference in the rates of smoking cessation among those randomized to nicotine e-cigarettes versus placebo e-cigarettes at 6 to 12 months’ followup. Surprisingly few trials (8 identified in this review) and no large (n>1000) observational cohort studies reported on the potential AEs of e-cigarette use when used to try to quit smoking. This is particularly concerning given the apparent longer-term use of e-cigarettes for cessation compared to pharmacotherapy. The paucity of trial data on AEs related to e-cigarette use is part of the ongoing debate regarding the appropriateness of their use as a cessation tool. However, none of the included trials reported statistically significant differences in rates of serious AEs between intervention and control groups. A 2019 outbreak of e-cigarette, or vaping, product use-associated lung injury (EVALI) involving more than 2800 cases, including 68 deaths, is discussed further below.^190^

### Pregnant Women

Evidence on the potential benefits and harms of pharmacotherapy for smoking cessation during pregnancy is limited, with few efficacy trials and limited power for detecting both potential benefits and harms (Table 14). Our review identified seven trials (five of which were placebo controlled) that evaluated the potential benefits and harms of NRT among pregnant women; our review included no trials evaluating other pharmacotherapies. Across the included trials, there were mixed findings for birth outcomes (KQ 1). Only one small trial had statistically significant findings of a benefit across birthweight, low birthweight (<2500 grams) and preterm birth (<37 weeks) outcomes. The largest trial provided evidence from 2-year followup data that survival without impairment was higher with NRT vs. placebo. However a separate study found no association between maternal smoking status and infants’ development impairment at 2 years (thus, that there was no evidence of better infant development among infants born to women who were randomized to NRT resulted from smoking cessation induced by nicotine patch use). The trials reported other rare outcomes such as stillbirth but were underpowered for detecting differences in potential adverse consequences of NRT use in pregnancy. Evidence from five large cohort studies did not find differences in stillbirth, birth outcomes, or any congenital anomaly for infants born to mothers with exposure to NRT, bupropion, or varenicline versus those who were unexposed to medications but whose mothers smoked, but incomplete adjustment for confounding limit these findings. Based on the evidence, we could not rule out the possibility of health benefits or of potential harms of smoking cessation medication use in pregnancy.

Table 14 Summary of Evidence for Pregnant Women

Key Question | Intervention | Number of included studies^*^ | Summary of findings | Consistency and precision | Other limitations | Strength of evidence^†^ | Applicability
1: Health outcomes | Pharm | 7 RCTs (n=2285) | Limited evidence of NRT on perinatal and child health benefits. Five placebo controlled NRT trials reported preterm births with the three largest trials reporting effects close to null and two reporting reduced risk with NRT. These five trials also reported birthweight; the two largest placebo-controlled trials reported no difference with NRT, and two trials reported higher mean birthweights associated with NRT. The risk for low birthweight was lower in the smallest trial, and results were mixed but null for the others.; Followup data from the largest NRT trial found higher rate of ‘survival with no impairment’ at 2 years among children of women assigned to NRT intervention vs placebo (73% vs 65%; OR 1.40 [95% CI 1.05 to 1.86]).; No trials of bupropion or varenicline among pregnant women. | Inconsistent; Imprecise | Rare health outcomes and few trials of NRT limited statistical precision and ability to draw conclusions.; Limited information on the women approached for participation that declined, and low participation rates.; Timing of the final antenatal assessment varied considerably among trials which may affect the amount of time women were exposed to the intervention as well as those lost to followup and measurement of perinatal outcomes. | Insufficient evidence for birth outcomes and child health outcomes | Trials mainly conducted in high-income countries including the US, relevant and applicable.; Pharmacotherapy trials were mostly placebo controlled and outcomes based on well-established measures used in routine health care settings, likely applicable results.; Given stigma of smoking during pregnancy, challenging to recruit pregnant smokers. Those who disclose smoking status and willing to participate in trials may differ from general population (e.g., motivation to quit).
1: Health outcomes | Behavioral | 1 review (26 RCTs, n=12,338) | Suggestive benefit of behavioral interventions on mean birthweight (mean difference, 55.60 [95% CI, 29.82 to 81.38]) and low birthweight (RR 0.83 [95% CI 0.72 to 0.94]), vs. usual care or control.; Uncertain evidence on the effect of behavioral interventions on preterm birth (RR 0.93 [95% CI, 0.77 to 1.11]) and stillbirths (RR 1.20 [95% CI, 0.76 to 1.90]). | Reasonably consistent; Reasonably precise | | High evidence of potential benefit on mean birthweight and risk of preterm birth
1: Health outcomes | Electronic cigarettes | 0 | NA | NA | NA | Insufficient | NA
2: Cessation outcomes | Pharm | 7 RCTs (n=2285) | No statistical evidence of NRT efficacy for validated smoking cessation in late pregnancy (RR 1.11, 95% CI 0.79 to 1.56) in pooled analysis of five placebo-controlled trials. Limited power, and all trials in the direction of benefit including two trials with no NRT control conditions.; No trials of bupropion or varenicline among pregnant women. | Reasonably consistent; Imprecise | Limited information on the women approached for participation that declined, and low participation rates. | Low evidence of no benefit | Trials mainly conducted in high-income countries including the US, relevant and applicable.; Pharmacotherapy trials were mostly placebo controlled and outcomes based on well-established measures used in routine health care settings, likely applicable results.; Given stigma of smoking during pregnancy, challenging to recruit pregnant smokers. Those who disclose smoking status and willing to participate in trials may differ from general population (e.g., motivation to quit).
2: Cessation outcomes | Behavioral | 1 review (97 RCTs, n=26,637) | The pooled estimate from 97 trials suggested an increased risk of quitting smoking in late pregnancy for psychosocial interventions compared with controls (RR 1.35 [95% CI, 1.23 to 1.48]), with a similar benefit when limited to the most common intervention (counseling) versus usual care (RR 1.44 [95% CI 1.19 to 1.73]); Heterogeneity was moderate for the pooled effect (44%), but there was no definitive evidence of subgroup effects by study, population, or intervention characteristics. | Reasonably consistent; Reasonably precise | Minimal information on the number of women who were eligible for inclusion or were approached to take place in the trials.; Timing of the final antenatal assessment of smoking status varied considerably among trials which may affect the amount of time women were exposed to the intervention as well as those lost to followup. | Moderate evidence of benefit
2: Cessation outcomes | Relapse prevention | 1 review (18 RCTs, n=5545) | No clear clear benefit on relapse prevention at the end of pregnancy (RR 1.05 [95% CI, 0.99 to 1.11]; k=8; n=1523; I^2^=0%) or during the postpartum period ( RR 1.02 [95% CI, 0.94 to 1.09]; k=15; n=4606; I^2^=3%). | Inconsistent; Imprecise | Variable interventions tested | Low evidence of no benefit of behavioral interventions
2: Cessation outcomes | Electronic cigarettes | 0 | NA | NA | NA | Insufficient | NA
KQ3: Harms | Pharm | 7 RCTs (n=2285); 5 cohort studies (n=1,293,379) | Limited evidence of perinatal harms from NRT; mixed findings on birth outcomes from trials, but most in direction of benefit rather than harm (KQ 1). Two-year followup from one NRT trial did not suggest harms (KQ 1). No trials of bupropion or varenicline among pregnant women. Observational evidence did not indicate harms of major congenital anomalies, stillbirth, premature birth, or low birthweight associated with NRT, bupropion, or varenicline. | Inconsistent; Imprecise | Few trials of NRT and not all reported consistently on health outcomes and adverse events.; Observational studies may not be able to fully account for confounding, substantial differences across a range of population characteristics among comparison groups. | Low evidence of no harm | Trials mainly conducted in high-income countries including the US, relevant and applicable.
KQ3: Harms | Behavioral | 1 review (13 RCTs, n=5831) | There did not appear to be any adverse effects from the psychosocial interventions. Five of 13 trials evaluating psychological impact reported an improvement in women’s psychological well-being and none reported a negative impact. | Reasonably consistent; Reasonably precise | Measures of adverse events rarely reported; most reliant on passive reporting. | Moderate evidence of no harm | Trials mainly conducted in high-income countries including the US, relevant and applicable.
KQ3: Harms | Electronic cigarettes | 0 | NA | NA | NA | Insufficient | NA

* Number of included studies reflects the number of systematic reviews designated as primary evidence for that body of evidence as well as the summed total number of included studies and observations from each review.

† For our review-of-reviews method, we adopted the strength of the overall body of evidence assigned within the primary systematic review. In most cases, these grades were based on the Grading of Recommendations Assessment, Development and Evaluation (GRADE) working group definitions which consider study limitations, consistency of effect, imprecision, indirectness and publication bias. Where strength of evidence grades were not available, we adapted the EPC approach to assign an overall strength of evidence grade based on consensus discussions involving at least two reviewers.^78^

Abbreviations: NA = not applicable; NRT = nicotine replacement therapy; pharm = pharmacotherapy; US = United States; vs = versus

There was evidence of statistically significant infant health benefits from behavioral tobacco cessation interventions among pregnant women (KQ 1). In pooled analyses, the mean birthweight of infants was modestly higher in the intervention group when considered across all types of interventions and when limited to counseling interventions. Consistent with this finding, the risk for low birthweight (<2500g) was also reduced with behavioral interventions. Meta-analysis of the trials reporting preterm birth resulted in statistical uncertainty for the estimate of a small potential benefit of behavioral interventions compared with controls. The number of trials reporting outcomes and event rates for very low birthweight, stillbirth, and neonatal death was too low to estimate effects with enough precision to draw conclusions.

In terms of the effects of interventions on smoking cessation outcomes, there was considerably more evidence available on the effects of behavioral interventions during pregnancy than for pharmacotherapies (Table 14). Based on pooled data from trials among over 26,000 women, behavioral interventions were more effective than usual care or minimal support for smoking cessation in late pregnancy (RR 1.35 [95% CI, 1.23 to 1.48]). Although the most common type of intervention was counseling, trials of financial incentive interventions, feedback, and health education had consistent findings of benefit, including some significant individual trials. There was some evidence that the positive effects on smoking cessation in late pregnancy continued into the postpartum period until approximately 18 months postpartum, although the smaller effect sizes show that many women who did quit during pregnancy relapsed postpartum.

In contrast, there was no evidence of NRT efficacy for validated smoking cessation in late pregnancy based on the currently available evidence (five placebo-controlled trials), although most trials reported slightly more cessation events in the intervention group. The low adherence to NRT reported in the trials hinders interpretation of the evidence since potential benefits and harms from exposure to NRT are more difficult to discern when exposure is limited and variable.

In terms of potential harms related to NRT cessation interventions used during pregnancy, the available evidence is somewhat reassuring in terms of common health outcomes, such as birthweight, but there was limited power to rule out potential rare harms (KQ 3) (Table 14). While there was no evidence showing differences in rare outcomes such as miscarriage, stillbirth, and neonatal death, these data are sparse and limited. There was no evidence of AEs related to behavioral interventions among pregnant women.

## E-Cigarettes

Laboratory tests of e-cigarette ingredients, in vitro toxicological tests, and short-term human studies suggest that e-cigarettes are likely less harmful in the short-term than combustible tobacco cigarettes. The 2018 National Academies of Sciences, Engineering, and Medicine (National Academies) report on the “Public Health Consequences of E-Cigarettes” concluded that there was substantial evidence that except for nicotine, under typical conditions of use, exposure to potentially toxic substances from e-cigarettes is significantly lower compared with combustible tobacco cigarettes.^5^ However, due to the lack of long-term epidemiological studies and large clinical trials, the associations between e-cigarette use and morbidity and mortality, especially in the long-term, are not yet clear. Furthermore, much is unknown about their absolute safety profile including concerns about the toxic properties of the variable combination of chemicals present in e-liquids and the additional chemicals generated during the aerosolization of e-liquids.

From August 2019 to February 2020, CDC, the FDA, state and local health departments, and public health and clinical stakeholders investigated a nationwide outbreak of e-cigarette, or vaping, product use–associated lung injury (EVALI).^191^ As of February 18, 2020, a total of 2,807 hospitalized cases of EVALI and 68 deaths had been reported to the CDC from all 50 states, the District of Columbia, and 2 U.S. territories (Puerto Rico and U.S. Virgin Islands).^190^ The number of EVALI cases reported to CDC peaked during the week of September 15, 2019, and steadily declined since that time.^190^

Laboratory data, including analyses of bronchoalveolar lavage (BAL) fluid samples of patients with EVALI, show that vitamin E acetate was strongly linked to the EVALI outbreak. Vitamin E acetate is an additive in some tetrahydrocannabinol (THC)-containing e-cigarette, or vaping, products.^192^ A study analyzed samples from 51 EVALI cases from 16 states and a comparison group of samples from 99 individuals without EVALI for vitamin E acetate and other toxicants; vitamin E acetate was identified in BAL fluid samples from 48 of 51 EVALI patients, but not in the BAL fluid from the comparison group.^192^ In an analysis among those hospitalized with EVALI, 82 percent reported using THC-containing products (with 33% reporting exclusive use of THC-containing product) and 57 percent reported using nicotine-containing products (14% was exclusive use of nicotine).^193^ National and state data from patient reports and product sample testing showed THC-containing e-cigarette, or vaping, products, particularly from informal sources like friends, or family, or in-person or online dealers, were linked to most of the cases and played a major role in the outbreak.^193^ Given this data, the CDC and FDA recommend that people not use THC-containing e-cigarette, or vaping, products, particularly from informal sources like friends, family, or in-person or online dealers^193^. Additionally, CDC and FDA recommend Vitamin E acetate should not be added to any e-cigarette, or vaping, products and people should not add any other substances not intended by the manufacturer to products, including products purchases through retail establishments. CDC recommends that adults using nicotine-containing e-cigarettes or vaping products as an alternative to cigarettes should not go back to smoking; they should weigh all available information and consider using FDA-approved cessation medications.^193^ Guidance also suggests that healthcare providers evaluating patients with respiratory symptoms should ask them about e-cigarette, or vaping, product use, evaluate whether they require hospital admission, consider empiric use of antimicrobials, including antivirals, and consider cautious use of corticosteroids.^194^ Those hospitalized for EVALI should be followed up, optimally within 48 hours of discharge, to reduce the risk of rehospitalization and death.^195^

Finally, the nicotine in the e-liquid can be hazardous if mishandled and is toxic to children. A national review of over 4000 e-cigarette related poison center calls found that monthly calls regarding e-cigarette exposures in children increased by almost 16 times during the three-year study period. Compared with other tobacco products, children exposed to e-cigarettes had 5.2 times high odds of health care facility admission and 2.6 times higher odds of a severe outcome.^196^ Studying the toxicity and safety of e-cigarettes is complicated by the large variation in devices and cartridge fluids available, and the new products rapidly entering the market.

Understanding the public health implications of e-cigarette use at the population level necessitates consideration of not only the risks of e-cigarettes on individual health outcomes, but also the relationship between e-cigarette use and the use of other tobacco products – namely combustible cigarettes. The context surrounding e-cigarette use is markedly different in adolescents and young adults versus middle-aged and older adults. Among high school students, current e-cigarette use fell from 2015 to 2016 before increasing from 2016 to 2017 and increasing sharply from 2017 to 2018; among middle school students, current e-cigarette use fell from 2015 to 2016 and from 2016 to 2017 before increasing sharply from 2017 to 2018.^197^ Some of the main conclusions of the National Academies 2018 report was that there was substantial evidence that e-cigarette use increases risk of ever using combustible tobacco cigarettes among youth and young adults and moderate evidence that e-cigarette use increases the frequency and intensity of subsequent combustible tobacco cigarette smoking among those who had ever used combustible cigarettes.^5^

The relationship between e-cigarette use and combustible tobacco use among adult smokers could take many pathways, including promoting cessation of combustible cigarette smoking (transitioning to e-cigarette use alone or quitting both products), causing former smokers to relapse to combustible smoking after e-cigarette use, or in facilitating dual use of both products simultaneously.^5^ Among adults, nearly all e-cigarette users report having started e-cigarette use after having been a regular smoker^198^ and most report that quitting smoking and health improvement are major reasons for starting e-cigarettes use.^199,^ ^200^ Given what we know about the relative safety of e-cigarettes compared with combustible cigarettes, established combustible tobacco smokers who completely switch to using e-cigarettes would be expected to reduce their tobacco-related health risks. Unfortunately, more than half of adults who report using e-cigarettes also report current smoking.^201^ Additional benefit would be expected if e-cigarette users subsequently stopped using both e-cigarettes and combustible tobacco products. Unfortunately, we found no studies meeting inclusion criteria that reported on potential health benefits related to e-cigarette use for quitting smoking among current smokers (Table 13). Our review identified five RCTs that examined use of e-cigarettes (with or without NRT) for conventional cigarette cessation at 6 months or longer. Evidence from two recent trials indicated that nicotine-based e-cigarettes (with or without co-use of NRT) may be superior in effectiveness to FDA-approved forms of NRT alone or e-cigarettes that contain no nicotine. The observed self-reported quit rates at 6 months in these two trials varied considerably: one trial reported 35 percent of e-cigarette users (versus 25% in the NRT group) quitting combustible smoking whereas the other reported 18 percent of e-cigarette plus patch users (versus 8% of patch users) quitting smoking. Though the treatment phase in both studies was 12 weeks, more than half of participants continued using e-cigarettes at 6 to 12 months followup, substantially more than subjects who were assigned NRT.

None of the nine trials included in our review to evaluate harms reported any serious AEs considered to be plausibly related to e-cigarette use. Moreover, we found no trials or large cohort studies reporting on long-term health outcomes of e-cigarettes. The paucity of long-term data on AEs and health outcomes related to use is of concern given the recent reports of severe lung injury and the uncertainty about how long persons who use e-cigarettes to quit smoking continue their e-cigarette use even after quitting smoking.

## Limitations of the Review

Our review has several limitations, including our overview of reviews approach, the methods and quality of the included reviews that synthesized the bodies of evidence, and the primary studies themselves.

The comprehensiveness of our overview of reviews is inevitably limited by the recency and quality of the source reviews. Although most of the primary reviews that served as the basis for the Primary results included evidence at least through 2015, there may be evidence on population and intervention subsets that has been published after each review’s last search date. If this occurred, the respective bodies of evidence may not reflect these newer studies. Given the consistency of the effects within each group over time, however, we expect that any new trials regardless of their sample size and effect estimates would have little bearing on the overall results of this overview of reviews.

By adopting an overview of reviews approach, we relied on the data as described and assessed by the original reviewers. In doing this we trusted that each review generally included the full available and eligible evidence base, that the data abstraction was accurate, and that the analyses were scientifically sound. We did apply scientific judgment when choosing which reviews to present as the basis for the primary findings and which pooled data were appropriate to present. For instance, although review authors may have presented several pooled analyses based on various subgroups within the main analysis, we carefully chose which data to include in our synthesis based on our a priori questions of interest (e.g., type and intensity of intervention, setting and provider, participant selection, verification of abstinence measures). We did not reassess the risk of bias or quality of individual trials; instead we reviewed the risk of bias as presented in the review and interpreted results considering these potential biases. Although we did not quality-rate the reviews based on the specific choice of meta-analytic models (i.e., random vs. fixed effects), we were cautious about reporting pooled results for small numbers of studies or highly heterogeneous bodies of evidence. We did not present pooled estimates for meta-analyses of less than six studies except in the case of a small number of highly clinically and statistically homogeneous trials (e.g., NRT among pregnant women). We also narratively described results rather than presenting pooled estimates in cases of substantial or considerable statistical heterogeneity produced in meta-analyses. Twenty-seven of the 33 primary reviews were Cochrane reviews. The general consistency and rigor of methods employed by the review authors^202^ strengthen this overview of reviews. Furthermore, we quality-rated each review according to AMSTAR 2 criteria^73^ and relied upon the available best-quality reviews for each body of evidence.

We did not describe or cite individual trials because of the large volume of trials represented among the primary reviews (over 1400). Although our text and descriptive tables provide some information on the types of interventions included in the bodies of evidence, we did not include a detailed description of each intervention or replicate the study characteristics data that were presented by the original review authors. More detailed information is available in the original reviews.

Because the included reviews were not mutually exclusive in their eligibility criteria and, as a result, were not mutually exclusive in their included studies, there are individual trials that are represented in more than one review and/or meta-analysis, particularly for trials related to behavioral interventions in adults. We could not address this overlap by recalculating all the estimates reported in reviews, but we do not expect such adjustments would alter our conclusions. By basing our estimates on primary reviews rather than reporting results from multiple reviews, we likely mitigated this potential shortcoming.

Furthermore, our presentation of results was limited according to the categories of interventions that have been systematically reviewed. That is, we present pooled findings according to categories of interventions that were developed by the systematic reviewers themselves – namely the Cochrane Tobacco Group. While we believe the totality of reviews to reflect the majority of tobacco cessation trials that are applicable to primary care in the United States (e.g., physician advice, nurse advice, group counseling, telephone-based counseling), there still may be applicable tobacco cessation trials that are not represented in any of the source reviews given scoping decisions. Additionally, our reporting of stratified analyses and potential population and intervention effect moderators was limited by the analyses and reporting by included reviews. While most reviews did conduct prespecified stratified analyses and meta-regression, there were few variables that were explored across all reviews.

While we did not re-evaluate the risk of bias within individual trials, several limitations are applicable to all included studies. Biochemical validation of self-reported quitting ranged from less than a quarter of included studies to 100 percent of trials within the included reviews. Most of the reviews that had a smaller percentage of included studies that required biochemical validation included a higher percentage of large community-based samples and included limited face-to-face contact (e.g., print-based self-help materials, telephone counseling, and computer-based interventions). It should be noted that the Society for Research on Nicotine and Tobacco subcommittee on measurement considers that verification is not necessary under these conditions.^220^ It is also important to remember that while biochemically validated findings will almost always reduce the absolute quit rate, the absence of validation will only lead to an overestimate of effects if intervention participants are more likely to misreport abstinence than control group participants. The likelihood of differential misreporting is small among those studies of large community-based samples with limited face-to-face contact. Similarly, while results based on point prevalence abstinence and sustained abstinence measures are strongly related and almost always result in similar relative effects, the absolute rates often differ with sustained or continuous abstinence rates averaging around 50 to 70 percent of point prevalence rates.

There is some evidence that industry funding is associated with greater NRT efficacy; but not for bupropion and is less clear for varenicline.^203,^ ^204^ This association for NRT may be an indication of a selection bias to publish trials with positive but not negative results. The possibility of small studies effects or potential publication bias is supported by the review we included here that found some evidence of asymmetry in a funnel plot for trials included in the main NRT vs. placebo comparison. Another reasonable explanation, however, is that industry-funded trials often recruit participants who are less likely to quit without medication (heavier smokers) and result in much lower quit rates among control group participants. One review^203^ found that industry funding was associated with lower odds of quitting smoking among varenicline versus placebo conditions, but the effect was entirely due to two influential trials. Thus, it is somewhat unclear if industry function influences varenicline trials.

Finally, the mechanism by which AEs are recorded (generally passively) makes them susceptible to underreporting. As a result, these findings may be less reliable than for those related to abstinence outcomes.

## Applicability

Most of the included studies within each review were conducted in North America and, as such, should be applicable to the U.S. health system. Most studies enrolled only individuals who were smokers who were generally motivated to quit with varying degrees of baseline smoking (i.e., cigarettes smoked per day) and nicotine dependence. These trials took place within a very wide range of settings with different types of providers and included individuals with smoking-related disease and those with mental health conditions. The literature almost exclusively addressed treatment for cigarette smoking, as opposed to the use of other forms of tobacco, so the results may not be generalizable to all forms of tobacco. The homogeneity of results across interventions and specific populations reflects the general applicability of the evidence. To that end, we believe the body of evidence represented in this overview of reviews is very applicable to primary care in the United States. Synthesized information regarding the details of the types of behavioral support represented in this review is provided in Appendix H to provide guidance to those wishing to implement smoking cessation interventions.

The available evidence on the use of e-cigarettes to help smokers quit smoking has very low applicability to clinical practice in the United States. Most importantly, giving the rapidly changing landscape of available products (we are currently in the fourth generation of products), the devices that were tested in the included trials are almost all either not available on the market or in the United States anymore or are not being used by most users. Furthermore, within trials, investigators are typically providing specific e-cigarette devices with predefined nicotine doses and schedules; whereas, clinically, we have no guidance on the appropriate devices, delivery of nicotine (e.g., liquid, salt), or dose that would be most effective to prescribe.

## Future Research Needs

The findings of these reviews, and the estimated sizes of the treatment effects, have remained remarkably stable over nearly three decades of evidence for the majority of smoking cessation interventions. For instance, in the original Cochrane review on nurse advice to support tobacco cessation published in 1999, 15 studies contributed to the main analysis, with a pooled RR of 1.30 (95% CI, 1.16 to 1.44). The number of studies and participants have more than doubled (now 44 trials and over 20,000 participants) and thus narrowed the CIs but have had very little impact on the point estimate, which in this most recent update is essentially the same as it was in 1999 (RR 1.29 [95% CI, 1.21 to 1.38]). Likewise, the Cochrane review on NRT was first published in 1996. Despite the number of included studies more than doubling over this time, the effect estimate has remained stable (and represents 136 trials) and per the Cochrane Tobacco Addition group, this latest review on NRT compared with placebo will be its final review on this subject. The review states: “In summary, based on 20 years of research and 136 randomized controlled trials in over 64,000 participants, we believe the question of whether NRT helps people to quit smoking to be definitively answered. We consider that further research is highly unlikely to change our confidence in the effect of NRT, and funders and researchers should give careful thought before pursuing further studies comparing established forms of NRT with control.”

This is not to say that all questions about tobacco cessation interventions have been answered. Evidence is still needed to compare different forms, doses, and durations of drugs; to compare drugs with one another; and to test interventions in special populations for which we may reasonably hypothesize that effectiveness differs from that in the general population (e.g., pregnant women, persons with current severe mental illness, those with physical disabilities, nondaily and intermittent smokers), including direct subgroup comparisons. Furthermore, given the promising results of a few trials testing the effectiveness of cytisine and its widespread use in other countries,^205^ more research on its effectiveness, comparative effectiveness, and harms are warranted. More trial evidence on the effectiveness of medications to stop smoking with and without behavioral support (including NRT bought over-the-counter) would help elucidate the potential generalizability of the broader evidence base as applied to populations for which intense behavioral support is not being provided or sought alongside medication-based treatment. Additionally, though the evidence has grown over the past 5 years in these areas, more research is warranted on the effectiveness of remotely delivered interventions such as internet- and mobile phone-based interventions. Though a few reviews sought to include trials evaluating tobacco cessation smartphone applications, none were identified that met inclusion criteria. Given the plethora of these programs that are publicly available,^206^ future research should be conducted to evaluate their effectiveness on long-term smoking rates. More research is also needed on adapting interventions for diverse populations. Most research in this area has focused on cessation of cigarette smoking. More research is needed on interventions to help people quit other tobacco products such as cigars, smokeless tobacco, and e-cigarettes. Finally, there is a pressing need for future research on relapse prevention to aid in long-term cessation as well as the optional duration of treatment to maximize long-term abstinence.

Given the variation and the limited evidence available from well-designed studies on the association between e-cigarette use and smoking cessation, further research is clearly needed. To definitively answer the question of e-cigarette efficacy for tobacco cessation, trials must compare an e-cigarette intervention with no intervention and with the most effective known combination of pharmacotherapy and behavioral support. Only such a comparative effectiveness study could address how e-cigarette use for cessation compares with known effective intervention. Furthermore, before such research is conducted, additional strategies and research to help standardize and quantify e-cigarette use and nicotine levels is imperative. Future studies should test the more recent generation of products (namely pod mods including JUUL) or the standard research e-cigarette being developed by the National Institute on Drug Abuse and supported through a small business innovation research contract to NJOY.^207^ Additionally, research on other new tobacco products, including heated tobacco products such as IQOS and nicotine pouches, which were recently authorized for marketing in the U.S. by the FDA,^208^ are encouraged. Studies of older variants of e-cigarettes which are no longer available or not being used by the public are not as helpful in the context of informing clinical practice. Work to understand the types of e-cigarettes and the e-cigarette use patterns, if any, that may be associated with greater success in using e-cigarettes for smoking cessation is needed as is the types, if any, of behavioral support that are associated with greater success in using e-cigarettes for smoking cessation. Research on interventions to help dual users of conventional cigarettes and e-cigarettes quit both products is necessary as is research on potential relapse back to cigarette use among former smokers who use e-cigarettes. Urgent work is needed to better define the causes of acute, severe lung injuries associated with e-cigarette use. Research on the causes and frequency of poisonings from e-cigarette fluid and injuries from exploding devices is also needed. The long-term health effects of use have not been reported from any study to date. In addition, research is needed to examine the longer-term transition rates of young e-cigarette users to conventional cigarettes and the relapse rates of smokers who have employed e cigarettes as cessation tools. We identified several clinical trials currently under way or planned that address, or will address, the effectiveness and safety of e-cigarettes as a tobacco cessation aid that may be of interest to the USPSTF in the future (Appendix I Table 1).

Finally, further research on the effectiveness and safety of cessation medications among pregnant women is warranted. Careful collection of AEs and systems for deriving long-term consequences of exposure during pregnancy is important in future trials, and data on adherence to medications and levels of nicotine exposure from NRT relative to what occurs with smoking would also be valuable. Despite the established importance of medications in aiding cessation in general populations, few studies of pharmacotherapy use have been conducted during pregnancy. For NRT, this is likely due to concerns about the potential harms of nicotine for fetal and child development mostly inferred from animal studies or extrapolated from observed effects of smoking in pregnancy. Since exposure to nicotine is present with smoking, shifting from smoking to NRT during pregnancy could reduce the risk of adverse infant health outcomes known to be caused by smoking. A recent systematic review and meta-analysis provides evidence that the nicotine exposure from standard-dose NRT is lower than the levels seen with smoking.^209^ Moreover, if NRT were found to increase the likelihood of long-term cessation after pregnancy, reduced exposure to second-hand smoke during infancy and childhood would further increase the health benefits. Recent evidence of child health benefits from 2-year followup on the largest NRT trial highlight the importance of further research. In the absence of clear evidence that NRT increases cessation in pregnancy, however, it is encouraging that behavioral counseling interventions alone are effective for some women.

For behavioral and NRT interventions, an effort to identify and enroll more representative samples of women into trials is needed to ensure intervention effects are observed in less select populations, or to simply report clearly on the characteristics of women approached who declined participation. Others have noted the importance of qualitative and observational research to understand why adherence to NRT in pregnancy is low.^210^ The effects of smoking cessation interventions on perinatal health outcomes are not recorded uniformly, and future behavioral trials should collect a comprehensive set of key outcomes, similar to those provided in the most recent, larger NRT trials. Well-powered trials of behavioral therapies that show promise for strong effects could serve to make important contributions to maternal and child health. Although few have been conducted, trials using incentives to aid smoking cessation efforts suggest possibly strong effects, but it is unknown how long-term cessation efforts are affected by this kind of short-term motivation. Different interventions spanning pregnancy, the postpartum period, and beyond may also be beneficial and should include longer-term trials that combine multiple interventions in sequence and their consequences for fetal, infant, child, and maternal health. Unfortunately, we identified few registered studies that appear to address these questions (Appendix I Table 2).

## Conclusions

There is extensive evidence that confirms the effectiveness of a range of pharmacological and behavioral interventions, alone and in combination, for smoking cessation in adults. Though there has been no decline in the production, sales, or use of e-cigarettes since our previous review on this subject, research on the potential benefits of these devices to help adults quit smoking is still lacking. Furthermore, more research is desperately needed on the absolute safety profile of e-cigarettes and the long-term health consequences of their use among former smokers as well as dual users of both combustible and electronic cigarettes. There is evidence that behavioral interventions can help pregnant women to quit smoking in late pregnancy and into the postpartum period but limited evidence on the benefits and harms of pharmacotherapy in pregnant women.

Further studies of medications and behavioral support among the general adult population are unlikely to yield new information that would change the direction and magnitude of effects of the findings of this overview of reviews. Clinicians have an array of tools to offer, refer, or prescribe, improving the likelihood that patients will find an acceptable option to which they can adhere. Continued research on the evolving landscape of available tobacco products and their role in helping smokers quit combustible cigarette use, along with the long-term risks associated with these products.