# Chapter 3 Results

This report addresses two populations of interest: the general adult population and pregnant women. Within each population, results are organized first by KQ and then by intervention-specific categories.

## Evidence for Adults

### Included Evidence

We identified 64 reviews that synthesized the benefits and/or harms of tobacco cessation interventions among adults, including those among an unselected population of adults and those limited to a specific subgroup of adults (Table 2).^79–142^ Fifty-eight of these reviews were newly identified (published from 2014 to 2020) and six reviews were carried forward from our previous systematic review. The remaining reviews included in our previous report were excluded because more recent and comprehensive reviews on each population or intervention have been published. Of the 210 full-text articles that were reviewed, the most common reasons for exclusion were study design (i.e., not a systematic review; k=42), absence of prespecified outcomes or cessation outcomes at 6 months or more (k=27), and critically low-quality rating (k=23) (Appendix B Figure 1).

Table 2 Characteristics of Included Systematic Reviews by Review Focus, Intervention, and Last Search Date

Focus; (Number of reviews) | Author, Year | Primary review^*^ | Quality^†^ | Specific intervention or subgroup | Last search date | Total # of included studies | KQ 1: Health outcomes | KQ 2: Cessation | KQ 3: Harms
Benefits of combined pharmacotherapy and behavioral support; (1 review) | Stead, 2016^127^ | X | Moderate | Combined pharmacotherapy and behavioral support | July-2015 | 53 | | X
Benefits and harms of pharmacotherapy; (13 reviews) | Hartmann-Boyce, 2018^96^ | X | High | NRT | July-2017 | 136 | | X | X
Benefits and harms of pharmacotherapy; (13 reviews) | Lindson, 2019a^104^ | X | High | NRT, different doses, durations, and combinations | Apr-2018 | 63 | | X | X
Benefits and harms of pharmacotherapy; (13 reviews) | Mills, 2010^114^,^‡^ | X | Moderate | NRT (Harms only) | Nov-2009 | 120 | | | X
Benefits and harms of pharmacotherapy; (13 reviews) | Howes, 2020^98^ | X | High | Bupropion | April-2019 | 115 | | X | X
Benefits and harms of pharmacotherapy; (13 reviews) | Cahill, 2016^85^ | X | Moderate | Varenicline | May-2015 | 44 | | X | X
Benefits and harms of pharmacotherapy; (13 reviews) | Agboola, 2015^79^ | | Low | Varenicline | Sept-2013 | 19 | | X
Benefits and harms of pharmacotherapy; (13 reviews) | Sterling, 2016^128^ | X | Low | Varenicline (Harms only) | June-2015 | 38 | | | X
Benefits and harms of pharmacotherapy; (13 reviews) | Thomas, 2015^131^ | X | High | Varenicline (Harms only) | May-2014 | 44 | | | X
Benefits and harms of pharmacotherapy; (13 reviews) | Chang, 2015^87^ | X | Moderate | Varenicline + NRT | Nov-2014 | 3 | | X | X
Benefits and harms of pharmacotherapy; (13 reviews) | Windle, 2016^140^ | | Moderate | NRT, bupropion, varenicline | July-2015 | 123 | | X | X
Benefits and harms of pharmacotherapy; (13 reviews) | Mills, 2014^113^,^‡^ | X | Moderate | NRT, bupropion, varenicline (Harms only) | Mar-2013 | 63 | | | X
Benefits and harms of pharmacotherapy; (13 reviews) | Rosen, 2018^121^ | | Low | NRT, bupropion, varenicline | Dec-11, July-12, July-13 | 61 | | X
Benefits and harms of pharmacotherapy; (13 reviews) | Hollands, 2019^97^ | X | High | Support for medication adherence | Sept-2018 | 10 | | X | X
Benefits and harms of behavioral interventions; (25 reviews) | Hartmann-Boyce, 2019^95^ | X | High | Behavioral support as an adjunct to pharmacotherapy | June-2018 | 83 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Stead, 2013^125^,^‡^ | X | High | Physician advice | Jan-2013 | 42 | X | X
Benefits and harms of behavioral interventions; (25 reviews) | Rice, 2017^119^ | X | High | Nurse support | Jan-2017 | 59 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Lancaster, 2017^103^ | X | High | Individual behavioral counseling | May-2016 | 49 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Stead, 2017^126^ | X | Moderate | Group behavioral therapy | May-2016 | 66 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Lindson, 2019b^106^ | X | High | Motivational interviewing | Aug-2018 | 37 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Denison, 2017^90^ | | Moderate | Cognitive therapy | Nov-2016 | 21 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Moyo, 2018^115^ | X | Moderate | Decision aids | July-2017 | 7 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Livingstone-Banks, 2019b^109^ | X | Moderate | Print-based interventions | Mar-2018 | 75 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Matkin, 2019^110^ | X | Moderate | Telephone counseling | May-2018 | 104 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Danielsson, 2014^89^ | | Low | Telephone- or internet-based support | May-2013 | 74 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Tzelepis, 2019^134^ | X | High | Real-time video counseling | Aug-2019 | 2 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Palmer, 2018^117^ | | Moderate | Mobile phone-based support | Jan-2016 | 18 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Whittaker, 2019^138^ | X | High | Mobile phone text messaging and app-based interventions | Oct-2018 | 26 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Do, 2018^91^ | | Moderate | Mobile phone- and Internet-based interventions | Mar-2017 | 108 | | X
Benefits and harms of behavioral interventions; (25 reviews) | McCrabb, 2019^111^ | | Moderate | Internet-based interventions | Sept-2017 | 45 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Taylor, 2017^129^ | X | High | Internet-based interventions | Aug-2016 | 77 | | X | X
Benefits and harms of behavioral interventions; (25 reviews) | Graham, 2016^94^ | | Moderate | Internet-based interventions | Apr-2015 | 40 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Notley, 2019^116^ | X | High | Incentives | July-2018 | 33 | | X | X
Benefits and harms of behavioral interventions; (25 reviews) | Giles, 2014^93^ | | Moderate | Financial-based incentives | Apr-2012 | 8 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Clair, 2019^88^ | X | Moderate | Biomedical risk assessment | Sept-2018 | 20 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Ussher 2019^135^ | X | High | Exercise | May-2019 | 24 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Klinsophon, 2017^102^ | | Moderate | Exercise | Nov-2016 | 19 | | X
Benefits and harms of behavioral interventions; (25 reviews) | White, 2014^137^,^‡^ | X | High | Acupuncture | Oct-2013 | 38 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Barnes, 2019^82^ | X | High | Hypnotherapy | July-2018 | 14 | | X | X
Benefits and harms of behavioral interventions; (25 reviews) | Boyle, 2014^84^ | X | High | Electronic health records support | July-2014 | 16 | | X
Benefits and harms of behavioral interventions; (25 reviews) | Thomas, 2017^130^ | X | High | System change interventions | Feb-2016 | 7 | | X
Benefits and harms of reduction-to-quit interventions; (1 review) | Lindson, 2019c^105^ | X | High | Reduce-to-quit interventions | Oct-2018 | 51 | | X | X
Benefits and harms of relapse prevention interventions; (1 review) | Livingstone-Banks, 2019a^108^ | X | Moderate | Relapse prevention | Feb-2018 | 77 | | X
Benefits and harms of behavioral interventions in pregnant persons; (5 reviews) | Chamberlain, 2017^185^ | X | High | Any behavioral support among pregnant persons | Nov-2015 | 102 | X | X | X
Benefits and harms of behavioral interventions in pregnant persons; (5 reviews) | Griffiths, 2018^186^ | | Moderate | Digital interventions among pregnant persons | May-2017 | 12 | | X
Benefits and harms of behavioral interventions in pregnant persons; (5 reviews) | Livingstone-Banks, 2019a^108^ | X | Moderate | Relapse prevention among pregnant persons | Feb-2018 | 77 | | X
Benefits and harms of behavioral interventions in pregnant persons; (5 reviews) | Notley, 2019^116^ | | High | Incentives among pregnant persons | July-2018 | 10 | | X | X
Benefits and harms of behavioral interventions in pregnant persons; (5 reviews) | Wilson, 2018^187^ | | Moderate | Psychotherapy or incentive-based interventions | July-2017 | 22 | | X
Reviews limited to other subgroups; (21 reviews) | Wu, 2015^141^ | | Moderate | Subgroup: Adults not motivated to quit; Any tobacco cessation intervention | Apr-2015 | 14 | | X | X
Reviews limited to other subgroups; (21 reviews) | Appolonio, 2016^81^ | | High | Subgroup: Adults with alcohol or drug dependence; Any tobacco cessation intervention | Aug-2016 | 34 | | X
Reviews limited to other subgroups; (21 reviews) | Thurgood, 2016^132^ | | High | Subgroup: Adults with alcohol or drug dependence; Any tobacco cessation intervention | Aug-2014 | 17 | | X
Reviews limited to other subgroups; (21 reviews) | Wilson, 2017^139^ | | Moderate | Subgroup: Disadvantaged persons; Any behavioral support | Jan-2017 | 24 | | X
Reviews limited to other subgroups; (21 reviews) | Boland, 2016^83^ | | Low | Subgroup: Disadvantaged persons; Mobile phone- or internet-based support | May-2016 | 13 | | X
Reviews limited to other subgroups; (21 reviews) | Liu, 2013^107^,^‡^ | | Low | Subgroup: Ethnic minorities; Adapted interventions for ethnic minorities | Apr-2013 | 28 | | X
Subgroups continued | Johnston, 2013^99^,^‡^ | | Low | Subgroup: Ethnic minorities; Any tobacco cessation intervention | May-2012 | 5 | | X
Subgroups continued | Carson, 2012^86^,^‡^ | | High | Subgroup: Ethnic minorities; Any tobacco cessation intervention | April-2011 | 4 | | X | X
Subgroups continued | Schuit, 2017^122^ | | High | Subgroup: Genetic biomarker differences; NRT, bupropion, varenicline | Aug-2016 | 18 | | X
Subgroups continued | Khanna, 2016^100^ | | High | Subgroup: Persons with SMI; Advice | Apr-2015 | 0 | | X
Subgroups continued | Tsoi, 2013^133^,^‡^ | | High | Subgroup: Persons with SMI; Any tobacco cessation intervention | Oct-2012 | 34 | | X | X
Subgroups continued | van der Meer, 2013^136^,^‡^ | | Moderate | Subgroup: Persons with SMI; Any tobacco cessation intervention | Apr-2013 | 49 | | X
Subgroups continued | Peckham, 2017^118^ | | Moderate | Subgroup: Persons with SMI; Any tobacco cessation intervention | Sept-2016 | 26 | | X | X
Subgroups continued | Roberts, 2016^120^ | | Moderate | Subgroup: Persons with SMI; NRT, bupropion, varenicline | Dec-2014 | 14 | | X | X
Subgroups continued | Ahmed, 2018^80^ | | Moderate | Subgroup: Persons with SMI; Varenicline | July-2018 | 4 | | X | X
Subgroups continued | Kishi, 2015^101^ | | Moderate | Subgroup: Persons with SMI; Varenicline (Harms only) | Aug-2014 | 7 | | | X
Subgroups continued | Wu, 2016^142^ | | High | Subgroup: Persons with SMI; Varenicline (Harms only) | Sept-2015 | 8 | | | X
Subgroups continued | Smith, 2016^124^ | | Low | Subgroup: Sex differences; NRT, bupropion, varenicline | Dec-2015 | 28 | | X
Subgroups continued | McKee, 2016^112^ | | High | Subgroup: Sex differences; Varenicline | Dec-2014 | 16 | | X
Subgroups continued | Ebbert, 2015^92^ | | High | Subgroup: Smokeless tobacco users; Any tobacco cessation intervention | June-2015 | 34 | | X | X
Subgroups continued | Schwartz, 2016^123^ | | Low | Subgroup: Smokeless tobacco users; Varenicline | Feb-2014 | 3 | | X | X

* Primary reviews are those that represented the most current and/or applicable evidence within each population and intervention subgroup and served as the basis for the main findings of this report.

† Review credibility assessed using AMSTAR-2^73^

‡ Included in previous USPSTF review and has not been updated

Abbreviations: KQ = key question; NRT = Nicotine replacement therapy; SMI = severe mental illness

We designated 32 of the 64 reviews as primary reviews on smoking cessation interventions for general adult populations (Table 2). As described in the methods section, we chose these primary reviews based on their comprehensiveness, appropriateness (in scope and applicability), and critical appraisal ratings. Table 3 lists the inclusion and exclusion criteria for each primary review. Table 4 lists the characteristics of the included evidence for each primary review and Table 5 presents the pooled results for tobacco cessation outcomes for all included interventions.

Table 3 Inclusion Criteria of Primary Systematic Reviews on the Effectiveness and Adverse Events of Tobacco Cessation Interventions, by Intervention Type

Author, Year | Last search date | Population | Specific intervention | Intervention criteria | Comparison | Outcomes | Setting | Followup | Study design
Stead, 2016^127^ | Jul-2015 | Adult smokers, excluding pregnant persons | Combined pharmacotherapy and behavioral support | Combined pharmacotherapy and behavioral support | Usual care; brief advice | Smoking abstinence | Any | ≥6 months | RCTs or quasi-RCT
Hartmann-Boyce, 2018^96^ | Jul-2017 | Smokers of any age motivated to quit | NRT | NRT | Placebo; non-NRT control | Smoking abstinence; AEs; SAEs | NR | ≥6 months | RCTs or quasi-RCTs
Lindson, 2019a^104^ | Apr-2018 | Smokers of any age motivated to quit | NRT, different doses, durations, and combinations | Any form, dose, duration, schedule of NRT use | Any other forms, doses, durations, or schedules of NRT | Smoking abstinence; AEs; SAEs; drop-outs due to AEs | Any | ≥6 months | RCTs
Howes, 2020^98,^ ^211^ | Apr-2019 | Smokers of any age, excluding pregnant persons | Bupropion | Antidepressant medication, including bupropion | Placebo; no pharmacotherapy; alternative therapeutic control; different dosage of antidepressant | Smoking abstinence; AEs; SAEs; drop-outs due to AEs | NR | ≥6 months | RCTs
Cahill, 2016^85^ | May-2015 | Adult smokers, excluding smokeless tobacco users | Varenicline | Selective nicotine receptor partial agonists, including varenicline | Placebo or alternative pharm | Smoking abstinence; AEs; Cardiovascular AEs; SAEs | NR | ≥6 months | RCTs
Chang, 2015^87^ | Nov-2014 | Adult smokers | Varenicline + NRT | Combination treatment of varenicline and NRT | Varenicline | Smoking abstinence; AEs | NR | NR | RCTs
Hollands, 2019^97^ | Sept-2018 | Adult smokers | Support for medication adherence | Intervention with clear focus on increasing adherence to pharmacotherapy for tobacco cessation | Usual care | Smoking abstinence; AEs | NR | ≥6 months | RCTs or quasi-RCTs
Mills, 2010^114^ | Nov-2009 | Smokers of any age | NRT (Harms only) | Any form of NRT (lozenge, skin patch, gum, nasal spray, inhaler, and tablet) | Placebo or standard of care | AEs | Any | Any | RCTs and observational studies
Mills, 2014^113^ | Mar-2013 | Smokers of any age | NRT, bupropion, varenicline (Harms only) | NRT, bupropion, or varenicline | Placebo or no drug | Cardiovascular AEs | NR | Any | RCTs
Thomas, 2015^131^ | May-2014 | Any^*^ | Varenicline (Harms only) | Varenicline at the maximum dosage (1 mg twice daily) | Placebo | AEs; Psychiatric AEs | Any | Any followup accepted | RCTs
Sterling, 2016^128^ | Jun-2015 | Tobacco users of any age | Varenicline (Harms only) | Varenicline | Placebo; behavioral intervention applied equally in intervention and control groups | Cardiovascular AEs; SAEs | NR | During study treatment or within 30 days of drug discontinuation | RCTs
Hartmann-Boyce, 2019^95^ | June-2018 | Smokers of any age, excluding pregnant persons | Behavioral support as an adjunct to pharmacotherapy | Behavioral support as an adjunct to pharmacotherapy, where all participants had access to a smoking cessation pharmacotherapy and in which one or more intervention conditions received more intensive behavioral support than the control condition | Any behavioral support of a lower intensity than the intervention or testing specific behavioral components but matched for contact frequency and duration | Smoking abstinence | Any | ≥6 months | RCTs or quasi-RCTs
Stead, 2013^125^ | Jan-2013 | Smokers of any age, excluding pregnant persons | Physician advice | Physician advice to stop smoking. Advice was defined as verbal instructions from the physician with a “stop smoking” message irrespective of whether or not information was provided about the harmful effects of smoking | No advice; usual care; differing levels of physician advice | Smoking abstinence | Any | ≥6 months | RCTs or quasi-RCTs
Rice, 2017^119^ | Jan-2017 | Adult smokers, excluding pregnant persons | Nurse support | Nursing intervention, defined as the provision of advice, counseling, and/or strategies to help people quit smoking. Advice was defined as verbal instructions from the nurse to stop smoking, whether they provided information about the harmful effects of smoking | Usual care; brief advice; no intervention | Smoking abstinence | Any | ≥6 months | RCTs
Lancaster, 2017^103^ | May-2016 | Adult smokers, excluding pregnant persons | Individual behavioral counseling | Individual counseling consisting of a face-to-face encounter between a smoker and a counselor trained in assisting smoking cessation, including counseling as an addition to pharmacotherapy^†^ | NR | Smoking abstinence | NR | ≥6 months | RCTs or quasi-RCTs
Stead, 2017^126^ | May-2016 | Adult smokers, excluding pregnant persons | Group behavioral therapy | Group behavioral therapy in which smokers met for scheduled meetings and received some form of behavioral intervention, such as information, advice and encouragement or cognitive behavioral therapy delivered over at least two sessions | Non-group-based cessation intervention; no-intervention control | Smoking abstinence | Any, except for antenatal care settings | ≥6 months | RCTs
Lindson, 2019b^106^ | Aug-2018 | Smokers of any age, excluding pregnant persons | Motivational interviewing | Behavioral intervention using motivational interviewing | No intervention, another smoking cessation intervention of any length or intensity, another type of MI intervention | Smoking abstinence | NR | ≥6 months | RCTs
Moyo, 2018^115^ | July-2017 | Adult smokers | Decision aids | Any tool a healthcare provider used to share with and inform people about treatment options, including print, video, and computer-based aids | Usual care without the use of shared decision-making and decision aids | Smoking abstinence | Any | Any | RCTs, nonrandomized controlled trials, before and after studies, interrupted time-series
Livingstone-Banks, 2019b^109^ | Mar-2018 | Adult smokers, excluding pregnant persons | Print-based interventions | Print-based self-help intervention, defined as any manual or program designed to be used by individuals to assist a quit attempt that is not aided by health professions, counselors, or group support | Another print-based self-help intervention; minimal control. | Smoking abstinence | NR | ≥6 months | RCTs or quasi-RCTs
Matkin, 2019^110^ | May-2018 | Smokers of any age | Telephone counseling | Telephone counselling alone, in combination with self-help materials, or as an adjunct to another smoking cessation treatment | Minimal intervention; brief intervention; no telephone counselling | Smoking abstinence | NR | ≥6 months | RCTs or quasi-RCTs
Whittaker, 2019^138^ | Oct-2018 | Smokers of any age | Mobile phone-based support | Any intervention that could be considered predominantly a mobile phone-based program (such as text messaging or smartphone apps) for smoking cessation | NR | Smoking abstinence | NR | ≥6 months | RCTs or quasi-RCT
Tzelepis, 2019^134^ | Aug-2019 | Smokers of any age | Real-time video counselling | Interventions where real-time video counselling was delivered by smoking cessation advisors or healthcare professionals as either the primary intervention or an adjunct to other smoking cessation treatments. Studies were eligible where administration of the intervention occurred via telemedicine video conferencing technology or other platforms such as Skype, FaceTime, Google+Hangouts, Talky Core, Facebook Messenger, Viber, Tango (or both) or alternative forms of video communication. | No intervention control; health information or brief advice; written self-help materials; proactive telephone counselling; individual face-to-face support; group face-to-face support; web-based interventions or any other smoking cessation intervention | Smoking abstinence | NR | ≥6 months | RCTs
Taylor, 2017^129^ | Aug-2016 | Smokers of any age, including pregnant women | Internet-based interventions | Internet-based interventions delivered alone or alongside an additional behavioral component or pharmacotherapy | No treatment; other forms of treatment | Smoking abstinence; AEs | Any | ≥6 months | RCTs or quasi-RCTs
Notley, 2019^116^ | July-2018 | Adult smokers | Incentives | Incentive schemes, lotteries, raffles, and contingent or non-contingent payments, to reward cessation and abstinence in smoking cessation programs | Usual care, other smoking cessation intervention without incentives, another incentive-based intervention differing by incentive type or amount | Smoking abstinence, Aes | Any | ≥6 months | RCTs
Clair, 2019^88^ | Sept-2018 | Smokers of any age | Biomedical risk assessment | Biomedical risk assessment in which a physical measurement, such as exhaled carbon monoxide, spirometry, atherosclerotic plaque imaging, or genetic testing was used to increase smoking cessation | Any control group that did not include reporting of such measurements. | Smoking abstinence | NR | ≥6 months | RCTs
Ussher, 2019^135^ | May-2019 | Tobacco smokers wishing to quit, or recent quitters | Exercise | Interventions aimed at increasing exercise, either alone or as an adjunct to a smoking cessation intervention | Smoking cessation program alone or another type of nonexercise control group | Smoking abstinence | NR | ≥6 months | RCTs
White, 2014^137^ | Oct-2013 | Tobacco users of any age wishing to stop smoking, excluding pregnant persons | Acupuncture | Acupuncture, acupressure, laser therapy or electrostimulation | No intervention; sham acupuncture (i.e., acupuncture to known spots that aren’t related to smoking cessation); usual care; placebo; other intervention (e.g. locked cigarette case controlled by time switch) | Smoking abstinence | Any | ≥6 months | RCTs
Barnes, 2019^82^ | July-2018 | Smokers of any age wishing to stop smoking | Hypnotherapy | Hypnotherapy for smoking cessation | No treatment or other therapeutic intervention | Smoking abstinence, Aes | NR | ≥6 months | RCTs
Boyle, 2014^84^ | Jul-2014 | Smokers of any age | Electronic health records support | Interventions that involved electronic health record systems in healthcare settings that were intended to improve documentation or assistance for patients who use tobacco, either by directly prompting clinician, clinic, or health system action or by measuring and reporting on clinical performance | NR | Smoking abstinence; changes in support action (system level) | Healthcare settings | ≥6 months | RCTs or observational studies
Thomas, 2017^130^ | Feb-2016 | Smokers of any age who are receiving care in a healthcare setting | System change interventions | Policies and practices designed by organizations to integrate the identification of all smokers and the subsequent offering of evidence-based smoking cessation treatments (pharmacological, behavioral, or both) into the routine delivery of health care^‡^ | NR | Smoking abstinence | Any healthcare setting | ≥6 months | RCTs or quasi-RCTs
Lindson, 2019c^105^ | Oct-2018 | Smokers of any age, excluding pregnant persons | Reduction-to-quit interventions | Instruction, advice, or support for participants to reduce the number of cigarettes with an ultimate goal of quitting | No intervention; abrupt quitting interventions, or another reduction-to-quit intervention | Smoking abstinence, Aes | NR | ≥6 months | RCTs
Livingstone-Banks, 2019a^108^ | Feb-2018 | Smokers of any age who quit on their own, were undergoing enforced abstinence, or were participating in treatment programs | Relapse prevention | Any pharmacologic, behavioral, or combination intervention aimed at tobacco relapse prevention | No intervention; shorter intervention; intervention not oriented towards relapse prevention | Smoking abstinence | NR | ≥6 months | RCTs or quasi-RCTs
Chamberlain, 2017^185^ | Nov-2015 | Women who are currently smoking or have recently quit smoking and are pregnant; women who are currently smoking or have recently quit smoking and are seeking a pre-pregnancy consultation; health professionals in trials of implementation strategies of psychosocial interventions to support pregnant women to stop smoking. | Any behavioral support | Psychosocial interventions where a primary aim of the study was smoking cessation in pregnancy. Psychosocial interventions were defined as non-pharmacological strategies that use cognitive behavioral, motivational and supportive therapies to help women to quit, including counselling, health education, feedback, financial incentives, social support from peers and/or partners, and exercise interventions, as well as dissemination trials | Usual care; less intensive intervention; alternative intervention | Smoking abstinence; Aes; smoking reduction; relapse prevention; perinatal outcomes; maternal outcomes; healthcare utilization | Any | ≥6 months, ≥12 months (postpartum); late pregnancy | RCTs or quasi-RCTs

* Includes studies among smokers and non-smokers

† Excludes studies of counseling delivered by doctors or nurses and studies of motivational interviewing as those studies are captured in other reviews

‡ Interventions that include at least one of the following six system-level strategies: 1. Implement a system for identifying smokers and documenting tobacco-use status in every clinic and hospital; 2. Provide education, resources and feedback to promote provider interventions; 3. Dedicate staff to provide smoking cessation treatment and assess its delivery in staff performance evaluations; 4. Promote hospital policies that support and provide smoking cessation services; 5. Provide evidence-based tobacco dependence treatments (both counselling and pharmacotherapy); 6. Reimburse providers for the delivery of effective tobacco dependence treatments and include these services among their defined duties.

Abbreviations: AE = Adverse event; mg = milligram; MI = motivational interviewing; NR = Not reported; NRT = Nicotine replacement therapy; RCT = Randomized controlled trial; SAE = Serious adverse event

Table 4 Descriptive Characteristics of Included Studies Within the Primary Reviews on the Effectiveness and Adverse Events of Tobacco Cessation Interventions, by Intervention Type

Author, Year | Specific intervention | Number of included studies | Sample size (Range) | Mean age (Range) | Mean CPD at BL (Range) | Intervention description | Setting | Providers
Stead, 2016^127^ | Combined pharmacotherapy and behavioral support | 53 | 15 – 5887 | 31 – 65 | 11 – 31 | Typical intervention involved multiple contacts with a specialist cessation adviser or counsellor, with most participants using some pharmacotherapy and receiving multiple contacts. However, there was a great deal of variation, including some interventions which involved making pharmacotherapy and behavioral components available to a large population in which take-up of treatment was low, or providing a brief intervention to all participants and offering stepped care for those willing to set a quit date. One intervention was delivered entirely by mail or prerecorded phone messages, using an expert system for tailoring contact and two by telephone counselling alone. All others included some face-to-face contact but additional sessions was sometimes provided by telephone. More than half the trials (n = 28, 53%) offered between four and eight sessions and a quarter (n = 13) over eight sessions. The modal category for contact time was 91 to 300 minutes (n = 22, 42%), with 17 (32%) offering between 31 and 90 minutes and eight (15%) over 300 minutes. We categorized interventions according to the maximum planned contact unless session duration was not described, so the typical time per participant would have been smaller, even in studies where the take-up of treatment was high. | Healthcare settings (k=43), community-based recruitment (k=8) | Most counselling and support was provided by specialist cessation counsellors or trained trial personnel. In a small subgroup the intervention was largely given by usual care providers including general practitioners/family physicians, dental hygienists, dentists and dental hygienist, or occupational physicians. Two studies used peer group counsellors and one used trained lay adviser.
Hartmann-Boyce, 2018^96^ | NRT | 136 | 50 – 8000 | 15 – 62 | 8 – 38 | Most trials comparing nicotine gum to control provided the 2 mg dose. A few provided 4 mg gum to more highly addicted smokers, and two used only the 4 mg dose. In three trials the physician offered nicotine gum but participants did not necessarily accept or use it. In one trial participants self-selected 2 mg or 4 mg doses. The treatment period was typically two to three months but ranged from three weeks to 12 months. Some trials did not specify how long the gum was available. Many of the trials included a variable period of dose tapering, but most encouraged participants to be gum-free by six to 12 months. In nicotine patch trials the usual maximum daily dose was 15 mg for a 16-hour patch, or 21 mg for a 24-hour patch. Thirty-two studies used a 24-hour formulation and nine a 16-hour product; the rest did not specify. One study offered, among other dosage options, a 52.5 mg/24-hour patch. The minimum duration of therapy ranged from three weeks, to three months. There are eight studies of nicotine sublingual tablets or lozenges. Three used 2 mg sublingual tablets. One used a 1 mg nicotine lozenge. One used 2 mg or 4 mg lozenges according to dependence level based on manufacturers’ instructions , and one used 2 mg or 4 mg based on participants’ time to first cigarette of the day (TTFC); smokers whose TTFC was more than 30 minutes were randomized to 2 mg lozenges or placebo , whilst smokers with a TTFC less than 30 minutes had higher-dose 4 mg lozenges or placebo. | Primary care practices, workplace clinics (k=2), university clinic (k=1), recruited through community physicians (k=1), Veterans Affairs Medical Centers, and recruited people with cardiac diseases in the primary care category (k=1), antenatal clinics (k=4), specialized smoking cessation clinics to which participants had usually been referred (k=6), hospital in- or outpatients, some of whom were recruited because they had a co-existing smoking-related illness (k=13), settings intended to resemble ’over the-counter’ (OTC) use of NRT (k=3), drug abuse treatment centers (k=2), psychiatric treatment setting (k=1), remaining trials were undertaken in participants from the community, most of whom had volunteered in response to media advertisements, but who were treated in clinical settings. | Therapists (sometimes specified as a GP but mostly not specified)
Lindson, 2019a^104^ | NRT, different doses, durations, and combinations | 63 | 45 – 3575 | 15 – 56.7 | 17 – 38 | Trials addressed a range of questions relating to the effectiveness of different types and uses of NRT. The variations on NRT use tested are included in the outcomes. | Community (k=31), internet advertisements (k=1), referrals from clinicians or from healthcare clinics, such as smoking cessation clinics or quitlines, substance abuse clinics, primary care clinics, referrals to a lung health clinic (k=1), previous smoking cessation studies (k=1), worksites (k=2), universities (k=1), a number of studies used a mixture of these approaches | Smoking cessation counsellors, research nurses, physicians
Howes, 2020^98^ | Bupropion (and other anti-depressant) | 115 | 5–8144 | 16 – 57 | 5 – 48 | Details of interventions not synthesized.; Bupropion vs. control (k=46); Comparing different bupropion doses (k=3); Bupropion as an adjunct to NRT vs. NRT (k=16); Bupropion as an adjunct to varenicline vs. varenicline (k=6); Bupropion vs. NRT (k=10); Bupropion vs. varenicline (k=10 trials); Bupropion vs. nortriptyline (k=3); Bupropion vs. gabapentin (k=1); Nortriptyline (k=10); Fluoxetine (k=7); Paroxetine (k=1); Moclobemide (k=1); Selegiline (k=5); Lazabemide (k=1); EVT302 (k=1); Venlafaxine (k=1); St. John’s wort (k=3); SAMe (k=1); Sertraline (k=1) | Community-based health care center, cessation outpatient clinics, community clinics, hospitals, community mental health center, Veterans Medical Center, primary care clinics, university, substance use disorder clinics, continuation high schools, preoperative clinic, prisons, HMO, psychiatric research center, anti-smoking clinics, community pharmacy | NR
Cahill, 2016^85^ | Varenicline | 44 | 32 – 8144 | 38 – 57 | NR | 33 studies used the standard 12-week regiment of varenicline, routinely titrating the first week up to the recommended daily dose of 1 mg twice a day; 3 trials compared different dosage arms of varenicline against a placebo arm; 1 trial in non-responders regulated dosage up to the target quit date (day 21) to a maximum of 5 mg a day; 1 allowed participants to regulate their own dosage throughout the treatment phase; 5 trials used NRT as a comparator condition and provided a 12-week course, reducing the dosage as a weaning process; 2 trials provided an 8-week course, one of which progressively reduced the dosage at the end of treatment; 1 trial gave a 24-week course of NRT, tailored to the level of nicotine dependency, and matched to the duration of the placebo and varenicline arms of the trial; 5 trials used Bupropion SR at 150 mg twice a day, 4 for 12 weeks and 1 for 7 weeks. | Smoking cessation clinics, hospitals, universities, and other research centers | NR
Chang, 2015^87^ | Varenicline + NRT | 3 | 117 – 435 | 44.5 – 46.3 | NR | One study administered trial patch two weeks before the Target Quit Date (TQD), while the other two studies started patch use on the TQD. Two studies used a 15 mg/16 hours patch, while the other used a 21 mg/24 hours patch. The use of varenicline was similar among the studies: All started at 0.5 mg per day one week before TQD, with increase to 2 g/day on TQD, and continued for 12 weeks. One study tapered the dose of varenicline on the 13^th^ week. All studies provided concurrent behavioral counseling during the treatment phase. | NR | NR
Hollands, 2019^97^ | Support for medication adherence | 10 | 40 – 928 | 32– 49 | NR | The interventions typically provided information on the rationale for, and emphasized the importance of, adherence to medication, and aided participants in developing strategies to overcome problems and barriers to maintaining adherence. As such, they included a combination of two intervention strategies: a) instruction for patients on medication use or b) counselling about smoking, and the value of medication in overcoming addiction. | Clinic settings apart from one study delivered by phone | Trained counselors, project staff, nurses, cognitive behavioral therapy practitioners
Mills, 2010^114^ | NRT (Harms only) | 120 | 7 – 1,429 (RCTs) 22 – 65,599 (obs) | NR | 21 – 35 | Details of interventions not synthesized.; RCTs (k=92); placebo controlled (k=83):; Patch (k=42); Gum (k=26); Spray (k=6); Inhaler (k=6); Tablet (k=4); Lozenge (k=1); NRT combination (k=35); *59 RCTs included co-interventions Counseling (k=20); Behavioral or psychological treatment (k=19); Advice (k=12); Education (k=3); Additional NRT/placebo (k=4); Rimonabant – appetite suppressant (k=1); Observational:; Patch (k=17); Spray (k=2); Gum (k=1); NRT combination (k=8); *Majority of observational studies included co-interventions; Counseling (k=12); Behavior/behavior modification (k=3); Education (k=3); Self-help booklet (k=1) | NR | NR
Mills, 2014^113^ | NRT, bupropion, varenicline (Harms only) | 63 | 32 – 3,296 | NR | 17 – 31 | Details of interventions not synthesized.; NRT vs. placebo (k=19); Bupropion vs. placebo (k=27); Varenicline vs. placebo (k=18); High-dose NRT vs. placebo (k=1); Combination NRT vs. control (k=1); Bupropion vs. varenicline (k=2); Bupropion vs. NRT (k=3); Varenicline vs. NRT (k=1) | NR | NR
Thomas, 2015^131^ | Varenicline (Harms only) | 44 | 9 – 1210 | 15 – 72 | Average, 20 (range NR) | Varenicline at the maximum dose (1 mg twice daily) | Smokers in hospital (k=1) | NR
Sterling, 2016^128^ | Varenicline (Harms only) | 38 | 10 – 1510 | 13.5 – 69.1 | 10.7 – 26.0 | The most common dose of varenicline was 1 mg twice daily, with some studies in which lower doses were prescribed. Length of treatment with varenicline ranged from 1 to 52 weeks, with the majority of studies treating patients for 12 weeks. | Varied: General population, inpatient, outpatient | NR
Hartmann-Boyce 2019^95^ | Behavioral support as an adjunct to pharmacotherapy | 83 | 30 – 4614 | 17 – 61 | 21.2 | NRT was offered in the majority of studies, with 41 providing nicotine patch only. Most provided a supply of NRT for between eight and 12 weeks. Eight studies used nicotine gum only, one used sublingual tablets and three did not specify the type. Five studies offered patch and/or gum. Seven studies provided bupropion alone, one provided nortriptyline alone and four provided varenicline alone. Three studies offered a choice of pharmacotherapy; NRT or bupropion, or NRT, bupropion, or varenicline. Three studies provided combination therapy of both NRT and bupropion. The intensity of the behavioral support, in both the number of sessions and their duration, was very varied for both intervention and control conditions. In seven trials, there was no counselling contact for the controls. In 30 studies, the control arms had between one and three contacts (which could be face-to-face or by telephone) and most of these had a total contact duration of between four and 30 minutes. In 34 studies, the control group was scheduled to receive between four and eight contacts, with all except eight involving a total contact duration of over 90 minutes. Twelve studies offered over eight contacts for the controls. Typically, the intervention involved only a little more contact than the control, so that the most intensive interventions were compared with more intensive control conditions. In five trials, the intervention consisted of between one and three sessions, with a total duration of 31 to 90 minutes. Forty-five studies tested interventions of between four and eight sessions, about half of which were in the 91- to 300-minute-duration category. The remaining 32 studies offered more than eight sessions, typically providing over 300 minutes of counselling in total. | Primary care, chest clinic, cardiovascular disease outpatient clinic, rheumatology clinic, immunology clinic, HIV clinic, lesbian, gay, bisexual, and transgender health center, mental health clinic, mental health research center, substance abuse clinic, Veterans Administration hospital, cardiac ward, any ward | Trained counselors, community-based educators, nurse practitioners, research staff with bachelor’s degree or higher, psychologists, masters-level counselors, research nurses, telephone counselors, exercise physiologist, smoking cessation specialists, trained advisors, abuse therapist, physicians, American Cancer Society-trained volunteers, advisors from helpline centers, wellness coaches, trained facilitator, study personnel, mental health clinicians
Stead, 2013^125^ | Physician advice | 42 | 60 – 3,215 | NR | 13 – 25 | The definition of what constituted ’advice’ varied considerably. In one study participants were asked whether they smoked and were given a leaflet if they wanted to stop. The control group were not asked about their smoking status until followup. In all other studies the advice included a verbal ’stop smoking’ message. This verbal advice was supplemented by provision of some sort of printed ’stop smoking’ material (27 studies), or additional advice from a support health worker or referral to a cessation clinic or both. Four studies described the physician intervention as behavioral counselling with a stop-smoking aim. One study compared motivational consulting (based on information from theoretical models) with simple advice. In two studies the smoker was encouraged to make a signed contract to quit. One study provided an incentive (a telephone card) to those who successfully quit. Three studies included an intervention which involved a demonstration of the participant’s pulmonary function), or expired air carbon monoxide. One study, using a cluster design, compared information and a letter alone to advice from a pediatrician to mothers of babies attending well-baby clinics with a view to reducing exposure of the children to passive smoke. One study used a computer-generated tailored report to assist with cessation, and another study compared brief advice to computer-generated tailored letters and to no intervention. One study compared brief advice, tailored letters and the combination of both. It only contributed to the direct comparison of advice and tailored letters. | Mostly family/general practice, but also government clinic, adult diabetic outpatient clinic, hospital cardiac unit, worksite, and community settings | Health care personnel (e.g., medical registrar, physicians, hospital consultants)
Rice, 2017^119^ | Nurse support | 59 | 25 – 2700 | 20.3 – 70 | 12 – 23 | Nine studies examined a smoking cessation intervention as a component of multiple risk factor reduction interventions in adults with cardiovascular disease; 36 interventions were considered high-intensity (i.e., initial contact lasted more than 10 minutes, there were additional materials or strategies or both, other than simple leaflets, and usually participants had more than one follow-up contact and 7 were considered low intensity (i.e., advice was provided with or without a leaflet during a single consultation lasting 10 minutes or less, with up to one follow-up visit). Eleven studies compared two different interventions including a nursing intervention, testing additional components or different intensities of the intervention. | Recruited from primary care or outpatient clinics (k=28), hospitalized patients (k=22), remaining trials recruited from workplaces, community-based settings, pediatric clinics, home healthcare, and university. | Nurses or health visitors
Lancaster, 2017^103^ | Individual behavioral counseling | 49 | 39 – 2095 | 24 – 63 | 8 – 29 | Counselling interventions typically included the following components: review of a participant’s smoking history and motivation to quit, help in the identification of high-risk situations, and the generation of problem-solving strategies to deal with such situations. Counsellors may also have provided non-specific support and encouragement. Some studies provided additional components such as written materials, video or audiotapes. | Healthcare and community settings; primary care (k=4) | Generally described as smoking cessation counselors; professional backgrounds included social work, psychology, psychiatry, health education and nursing
Stead, 2017^126^ | Group behavioral therapy | 66 | 45 – 2720 | 21 – 61 | 13 – 32 | Most programs used between six and eight sessions, with the first few sessions devoted to discussion of motivation for quitting, health benefits, and strategies for planning a quit attempt. Specific components at this stage may include signing a contract to quit, or making a public declaration, and nicotine fading (changing the type of cigarette smoked to a lower nicotine brand). Participants may also keep records of the number of cigarettes smoked and the triggers for smoking (self-monitoring). Part of the group process also includes discussion and sharing of experiences and problems (intra-treatment social support). Participants may also be instructed on ways to seek appropriate support from friends, colleagues and family (extra-treatment social support). A range of other problem-solving skills may also be introduced, including identifying high-risk situations for relapse, generating solutions and discussing or rehearsing responses. Some programs incorporate more specific components intended to help manage poor mood or depression associated with quitting and withdrawal. | Most studies recruited community volunteers; recruited in primary care settings (k=3); recruited participants with specific health problem (inpatient included) (k=5); conducted or recruited at work site (k=4) | NR
Lindson, 2019b^106^ | Motivational interviewing | 37 | 56 – 4614 | 15 – 63 | 2 – 30 | All of the studies included in this review made explicit reference to using MI principles defined by Miller and Rollnick. Most studies merely specified that the intervention was carried out according to established MI techniques, rather than providing a more detailed description of counselling content. MI was conducted in one to 12 sessions, with the total duration of MI ranging from five to 315 minutes across studies. MI was delivered in face-to-face sessions in 17 of the 37 studies; in another 12 studies, the counselling was delivered in a combination of face-to-face and telephone sessions, usually with an initial session or sessions conducted face-to-face, followed by follow-up counselling over the phone. Six studies provided counselling over the phone only; a further study had an MI intervention group that received calls and text messages based on CBT and MI and another MI group that received text messages only, and a final study provided MI counselling for adolescents in an online virtual environment. Twenty of the 37 studies offered or recommended the use of pharmacotherapy for smoking cessation to all, or a subset of participants. | NR | Physicians, nurses, counselors/psychologists, specialist smoking cessation advisors, and lay healthcare workers
Moyo, 2018^115^ | Decision aids | 7 | 8 – 1014 | NR | NR | Only two decision aids were delivered directly by a healthcare provider. The other studies all evaluated a decision aid where provider follow-up was optional based on the participant’s decision after use of the aid. The decision aids in all of the included studies were used at a single time point and included web- or computer-based aids, videos, print materials, or a combination of aids. | Outpatient clinic, psychosocial rehabilitation centers | NR
Livingstone-Banks, 2019b^109^ | Print-based interventions | 75 | 40 – 6697 | 34 – 57^*^ | 15 – 32 | Thirty-four of the included studies compared standard self-help materials with no intervention or provided standard materials as an adjunct to advice. The other studies compared targeted or tailored self-help methods or compared other variations of programs. Some studies used multiple interventions, testing the effects of different types of information or of increasing amounts of material. Studies of self-help materials were carried out in a range of settings. Some studies provided the materials without face-to-face contact or any additional motivating strategy. Some studies tested the use of materials for people who had called quitlines (self-help materials were the main form of support offered) or the use of materials as an adjunct to counselling. In healthcare settings, studies more frequently provided self-help materials as an adjunct to brief advice to quit. Some studies described as testing self-help materials included relatively high levels of face-to-face support, although less than informal counselling programs. Most studies did not specify an interest in quitting as a selection criterion. The content and format of the self-help programs varied. The most frequently used materials were the American Lung Association (ALA) cessation manual: Freedom from Smoking in 20 days, and the maintenance manual: A Lifetime of Freedom from Smoking. Most other programs were not named or described fully. Materials have tended to become more complex over time and to incorporate more techniques from behavior therapy approaches. Most recent studies have used computerized expert systems to provide tailored materials judged to be relevant to the characteristics of each smoker, using baseline data. We specified that materials should contain a structured program for quitting. | Studies of self-help materials were carried out in a range of settings | NR
Matkin, 2019^110^ | Telephone counseling | 104 | 40 – 7354 | 15 – 65+ | 10.6 – 28 | Most of the studies were trials of proactive calls from a counsellor, or from an automated interactive voice response system (IVR). Only five assessed interventions that did not involve a counsellor contacting a participant. Some studies included participants who had called helplines that provide smoking counselling (quitlines). Other studies included people who had not called quitlines, but received calls from counsellors or other healthcare providers.; Some studies provided telephone counselling alone, but many others provided telephone counselling along with minimal support such as self-help leaflets, or more active support such as face-to-face counselling, or with stop-smoking medication. The number of calls offered ranged from a single call to 12 calls. Some studies only recruited people trying to stop smoking, while others offered support even to those not actively trying to stop. The number, duration and content of the telephone calls was variable. The potential number of calls ranged from one to 12 and in some studies was flexible. The duration of the calls also varied; 10 to 20 minutes was common, although the initial call might be longer. The call schedule could be spaced over weeks or months. We grouped trials into three broad categories: trials of interventions for smokers who contacted a helpline; trials assessing the effect of providing access to a helpline; and trials that offered support proactively in other settings. There are 10 trials that do not fit into any of these categories, so are considered individually. | Recruited participants in healthcare settings and referred them to services provided by quitlines, involving proactive counselling for those following through referral (k=16) | Most of the studies were trials of proactive calls from a counsellor, or from an automated interactive voice response system (IVR)
Whittaker, 2019^138^ | Mobile phone-based support | 26 | 49–8000 | 18.2–57 | 14.5 | All studies tested automated text messaging interventions. Eighteen studies used text messaging (SMS) as a central component of the intervention. One study sent text messages containing links to theoretically driven video messages from ‘ordinary’ role models coping with quitting. Several studies paired text messages with in-person visits or assessments. The text message interventions varied in length from one week to five weeks, six weeks, eight weeks, three months, and six months, or were variable. Eight studies did not state that text messages were tailored to the individual. In other studies using text messages, the degree of individual tailoring varied. One study tailored messages to include first name, quit date, top three reasons for quitting, money saved by quitting, and use of quit-smoking medications. Two studies tailored messages to the stage of readiness to quit. Another study’s program could be interacted with by reporting changes in smoking behavior (e.g. a quit attempt, relapse), so that appropriate stage-specific messages could be sent. One study tailored their intervention text messages to contain advice and encouragement tailored to participants’ current quit status (preparing to quit, first week of the quit attempt, second week of attempt etc.). Two studies tailored the messages to information collected at baseline about the individual. One study individually tailored messages using 24 items from the iQuit questionnaire and information on smoking status at three and seven weeks. Another study matched participant characteristics to messages by keyword to create an individualized program. One study’s participants selected the role model from whom they wished to receive messages. A number of text messaging interventions included interactive components such as the ability to text for more support in the instance of cravings or lapses, an optional Quit Buddy, a Quit support network, polls and quizzes, regular checking in on smoking status, and one study included some degree of choice. Participants received offers of support via a personalized tailored Internet program, a text message program, both programs, a choice of all three, or a minimal control. | Community | NR
Tzelepis, 2019^134^ | Real-time video counselling | 2 | 49–566 | 47.4–51.12 | 17.0 | Both studies delivered real-time video counselling for smoking cessation individually and not in a group format. In one study, the video counselling intervention consisted of eight sessions, while in the other study the intervention comprised four sessions. The length of the video treatment was eight weeks in both studies. One study used 10- to 30-minute video sessions, while the other study did not report video session duration. One study delivered the real-time video counselling intervention via videoconferencing equipment located at primary care clinics, so participants were required to travel to receive video counselling, while the other study delivered the video counselling intervention via software installed on the participants’ own smartphones. One study delivered the video counselling intervention between 2009 and 2011 and the other study between 2016 and 2017. Both studies compared the real-time video counselling intervention with a telephone counselling intervention for smoking cessation, and delivered the telephone counselling interventions directly to participants via their own telephones. The intended number and timing of sessions, length of treatment and duration of sessions in the telephone counselling interventions were identical to those of the video counselling interventions delivered in each study. One study based the counselling content for both the video counselling and telephone counselling interventions on a behavioral therapy foundation, guided by Bandura’s Social Cognitive Theory and, the other study on a combination of motivational interviewing and CBT. A tobacco treatment specialist and a trained graduate student delivered the counselling in one study, and trained counsellors delivered the counselling in the other. One study provided all participants with nicotine patches. The other study provided information about the cessation medications covered by participants’ insurance plan or public assistance program, and study staff assisted income-eligible participants with no insurance coverage to apply for cessation medications from the pharmacy assistance programs of pharmaceutical drug companies. | Community, healthcare | NR
Taylor, 2017^129^ | Internet-based interventions | 77 | 66 – 12,000 | 16 – 63 | NR | Range of interventions provided, from a very low intensity intervention providing a list of websites for smoking cessation, to highly intensive interventions consisting of Internet-, email- and mobile phone-delivered components. Tailored Internet interventions differed in the amount of tailoring, from a bulletin board facility, a multimedia component, tailored and personalized access to very high depth tailored stories and highly personalized message sources. Some trials also included counselling or support from nurses, peer coaches or tobacco treatment specialists. Other trials also incorporated online social networks, such as Facebook, Twitter, and WeChat, and online forums, chat rooms, and support groups. Two interventions were very distinct from the rest. In addition to brief smoking advice, one study used an Internet-based three-dimensional face age progression simulation software package to create a stream of aged images of faces from a standard digital photograph. The resulting aged image was adjusted to compare how the participant aged as a smoker versus as a non-smoker. In one study, the authors used an online version of the approach-avoidance task, where participants used the computer mouse to pull (i.e. approach, leading to an enlarged picture) or push (i.e. avoid, leading to a reduced picture) neutral or smoking-related pictures. We also identified nine trials of lifestyle interventions that included a smoking cessation component. These interventions included content on a range of topics, including diet and healthy eating, physical activity and fitness, alcohol and drug use, sexual behavior, unpleasant sexual experiences, bullying, mental health, patient-provider relationships, and medication management. | Recruited from primary care (k=7); most recruitment was web-based with participants finding the sites through search engines and browsing | NR
Notley, 2019^†^,^116^ | Incentives | 33 | 14 – 6006 | 19.7 – 55 | 8 – 26 | Approximately half of studies offered cash for abstinence (contingent rewards), or monetary incentives in the form of vouchers. Four studies used entry into a prize drawing alongside a guaranteed reward. Two studies used self-deposited money as the reward incentive and a further four studies used a combination of deposit arms with cash rewards or mixed-rewards arms for abstinence at fixed time points. Seven studies included more complex payment schedules, especially with a ’reset’ option, meaning that a non-abstinent biochemically confirmed outcome at any time point would reset the escalating schedule of reinforcement to a lower level, thus reinforcing continued abstinence. | Community setting, clinics, substance misuse clinics, worksites | NR
Clair, 2019^88^ | Biomedical risk assessment | 20 | 64 – 2110 | 31.7 – 53.0 | 11.9 – 29.2 | One included study tested two interventions: the intervention was feedback about genetic susceptibility combined with CO measurement, which could either be compared to a control group of CO measurement alone, or to a control group without biomarker feedback, thereby testing the combination of the two interventions.) Out of the 21 interventions, five tested feedback on smoking exposure, each measuring the effect of exhaled CO measurements. Five studies tested feedback on smoking-related disease risk; of these, four tested feedback about genetic susceptibility to cancer, and one tested feedback about genetic susceptibility to Crohn’s disease. Eleven studies assessed feedback on smoking-related harm: four tested the combination of exhaled CO measurement and spirometry; five tested the effect of spirometry alone, or with the addition of feedback on lung age; two tested the effect of undergoing an ultrasonography of carotid arteries (and femoral arteries for one study) with photographic demonstration of atherosclerotic plaques when present | Community (k=1), smoking cessation clinics (k=2), health promotion army clinic (k=1), mental health clinic (k=1), worksite (k=1), research institutes (k=3) | Physician (k=5); Nurse (k=4); Specific study staff member (k=7); Trained health educator or research counsellor (k=2); Principal investigator with help from trained smoking cessation practitioners (k=1); Web-based (k=1)
Ussher, 2019^135^ | Exercise | 24 | 20 - 2318 | 28 - 59 | 16.76 - 32 | Most of the trials employed supervised, group-based cardiovascular-type exercise supplemented by a home-based exercise program and combined with a multi-session cognitive behavioral smoking cessation program. The comparator in most cases was a multi-session cognitive behavioral smoking cessation program alone. | Community, healthcare | NR
White, 2014^137^ | Acupuncture | 38 | 18 - 651 | NR | NR | All acupuncture studies used a traditional approach to acupuncture in choosing points nominated as specific for smoking cessation. Five studies used facial acupuncture and ten used auricular acupuncture alone. All but three of these used some form of continuous stimulation, either needle or pressure device. Eight studies combined body and auricular acupuncture. Three used continuous stimulation with either indwelling needles or seeds. One study used facial, body, indwelling, and sham auricular acupuncture in different groups. Five studies used acupressure alone, three studies used laser; three studies investigated electrostimulation given over the mastoid bone; and four studies gave electrostimulation to the ear (one also used continuous acupressure stimulation). | NR | NR
Barnes, 2019^82^ | Hypnotherapy | 14 | 20 – 360 | 30 – 40 | 20 – 24 | The studies varied in the method of hypnotic induction used, number of hypnotherapy sessions, and duration of hypnotic treatments. The number of hypnotherapy sessions varied from a single session to up to 8 sessions and the total duration of hypnosis ranged from 30 min to 9 hrs. Seven studies provided hypnotherapy in a group format. | NR | NR
Boyle, 2014^84^ | Electronic health records support | 16 | NA | NA | NR | 6 RCTs: In each of these studies treatment conditions tested an electronic health record (EHR) with enhancements intended to facilitate the provider interaction with a smoker patient. One study provided intervention clinics with additional tools within the EHR and clinical staff were reminded to use them. In one, the enhancement was based on information in an existing EHR. Clinical staff (physicians and medical assistants) in the intervention clinics received feedback reports on their use of the existing tools with smoking patients. Sherman 2008 also provided additional tools for clinical staff in the EHR system with some restrictions on use of the tools by the control clinics. The dental study created text boxes or scripts within the intervention clinic dental record. The scripts served as language the dental providers could use based on patient-specific information obtained during the dental encounter. In the other studies, the intervention clinics were able to link patients through the EHR to a telephone quitline, and the quitline proactively called the patient. Other studies: Of the other ten studies, three used a control condition or comparison clinic. In one study, the comparison clinic was a paper records-based clinic without an electronic health record. Another study used four control clinics, two were based on usual care and two had access to a new electronic health record vital sign screen but were provided no training or support on the use of the screen. One study randomly assigned patients in one clinic to either intervention or usual care based on their family medical record number. The seven additional studies measured outcomes before and after the introduction of an enhancement to an existing electronic health record, without any comparison group. One study was conducted in a family practice clinic and a pulmonary specialty clinic within the same health system. Another study was conducted in a single primary care clinic. One study studied the intervention in a single hospital. Two other studies each involved 3 clinics, and another study studied one large health system with 18 primary care clinics. Two studies involved retrospective cohorts. Followup: There was wide variation in the type and length of follow-up across the studies. For example, one study made telephone contact with dental patients a few days after a dental visit to measure intervention effects but no other follow-up was conducted. One study collected follow-up data through a patient survey about two weeks after a medical care visit during an eight month study period. One study collected data during a three-month period, and another study collected 12 month outcome data. One study followed patients to 19 months. Another study provided data one year before and one year after the intervention. One study examined outcomes four months before and after implementation. Another study followed a cohort for eight months. One study included patients with two or more visits during a six-month post intervention period. Another study collected outcome data from electronic records 6 months post intervention. | General practice/primary care medical clinics (k=14), dental clinic (k=1), hospital (k=1) | Variable
Thomas, 2017^130^ | System change interventions | 7 | 1980 - 66516 | 30 - 64 | NR | All studies included system-level interventions that involved identifying all smokers, training staff, and providing free evidence-based treatment (i.e., NRT or other pharmacotherapy). Five of the included studies also implemented organizational policies to improve access to cessation interventions (e.g., referrals). All included studies provided clinicians with training ranging from 30 minutes to 20 hours. | Primary care clinics (k=2), dental clinics (k=2), community pharmacy (k=1), VA medical center (k=1), pediatric practice (k=1) | All health professionals including pharmacists and dentists.
Lindson, 2019c^105^ | Reduction-to-quit interventions | 51 | 24 - 3297 | 15.4 – 57.9 | 11 - 31 | Reduction methods varied greatly: some studies simply asked participants to reduce the amount they smokers whereas others provided detailed instructions or suggestions on how to do so, including a goal number of cpd, gradually increasing time between cigarettes, increasing time in the morning before first cigarette, reducing scenario-specific smoking, or replacing cigarette smoking with a form of pharmacotherapy. | Primary care, smoking cessation clinics, worksite, and community | NR
Livingstone-Banks, 2019a^108^ | Relapse prevention | 77 | 11 - 18010 | 19 - 60 | 10.2 - 29.9 | Pharm interventions consisted of varenicline, rimonabant, NRT, and bupropion; behavioral interventions consisted of brief interventions (phone calls, mailings, written pamphlets), pharm in conjunction with behavioral support, a 50-minute in person training session, self-help materials, support groups, and group training sessions. | Cessation clinic, participants’ own homes, Quitline, community, hospital, mobile applications, Naval training, hospitals, HMO health center, community mental health centers, antenatal clinics, maternity services, mail, Air Force, substance abuse outpatient facility, prenatal clinic, workplaces, Army Medical Center, Quit for Life employers/health plans, obstetric clinics, pediatric practices, narcotics treatment centers | NR
Chamberlain, 2017^185^ | Any behavioral support | 102 | 24 - 15,530 | 19.4 - 30.8 | 6 - 18 | Interventions:; Smoking cessation interventions implemented during pregnancy differ substantially in their intensity, their duration, and the people involved in their implementation. In 57/106 study arms the intervention was coded as a single intervention, therefore the ’main intervention strategy’ most accurately reflects the type of intervention. However, in 36 study arms the intervention was coded as ’multiple’, where other components of the intervention were offered to all women. In 12 studies the intervention was coded as ’tailored’ whereby different intervention components were offered and tailored to women’s needs. Of the 56 study arms coded as counselling, most involved face-to-face contact, using a variety of strategies either alone or in combination (such as motivational interviewing, cognitive behavioral therapy, stages of change). Four trials with the main intervention strategy coded as counselling included a lottery chance for women who reported quitting; nine included support from peers and/or partners with three of these including support for partners to quit. The duration and frequency of the intervention also varied considerably and has generally increased over time. Twenty of the interventions involved telephone counselling and in five of these studies all counselling was provided via telephone, and one had only brief additional face-to-face contact. Thirty-eight study arms included self-help manuals as part of the intervention, and in 27 study arms there was a brief introduction to the manuals (less than five minutes) and the intervention was therefore coded as counselling, with sensitivity analysis conducted to assess the independent effect of these studies. In 10 study arms the intervention involved use of a video; 11 study arms included use of computers in the intervention. Studies using tools or technology where there was no clear personal contact were coded as health education, including: self-help manuals; text messaging; audiotape; and computer. Three other studies that reported the intervention consisted of advice to quit only, either in person or by post were coded as health education. Among all 120 study arms with and without outcomes: six dissemination trials were identified, carried out in Australia, the US, and Europe. Three trials reported only dissemination outcomes, and not the primary outcomes of abstinence in late pregnancy, therefore outcomes not able to be included in the meta-analysis are reported in Table 1. Nine studies (with 12 study arms) were cluster-randomized at service level, providing an indication of implementation under routine care conditions; while four studies were cluster-randomized at provider level.; Comparisons:; Women in the control arms in 56 of 106 study arms with primary outcome data received ’usual care’ in relation to smoking cessation, which generally included information about the risks of smoking and advice to quit. In 44 study arms the comparison group received some kind of ’less intensive’ intervention, which included studies where a dedicated research team consistently provided what they considered to be ’usual care’ for women in the comparison group. In six study arms the comparison group received an ’alternative intervention’, which was categorized as having the same intensity (duration and frequency) as the intervention group, providing a comparison as close to a ’placebo-controlled trial as is feasible for psychosocial interventions, to assess the independent effect of the intervention component). One was a counselling intervention using cognitive behavioral therapy compared with traditional health education, one compared two types of text messaging strategies, and four compared provision of incentives, contingent or not contingent on smoking status. As expected, the intensity of both interventions and controls has increased over time, as indicated by the change in frequency and duration of contact during the interventions. In many cases the comparison/control group was described as receiving ’usual care’ without specifying further what constituted usual practice (at a particular time and in a particular setting) with respect to advice and assistance. | Most trials of interventions to support pregnant women were conducted in public hospitals or community antenatal clinics | In 27 study arms the intervention was provided by staff involved in routine pregnancy care (coded as effectiveness studies), and in 70 study arms the intervention was provided by dedicated research project staff (coded as efficacy studies), with 11 coded as unclear or not applicable as dissemination trials or the intervention was automated (e.g. text messaging) or provided by use of other materials (e.g. mail-outs).

* 1 trial ~47% mean age <30; 1 trial ~62% fell between ages 20–39; 1 trial ~44% were >50

† Evidence for general (non-pregnant) adults only

Abbreviations: BL = Baseline; CBT = Cognitive behavioral therapy; CO = Carbon monoxide; CPD = Cigarettes per day; GP = General practitioner; HIV = Human immunodeficiency virus; HMO = Health maintenance organization; mg = milligram; MI = Motivational interviewing; NR = Not reported; NRT = Nicotine replacement therapy; RCT = Randomized controlled trial; SAMe = S-adenosyl-L-methionine; SMS = Short message service; TTFC = Time to first cigarette of the day; WIC = Women, infants, and children

Table 5 Smoking Cessation^*^ Results at 6 or More Months^†^ (KQ 2) From Reviews of Tobacco Cessation Interventions Among Adults, by Type of Intervention

Author, Year | IG | CG | # of RCTs | N analyzed | IG events | IG N | IG quit rate^‡^ | CG events | CG N | CG quit rate^‡^ | Risk ratio (95% CI) | I ^2^
Stead, 2016^127^ | Combined pharmacotherapy and behavioral support | Brief advice or usual care | 52 | 19,488 | 1529 | 10,070 | 15.2% | 808 | 9418 | 8.6% | 1.83 (1.68, 1.98) | 36%
Hartmann-Boyce, 2018^96^ | NRT, any form | Placebo or no drug | 133 | 64,640 | 5574 | 32,918 | 16.9% | 3315 | 31,722 | 10.5% | 1.55 (1.49, 1.61) | 39%
Hartmann-Boyce, 2018^96^ | NRT, gum | Placebo or no drug | 56 | 22,581 | 1732 | 10,596 | 16.3% | 1196 | 11,985 | 10.0% | 1.49 (1.40, 1.60) | 40%
Hartmann-Boyce, 2018^96^ | NRT, patch | Placebo or no drug | 51 | 25,754 | 2160 | 13,773 | 15.7% | 1131 | 11,981 | 9.4% | 1.64 (1.53, 1.75) | 24%
Hartmann-Boyce, 2018^96^ | NRT, inhaler | Placebo or no drug | 4 | 976 | 84 | 490 | 17.1% | 44 | 486 | 9.1% | 1.90 (1.36, 2.67) | 0%
Hartmann-Boyce, 2018^96^ | NRT, intranasal spray | Placebo or no drug | 4 | 887 | 107 | 448 | 23.9% | 52 | 439 | 11.8% | 2.02 (1.49, 2.73) | 0%
Hartmann-Boyce, 2018^96^ | NRT, tablets | Placebo or no drug | 8 | 4439 | 488 | 2326 | 20.9% | 273 | 2113 | 12.9% | 1.52 (1.32, 1.74) | 71%
Hartmann-Boyce, 2018^96^ | NRT, participant’s choice | Placebo or no drug | 7 | 8288 | 793 | 4179 | 19.0% | 569 | 4109 | 13.8% | 1.37 (1.25, 1.52) | 42%
Lindson, 2019a^104^ | NRT combination | NRT single form | 14 | 11,356 | 881 | 5218 | 16.9% | 852 | 6138 | 13.9% | 1.25 (1.15, 1.36) | 4%
Howes, 2020^98^ | Bupropion | Placebo or no drug | 46 | 17,866 | 1846 | 9714 | 19.0% | 900 | 8152 | 11.0% | 1.64 (1.52, 1.77) | 15%
Cahill, 2016^85^ | Varenicline | Placebo | 27 | 12,625 | 1695 | 6632 | 25.6% | 668 | 5993 | 11.1% | 2.24 (2.06, 2.43) | 60%
Hughes, 2014^211^ | Nortriptyline | Placebo | 6 | 975 | 96 | 480 | 20.0% | 49 | 495 | 9.9% | 2.03 (1.48, 2.78) | 16%
Howes, 2020^98^ | Bupropion | NRT, any form | 10 | 9230 | 681 | 3563 | 19.1% | 987 | 4667 | 21.1% | 0.99 (0.91, 1.09) | 18%
Howes, 2020^98^ | Bupropion | Varenicline | 6 | 6286 | 474 | 3096 | 15.3% | 677 | 3190 | 21.2% | 0.71 (0.64, 0.79) | 0%
Cahill, 2016^85^ | Varenicline | NRT, any form | 8 | 6264 | 767 | 3227 | 23.8% | 575 | 3037 | 18.9% | 1.25 (1.14, 1.37) | 39%
Hollands, 2019^97^ | Support for medication adherence | Usual care | 5 | 3593 | 412 | 1816 | 22.7% | 361 | 1777 | 20.3% | 1.16 (0.96, 1.40) | 48%
Hartmann-Boyce 2019^95^ | Behavioral therapy as an adjunct to pharmacotherapy | Pharmacotherapy | 65 | 23,331 | 2291 | 11,630 | 19.5% | 2006 | 11,701 | 17.1% | 1.15 (1.08, 1.22) | 8%
Stead, 2013^125^ | Physician advice | Usual care | 26 | 22,239 | 1008 | 12,583 | 8.0% | 462 | 9656 | 4.8% | 1.76 (1.58, 1.96) | 40%
Rice, 2017^119^ | Nurse advice | Usual care | 44 | 20,881 | 1607 | 11,319 | 14.2% | 1165 | 9562 | 12.2% | 1.29 (1.21, 1.38) | 50%
Lancaster, 2017^103^ | Individual counselling with cessation specialist | Minimal contact control | 33 | 13,762 | 765 | 6715 | 11.4% | 546 | 7047 | 7.7% | 1.48 (1.34, 1.64) | 46%
Stead, 2017^126^ | Group behavioral intervention | Self-help program | 13 | 4395 | 249 | 2388 | 10.4% | 116 | 2007 | 5.8% | 1.88 (1.52, 2.33) | 0%
Lindson, 2019b^106^ | Motivational interviewing + another smoking cessation intervention | Smoking cessation intervention alone | 12 | 4167 | 399 | 2134 | 18.7% | 306 | 2033 | 15.1% | 1.07 (0.85, 1.36) | 47%
Moyo, 2018^115^ | Decision aid | Usual care without decision aid | 7^§^ | 1772 | NA | NA | NA | NA | NA | NA | NA^‖^ | NA
Livingstone-Banks, 2019b^109^ | Print-based, non-tailored self-help materials^¶^ | No self-help | 32 | 28,451 | 983 | 11,114 | 8.8% | 794 | 13,337 | 6.0% | 1.06 (0.95. 1.19) | 25%
Livingstone-Banks, 2019b^109^ | Print-based, non-tailored self-help materials with no face-to-face contact | No self-help | 11 | 13,241 | 416 | 6723 | 6.2% | 331 | 6518 | 5.1% | 1.19 (1.03, 1.37) | 0%
Livingstone-Banks, 2019b^109^ | Print-based, tailored self-help materials^¶^ | No self-help | 10 | 14,359 | 501 | 6786 | 7.4% | 455 | 7573 | 6.1% | 1.34 (1.19, 1.51) | 0%
Matkin, 2019^110^ | Proactive telephone counseling (quitline callers) | Control (various) | 14 | 32,484 | 2123 | 19,600 | 10.8% | 1004 | 12,884 | 7.8% | 1.38 (1.19, 1.61) | 72%
Matkin, 2019^110^ | Proactive telephone counseling (not initiated by quitline) | Control (various) | 65 | 41,233 | 2924 | 21,001 | 13.9% | 2229 | 20,232 | 11.0% | 1.25 (1.15, 1.35) | 52%
Whittaker, 2019^138^ | Mobile phone-based interventions | Usual care of minimal intervention | 13 | 14,133 | 694 | 7324 | 9.5% | 382 | 6809 | 5.6% | 1.54 (1.19, 2.00) | 71%
Whittaker, 2019^138^ | Mobile phone-based interventions | No intervention | 4 | 997 | 64 | 497 | 12.9% | 39 | 500 | 7.8% | 1.59 (1.09, 2.33) | 0%
Tzelepis, 2019^134^ | Real-time video counselling | Telephone counselling | 2 | 608 | 30 | 301 | 10.0% | 22 | 307 | 7.2% | 2.15 (0.38, 12.04) | 66%
Taylor, 2017^129^ | Internet (interactive and tailored) | Self-help or usual care | 8 | 6786 | 516 | 4020 | 12.8% | 356 | 2766 | 12.9% | 1.15 (1.01, 1.30) | 58%
Notley, 2019^116^ | Incentives | Usual care or non-incentive-based intervention | 30 | 20,060 | 1336 | 12,800 | 10.4% | 516 | 7260 | 7.1% | 1.49 (1.28, 1.73) | 33%
Clair, 2019^88^ | Feedback on smoking exposure | Usual care or minimal intervention | 5 | 2368 | 183 | 1199 | 15.3% | 179 | 1169 | 15.3% | 1.00 (0.83, 1.21) | 0%
Clair, 2019^88^ | Feedback on smoking-related disease risk | Usual care or minimal intervention | 5 | 2064 | 106 | 1018 | 10.4% | 136 | 1046 | 13.0% | 0.80 (0.63, 1.01) | 0%
Clair, 2019^88^ | Feedback on smoking-related harms | Usual care or minimal intervention | 11 | 3314 | 239 | 1646 | 14.5% | 195 | 1668 | 11.7% | 1.26 (0.99, 1.61) | 34%
Ussher, 2019^135^ | Exercise | No exercise | 21 | 6607 | 457 | 3326 | 13.7% | 407 | 3281 | 12.4% | 1.08 (0.96, 1.22) | 0%
White, 2014^137^ | Acupuncture | Sham acupuncture | 9 | 1892 | 122 | 997 | 12.2% | 97 | 895 | 10.8% | 1.10 (0.86, 1.40) | 23%
Barnes, 2019^82^ | Hypnotherapy | No intervention or other cessation intervention | 14 | 1926 | NA | NA | NA | NA | NA | NA | NA#^**^ | NA
Boyle, 2014^84^ | EHR-facilitated interventions | No change to EHR | 16^††^ | NA^‡‡^ | NA | NA | NA | NA | NA | NA | NA^††^ | NA
Thomas, 2017^130^ | System change interventions | No system changes | 7 | NA^§§^ | NA | NA | NA | NA | NA | NA | NA^‡‡^ | NA
Lindson, 2019c^105^ | Reduction-to-quit interventions | No cessation intervention | 6 | 1599 | 87 | 915 | 9.5% | 25 | 684 | 3.7% | 1.74 (0.90, 3.38) | 45%
Lindson, 2019c^105^ | Reduction-to-quit interventions | Abrupt quitting interventions | 22 | 9219 | 584 | 4922 | 11.9% | 528 | 4297 | 12.3% | 1.01 (0.87, 1.17) | 29%

* Used strictest available criteria to define abstinence (i.e., continuous, sustained, or prolonged abstinence was preferred over point prevalence abstinence and biochemically validated rates were used where available).

† Each review pooled data from the longest followup time point reported at 6 or more months followup

‡ Weighted average quit rates

§ Includes 3 RCTs and 4 quasi-experimental studies

‖ No meta-analysis performed. Six studies reported the effects of the intervention on smoking cessation. Only one study reported a statistically significant benefit of the use of a decision aid versus usual care on smoking cessation at 6 months.

¶ Irrespective of level of contact and support common to control group # No overall meta-analysis performed given variation in intensity of the hypnotherapy tested, little information on the hypnotherapy used, and large variation in control conditions

** In general, this review found no evidence of a difference in smoking cessation at 6 months’ or greater followup among trials that compared hypnotherapy versus no intervention or other smoking cessation interventions. In the group with the most trials, there was no overall difference in smoking cessation rates between groups at 6 months or greater followup between hypnotherapy versus attention-matched smoking cessation behavioral intervention (RR 1.21 [95% CI, 0.91 to 1.61]; k=6; n=957; I^2^=36%)

†† Includes 7 RCTs and 9 non-randomized observational studies

‡‡ Only one RCT (n=9589) reported effects on smoking cessation, as captured in the EHR, and found that more intervention vs. control clinic smokers quit (5.3% vs. 1.9%, p<0.001). The remaining studies focused on the impact of EHR changes on smoking support actions by clinicians, clinics, and health systems with most studies reporting improved processes following EHR-facilitated intervention implementation.

§§ Four trials (n=7142) reported the effects of the intervention on smoking cessation finding mixed results. Across all 7 trials, there was mixed evidence on secondary process outcomes such as documentation of smoking status and provision of counseling.

Abbreviations: CG = control group; CI = confidence interval; EHR = electronic health record; I^2^ = percentage of the variability in effect estimates that is due to heterogeneity rather than sampling error; IG = intervention group; N = number; RCT = randomized controlled trial; RR = risk ratio

Eleven “ancillary” reviews had overlapping evidence with that synthesized in the primary reviews; results were consistent with the primary reviews in terms of statistical significance and effect magnitude and are not discussed further. An additional 21 reviews focused on specific subpopulations of adults (e.g., people with severe mental illness, smokeless tobacco users). Results of these subpopulation reviews were compared with results from general adult reviews; we only discussed findings of these subgroup reviews if they suggested substantive differences than that of the broader reviews. Seven of these reviews among specific subgroups presented results related to harms of medication use and are also included as main results. Characteristics of these additional reviews (ancillary and those limited to subpopulations) are provided in Appendix C.

Our review of the primary evidence on the use of e-cigarettes for tobacco cessation resulted in nine included trials (reported in 16 publications), five of which addressed tobacco cessation and all of which address potential harms (Appendix B, Figure 2).^143–158^ Two of these trials were included in our previous review, and seven trials are new to this update.

Appendix D lists all included studies and Appendix E lists the excluded studies, with reasons for exclusion.

### Credibility/Quality Assessment

We rated 29 of the reviews in adults as having high credibility, 26 as having moderate credibility, and the remaining 9 as having low credibility according to AMSTAR 2 criteria. Most of the main results (primary reviews) were based on reviews we rated as high or moderate credibility; only three reviews rated as low credibility were presented as main results given their unique foci (harms of varenicline, sex differences in the effectiveness of medications, and harms of varenicline use among smokeless tobacco users). Though they were rated as low credibility, the flaws noted in these reviews (e.g., lack of dual study selection, unclear ascertainment of funding of included studies, not accounting for risk-of-bias of studies in interpretation of the findings) are unlikely to invalidate the results we present from these reviews. We excluded 26 reviews as having very low credibility; these reviews had more than one critical flaw and thus, we felt could not be relied on to provide an accurate and comprehensive summary of the available evidence. Many of these critical flaws related to the search and selection of included studies (e.g., a partial search strategy, no dual selection of studies), a lack of a risk-of-bias assessment, very little information about the included studies, or an inappropriate data synthesis or analysis method. Of the 64 included reviews, 32 were Cochrane Collaboration reviews. These reviews are generally well-conducted, well-reported, and use similar robust methods for study selection and synthesis, strengthening our confidence in these findings.

We rated all eight trials of e-cigarettes as fair quality (Table 6). Major quality limitations of these trials included uncertain validity of randomization and allocation concealment procedures, differences in reasons for missing data across treatment groups, unclear blinding of outcome assessors, substantial crossover and relatively high loss to follow-up with unclear treatment of missing data.

Table 6 Study and Population Characteristics for Evidence on the Use of Electronic Cigarettes for Tobacco Cessation, Sorted by KQ

Key questions | Author, Year; Trial name; Quality | Country | N rand | Brief population description | Intervention/ Exposure | Comparison | Outcomes of interest
Included for KQ 2 and KQ 3 | Bullen, 2013^144^; ASCEND; Fair | New Zealand | 657 | Age ≥18 years, had smoked >10 CPD for at least the past year.; Wanted to stop smoking | E-cig with 16 mg nicotine/ml plus behavioral support (voluntary quitline) for 13 weeks; Device: Elusion e-cigarette with nicotine solution cartridges | CG1: NRT patch (21 mg nicotine per 24 hours) plus behavioral support; CG2: E-cig device with placebo (nicotine-free) cartridges plus behavioral support | - Tobacco abstinence at 6 months; - Adverse events; - Tobacco use outcomes at 6 months
Included for KQ 2 and KQ 3 | Caponnetto, 2013^145^; ECLAT; Fair | Italy | 300 | Ages 18–70 years, had smoked >10 CPD for at least the past 5 years.; Not currently attempting to quit smoking or wishing to do so in the next 30 days | IG1: E-cig with 7.2 mg nicotine cartridges used at will for 12 weeks; IG2: E-cig with 7.2 mg nicotine cartridges used at will for 6 weeks and E-cig with 5.4 mg nicotine cartridges for 6 weeks; Followed for 1 year (8 visits total); Device: Categoria 401 e-cigarette | Nicotine-free E-cig cartridges | - Tobacco abstinence at 12 months; - Adverse events
Included for KQ 2 and KQ 3 | Hajek, 2019^154^; TEC; Fair | UK | 886 | Adult smokers attending NHS stop-smoking services.; No strong preference to use or not to use NRT or e-cigarettes | E-cig starter pack with 30 ml bottle of tobacco-flavored e-liquid with 18 mg nicotine per ml (follow up use of any flavor or strength of e-liquid purchased by participant) for 1 year plus 4 weeks of behavioral support; Device: One Kit (Aspire) and One Kit 2016 (Innokin) | NRT (any kind, any combination) plus 4 weeks behavioral support | - Tobacco abstinence at 6 and 12 months^*^; - Adverse events; - Tobacco use outcomes at 6 months
Included for KQ 2 and KQ 3 | Lee, 2019^157^; Fair | Korea | 150 | Male adults over 18 years, smoked at least 10 CPD during preceding year, had smoked for at least 3 years, and were motivated to quit or reduce cigarette consumption. | E-cig (0.01 mg/mL), distributed in 12-wk supply plus 50-min edu support | Nicotine gum (2mg/tablet), distributed in 12-wk supply plus 50-min edu support | - Tobacco abstinence at 9 to 24 weeks; - Adverse events
Included for KQ 2 and KQ 3 | Walker, 2019^155^; Fair | New Zealand | 1124 | Ages ≥18 years, current tobacco smokers (any amount); Currently motivated to quit but no use of cessation products in the past year | 21 mg, 24-hour nicotine patches + E-cigarette starter kit with a 14 - week supply of 18 mg/mL e-liquid plus 6 weeks of withdrawal-oriented behavioral support; Device: eVOD (2^nd^ gen) | CG1: 21 mg, 24-hour nicotine patches + E-cigarette starter kit with a 14 -week supply of no nicotine e-liquid plus 6 weeks of withdrawal-oriented behavioral support; CG2: 21 mg, 24-hour nicotine patch for 14 weeks plus 6 weeks of withdrawal-oriented behavioral support | - Tobacco abstinence at 6 and 12 months; - Adverse events; - Tobacco use outcomes at 6 months
Included for KQ 3 only | Carpenter, 2017^147^; Fair | US | 68 | Age ≥18 years, current smoker of ≥5 CPD for 1 year.; At least some concern for health effects of smoking | IG1: E-cig with 16mg nicotine cartridges used at will for 3 weeks; IG2: E-cig with 24mg nicotine cartridges used at will for 3 weeks; After 3-week sampling period, both groups followed for 3 months (3 follow up visits); Device: BluCig and BluPlus+ | No intervention (continued smoking with conventional cigarettes) | - Adverse events; - Tobacco abstinence and use outcomes at 4 months (not abstracted)^†^
Included for KQ 3 only | Cravo, 2016^148^; Fair | UK | Cohort 1: 408; Cohort 2: 40 | Age 21 - 65 years, 5–30 CPD for at least one year.; Established smokers not trying to stop smoking or with quit intentions | Cohort 1: E-cig with 2.7 mg nicotine capsules (menthol or tobacco flavor) for 12 weeks; Cohort 2: E-cig with 2.7 mg nicotine capsules (menthol or tobacco flavor) with 12 weeks plus 1-week inpatient confinement at onset; Device: E-cig Prototype from Fontem Ventures B.V. | Cohort 1: No intervention (continued smoking with conventional cigarettes); Cohort 2: No intervention (continued smoking with conventional cigarettes) plus 1-week inpatient confinement at onset | - Adverse events
Included for KQ 3 only | Masiero, 2017^146^; Fair | Italy | 210 | Aged ≥55 years; smoked ≥10 CPD for the past 10 years.; High motivation to stop smoking | IG1: E-cig with 8mg/mL nicotine concentration - no more than 1 mL of consumption per day – plus behavioral counseling for 3 months; IG2: E-cig-like device with nicotine free capsules plus behavioral counseling for 3 months; Device: VP5 electronic cigarette | Behavioral counseling | - Adverse events; - Tobacco abstinence and use outcomes at 3 months (not abstracted)^†^
Included for KQ 3 only | Tseng, 2016^150^; Fair | US | 99 | Age 21–35 years, smoked ≥ 10 CPD.; Interested in reducing cigarette consumption | E-cig (disposable, 4.5% nicotine) for 3 weeks plus behavioral counseling to reduce CPD; Device: NJOY and King Bold | Placebo E-cig device plus behavioral counseling to reduce CPD | - Adverse events; - Tobacco abstinence and use outcomes at 3 weeks (not abstracted)^†^

* Defined as no more than 5 conventional cigarettes in the 2 weeks after a subject’s target quit date.

† Tobacco abstinence outcomes only included for followup ≥6 months

Abbreviations: ASCEND = A Study of Cessation using Electronic Nicotine Devices; CG = control group; CPD = cigarettes per day; ECLAT = EffiCiency and safety of an eLectronic cigAreTte; eCO = expired carbon monoxide; E-cig = electronic cigarette; edu = education; KQ = key question; IG = intervention group; rand = randomized; TEC = Trial of Electronic Cigarettes

### Key Question 1 Do Tobacco Cessation Interventions Improve Mortality, Morbidity, and Other Health Outcomes in Adults Who Currently Use Tobacco?

#### Combined Pharmacotherapy and Behavioral Interventions

None of the included systematic reviews reported the effectiveness of combined pharmacotherapy and behavioral interventions on health outcomes, including mortality and tobacco-related morbidity.

#### Pharmacotherapy Interventions

None of the included systematic reviews that assessed pharmacotherapy interventions among a general adult population reported the effects of interventions on mortality, morbidity, or other health outcomes.

#### Behavioral Interventions

One systematic review^125^ reported the results from a single RCT^159^ that evaluated the effect of a behavioral tobacco cessation intervention on health outcomes. In this trial, males considered to be at high risk of cardiorespiratory disease (n=1,445) were randomized to an intensive stop-smoking intervention that included advice, written materials, and one followup visit on health outcomes or a no intervention control group. At 20-year followup, in the intervention compared with the control group, total mortality was 7 percent lower, fatal coronary disease was 13 percent lower and lung cancer (death plus registrations) was 11 percent lower.^160^ These differences were not statistically significant, reflecting low power and the diluting effects of incomplete compliance with the cessation advice in the intervention group, and a progressive reduction in smoking by men in the control group.^160^

#### E-Cigarettes

We did not identify any primary evidence on the use of e-cigarettes as tobacco cessation interventions that reported results related to health outcomes.

### Key Question 2 Do Tobacco Cessation Interventions Increase Tobacco Abstinence in Adults Who Currently Use Tobacco?

#### Combined Pharmacotherapy and Behavioral Interventions

##### Primary Results

Only one review, the moderate-credibility review by Stead (2016), assessed the effect of combining pharmacotherapy and behavioral support for smoking cessation among adults.^127^ The review included 53 trials (12 of which were new to this update) that enrolled 15 to 5887 participants. In a meta-analysis that combined 52 of the 53 trials, there was a statistically significant benefit of combined pharmacotherapy and behavioral interventions versus control on smoking cessation at 6 months’ followup or longer (risk ratio [RR] 1.83 [95% confidence interval [CI], 1.68 to 1.98]; I^2^=36%; k=52; n=19,488) (Table 5).^127^ Average quit rates in these trials ranged from 2 to 50 percent (mean: 15.2%) among participants receiving pharmacotherapy and behavioral support versus 0 to 36 percent (mean: 8.6%) among participants randomized to a control group. The review found some evidence of asymmetry in a funnel plot, with an excess of smaller trials detecting larger effects, suggesting the possibility of publication or other bias; however, a sensitivity analysis removing the smaller trials did not have a marked effect on the pooled estimate.^127^

Control participants were offered usual care, self-help materials or brief advice on quitting that was of lower intensity than that given to intervention participants.^127^ Studies limited to adolescents or pregnant women were excluded. About half of the studies were conducted in the United States. A high proportion of trials were conducted in health care settings (e.g., primary care clinics, dental clinics, Veterans Administration medical centers) and/or recruited people with specific health needs (e.g., general and psychiatric hospital inpatients, patients awaiting admission for surgery, mental health patients, those with mild airway obstruction or COPD). In more than half of the trials (32/53, 60%), participants were required to be motivated to quit smoking for inclusion or were classified as likely to be interested in quitting; the remaining trials (21/53, 40%) did not select participants based on motivation to quit. The average age of participants typically ranged from low 40s to mid-50s.^127^

The included interventions typically offered or prescribed NRT; only seven trials offered bupropion or nortriptyline, and no trials offered varenicline.^127^ There was a great deal of variation in the intensity (number of sessions) and format of behavioral support. The typical intervention involved multiple contacts with a trained specialist cessation adviser or counselor, including face-to-face contact with additional sessions often provided by phone. Most trials (28/53, 53%) offered between four and eight sessions and a quarter (13/53, 25%) offered more than eight sessions. Total planned intervention contact time typically ranged from 90 to 300 minutes. Specialized cessation counselors or trained trial staff delivered most of the interventions. A primary care provider was the main interventionist in only four included studies.^127^

##### Evidence of Effect Modification

The review by Stead conducted planned subgroup analyses by setting, participant motivation to quit, provider, intensity, and compliance with medication and behavioral support.^127^ They found that the pooled effect of combined interventions was higher among 43 studies that were conducted in or recruited participants from a health care setting, compared with eight trials that recruited community volunteers. The results in both settings, however, showed significant benefit (health care: RR 1.97 [95% CI, 1.79 to 2.18] vs. community: RR 1.53 [95% CI: 1.33 to 1.76]) (Chi^2^ test for subgroup difference, p=0.00). There was no evidence that the relative effect of the intervention differed according to participant readiness-to-quit (meta regression, p=0.09). The subgroup of trials that included participants selected for motivation to change had a slightly larger effect estimate than the subgroup not selected for motivation, although the confidence intervals overlapped. Likewise, there was not an important difference in the effects of interventions delivered by cessation counseling specialists versus those provided by a nonspecialist health care provider, peer supporter, or lay health advisor (meta-regression, p=0.37). There was no clear evidence that increasing number of sessions or duration of personal contact had larger effects (bivariate meta regression, p=0.73). The subgroup of trials that offered eight or more sessions had the largest estimate (RR 2.10 [95% CI, 1.65 to 2.68])), but the confidence intervals overlapped for all four groups of interventions categorized by the number of sessions that included personal contact (i.e., 0 sessions, 1–3 sessions, 4–8 sessions, more than 8 sessions). Finally, there was no evidence of effect modification according to treatment uptake when comparing those with high (over 70% starting pharmacotherapy and receiving at least one session of support), moderate (over 30% starting pharmacotherapy and over 50% receiving at least one session of support), or low (less than 30% starting pharmacotherapy or less than 50% receiving at least one session of support) compliance with the intervention (Chi^2^ test for subgroup difference, p=0.07).^127^

#### Pharmacotherapy Interventions

##### Nicotine Replacement Therapy

###### Primary Results

The most recent high-credibility review, conducted by Hartmann-Boyce (2018), systematically searched for evidence through July 2017 that compared NRT with placebo or no NRT control groups among adult smokers.^96^ The review included 136 RCTs, 18 of which are new to this update, that ranged in size from fewer than 50 to over 8000 participants (median: 257). All six forms of NRT significantly increased the rate of cessation compared with placebo or no NRT, as did choice of NRT product (Table 5). Considering any form of NRT compared with placebo or no NRT, the pooled RR for abstinence was 1.55 (95% CI, 1.49 to 1.61; I^2^=39%; k=133; n=64,640) at the longest followup (6 months or more). Overall, 16.9 percent of participants who received some type of NRT achieved abstinence at 6 months or longer (range 1.7% to 60.0%), compared with 10.5 percent of control participants (range 0.5% to 46.0%).

The review included trials among men or women, including six trials among pregnant women who smoked and were motivated to quit, irrespective of the setting from which they were recruited or their initial level of nicotine dependence. In most studies, participants were an average age of 40 to 50 years and the average number of cigarettes smoked was over 20 per day. Most studies took place in North America (k=62) and Europe (k=56) and included members of the community who volunteered in response to media advertisements and were treated in clinical settings. Twenty-six trials were conducted in a primary care or similar setting, with smokers typically recruited in response to a specific invitation from their doctor. The remaining trials were conducted in antenatal clinics, specialized smoking-cessation clinics, hospitals (in- or outpatient), drug abuse or psychiatric treatment centers, schools, or in settings designed to resemble over the counter (OTC) use of NRT.^96^

The primary analysis (i.e., the effectiveness of one or more types of NRT compared with a placebo or a control group receiving no NRT) consisted of 131 trials reporting 133 comparisons among 64,640 participants.^96^ In this group of studies, 56 trials evaluated nicotine gum, 51 trials evaluated transdermal nicotine patches, 8 evaluated an oral nicotine tablet or lozenge, 7 evaluated a choice of products being offered, 4 evaluated intranasal nicotine spray, 4 evaluated nicotine inhaler, 2 evaluated the provision of patch and inhaler, 1 evaluated oral spray, and 1 each evaluated the provision of a patch and lozenge, patch and inhaler, and patch, gum, and lozenge. Most of the 56 trials that compared nicotine gum to a control provided the 2 milligram (mg) dose, while the remaining trials provided 4 mg. The treatment periods were usually 2 to 3 months but ranged from 3 weeks to 12 months. Many of the trials included a variable period of dose tapering, but most encouraged participants to be gum-free by 6 to 12 months. Among the nicotine patch trials (k=51), the typical maximum daily dose was 15 mg for a 16-hour patch or 21 mg for a 24-hour patch. Eight trials directly compared a higher-dose patch to a standard-dose patch. The minimum duration of therapy ranged from 3 weeks to 3 months. In the nicotine tablet or lozenge studies (k=8), three trials used 2 mg sublingual tablets, one trial used a 1 mg lozenge, and two trials used 2 mg or 4 mg lozenges. All trials provided the same behavioral support in terms of advice, counseling, and number of followup visits to the active pharmacotherapy and control groups, but different trials provided different amounts of support (in terms of number and duration of support).^96^

###### Evidence of Effect Modification

Indirect comparisons of trials within the Hartmann-Boyce review based on various study-, population-, intervention-, and outcome-related characteristics showed that the relative rates of abstinence were similar across groups.^96^ For instance, there was no evidence that timing (12- vs. 6-months) or choice of outcome (continuous vs. point prevalence abstinence) produced different treatment effects among trials of nicotine gum or patch (there were too few trials to test these differences for other products). Likewise, there was no evidence of effect modification through indirect subgroup comparisons according to the intensity or type of behavioral support that was provided to the intervention and control groups. As expected, absolute quit rates among control groups varied according to the intensity of the behavioral support; for example, rates averaged 3.5 percent with low-intensity support, 9 percent with high-intensity individual support, and 11.7 percent with group-based support. In terms of setting, the pooled RRs according to subgroup were all similar, with overlap in the 95% confidence intervals. The pooled RR for trials of any form of NRT among community volunteers for whom care was provided in a medical setting was 1.62 (95% CI, 1.53 to 1.72; I^2^=25%; k=6; n=24,957), similar to that of trials conducted in smoking clinics (RR 1.70 [95% CI, 1.48 to 1.96; I^2^=0%; k=12; n=3300), in primary care settings (RR 1.50 [95% CI, 1.33 to 1.69]; I^2^=0%; k=24; n=11,974), in hospitals (RR 1.39 [95% CI, 1.24 to 1.55]; I^2^=15%; k=13; n=7037), and in settings similar to OTC (RR 1.40 [95% CI, 1.26 to 1.55; I^2^=83%; k=9; n=13,163). Finally, there was no substantive change in the pooled effect estimate after a series of sensitivity analyses accounting for trial risk of bias (i.e., either excluding studies at high risk of bias or limiting the analysis to only those at low risk of bias) or study methods (i.e., removing studies with no biochemical verification or restricting to only placebo-controlled trials).^96^

###### Comparative Effectiveness of Different Doses, Duration, and Modes of NRT

A separate high-credibility review by Lindson (2019a) evaluated the effectiveness and safety of different forms, deliveries, doses, durations, and schedules of NRT for achieving smoking cessation.^104^ The review included trials among people of any age who smoked and were motivated to quit, irrespective of the setting from which they were recruited or of their initial level of nicotine dependence. Any form of NRT was included, with eligible comparisons being any other form, dose, duration, or schedule of NRT use. Studies were not eligible if one of the study arms received an additional intervention component that could not be separated from the NRT intervention, making it impossible to establish whether any effect found was as a result of the difference in NRT use or the additional component.^104^

The review included 63 studies (n=41,509), 21 of which were new to this update.^104^ The median sample size was 400 participants but ranged from 45 to 3575 participants. Most trials were among adult cigarette smokers with an average age of approximately 45 years old; six trials targeted specific populations including adolescents (1 trial), older adults (1 trial), men only (1 trial), those who were alcohol dependent or who had a history of alcohol dependence (2 trials), and adults with PTSD (1 trial). Trials typically recruited people who smoked at least 15 cigarettes per day; in most, the average number smoked was great than or equal to 20 cigarettes per day. Just about half of the studies (31/63, 49%) recruited participants directly from the community, typically in response to media advertisements, with the remaining trials mostly recruiting from referrals from clinicians or health care clinics including smoking cessation clinics or quitlines, substance abuse clinics, or primary care clinics.^104^

Fourteen studies compared the use of combination NRT (a fast-acting form plus a patch) with a single form of NRT and found that combination NRT resulted in higher long-term (6 months or longer) quit rates (RR 1.25 [95% CI, 1.15 to 1.36]; I^2^=4%; k=14; n=11,356) (Table 5).^104^ There was no evidence of subgroup differences when comparing combination therapy versus patch alone or a fast-acting form of NRT alone (Chi^2^ test for subgroup difference, p=0.61). There was no evidence from direct comparisons that a higher dose patch of 42/44 mg or 21/25 mg patch was more effective than a lower dose patch of 21/22 mg patch or 14/15 mg. Five trials compared 4 mg to 2 mg gum use; overall, there was a statistically significant greater effect of the higher dose of gum on cessation; however, sensitivity analyses revealed that was only true among trials that were among high dependency smokers, with no evidence of an effect in low dependency smokers. Evidence from eight trials suggested that using either a form of fast-acting NRT or a patch resulted in similar quit rates at 6 months or more (RR 0.90 [95% CI, 0.77 to 1.05]; I^2^=0%; k=8; n=3319). Nine trials compared the use of NRT or no NRT prior to the set quit date (i.e., “preloading” by using NRT while still smoking prior to an official quit date). The pooled effect found a positive statistically significant effect of NRT preloading on abstinence at 6 months or longer (RR, 1.25 [95% CI, 1.08 to 1.44]; I^2^=0%; k=9; n=4395). No comparisons based on duration of combination therapy or patch therapy showed a statistically significant difference on smoking abstinence. Except for the comparison of combination versus single form NRT, these comparisons and findings are based on a relatively small number of trials and should be interpreted cautiously.^104^

##### Bupropion

###### Primary Results

The high-credibility Howes (2020) review included the most comprehensive evidence synthesis on the effectiveness of bupropion versus placebo or no pharmacotherapy.^98^ The review included 87 studies that evaluated the effects of bupropion on smoking cessation and provided an analysis of 46 trials that evaluated smoking cessation after 6 months or more in those taking bupropion versus those taking a placebo or no pharmacotherapy. The pooled RR was 1.64 (95% CI, 1.52 to 1.77; k=46; n=17,866) with little evidence of heterogeneity (I^2^=15%) (Table 5).^98^ Within this analysis, most studies were based on continuous abstinence measures that were biochemically validated and were placebo controlled. Quit rates ranged from 3.7 to 43.5 percent (mean, 23.3%) among those receiving bupropion and from 0 to 32.8 percent (mean, 11.0%) among those in the control groups. Almost all included studies (45 of 46) randomized intervention participants to the recommended dose of bupropion at 300 mg daily (150 mg twice per day). Treatment duration ranged from 7 to 26 weeks.^98^

The Howes review assessed the effects of antidepressant medications, including bupropion, on smoking cessation rates at followup at least 6 months following initiation of treatment.^98^ Evidence related to other antidepressant medications, such as nortriptyline or citalopram, from the Howes review is discussed below under “Other Medications.” For smoking cessation outcomes, the review required RCTs to compare bupropion with placebo or another nonbupropion control or compare different dosages of bupropion. The authors excluded trials in which all participants received the same bupropion treatment but different behavioral support. Most trials (75%) were conducted in North America. Forty-five (52%) of the trials recruited special populations, such as individuals with comorbid health conditions (e.g., chronic obstructive pulmonary disease, schizophrenia, cardiovascular disease), adolescents, specific racial and ethnic groups (African American, Maori), or those who had previously failed to quit smoking using bupropion or NRT.^98^

###### Evidence of Effect Modification

In the review by Howes, the effects of bupropion were found to be similar regardless of the level of behavioral support offered.^98^ None of the three studies that used factorial designs to compare the effects of bupropion with varying levels of behavioral support found evidence that the efficacy of bupropion varied between lower and higher levels of behavioral support or by type of counseling approach provided (i.e., individual-based cognitive behavioral therapy vs. group therapy). There was also no evidence of a differential effect of bupropion on cessation between subgroups depending on whether they participants were recruited specifically because they had a mental health disorder or they represented the general population. Additionally, four included studies – including the large EAGLES trial,^161^ directly assessed whether there was any interaction between depression and cessation rates; none of these studies found evidence of effect modification.^98^

##### Varenicline

###### Primary Results

A 2016 moderate-credibility review by Cahill included 39 RCTs among adult smokers that evaluated the efficacy or safety of varenicline.^85^ The review found that varenicline at standard doses more than doubled the chances of quitting compared with placebo. The pooled RR for validated continuous abstinence at 6 or more months’ followup was 2.24 (95% CI, 2.06 to 2.43; I^2^=60%; k=27; n=12,625) (Table 5). Quit rates ranged from 5.3 to 46.8 percent (mean, 25.6%) among those receiving varenicline and from 0 to 28.2 percent (mean, 11.1%) among those in the control groups.^85^

Just over half of the studies were conducted in the United States or were multisite and included settings in the United States or Canada.^85^ The trials were conducted in smoking cessation clinics, hospitals, and universities and other research centers. None of the included studies took place in or involved primary care staff. Participants in most trials were adult smokers who were willing to make a quit attempt. Several trials were conducted in clinical subgroups, including among hospital inpatients and disease-specific subgroups (i.e., people with CVD, asthma, substance use disorder, depression, and bipolar/schizoaffective disorder).^85^

Most of the trials used the standard 12-week regimen of varenicline, routinely titrating the first week up to the recommended daily dose of 1 mg twice a day.^85^ Three trials compared different dosage arms of varenicline against a placebo arm. Most trials compared varenicline with an identical placebo regimen; trials comparing varenicline with other pharmacotherapies are discussed below (“Comparative Effectiveness”). All trials provided brief counseling for quit support to both treatment and control groups. As a condition of inclusion, all the trials reported cessation at least 6 months from the start of the intervention. All the trials except one used biochemical verification of abstinence.^85^

###### Evidence of Effect Modification

There was no evidence of differences in the effects of varenicline according to different study, drug, and population characteristics in the review by Cahill.^85^ A separate review by McKee (2016) found that varenicline versus placebo had a larger statistically significant effect size for women than men for continuous abstinence at both 3 and 6 months’ followup (sex x medication interaction, p<0.05).^112^ For example, at 6 months, varenicline increased the odds of quitting in women by 3.49 times (95% CI, 2.64 to 4.57) and by 2.59 times (95% CI, 2.20 to 3.06) in men, with the interaction demonstrating that varenicline was 31 percent more efficacious in women (OR, interaction for treatment condition by sex 1.31 [95% CI, 0.97 to 1.84; p<0.05). Equal efficacy was seen between men and women for both point prevalence abstinence and continuous abstinence at 1 year.^112^

##### Other Medications

In addition to the seven FDA-approved medications for smoking cessation (i.e., five forms of NRT, bupropion, and varenicline), various other antidepressants and nicotine receptor partial agonists have been evaluated for their effectiveness and safety in helping people stop smoking.

The review by Howes included a synthesis of the effectiveness of antidepressants including bupropion (discussed above), nortriptyline, selective serotonin reuptake inhibitors (SSRIs: fluoxetine, paroxetine, sertraline, citalopram and zimelidine), monoamine oxidase inhibitors (MAOIs: moclobemide, selegiline, lazabemide, EVT302), and other antidepressants (venlafaxine, St. John’s wort, S-Adenosly-L-Methionine, doxepin, imipramine, tryptophan).^98^ There was limited evidence for all comparisons, which prevents drawing robust conclusions about these therapies. A pooled analysis of six trials showed evidence of a significant benefit of nortriptyline versus placebo at 6 or more months followup (RR 2.03 [95% CI, 1.48 to 2.78]; I^2^=16%; k=6; n=975). In contrast, none of the individual trials of SSRIs (k=7), MAOIs (k=6), or other antidepressants (k=4) showed a benefit on smoking cessation at 6 or more months followup nor did pooled estimates of these medications. Furthermore, comparing any of these other antidepressants as an adjunct to nicotine patch therapy versus nicotine patch alone did not show evidence of an additional benefit over NRT.^98^

In addition to synthesizing the evidence on varenicline (discussed above), the review by Cahill on nicotine receptor partial agonists included five trials testing the effects of cytisine (k=4, n=3461) to increase smoking abstinence.^85^ The pooling two of the more recent trials of cytisine found that more participants taking cytisine stopped smoking compared with placebo at 6 or more months’ followup, with a pooled RR of 3.98 (95% CI, 2.01 to 7.87).^85^

##### Comparative Effectiveness of Different Pharmacotherapy Agents or Regimens

###### Comparison of Different Types of NRT

As noted above, no studies that compared fast-acting NRT with a nicotine patch found a differential effect on smoking cessation (RR 0.90 [95% CI, 0.77 to 1.05]; I^2^=0%; k=8; n=3319).^104^ One trial (n=1410) included in the Lindson review also compared participant- versus clinician-selected NRT and found no difference in quit rates at 6 months.^104^

###### Combination NRT vs. Single NRT

As stated above, combination NRT (i.e., the use of a fast-acting product and nicotine patch) was found to be superior to a single form of NRT in a pooled analysis of 14 direct comparisons (RR 1.25 [95% CI, 1.15 to 1.36]; I^2^=4%; k=14; n=11,356) (Table 5).^104^

###### NRT vs. Bupropion

Howes included ten studies that directly compared bupropion with any form of NRT.^98^ Pooled results did not detect a significant difference between the bupropion versus NRT (RR 0.99 [95% CI, 0.91 to 1.09]; I^2^=18%, k=10; n=8230) (Table 5).^98^

###### NRT vs. Varenicline

Cahill and colleagues included eight trials that tested NRT against varenicline.^85^ A pooled analysis of all of the trials indicated a benefit for varenicline over NRT at 6 months (RR 1.25 [95% CI, 1.14 to 1.37]; I^2^=39%; k=8; n=6264) (Table 5). Removing three open-label trials (all at high risk of bias for blinding) slightly strengthened the effect estimate (RR 1.34 [95% CI, 1.19 to 1.50]) and increased the I^2^ to 47%. In a separate review examining sex differences in the relative effectiveness of pharmacotherapy, the benefits of varenicline over NRT were greater for women than with men (RR for interaction effect, 1.19 [95% CI, 1.01 to 1.40).^124^ In that review, women treated with varenicline were 41 percent more likely to achieve 6-month abstinence than women treated with NRT (RR 1.41 [95% CI, 1.12 to 1.76]). For men, the benefit of varenicline over NRT (16%) was smaller and not statistically significant (RR 1.16 [95% CI, 0.91 to 1.47]).^124^

###### NRT vs. Cytisine

One recent trial comparing cytisine with NRT in 1310 people found a benefit for cytisine at 6 months (RR 1.43 [95% CI, 1.13 to 1.80]).^85^

###### Bupropion vs. Varenicline

Six trials included in the Howes review directly compared the effects of bupropion versus varenicline on smoking cessation.^98^ All six studies showed more favorable effects for varenicline compared with bupropion, and all but one found these differences to be statistically significant. A pooled estimate of the six trials found that bupropion was less effective than varenicline (RR 0.71 [95% CI, 0.64 to 0.79]; I^2^=0%; k=6; n=6286) (Table 5).^98^ A separate review and network meta-analysis found greater effectiveness of varenicline versus bupropion in achieving 6-month abstinence among women (RR 1.38 [95% CI, 1.08 to 1.77]) versus men (RR 1.11 [95% CI, 0.85 to 1.45] (RR for interaction effect, 1.22 [95% CI, 1.02 to 1.47]).^124^

###### Bupropion Plus NRT vs. NRT

A pooled estimate of 12 studies that directly compared the addition of bupropion to NRT versus NRT alone did not suggest a significant benefit of this combination of drugs versus NRT alone (RR 1.19 [95% CI, 0.94 to 1.51]; I^2^=52%; k=12; n=3487), although studies were clinically and statistically heterogeneous.^98^

###### NRT Plus Varenicline vs. Varenicline

A review by Chang and colleagues (2015) included three RCTs with 904 participants that compared combined varenicline and NRT therapy with varenicline alone.^87^ Only two of the trials reported continuous smoking abstinence at 6 months. Both trials showed a favorable effect of combination therapy, although only one reached statistical significance.^87^

###### Bupropion Plus Varenicline vs. Varenicline

In the Howes review, there was no evidence that combination bupropion and varenicline resulted in higher smoking cessation rates than varenicline alone (RR 1.21 [95% CI, 0.95 to 1.55]; I^2^=15%; k=3; n=1057).^98^

##### Support for Medication Adherence

Finally, a 2019 review by Hollands assessed the effectiveness of interventions that aimed to increase adherence to medications for smoking cessation.^97^ The review included 10 studies, all of which reported the effects of the intervention on adherence outcomes. There was some evidence that interventions that devote special attention to improving adherence through the provision of information and facilitation of problem-solving can lead to modest increases in adherence, when added to behavioral support for smoking cessation. Five studies also reported on the effects of the adherence intervention on abstinence at 6 months or greater, with evidence of no effect on smoking abstinence (RR 1.16 [95% CI 0.96 to 1.40]; I^2^=48%; k=10; n=3593) (Table 5).^97^

#### Behavioral Interventions

##### Behavioral Support as an Adjunct to Pharmacotherapy

###### Primary Results

The high-credibility review by Hartmann-Boyce (2018) assessed the effect of increasing the intensity or changing the content of behavioral support among smokers using smoking cessation medications.^95^ The review included RCTs in which adult smokers in both the intervention and control conditions received pharmacotherapy for smoking cessation, but they differed by the amount or content of behavioral support. Participants in the control condition received less-intensive behavioral support than participants in the intervention condition, often limited to written information alone, or a different approach to behavioral support but matched for contact time.^95^

Eighty-three studies were included, of which 36 are new for this update.^95^ Over 29,000 participants are represented in the included study arms, with a range of 30 to 4614 participants in the individual trials. A meta-analysis of 65 trials suggested that increasing the intensity of behavioral support for smokers making a cessation attempt with the aid of pharmacotherapy typically leads to a relatively small increase in the proportion who have quit at 6 to 12 months. The estimated RR was 1.15 (95% CI, 1.08 to 1.22; I^2^=8%; k=65; n=23,331) (Table 5). The average absolute quit rate of both the intervention (20%) and control groups (17%) were quite high and were comparable to the intervention groups in the trials of pharmacotherapy versus placebo. While most studies reported point prevalence abstinence instead of continuous or prolonged abstinence, the review found no difference in the relative effect between studies that reported point prevalence rather than continuous abstinence at 12 months.^95^

Twenty-nine studies (35%) recruited people in a health care setting (excluding smoking cessation clinics), including 10 studies that took place in primary care.^95^ Since the intervention included the provision of pharmacotherapy, most of the studies recruiting in a health care setting enlisted volunteers who were interested in making a quit attempt, although motivation to quit was not always an explicit eligibility criterion. The remaining studies recruited community volunteers interested in quitting.^95^

Most studies offered NRT, specifically the nicotine patch.^95^ Seven studies provided bupropion alone, one provided nortriptyline alone, and four provided varenicline alone. The remaining studies offered participants a choice or combination of medications. The intensity of the behavioral support, in both the number of sessions and their duration, was very heterogeneous for both the intervention and control arms. In seven studies, the controls received no counseling. In 30 studies, the control arms had one to three contacts (either face-to-face or by telephone), and most of these had a total contact duration of 4 to 30 minutes. In 34 studies the control group was scheduled to receive four to eight contacts, with most involving a total contact duration of over 90 minutes. The 12 remaining studies scheduled over eight contacts for the controls. Typically, the intervention involved only a little more contact than the control, so that the least intensive control conditions were in trials with only moderate-intensity interventions.^95^

###### Evidence of Effect Modification

The effect was similar and statistically significant for the subgroup of studies that examined behavioral support as an adjunct to NRT (k=50) and bupropion (k=5) specifically.^95^ Results of the remaining trials among smokers using other pharmacotherapies (e.g., varenicline) or a choice of pharmacotherapy were generally not statistically significant, although there were few trials in these subgroups and a test for difference between subgroups was not significant. There was little evidence of any dose-response effect according to the number of contacts in the intervention and control groups (and the contrast between those groups), although the point estimate was highest for the subgroup in which controls did not have any personal contact (RR 1.20 [95% CI, 1.02 to 1.43]). Seventeen studies, all new to this update, compared interventions matched for contact time but provided through different modalities, providing different content, or employing different behavior change techniques. All studies in this group employed different comparisons and were not pooled. Only one trial – comparing motivational interviewing with health education – found a statistically significant difference between the two interventions, with the finding in favor of health education.^95^

##### Physician Advice

###### Primary Results

The high-credibility review by Stead (2013b) summarized evidence from 42 trials on the effectiveness of physician advice in promoting smoking cessation published through January 2013.^125^ This review included RCTs that compared physician advice to stop smoking versus no advice (or usual care), or compared different levels of physician advice to stop smoking. Advice was defined as verbal instructions from the physician with a “stop smoking” message regardless of whether information was provided about the harmful effects of smoking. In a meta-analysis, smokers who were offered cessation advice by a physician had a statistically significant increase in the likelihood of quitting at 6 months or longer compared with smokers receiving no advice or usual care (RR 1.76 [95% CI, 1.58 to 1.96]; I^2^=40%; k=26; n=22,239) (Table 5). Absolute quit rates ranged from 1 to 23 percent among intervention participants (mean: 8.0%), and from 1 to 14 percent among control participants (mean: 4.8%).^125^

###### Evidence of Effect Modification

The results of the main meta-analyses were not sensitive to exclusion of trials at high risk of bias for any item.^125^ When stratified by intervention intensity, both brief advice (single consultation lasting less than 20 minutes plus up to one followup visit) (RR 1.66 [95% CI, 1.42 to 1.94]) and intensive advice (greater time commitment at the initial consultation, use of additional materials beyond a brochure, or more than one followup visit) (RR 1.86 [95% CI, 1.60 to 2.15]) showed statistically significant increases in quit rates when compared with no advice controls. There was no evidence of an interaction effect between strata (p=0.31). However, direct comparisons between intensive and minimal advice in 15 trials suggested a statistically significant advantage of more intensive advice (RR 1.37 [95% CI, 1.20 to 1.56]; I^2^=32%; k=15; n=9,775). Subgroup analyses within this group of 15 trials suggested that this effect might be small or nonexistent among smokers without smoking-related disease (10 studies), but the effect might be larger when the intervention is provided to smokers in high-risk groups (e.g., those with heart disease, chronic obstructive pulmonary disease) (based on only 5 trials).^125^

An indirect comparison between subgroups of studies within the main analysis suggested that interventions that included additional followup visits had a slightly larger effect estimate (RR 2.27 [95% CI, 1.87 to 2.75]; I^2^=27%; k=6; n=4,510) compared with no advice than interventions delivered at a single visit versus no advice (RR 1.55 [95% CI: 1.35 to 1.79]; I^2^=35%; k=18; n=14,675).^125^ Five additional included trials directly compared the addition of further followup to a minimal intervention but were not included in the main analysis of advice versus no advice. None of these five trials individually detected significant differences between groups.^125^

##### Nurse Advice

###### Primary Results

A more recent high-credibility review by Rice (2017) synthesized the evidence on nursing interventions for smoking cessation.^119^ Similar to the review of physician advice, included nursing interventions consisted of the provision of advice, counseling, and/or other strategies to help people stop smoking provided by a nurse. This review used the same definition of what constituted “advice” but defined intervention intensity slightly differently. In the Rice review, low-intensity interventions were those that were conducted during a single consultation lasting 10 minutes or less, with up to one followup visit (as opposed to 20 minutes in the physician advice review) and high-intensity interventions as those in which the initial contact lasted more than 10 minutes (again, as opposed to more than 20 minutes for physician advice). These high-intensity interventions also distributed additional materials, used additional strategies, and typically included more than one followup visit.^119^

The Rice review included 58 trials, nine of which are new to this update.^119^ Twenty-eight trials (48%) recruited from primary care or outpatient settings, and another 22 trials (38%) intervened with hospitalized patients. The remaining trials recruited from workplaces, communities, universities, and other sites. Just under half of the trials recruited individuals with chronic diseases (e.g., cardiovascular disease, respiratory disease, diabetes) or hospitalized patients. Most trials (k=44) compared a nursing intervention to a usual care or minimal intervention control and contributed to the primary meta-analysis. The remaining comparisons were made between two nursing interventions that involved different components or a different number of contacts (k=11) or were excluded from meta-analyses because of incomplete data (k=6). The estimated pooled RR comparing smoking cessation support provided by a nurse with usual care or minimal intervention was 1.29 (95% CI, 1.21 to 1.38; I^2^=50%; k=44; n=20,881) (Table 5).^119^

###### Evidence of Effect Modification

There was no evidence of different effects among interventions classified as low- versus high-intensity (Chi^2^ test for subgroup difference, p=0.87).^119^

##### Individual Behavioral Counseling

###### Main Results

We identified one recent high-credibility review by Lancaster (2017) that reviewed the evidence on individual counseling in promoting smoking cessation.^103^ The review included studies among nonpregnant smokers that tested the effect of an individual counseling intervention compared with no treatment, brief advice, self-help materials, or a less intense individual counseling intervention. Individual counseling was defined as a face-to-face encounter between a smoker and a counselor trained in providing smoking cessation assistance. Studies of counseling delivered by physicians or nurses, those that combined counseling with pharmacotherapy, and those using motivational interviewing were excluded given their inclusion in other relevant reviews (which are all included in this overview of reviews). Forty-nine trials were included, with around 19,000 participants. Thirty-three studies contribute to the primary analysis comparing individual counseling with a minimal-contact behavioral intervention. Eleven studies compared different intensities of interventions, and five compared counseling approaches that were similar in intensity of contact. The recruitment settings and study populations were highly variable and included those recruited as medical or surgical inpatients or outpatients, at primary care clinics and worksites, and as community volunteers. The counseling intervention typically included a review of a participant’s smoking history and motivation to quit, help in identification of high-risk situations, and the generation of problem-solving strategies to deal with such situations. Some studies also provided additional components such as written materials or videos. The therapists who providing the counseling were generally described as smoking cessation counselors with professional backgrounds in social work, psychology, psychiatry, health education, and nursing.^103^

The pooled effect size based on 33 studies demonstrated statistically significant benefit of individual counseling compared with a minimal contact control (RR 1.48 [95% CI, 1.34 to 1.64]; I^2^=46%; k=33; n=13,762) (Table 5).^103^ In these studies, a minimal contact control ranged from usual care to up to 15 minutes of advice, with or without the provision of self-help materials. Most of the interventions implemented multiple sessions of face-to-face support in addition to telephone contact. Within this group of studies, six trials included pharmacotherapy for both arms. The effect estimate was higher in the subgroup of studies when pharmacotherapy was not provided (RR 1.57 [95% CI, 1.40 to 1.77]; I^2^=50%; k=27; n=11,100) than in the studies testing the additional effect of counseling when participants had access to pharmacotherapy (RR 1.24 [95% CI, 1.01 to 1.51]; I^2^=0%; k=6; n=2662) and the test for a subgroup difference was statistically significant (Chi^2^ test for subgroup difference, p=0.04). There was some evidence that more intensive versus less intensive counseling resulted in greater cessation (16.8% vs. 12.7% absolute quit rates, respectively) (RR 1.29 [95% CI, 1.09 to 1.53]; I^2^=48%; k=8; n=2920), and there was a difference in this effect according to whether pharmacotherapy was also provided (Chi^2^ test for subgroup difference, p=0.04). There was limited evidence from studies comparing different types of individual counseling.^103^

##### Group Behavioral Therapy

###### Primary Results

The moderate-credibility review by Stead (2017) synthesized the evidence on the effect of group-delivered behavioral interventions in achieving long-term (6 months or more) smoking cessation among nonpregnant adult smokers.^126^ Included interventions were those in which smokers attended scheduled meetings and received some form of behavioral intervention, such as information, advice, and encouragement or cognitive behavioral therapy delivered over at least two sessions. The review included 66 trials, 44 of which compared a group program with a non-group-based cessation intervention or a no-intervention control. The remaining 22 did not have a non-group control and only contributed to comparisons between different group-based programs. Most studies recruited community volunteers prepared to participate in group programs; only three recruited from primary care. The group programs varied in length, format, and content. Most programs offered six to eight sessions, with the first few sessions devoted to motivation for quitting, health benefits, and strategies for planning a quit attempt. Compared with non-group self-help programs, group-based therapy interventions resulted in a statistically significant increased risk of quitting tobacco at 6 or more months’ followup (RR 1.88 [95% CI, 1.52 to 2.33]; I^2^=0; k=13; n=4395) (Table 5). A separate analysis of 14 trials found a small benefit of group support compared with brief support from a physician, nurse, or pharmacist with a conference interval just excluding no effect (RR 1.22 [95% CI, 1.03 to 1.43]; I^2^=59%; k=14; n=7286). When combining the results of five trials (n=1523) that examined group therapy as an adjunct to pharmacotherapy, the analysis did not detect a statistically significant increased quit rate for combined therapy over pharmacotherapy without group support. Similarly, there was no evidence, based on six trials (n=980), that group therapy was more effective than individual therapy when the number of sessions were matched.^126^

##### Motivational Interviewing

###### Primary Results

A 2019 high-credibility review by Lindson (2019b) reviewed the evidence on the effectiveness of motivational interviewing (MI) to increase smoking cessation.^106^ In this review, RCTs conducted among nonpregnant smokers with an MI intervention were included. The intervention must have been based on the MI principles as defined by Miller and Rollnick,^162^ making explicit reference to at least some MI principles: exploration of ambivalence, decision balance, assessment of motivation and confidence to quit, elicitation of “change talk,” and support for self-efficacy and in the opinion of the review authors, complied with these principles and practices. The review identified 37 trials, involving over 15,000 participants. The included MI interventions were conducted in one to 12 sessions, with the total duration of MI ranging from 5 to 315 minutes. Interventions were primarily delivered by primary care physicians, nurses, or counselors. Pooling studies that compared a smoking cessation intervention supplemented by MI with the same smoking cessation intervention without MI suggested a small potential benefit of MI; however, the 95% CI spanned one and there was moderate heterogeneity detected (RR 1.07 [95% CI, 0.85 to 1.36]; k=12; n=4167; I^2^=47%) (Table 5). Nineteen trials compared an MI intervention to another type of smoking cessation intervention. The point estimate was in favor of MI; however, the confidence intervals were consistent with substantial benefit and with potential harm (RR 1.24 [95% CI, 0.91 to 1.69]; k=19; n=5192; I^2^=54%). Furthermore, there was no evidence of a benefit of a MI smoking cessation intervention when compared with no intervention within four trials.^106^

###### Evidence of Effect Modification

There was no clear evidence to suggest that the effect of MI was moderated by the intervention provider participants’ motivation to quit at baseline, whether MI was delivered face-to-face, or whether MI fidelity monitoring took place.^106^ Five trials directly compared the effectiveness of more intensive versus less intensive MI intervention. There was some suggestion that more intensive interventions were associated with greater smoking abstinence; however, this analysis included several studies at high risk-of-bias and removing those studies produced a nonsignificant result.^106^

##### Decision Aids

###### Primary Results

A 2018 moderate-credibility review by Moyo synthesized the evidence on the effectiveness of decision aids for smoking cessation in adults.^115^ Both experimental and quasi-experimental studies that evaluated the use of decision aids to promote shared decision making between a patient and healthcare provider were included. For the purpose of this review, a decision aid was defined as a tool any healthcare provider used to share with and inform people about treatment options, including the risks, and costs and benefits of potential choices. Any form of decision aid was included such as pamphlets, brochures, cards, DVDs, or web-based applications. The review identified seven studies that met eligibility criteria with decision aids including web- or computer-based aids (3 studies), a video decision aid (1 study), a print-based aid (2 studies), and a video plus print decision aid (1 study). The decision aids were delivered by a healthcare provider in only two cases. The other studies all evaluated a decision aid where provider followup was optional based on the participant’s decision after use of the aid. Of the six studies that measured abstinence, only two suggested a benefit of using a decision aid (versus usual care) on smoking abstinence and only one was statistically significant.^115^

##### Print-Based Self-Help Materials

###### Primary Results

A recent updated moderate-credibility review by Livingstone-Banks (2019b) assessed the effectiveness of different forms of print-based self-help materials compared with no treatment or other minimal intervention strategies.^109^ The review included 75 studies, with only 3 of them new to this update. Self-help interventions were defined as any manual or program designed to be used by individuals to assist a quit attempt not aided by health professionals, counselors, or group support. For the most part, that included written materials such as booklets and leaflets/brochures, but information could also have been provided via audio, video, or a similar medium. Brief leaflets on the health effects of smoking were considered a control condition if they were compared with a more substantial print-based intervention. Interventions that included a single face-to-face session for the purpose of supplying the print-based materials were included, but interventions that provided repeated sessions of advice in addition to self-help materials were excluded. Additionally, interventions delivered via a computer or mobile phone as well as those that included telephone counseling as adjuncts to self-help materials were excluded because these interventions were covered in other published reviews (which are also included in this overview of reviews).^109^

The content and format of the self-help programs varied.^109^ The most frequently used materials were the American Lung Association’s cessation manual: Freedom From Smoking in 20 Days, and the maintenance manual: A Lifetime of Freedom From Smoking.^163^ Most other programs were not named or fully described. Most of the recent studies used computerized expert systems to provide tailored materials judged to be relevant to the characteristics of each smoker, based on baseline data.^109^

Overall, after pooling 32 studies of non-tailored self-help materials compared with no self-help, irrespective of the level of contact and support common between groups, the point estimate showed a small, but not statistically significant, benefit of the intervention (RR 1.06 [95% CI, 0.95 to 1.19]; I^2^=25%; k=32; n=28,451) (Table 5).^109^ Trials varied considerably in ways that could potentially impact results, such as whether the materials were tailored, and the amount of face-to-face advice or counseling provided to both the intervention and control groups.^109^

###### Evidence of Effect Modification

When isolated to only studies that compared groups who received self-materials versus groups who received no intervention at all, results were statistically significant: a meta-analysis of 11 trials that provided standard non-tailored self-help manuals or materials compared with no materials for the control group showed some benefit of self-help materials, although the confidence interval only narrowly excluded 1.0 (RR 1.19 [95% CI, 1.03 to 1.37]; I^2^=0%; k=11; n=13,241).^109^ Relative effects were also larger when comparing the subset of studies in which participants in the intervention group received tailored self-help materials versus controls receiving no intervention (RR 1.34 [95% CI, 1.19 to 1.51]; I^2^=0%; k=10; n=14,359). However, there was no evidence that tailored materials were superior to nontailored materials in indirect or direct comparisons.^109^

##### Telephone Counseling and Support

###### Primary Results

A recent moderate-credibility review by Matkin (2019) evaluated the effects of telephone support to help smokers quit.^110^ Included trials evaluated the impact of proactive (i.e., recruiter-initiated contact) and reactive (i.e., smoker-initiated contact) among smokers of any age, including pregnant individuals. The review identified 104 trials (30 of which are new to this update) including 111,653 participants that met inclusion criteria. All included trials were relatively large, with a median sample size of 735 and only 7 trials with a sample size of less than 100. Participants were mostly adult smokers from the general population, but some studies included adolescents, pregnant women, and people with long-term or mental health conditions. Most studies (100/104) assessed proactive telephone counseling programs as opposed to reactive forms. Proactive telephone counseling interventions included: 1) additional counseling calls that took place following smokers calls to helplines and 2) counseling calls from counselors or other health care providers that were among samples of smokers who had not originally contacted a help line (essentially a “cold call”). Some studies provided telephone counseling alone, but many others provided telephone counseling along with minimal support such as self-help materials, or more active support such as face-to-face counseling, or with medications. The number of calls ranged from a single call to 12 calls. The duration of the calls was typically 10 to 20 minutes, although the first calls were often longer. Counseling was most often provided by professional counselors or trained health care professionals.^110^

Among trials including smokers who contacted helplines, quit rates were higher for smokers receiving multiple additional telephone counseling sessions (mean quit rate, 10.8%) compared with a control condition that was provided self-help materials or brief counseling in a single call (mean quit rate, 7.8%) (RR 1.38 [95% CI, 1.19 to 1.61]; I^2^=72%; k=14; n=32,484) (Table 5).^110^ Likewise, in studies that recruited smokers who did not call a helpline, telephone counseling increased quit rates (mean quit rate, 13.9%) modestly compared with other minimal or brief counseling control groups (mean quit rate, 11.0%) (RR 1.25 [95% CI, 1.15 to 1.35]; I^2^=52%; k=65; n=41,233) (Table 5). In both instances, however, statistical heterogeneity was moderate to substantial. Only three included studies assessed the impact of offering reactive counseling by providing access to a helpline/quitline, compared with not being provided access with only one finding a statistically significant increased rate of quitting among those with helpline access. Both proactive and reactive telephone counseling appeared to increase quit rates compared with health care provider counseling, but this finding is limited by the small number of trials testing this comparison (four trials).^110^

###### Evidence of Effect Modification

The exclusion of trials among pregnant women, adolescents, and those at high risk of bias did not have a large influence on the effect size or statistical heterogeneity in the review.^110^ Likewise, subgroup analyses based on the baseline support provided to both intervention and control groups, counseling intensity, or motivation did not fully explain the heterogeneity in the results. However, there was some evidence through multivariate meta regression that the baseline support offered to both treatment arms as well as whether participants were selected for motivation to quit may have had some influence on the effect size related to proactive telephone counseling for smokers who did not call quitlines. The relative difference was greater for those receiving adjunctive self-help materials (35% greater) or brief face-to-face counseling (37% greater) than pharmacotherapy (referent). In the same model, studies that selected participants because of their motivation to quit were associated with a 26 percent increased relative risk compared with studies that did not select participants based on their motivation to quit. There was not enough evidence to suggest that a higher number of calls would result in a larger effect, although there was limited evidence that offering 3 to 6 calls may be more effective than offering just one single proactive call.^110^

##### Mobile Phone-Based Support

###### Primary Results

The high-credibility review by Whittaker (2019) identified 26 RCTs 14 of which are new) (n=33,849) that included an evaluation of a mobile phone-based intervention.^138^ The review included interventions that were aimed at mobile phone users, were based on delivery via mobile phone, or used any functions or applications that could be used or sent via a mobile phone. The review excluded trials that used mobile phones as an adjunct to face-to-face or internet-based programs or that could not separate the effects of the mobile phone intervention components from the effects of a multicomponent intervention. All studies tested automated text messaging interventions (SMS) as a central component of the intervention. Several studies paired SMS with in-person visits, although the majority were purely test-messaging interventions. Five studies tested the effectiveness of smoking cessation smartphone apps alone, although the apps varied considerably in intervention content and components. Trials represented both young adults (mean age 18–27 years) and middle-age adults (up to mean age of 45 years).^138^

A meta-analysis of 13 studies that compared a text messaging intervention with minimal smoking cessation support showed a positive benefit of text messaging interventions on smoking cessation at 6 months’ followup (RR 1.54 [95% CI, 1.19 to 2.00]; I^2^=71%; k=13; n=14,133) (Table 5) with the average absolute quit rates of 9.5 percent versus 5.6 percent in the intervention versus control groups, respectively.^138^ A similar effect was found when comparing mobile phone-based interventions with no intervention (RR 1.59 [95% CI, 1.09 to 2.33]; I^2^=0%; k=4; n=997).^138^

###### Evidence of Effect Modification

The review found minimal differences in the overall result when pooled subgroups of studies were based on frequency of text messages (high-frequency vs. low-frequency), text message-only interventions, or those with only minimal (versus active) controls.^138^

##### Real-Time Video Counseling

###### Primary Results

A new high-quality review by Tzelepis (2019) assessed the effectiveness of real-time video counseling delivered individually or to a group (e.g., via video communication software such as Skype and FaceTime) in increased smoking cessation.^134^ Only two trials were identified (n=615). Both studies delivered real-time video counseling for smoking cessation individually, compared with telephone counseling. There was no statistically significant tretement effect for smoking cessation across the two included studies (RR 2.15 [95% CI, 0.38 to 12.04]; I^2^=66%; k=2; n=608) (Table 5).^134^

##### Internet-Based Support

###### Primary Results

An updated high-credibility review by Taylor (2017) was designed to determine the effectiveness of internet-based interventions for smoking cessation and to evaluate whether intervention effectiveness was altered by tailoring interactive features, and if there was a difference in effectiveness between adolescents, young adults, and adults.^129^ Any type of internet intervention was eligible, and the comparison could be a no-intervention control, a different internet intervention, or a non-internet intervention. The review identified 67 RCTs, including data from over 110,000 participants. Thirty-nine of the trials were new to this update. Most of the studies were among adults; three studies recruited adolescents only and seven studies recruited young adults or university or college students. Most studies were conducted in the United States and recruitment and all intervention components were Web-based, with participants finding the sites through search engines and browsing. As a result of the recruitment methods, participants in these trials were motivated to quit smoking and chose the internet as a tool for smoking cessation support. Sample sizes ranged from fewer than 70 to nearly 12,000.^129^

A range of internet interventions was tested in the included studies, from a very low-intensity intervention providing a list of websites for smoking cessation, to highly intensive interventions consisting of internet-, email- and mobile phone-delivered components.^129^ Many interventions provided tailored interventions but differed substantially in the amount of tailoring. Some trials also included counseling or support from nurses, peer coaches, or tobacco treatment specialists. Some of the more recent trials incorporated online social networks such as Facebook, Twitter, and online forums. In 15 trials, all participants were using, or were offered, pharmacotherapy and the internet component was thus evaluated as an adjunct to pharmacotherapy. Nine trials of lifestyle interventions provided content on a range of topics, including smoking cessation. These trials were not included in the main synthesis and meta-analysis given that results were not isolated for smokers only.^129^

Given the heterogeneity of the included evidence in terms of the interventions (i.e., tailored vs. not, interactive vs. not) and control conditions (i.e., nonactive controls [printed self-help guides, usual care], active controls [telephone, face-to-face counseling], addition of an internet program plus behavioral support, or comparing one internet intervention with another), the results were synthesized into distinct subgroups.^129^ Compared with a nonactive control group, pooled results demonstrated an effect in favor of interactive and tailored internet-based interventions (RR 1.15 [95% CI, 1.01 to 1.30]; I^2^=58%; k=8, n=6786) (Table 5). However, these results should be interpreted with caution, as statistical heterogeneity was high and was unexplained despite perceived clinical homogeneity. Furthermore, though the pooled effect was in the direction of potential benefit, this analysis was based on a fixed effect model which can result in substantially different results compared with a random effect model when there are big imbalances in sample sizes in the studies being pooled. In fact, in this analysis, average absolute quit rates were slightly lower for the intervention (12.8%) vs. control (12.9%) groups. Five studies evaluated an internet intervention plus behavioral therapy compared with a nonactive control and indicated a collective positive effect on the intervention (RR 1.69 [95% CI, 1.30 to 2.18]; k=5; n=2334), although again, the statistical heterogeneity was quite high (I^2^=60%).^129^

###### Evidence of Effect Modification

Given the heterogeneity in the included interventions and comparators, the review analyzed studies within distinct groups (interactive and tailored internet-based interventions, interactive but not tailored internet-based interventions, and neither interactive nor tailored internet-based interventions).^129^ When compared with a nonactive control group, in all cases, statistical heterogeneity was high and unexplained; although the review performed no further analyses to explain this heterogeneity (likely due to largely null effects). In direct comparisons, none of the studies comparing an Internet intervention or Internet intervention plus behavioral support with an active control detected statistically significant evidence for differences between the conditions. Seven studies compared an interactive and/or tailored internet program or website with an internet intervention that was neither tailored nor interactive. Pooled results favored the intervention group; however, they were not statistically significant (RR 1.10 [95% CI, 0.99 to 1.22]; I^2^=0%; k=7; n=14,623).^129^

##### Incentives

###### Primary Results

We included one high-credibility review by Notley (2019) that examined whether incentives and contingency management programs led to higher long-term quit rates among smokers.^116^ Thirty-three studies among adults met inclusion criteria, including over 21,600 participants. Nearly three-quarters of the trials (22/33) took place in the United States. The incentives included cash rewards or monetary incentives in the form of vouchers, prize drawings alongside a guaranteed reward, the recovery of money deposited by those taking part, or a combination of incentive types. Seven studies included complex payment schedules that specifically rewarded continuous abstinence. The total financial amount of incentives (where reported) varied considerably between trials, from zero (self-deposits) to a range between $45 and $1,185. All but one study included additional cessation support such as brief advice, pharmacotherapy, and in one case – e-cigarettes. Most of the studies took place in worksites or substance misuse clinics; six studies delivered support in a health clinic including mental health clinics, head and neck cancer clinics, or primary care clinics. The pooled RR for quitting with incentives at longest followup (6 months or more) compared with usual care or a non-incentive-based intervention was 1.49 ([95% CI, 1.28 to 1.73]; I^2^=33%; k=30; n=20,097) (Table 5).^116^

###### Evidence of Effect Modification

There was no significant difference between studies that offered incentives up until the point of measuring abstinence (i.e., at 6 months) versus those where the longest followup occurred after the incentive schedule had ended.^116^ In the subgroup of studies in which followup was beyond the provision of incentives a statistically significant benefit was found, suggesting that the impact of incentives continues for a least some time after incentives are no longer provided. The results of an exploratory meta-regression suggested that there was no clear direction of effect between trials offering low or high total value of incentives. Two studies conducted a head-to-head comparison between a rewards-based and deposit-refund-based approach and found both to be effective with no significant differences or negligible differences between groups.^116^

##### Biomedical Risk Assessment

###### Primary Results

We identified one moderate-credibility review, Clair (2019), that evaluated the efficacy of biomedical risk assessment (with or without other behavioral counseling) to aid in smoking cessation.^88^ Biomedical risk assessment interventions included a physical measurement to increase motivation to quit smoking, such as exhaled carbon monoxide (CO), spirometry, atherosclerotic plaque imaging, and genetic testing. The review identified 20 studies, 5 of which are new to this update, that met inclusion criteria. These trials represented over 9000 participants, with studies ranging from 64 to 2110 participants per study. In most studies, the biomedical testing component was added to intensive quit-smoking sessions (which both the intervention and control groups received), with counseling lasting up to 60 minutes and complemented by written material and reinforcement sessions or followup phone calls.^88^

Five studies tested feedback on smoking exposure, each measuring the effect of exhaled CO measurements; there was no evidence of a statistically significant benefit from these studies in pooled analysis (RR 1.00 [95% CI, 0.83 to 1.21]; I^2^=0%; k=5; n=2368) (Table 5).^88^ Likewise, there was no evidence of a significant benefit of interventions providing feedback on participants’ genetic susceptibility to smoking-related cancer or Crohn’s disease (RR 0.80 [95% CI 0.63 to 1.10]; I^2^=0%; k=5; n=2064). Eleven studies provided feedback on smoking-related harm: four tested the combination of exhaled CO measurement and spirometry, five tested the effect of spirometry alone or with the addition of feedback on lung age; and two tested the effect of undergoing an ultrasonography of carotid arteries and/or femoral arteries with photographic demonstration of atherosclerotic plaques when present. A pooled analysis of all 11 studies resulted in an unclear effect on smoking cessation (RR 1.26 [95% CI, 0.99 to 1.61]; I^2^=34%; k=11; n=3314).^88^

###### Evidence of Effect Modification

There was no evidence that the effectiveness of these interventions differed according to the type of biomedical feedback given (i.e., smoking exposure risk, smoking-related disease risk, or smoking-related harm).^88^

##### Exercise

###### Primary Results

We included one high-credibility review by Ussher (2019) that evaluated the effect of exercise on smoking cessation (n=7,279).^135^ The review included RCTs that compared an exercise program alone, or an exercise program as an adjunct to another smoker cessation program, with a cessation program alone or another non-exercise control group among adult smokers who were motivated to quit. Trials among adolescents as well as persons with psychological health conditions were excluded. The review included 24 trials that met inclusion criteria; six new studies were identified since the last review on this subject. Most of the trials used supervised, group-based aerobic exercise intervention supplemented by home-based exercise. In most cases, the exercise intervention started before the stated quit date. Twenty-two studies included smoking cessation support as the comparator, and two studies had relapse prevention support as the comparator, with all but one study offering this support for both exercise and control groups. The sample size in these trials was smaller than that seen in other smoking cessation trials, ranging from 20 to 2318, with more than half of the studies enrolling fewer than 100 participants.^135^

In pooled analyses, there was no statistically significant difference between smoking cessation interventions that included exercise versus those that did not (RR 1.08 [95% CI, 0.96 to 1.22]; I^2^=0%; k=21; n=6607) at 6 or more months’ followup (Table 5).^135^

###### Evidence of Effect Modification

There was no evidence in the review that the effects differed according to whether the exercise included aerobic exercise, resistance training combined modalities, or unknown types of physical activity.^135^ None of the effects were statistically significant among these subgroups by exercise type, and the confidence intervals of pooled analyses and individual effects all overlapped. Excluding studies among special populations such as those with mental health issues, or pregnant populations did not affect the interpretation of the results.^135^

##### Complementary and Alternative Therapies

###### Primary Results

We included two reviews that examined the effectiveness of complementary and alternative therapies on smoking cessation, one on acupuncture and acupressure^137^ and one on hypnotherapy.^82^ The high-credibility review on acupuncture, by White (2014), included 38 RCTs that compared the effects of acupuncture (23 studies), acupressure (5 studies), laser therapy (3 studies), and electrostimulation (7 studies) versus no or sham intervention for smoking cessation at short-term (6 weeks or less) and long-term (6–12 months) followup.^137^ This review reported a positive effect for acupuncture compared with sham acupuncture on short-term cessation (RR 1.22 [95% CI, 1.08 to 1.38]; I^2^=46%; k=16; n=2,588) but failed to find a pooled effect on longer term outcomes (RR 1.10 [95% CI, 0.86 to 1.40]; I^2^=23%; k=9; n=1,892) (Table 5). Similarly, there was no evidence of a benefit of acupressure, continuous auricular stimulation, or electrostimulation versus sham interventions on long-term cessation.^137^

The high-credibility review on hypnotherapy, by Barnes (2019), included 14 trials.^82^ Given the clinical heterogeneity of intervention and control conditions in the body of evidence, this review grouped the studies into comparisons according to the control conditions (i.e., no intervention, attention-matched behavioral interventions, brief behavioral interventions, intensive behavioral interventions, rapid/focused smoking, drug, and placebo). The studies varied greatly in the method of hypnotic induction and the number and duration of hypnotherapy sessions. In general, this review found no evidence of a difference in smoking cessation at 6 months’ or greater followup among trials that compared hypnotherapy versus no intervention or other smoking cessation interventions (Table 5). In the group with the most trials, there was no overall difference in smoking cessation rates between groups at 6 months or greater followup between hypnotherapy versus attention-matched smoking cessation behavioral intervention (RR 1.21 [95% CI, 0.91 to 1.61]; k=6; n=957; I^2^=36%).^82^

##### Systems-Level Interventions

###### Primary Results

We included two reviews that addressed the effectiveness of system-level interventions to support smoking cessation.^84,^ ^130^ The reviews contained mutually exclusive bodies of evidence given differences in scope. The first high-credibility review, by Boyle (2014), focused on the effectiveness of electronic health record (EHR)-facilitated interventions on smoking cessation support actions by clinicians, clinics, and health care delivery systems.^84^ The most common enhancement of the EHR was connecting smoking patients with a telephone-based quitline. While the review included 16 studies (6 group RCTs, 1 individual RCT, and 9 nonrandomized observational studies), none of the studies included a direct assessment of patient quit rates (Table 5). One group RCT (n=9589) reported a comparison of quit rates between intervention and control clinics that were measured indirectly based on EHR documentation of smoking status. In that study, significantly more smokers in the intervention clinics were subsequently documented as nonsmokers compared with smokers in the control clinics 6 months after changes were implemented (5.3% vs. 1.9%, p<0.001). The remaining studies focused on the impact of EHR changes on smoking support actions by clinicians, clinics, and health systems and specifically focused on the 5 A’s (Ask, Advise, Assess, Assist, Arrange). In general, most studies found an increase in the documentation of tobacco use and quit assistance following the introduction of an electronic reminder.^84^

The other high-credibility review, by Thomas (2017), was more broadly scoped and focused on the effectiveness of practice and policy changes within organizations to integrate the identification of smokers and the subsequent offering of evidence-based nicotine dependence treatments into usual care, beyond just changes to the EHR.^130^ The review included seven group RCTs, of which all but one was conducted in the United States. The settings included primary care clinics (2 trials), dental clinics (2 trials), a community pharmacy (1 trial), VA medical center (1 trial), and a pediatric practice focused on parents (1 trial). Interventions were characterized based on the provision of six system change components: 1) identification/documentation of smoking status, 2) smoking cessation training/resources/feedback for providers, 3) dedicated staff to support cessation activities, 4) policies to improve access to cessation interventions, 5) free smoking cessation treatment from the organization, and 6) reimbursement of clinics for providing smoking cessation support. None of studies incorporated all six system change strategies. The identification of all smokers and training staff and provision of evidence-based treatment were components of all seven included studies. All included studies used the services of existing staff to provide the intervention. Four studies (n=7142) reported the effects of the intervention on smoking cessation. Of these, two studies found that the quit rate was higher in the intervention group than in the control group at 6 and 12 months’ followup whereas the other two showed no difference between groups. There was some evidence for the effectiveness of the interventions on secondary outcomes such as documentation of smoking status and provision of cessation counseling, but each outcome was not consistently reported and several showed mixed effects (Table 5).^130^

#### Reduce-to-Quit Interventions

Most standard smoking cessation interventions, including most of the interventions synthesized above, encourage quitting smoking abruptly on a designated quit day. One recent high-credibility review by Lindson (2019c) assessed the effect of reduction-to-quit interventions versus no cessation intervention or abrupt quitting on long-term (6 months or more) cessation.^105^ Trials that included at least one arm where smokers were advised to reduce their smoking consumption before quitting smoking altogether were included. This advice could be delivered through self-help materials or behavioral support or alongside smoking cessation medications. Fifty-one trials (n=22,509) were identified. Compared with no smoking cessation intervention, there was no evidence that reducing smoking consumption before quitting was more effective for abstinence at 6 months or greater (RR 1.74 [95% CI, 0.90 to 3.38]; I^2^=45%; k=6; n=1599) and no evidence that reducing consumption was superior (or inferior) to abrupt quitting (RR 1.01 [95% CI, 0.87 to 1.17]; I^2^=29%; k=22; n=9219) (Table 5).^105^

#### Interventions for Relapse Prevention

A separate moderate-credibility review by Livingstone-Banks (2019a) focused on relapse prevention interventions for tobacco cessation.^108^ While there is no clear definition of a relapse prevention intervention, in general, relapse prevention is considered to apply to interventions that explicitly seek to reduce relapse rates after an acute treatment phase is successfully completed, or at some time after the quit date. The duration of the acute treatment phase varies, leading to variability in the post at which measurement of a relapse prevention effect begins. Studies of interventions for relapse prevention may randomly assign people who have already quit, or they may randomly assign smokers before their quit attempt and provide a general smoking cessation intervention to all participants, in addition to an extra component provided for those randomly assigned to relapse prevention.^108^

The 77 studies included in the review were highly variable and included both pharmacologic and behavioral interventions to help prevent relapse.^108^ They (a) focused on people who had already quit or (b) helped people to quit, then tested treatments to prevent relapse. Several studies centered on special populations that needed to stop smoking for a limited period of time because they were pregnant (18 studies), in a hospital (5 studies, or serving in the military (3 studies). Analyses of behavioral interventions among abstainers did not detect an effect in both studies of assisted abstainers (RR 0.99 [95% CI, 0.87 to 1.13]; I^2^=56%; k=10; n=5408) and unaided abstainers (RR 1.06 [95% CI, 0.96 to 1.16]; I^2^=1%; k=5; n=3561) from the general population. Twelve included studies focused on pharmacologic interventions for existing abstainers (either unaided or following cessation pharmacotherapy, 11 studies) or for those that were randomly assigned extended treatment (1 study). There was some evidence that extending varenicline could be beneficial in preventing relapse, but it was only reported by two studies. NRT was found to help in unassisted abstainers, but no difference was seen among those who achieved abstinence with NRT. None of the six studies that examined the use of bupropion to prevent relapse found a statistically significant effect.^108^

#### Ancillary and Population Subgroup Effects

Two reviews specifically explored the differences in the effectiveness of pharmacotherapy according to sex^112,^ ^124^ and were discussed within the sections on pharmacotherapy results. Nineteen additional reviews synthesized the evidence on the benefits of pharmacotherapy or behavioral interventions among specific subpopulations of adults (Table 2). These included: eight reviews limited to persons with severe mental illness;^80,^ ^100,^ ^101,^ ^118,^ ^120,^ ^133,^ ^136,^ ^142^ two limited to those with or in treatment for alcohol or drug dependence;^81,^ ^132^ five focused on adapted interventions for ethnic minorities^86,^ ^99,^ ^107^ or otherwise disadvantaged persons;^83,^ ^139^ two limited to smokeless tobacco users;^92,^ ^123^ one among individuals categorized as not motivated to quit,^141^ and one that explored the effectiveness of pharmacotherapy by subgroups defined by genetically informed biomarkers.^122^ Within these 19 reviews, most included trials were limited to these subpopulations and very few included trials (or reviews) addressed the relative effectiveness according to subgroup (e.g., the relative effects among those with or without depression). Results of these reviews were consistent with the broader evidence among general adult populations (reviews in which many of these subpopulation studies were included) and suggested effectiveness of both pharmacotherapy and behavioral interventions, alone and combined, to quit smoking. Where pooled results were presented, the direction and magnitude of effects was almost identical to that seen with the broader evidence base, although the number of studies within each review was considerably smaller given the focus on specific subpopulations.

#### E-Cigarettes

We identified five fair-quality RCTs (reported in 10 publications) that evaluated the effectiveness of using e-cigarettes to help current conventional smokers stop or reduce smoking compared with placebo or nicotine replacement therapy (Table 6).^143–145,^ ^151–157^ The five trials all took place outside of the United States with one in the United Kingdom, one in Italy, one in Korea, and two in New Zealand. The mean age of enrolled smokers was 41 to 44 years in all five trials. Three trials enrolled mostly females (~60–70%) whereas one enrolled only males, and the other enrolled mostly males (36.7% female). Smokers within all five trials were heavy smokers with the median cigarettes smoked per day ranging from 15 to 20 and most had tried to quit in the past year. Further demographic details of the enrolled samples were sparsely reported (Appendix F Table 1). The types of e-cigarettes, nicotine content, delivery of the intervention, and additional intervention components differed across all five trials as did the comparisons (Appendix F Table 2). One trial compared 1) NRT patch plus a nicotine e-cig (18 mg/mL), 2) NRT patch plus a nicotine-free e-cig (0 mg/mL), and 3) NRT patch only. Another trial compared 1) nicotine e-cig (18 mg/mL) to 2) any form of NRT. Another trial compared 1) nicotine e-cig (16 mg/mL), 2) nicotine patch (21 mg), and 3) nicotine-free e-cig. A small Korean trial in males compared nicotine e-cigarettes (0.01 mg/mL) with nicotine gum (2mg/tablet). And, the final trial compared 1) nicotine e-cig (7.2 mg/mL) for 12 weeks, 2) nicotine e-cig (7.2 mg/mL for 6 weeks followed by 5.4 mg for 6 weeks), or 3) nicotine-free e-cigs. Whereas one trial allowed participants to use any brand of e-cigarette with any concentration of nicotine after a 4-week run-in period with a starter kit, four trials provided participants with e-cigarette cartridges for the whole study period. Of the five e-cigarettes evaluated for cessation, only the eVOD device (Walker trial), OneKit Aspire (TEC trial), and eGo-C (Lee trial) are currently available in US markets; the Elusion e-cigarette model used in the ASCEND trial has been discontinued and the Categoria e-cigarette (ECLAT trial) is not sold in US markets.

The largest trial, conducted in New Zealand, randomized participants to a 12-week treatment phase of 1) a nicotine patch plus a nicotine e-cig (n=500); 2) a nicotine patch plus a nicotine-free e-cig (n=499), or 3) a nicotine patch only (n=125).^155^ All three groups also received behavioral counseling, although compliance data indicated that the patch plus nicotine e-cig group received more calls than the patch-only group. After 6 months following the agreed-upon quit date, verified continuous abstinence was statistically significantly higher in the patches plus nicotine e-cig group (7%) versus the patch plus nicotine-free e-cig group (4%) (RR 1.75 [95% CI, 1.02 to 2.98; p=0.038) but not the patch-only group (2%) (RR 2.92 [95% CI, 0.91 to 9.33]; p=0.05) (Table 7). Complete case and per-protocol analyses produced similar results with differences found between the two e-cig groups but not the nicotine-containing e-cig versus patch only groups. Absolute rates of self-reported quitting at 6 months were considerably higher than verified abstinence in all three groups (patch plus nicotine e-cigs: 18%, patch plus nicotine-free e-cigs: 11%, and patches only: 8%) with statistically significant differences found when comparing the nicotine-containing e-cigs to the other two groups, respectively.^155^

Table 7 Smoking Cessation Results at 6 or More Months (KQ 2) for Electronic Cigarettes for Tobacco Cessation, by Author

Author, Year; Quality | Population | IG | CG | FU (mo) | IG events | IG N | IG quit rate | CG events | CG N | CG quit rate | Effect estimate (95% CI) | Study product use after abstinence
Bullen, 2013^144,^ ^151^; ASCEND; Fair | All | E-cig (16mg) | NRT (21mg patch) | 6 | 21 | 289 | 7.3% | 17 | 295 | 5.8% | RR 1.26 (0.68, 2.34) | IG: 38% (8/21); CG: NR
Bullen, 2013^144,^ ^151^; ASCEND; Fair | All | E-cig (16mg) | Placebo (0mg E-cig) | 6 | 21 | 289 | 7.3% | 3 | 73 | 4.1% | RR 1.77 (0.54, 5.77) | IG: 38% (8/21); CG: NR
Bullen, 2013^144,^ ^151^; ASCEND; Fair | Adults with mental illness | E-cig (16mg) | NRT (21mg patch) | 6 | 2 | 39 | 5.1% | 5 | 35 | 14.% | p=0.245 | NR
Bullen, 2013^144,^ ^151^; ASCEND; Fair | Adults with mental illness | E-cig (16mg) | Placebo (0mg E-cig) | 6 | 2 | 39 | 5.1% | 0 | 12 | NA^*^ | NA^*^ | NR
Caponnetto, 2013^145^; ECLAT; Fair | All | E-cig (both study groups)^†^ | Placebo (0mg E-cig) | 12 | 22 | 200 | 11.0% | 4 | 100 | 4.0% | RR 2.75 (0.97, 7.76), p=0.0561^‡^; Adjusted: p=0.04 | IG and CG (combined): 26.9% (7/26)
Hajek, 2019^154^; TEC; Fair | All | E-cig (any) | NRT (any) | 6 | 155 | 438 | 35.4% | 112 | 446 | 25.1% | RR 1.40 (1.14, 1.72); ARR^§^ 1.36 (1.15, 1.67) | NR
Hajek, 2019^154^; TEC; Fair | All | E-cig (any) | NRT (any) | 12 | 79 | 438 | 18.1% | 44 | 446 | 9.9% | RR 1.83 (1.30, 2.58); ARR^§^ 1.75 (1.24, 2.46) | IG: 80% (63/79); CG: 9% (4/44)
Lee, 2019^157^; Fair | All | E-cig | NRT, gum | 6 | 16 | 75 | 21.3% | 75 | 21 | 28.0% | p=0.291 | NR
Walker, 2019^155^; Fair | All | E-cig (18 mg) + NRT (21mg patch) | Placebo (0mg E-cig) + NRT (21mg patch) | 6 | 35 | 500 | 7.0% | 20 | 499 | 4.0% | RR 1.75 (1.02, 2.98); p=0.038^‖^ | Use of both patch and e-cig at 6 months:^#^; IG: 11% (36/317); CG: 13% (41/308); Use of e-cig only at 6 months:^#^; IG: 45% (143/317); CG: 36% (111/308)
Walker, 2019^155^; Fair | All | E-cig (18 mg) + NRT (21mg patch) | NRT (21mg patch) | 6 | 35 | 500 | 7.0% | 3 | 125 | 2.0% | RR 2.92 (0.91, 9.33); p=0.05^⁋^ | Use of e-cig only at 6 months:^#^; IG: 45% (143/317); CG: NR; Use of patch only at 6 months:^#^; IG: 22% (70/317); CG: 40% (21/52)

Note(s): Abstinence measured as continuous abstinence and biochemically validated with expired carbon monoxide for all trials.

* Not applicable due to low (0) event rate.

† Group A=7.2 mg E-cig for 12 weeks; Group B=7.2 mg E-cig for 6 weeks and 5.4 mg E-cig for 6 weeks.

‡ Calculated

§ Adjusted for trial center, marital status, age at smoking initiation, and score on the Fagerström Test for Cigarette Dependence.

‖ Results based on self-reported quit rate were consistent with 18% of the patch plus nicotine e-cig group versus 11% of the patch plus nicotine-free e-cig group reporting abstinence at 6 months (RR 1.68 [95% CI, 1.22 to 2.30]; p=0.001). Per protocol sensitivity analyses also showed a statistically significant difference (p=0.020).

⁋ In contrast, results based on self-reported quit rate showed statistically significantly greater abstinence at 6 months (RR 2.23 [95% CI, 1.19 to 4.15]; p=0.007) among patch plus nicotine e-cig group (18%) versus patches-only group (8%).The per protocol sensitivity analysis did not yield a statistically significant difference (p=0.11).

# Adherence was defined as having used the allocated product since last contact. Findings relate to allocated treatment only, in participants for whom adherence data were available. Data does not include adherence in those who crossed-over to an e-cig or those who changed their type of e-cig.

Abbreviations: ARR=adjusted relative risk; CG = control group; eCO=expired carbon monoxide; E-cig = electronic cigarette; IG = intervention group; mg = milligram(s); MI = mental illness; mo = months; NA = not applicable; NR = not reported; NRT = nicotine replacement therapy; RR = relative risk

Median time to relapse (defined as smoking at least 5 cigarettes in the past 7 days) did not differ significantly between the patch plus nicotine e-cig group (193 days) versus the patch plus nicotine-free e-cig group (153 days) (hazards ratio [HR] 0.85 [95% CI, 0.70 to 1.03]; p=0.01) or patch only group (160 day (HR 0.90 [95% CI, 0.63 to 1.28; p=0.56).^155^ Thirty-nine percent of the participants in the patch plus nicotine e-cig group relapsed within 6 months versus 43 percent of participants in the patch plus nicotine-free e-cig group and 31 percent of participants in the patch only group. Furthermore, in those still smoking at 6 months, there was no significant difference in change from baseline in the average number of cigarettes smoked per day or the proportion who reduced the number of cigarettes smoked per day by at least 50 percent.^155^

The results of this trial should be interpreted in light of some considerable limitations including high and differential loss to followup: at 6 months, only 50 percent of participants in the patch-only group were retained as opposed to 68 percent in both the nicotine and nicotine-free e-cig groups.^155^ The majority of participants in the patch group who withdrew did so immediately post-randomization citing not wanting to be in that group. Furthermore, of those retained in the patch-only group, 15 percent crossed over and used an e-cigarette during the trial, with most crossing over within the first 6 weeks. Similarly, 11 percent of those randomized to the nicotine-free e-cig group crossed over to using nicotine-containing e-cigarettes. Detection bias was also likely with 70 percent of the nicotine e-cig group correctly identifying the presence of nicotine in their e-liquid. At 6 months, 22 to 40 percent of participants in all three groups were still using the patch whereas 49 to 56 percent of participants were still using an e-cig only or both a patch and e-cig.^155^

In another large trial (the TEC trial) in the United Kingdom, Hajek and colleagues randomized 886 smokers participating in National Health Services stop-smoking services to tobacco flavored e-cigarettes with 18 mg nicotine/ml (intervention group) or any form of NRT (comparison group).^154,^ ^156^ Both groups received 4 weeks of behavioral counseling. The primary outcome was abstinence at 1 year, defined as self-report of not more than five cigarettes from the target quit date, validated by expired CO<8 parts per million (ppm). At 1 year, 18 percent in the e-cigarette group were abstinent from smoking, compared with 9.9 percent in the comparison group (RR 1.83 [95 % CI, 1.30 to 2.58]) (Table 7). However, 80 percent of abstinent subjects assigned to the intervention group were still using e-cigarettes, compared with 9 percent in the comparison group continuing to use nicotine replacement therapy at 1 year. Overall loss to followup was 21 percent (19% in the e-cigarette group and 23% in the NRT group).^154^

In the ASCEND trial, Bullen and colleagues randomized 657 smokers in New Zealand who wanted to stop smoking to one of three interventions: 16 mg nicotine e-cigarette (n=285), 21 mg nicotine patch (n=295), or placebo e-cigarette (n=73).^144^ Those randomized to one of the e-cigarette arms were directly mailed the e-cigarette, a spare battery and charger, cartridges, and simple instructions on how to use the e-cigarette, whereas those randomized to receive a patch were mailed cards and vouchers to redeem a patch from community pharmacies. All participants were also offered telephone-based support via a quitline that called them directly; participants who declined or did not call back were still able to access other quitline support such as text messages. The primary outcome, abstinence at 6 months, was verified by exhaled CO<10ppm. Tobacco smoking cessation was generally low in all three groups: 7.3 percent with e-cigarettes, 5.8 percent with nicotine patches (RR for nicotine e-cigarettes vs. patches 1.26 [95% CI, 0.68 to 2.34]), and 4.1 percent with placebo e-cigarettes (RR for nicotine e-cigarettes vs. placebo 1.77 [95% CI, 0.54 to 5.77]) (Table 7). Thirty-eight percent of those who were abstinent and assigned to e-cigarettes still used e-cigarettes at 6 months, although it was unknown whether they were using nicotine or non-nicotine cartridges. There was differential loss-to-followup between groups at 6 months: 27 percent of those assigned to the patch versus 17 percent and 22 percent of those randomized to the nicotine and placebo e-cigarette groups, respectively.^144^

In a secondary analysis of cessation data from the ASCEND trial, O’Brien and colleagues examined the effectiveness of e-cigarettes among patients with (n=86) and without (n=571) a mental illness (defined as taking prescription medication for a diagnosed mental illness) at the time of randomization.^151^ At the 6-month followup among participants randomized to e-cigarettes, there were no significant differences in smoking cessation between people with (5%, n=2/39) and without mental illness (n=7%, 19/250) (p=0.75). Among those with a mental illness (n=86), there were no significant differences in quit rates among those randomized to e-cigarettes (5%, 2/39) had biochemically verified smoking abstinence) as compared with those who used nicotine patches (14%, 5/35) (p=0.245). Among participants with mental illness randomized to placebo e-cigarettes, none had achieved cessation at 6 months (Table 7).^151^

Caponnetto and colleagues conducted an RCT in Italy, the ECLAT trial, in which 300 conventional smokers who were not intending to quit were randomized to receive one of three e-cigarette nicotine cartridge doses for the Categoria brand model 401 e-cigarette: 7.2 mg nicotine for 12 weeks; 7.2 mg nicotine for 6 weeks followed by 5.4 mg nicotine for 6 weeks; or cartridges with no nicotine.^145^ The appearance of the cartridges was identical to maximize blinding, although it is unclear whether allocation was concealed. After the 12-week intervention phase, participants were free to purchase e-cigarettes on their own. At 1 year, abstinence rates (verified by <7.5 ppm exhaled CO) were 11 percent for participants in the combined nicotine groups compared with 4 percent in the group receiving no-nicotine cartridges (p=0.04) (Table 7). At the 1-year assessment, 26.9 percent of all study participants were still using e-cigarettes. There was substantial loss to followup in the study: no followup data was available for 36 percent of those randomized to one of the nicotine-containing cartridges and 45 percent of those receiving no-nicotine cartridges.^145^

Lee and colleagues conducted a small RCT in male workers from a Korean motor company, randomizing 150 participants to receive a 12 week supply of either e-cigarettes or nicotine gum.^157^ Eligible participants smoked at least 10 cigarettes per day for the past year, had smoked for at least three years, and were motivated to stop or reduce their cigarette smoking. All participants received a fifty-minute education session on smoking cessation and use of smoking-cessation aids and they were instructed to visit the medical office every four weeks for evaluation and counseling from an independent health practitioner. Continued abstinence was verified using self-report questionnaires and both end-expiratory carbon monoxide (<10 ppm) and urine cotinine (negative result). Biochemically validated continued abstinence rates from weeks 9 to 24 did not differ significantly between the groups (21.3% vs. 28% (p=0.344) in the e-cigarette group and nicotine group respectively) (Table 7). The seven-day point prevalence abstinence at 24-weeks was similar, with 22.7 percent in the e-cigarette group and 29.3 percent in the nicotine gum group reporting no smoking (p=0.352).^157^

### Key Question 3 What Harms Are Associated With Tobacco Cessation Interventions in Adults?

#### Combined Pharmacotherapy and Behavioral Interventions

None of the included reviews synthesized the evidence on harms related to combined pharmacotherapy and behavioral support versus no or minimal interventions. Any harms of combined therapy are assumed to be like those of the pharmacotherapy being used.

#### Pharmacotherapy Interventions

We included nine primary reviews^85,^ ^87,^ ^96,^ ^98,^ ^104,^ ^113,^ ^114,^ ^128,^ ^131^ that reported AEs related to pharmacotherapy interventions for smoking cessation in general adult populations. In addition, six reviews^80,^ ^101,^ ^118,^ ^120,^ ^133,^ ^142^ addressed the harms of pharmacotherapy among persons with severe mental illness.

##### Nicotine Replacement Therapy

Harms related to NRT use were reported in four reviews among the general adult population^96,^ ^104,^ ^113,^ ^114^ and one review among persons with severe mental illness.^120^ All five of these reviews were rated as moderate or high credibility. AEs from the use of NRT are typically related to the type of product and include skin irritation from patches and irritation to the inside of the mouth from gum and lozenges.^96,^ ^104,^ ^114^ Pooled results from multiple reviews indicate a higher risk of heart palpitations and chest pains, or any CV event (any clinical diagnoses of a CV event including minor events such as palpitations, bradycardia, and arrhythmia) from NRT versus non-NRT control groups (Table 8).^96,^ ^113,^ ^114^ For instance, among non-high-risk adults, one review found an approximate 80 percent increase risk of any CV event among those randomized to NRT compared with placebo (RR 1.81 [95% CI, 1.35 to 2.43]; I^2^=0%; k=21; 11,647).^113^ A sensitivity analysis found that these treatment effects were driven predominantly by more minor CV events, however, including bradycardia and arrhythmia, and occurred primarily in studies with longer followup periods. When restricted to major adverse CV events (defined by the FDA as a combined outcome of cardiovascular death, nonfatal myocardial infarction, and nonfatal stroke), pooled results did not clearly establish harm (RR 1.38 [95% CI, 0.58 to 3.26]; I^2^=0%), but the confidence interval was quite wide and incorporated potential benefit as well as significant harm and the overall number of SAEs was very low.^113^ Pooled results also found an increased risk of NRT versus non-NRT control for nausea and vomiting (although patch users had a decreased risk), gastrointestinal complaints, and insomnia.^114^ There was no statistically significant increased risk of headache, dizziness, anxiety or depression, or mortality.^114^ Eight studies reported on mortality and did not find a significant association between NRT and controls (OR 0.74 [95% CI, 0.33 to 1.67]; I^2^=0%; k=8; n=2765).^96^

Table 8 Adverse Event Results (KQ 3) From Systematic Reviews on Pharmacotherapy, by Comparison

Comparison | Author, Year | Adverse event | Subgroup | k | N | IG events | IG N | CG events | CG N | Pooled effect estimate (95% CI) | I2
NRT vs. placebo | Mills, 2010^114^ | Mortality | - | 8 | 2765 | 11 | 1387 | 16 | 1378 | OR=0.74 (0.33, 1.67) | 0%
NRT vs. placebo | Mills, 2010^114^ | Heart palpitations/chest pains | - | 12 | 10,234 | 189 | 6249 | 64 | 3985 | OR=2.06 (1.51, 2.82) | 0%
NRT vs. placebo | Hartmann-Boyce, 2018^96^ | Heart palpitations/chest pains | - | 15 | 11,074 | 165 | 6673 | 62 | 4401 | OR=1.88 (1.37, 2.57) | 10%
NRT vs. placebo | Mills, 2014^113^ | CV AEs | - | 21 | 11,647 | 202 | 6329 | 83 | 5318 | RR=1.81 (1.35, 2.43) | 0%
NRT vs. placebo | Mills, 2014^113^ | Major CV AEs | - | 21 | 11,647 | 12 | 6329 | 7 | 5318 | RR=1.38 (0.58, 3.26) | 0%
NRT: combo vs. single | Lindson, 2019^104^ | SAEs | - | 6 | 2888 | 6 | 1475 | 1 | 1413 | RR=4.44 (0.76, 25.85) | 35%
NRT, patch: longer duration vs. shorter duration | Lindson, 2019^104^ | SAEs | - | 3 | 1173 | NR | NR | NR | NR | NA^*^ | NA
NRT, patch: high vs. low dose | Lindson, 2019^104^ | SAEs | - | 2 | 1023 | 7 | 511 | 1 | 512 | RR=5.01 (0.87, 28.82) | 0%
NRT: combo vs. single | Lindson, 2019^104^ | Withdrawals due to treatment | - | 7 | 3070 | 18 | 1169 | 23 | 1901 | RR=1.12 (0.57, 2.20) | 73%
NRT, fast-acting vs. NRT, patch | Lindson, 2019^104^ | Withdrawals due to treatment | - | 4 | 1482 | 18 | 740 | 4 | 742 | RR=4.23 (1.54, 11.63) | 0%
NRT, patch: high vs. low dose | Lindson, 2019^104^ | Withdrawals due to treatment | - | 2 | 554 | 17 | 277 | 3 | 277 | RR=4.99 (1.60, 15.50) | 0%
NRT, patch: longer duration vs. shorter duration | Lindson, 2019^104^ | Withdrawals due to treatment | - | 2 | 648 | NR | NR | NR | NR | NA^†^ | NA
Bupropion vs. placebo/no bupropion | Howes, 2020^98^ | SAEs | - | 21 | 10,625 | 139 | 6094 | 107 | 4531 | RR=1.16 (0.90, 1.48) | 0%
Bupropion vs. placebo | Mills, 2014^113^ | CV AEs | - | 27 | 10,402 | 50 | 5947 | 42 | 4455 | RR=1.03 (0.71, 1.50) | 0%
Bupropion vs. placebo | Mills, 2014^113^ | Major CV AEs | - | 27 | 10,402 | 15 | 5947 | 25 | 4455 | RR=0.57 (0.31, 1.04) | 0%
Bupropion vs. placebo | Roberts, 2016^120^ | Discontinuation due to AEs | SMI | 6 | 201 | 6 | 114 | 6 | 87 | OR=0.93 (0.18, 4.74) | NR
Bupropion + NRT vs. placebo + NRT | Roberts, 2016^120^ | Discontinuation due to AEs | SMI | 1 | 51 | 2 | 25 | 2 | 26 | OR=1.04 (0.14, 8.04) | NR
Varenicline vs. placebo | Cahill, 2016^85^ | SAEs | - | 29 | 15,370 | 269 | 8125 | 196 | 7245 | RR=1.25 (1.04, 1.49) | 0%
Varenicline vs. placebo | Cahill, 2016^85^ | CV SAEs | - | 21 | 8587 | 57 | 4696 | 35 | 3891 | RR=1.36 (0.91, 2.04) | 0%
Varenicline vs. placebo | Cahill, 2016^85^ | Neuropsychiatric SAEs (not deaths) | - | 23 | 8955 | 41 | 4920 | 43 | 4035 | RR=0.82 (0.57, 1.19) | 0%
Varenicline vs. placebo | Mills, 2014^113^ | Major CV AEs | - | 18 | 9072 | 22 | 5469 | 13 | 3603 | RR=1.44 (0.73, 2.83) | 0%
Varenicline vs. placebo | Mills, 2014^113^ | CV AEs | - | 18 | 9072 | 63 | 5469 | 41 | 3603 | RR=1.24 (0.85, 1.81) | 0%
Varenicline vs. placebo | Sterling, 2016^128^ | Mortality | - | 38 | 12,706 | 11 | 7213 | 9 | 5493 | RR=0.88 (0.50, 1.52) | 0%
Varenicline vs. placebo | Sterling, 2016^128^ | CV SAEs | - | 38 | 12,706 | 57 | 7213 | 43 | 5493 | RR=1.03 (0.72, 1.49) | 0%
Varenicline vs. placebo | Thomas, 2015^131^ | Suicide and attempted suicide | - | 31 | 9830 | 4 | 5352 | 2 | 4478 | OR=1.67 (0.33, 8.57) | 10.3%
Varenicline vs. placebo | Thomas, 2015^131^ | Suicidal ideation | - | 20 | 2990 | 15 | 799 | 18 | 2191 | OR=0.58 (0.28, 1.20) | 0%
Varenicline vs. placebo | Thomas, 2015^131^ | Depression events | - | 31 | 9843 | 163 | 5356 | 139 | 4487 | OR=0.96 (0.75, 1.22) | 0%
Varenicline vs. placebo | Thomas, 2015^131^ | Mortality | - | 36 | 10,647 | 13 | 5760 | 11 | 4887 | OR=1.05 (0.47, 2.38) | 38.7%
Varenicline vs. placebo | Roberts, 2016^120^ | Discontinuation due to AEs | - | 5 | 222 | 14 | 131 | 7 | 91 | OR=1.29 (0.47, 3.56) | NR
Varenicline vs. placebo | Kishi, 2014^101^ | Discontinuation due to all causes | - | 7 | 439 | NR | NR | NR | NR | RR=0.92 (0.54, 1.56) | 44%
Varenicline vs. placebo | Kishi, 2014^101^ | Discontinuation due to side effects | - | 7 | 439 | NR | NR | NR | NR | RR=1.29 (0.67, 2.48) | 0%
Varenicline vs. placebo | Thomas, 2015^131^ | Suicidal ideation | Age 40 years and older | 18 | 4782 | 14 | 2655 | 17 | 2127 | OR=0.58 (0.28, 1.24) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Depression events | Age 40 years and older | 27 | 9318 | 144 | 5050 | 129 | 4268 | OR=0.99 (0.77, 1.27) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Suicidal ideation | Age less than 40 years | 2 | 208 | 1 | 144 | 1 | 64 | OR=0.58 (0.28, 1.20) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Depression events | Age less than 40 years | 4 | 525 | 19 | 306 | 10 | 219 | OR=0.96 (0.75, 1.22) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Suicidal ideation | 50% male or greater | 14 | 3660 | 12 | 2097 | 14 | 1563 | OR=0.57 (0.25, 1.30) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Depression events | 50% male or greater | 24 | 8145 | 93 | 4406 | 89 | 3739 | OR=0.89 (0.66, 1.21) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Suicidal ideation | Less than 50% male | 6 | 4990 | 3 | 702 | 4 | 628 | OR=0.58 (0.28, 1.20) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Depression events | Less than 50% male | 7 | 9843 | 163 | 5356 | 139 | 4487 | OR=0.96 (0.75, 1.22) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Suicidal ideation | 50% White or greater | 15 | 3498 | 11 | 1956 | 13 | 1542 | OR=0.56 (0.24, 1.30) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Depression events | 50% White or greater | 24 | 8083 | 117 | 4378 | 95 | 3705 | OR=0.95 (0.72, 1.27) | 1.6%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Suicidal ideation | Less than 50% White | 3 | 681 | 4 | 436 | 2 | 245 | OR=1.83 (0.29, 11.75) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Depression events | Less than 50% White | 4 | 931 | 27 | 562 | 27 | 369 | OR=0.82 (0.43, 1.58) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Suicidal ideation | 100% with psychiatric illness | 5 | 809 | 11 | 416 | 11 | 393 | OR=0.79 (0.32, 1.93) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Depression events | 100% with psychiatric illness | 5 | 809 | 31 | 416 | 20 | 393 | OR=1.49 (0.84, 2.65) | 0%
Varenicline vs. placebo continued | Thomas, 2015^131^ | Suicidal ideation | 10%–20% psychiatric illness | 1 | 192 | 0 | 86 | 1 | 106 | OR=0.16 (0.00, 8.42) | NA
Varenicline vs. placebo continued | Thomas, 2015^131^ | Depression events | 10%–20% psychiatric illness | 1 | 192 | 6 | 86 | 14 | 106 | OR=0.51 (0.20, 1.30) | NA
Varenicline vs. placebo continued | Thomas, 2015^131^ | Suicidal ideation | No psychiatric illness | 14 | 3989 | 4 | 2297 | 6 | 1692 | OR=0.34 (0.09, 1.29) | 0%
Varenicline vs. placebo | Thomas, 2015^131^ | Depression events | No psychiatric illness | 25 | 8842 | 126 | 4854 | 105 | 3988 | OR=0.91 (0.69, 1.21) | 0%
Varenicline vs. placebo | Wu, 2016^142^ | Suicidal ideation | SMI | 4 | 203 | 9 | 124 | 5 | 79 | RR=1.06 (0.40, 2.82) | 0%
Varenicline vs. placebo | Wu, 2016^142^ | Depressed mood | SMI | 3 | 198 | 13 | 121 | 6 | 77 | RR=1.45 (0.45, 1.64) | 28.6%
Varenicline vs. placebo | Wu, 2016^142^ | Anxiety | SMI | 4 | 267 | 13 | 155 | 14 | 112 | RR=0.77 (0.28, 2.17) | 33.7%
Varenicline vs. placebo | Kishi, 2014^101^ | Discontinuation due to side effects | SMI | 7 | 439 | NR | NR | NR | NR | RR=1.29 (0.67, 2.48) | 0%
Varenicline vs. placebo | Kishi, 2014^101^ | Discontinuation due to all causes | SMI | 7 | 439 | NR | NR | NR | NR | RR=0.92 (0.54, 1.56) | 44%
Varenicline vs. placebo | Roberts, 2016^120^ | Discontinuation due to AEs | SMI | 5 | 222 | 14 | 131 | 7 | 91 | OR=1.29 (0.47, 3.56) | NR
Varenicline vs. placebo | Schwartz, 2015^123^ | Mood disorders | Smokeless tobacco users | 3 | 744 | 6 | 370 | 9 | 374 | RR=0.71 (0.26, 1.90) | 0%

* None of the comparisons based on duration of patch therapy showed a clinically or statistically significant difference for SAEs.

† Not pooled due to substantial heterogeneity; no significant differences in either study

Abbreviations: AE = Adverse event; CG = Control group; CI = Confidence interval; CV = Cardiovascular; IG = Intervention group; NA = Not applicable; NR = Not reported; NRT = Nicotine replacement therapy; OR = Odds ratio; RR = Risk ratio; SAE = Serious adverse event; SMI = Serious mental illness

There was no evidence of an effect on cardiac AEs, SAEs, or withdrawals when looking at different forms, deliveries, doses, durations, and schedules of NRT (Table 8).^104^ Furthermore, there was no evidence of a difference in harms, including a worsening of psychiatric symptoms, related to NRT within three reviews that focused on trials limited to smokers with severe mental illness.^120^

##### Bupropion

Harms related to bupropion use were reported in two moderate-to-high credibility reviews among unselected adults^98,^ ^113^ and one moderate credibility review among persons with severe mental illness.^120^ The Howes review (2020) examined SAEs reported in 21 trials of bupropion versus placebo or no pharmacotherapy control, including trials that were excluded from their efficacy analysis because of short followup (i.e., less than 6 months).^98^ SAEs were defined per the FDA as any event that was life-threatening, resulted in hospitalization, death, disability, or permanent damage, or required intervention to prevent one of the above outcomes reported during or within 30 days of drug treatment. Meta-analysis of 21 trials did not provide clear evidence that the use of bupropion increased the risk of SAEs control (RR 1.16 [95% CI, 0.90 to 1.48], I^2^=0%; k=21; n=10,625), with very low SAE rates of 2.3 percent for bupropion users and 2.4 percent for placebo users or non-bupropion participants (Table 8).^98^

A separate older review (Mills 2014) suggested no significant increased risk of any CV event for bupropion versus placebo (RR 1.03 [95% CI, 0.71 to 1.50], I^2^=0%; k=27; n=10,402) (Table 8).^113^ The confidence interval of the pooled estimate was wide and consistent with a mildly beneficial or mildly harmful effect. While the results for major CV events were imprecise due to small numbers of events, they were consistent with a possible protective effect or very minor harms (RR 0.57 [95% CI, 0.31 to 1.04]; I^2^=0%; k=27; n=10,402) (Table 8). When restricted to the eight trials of high-risk patients, the results were in the same direction as non-high-risk adults but were not statistically significant. In the recent EAGLES trial, there was no significant difference in the incidence of cardiovascular events during treatment between those on bupropion versus placebo, nor a significant difference in time to onset of major cardiovascular AEs (hazard ratio [HR] 0.50 [95% CI, 0.10 to 2.50]).^164^

In the review by Howes there was evidence to suggest that participants randomized to bupropion were more likely to report psychiatric AEs compared with those randomized to placebo.^98^ A pooled analysis of six placebo-controlled trials found a 25 percent increased risk of any neuropsychiatric AEs among those taking bupropion (RR 1.25 [1.15 to 1.36]; k=6; n=4439).^98^ In the Howes review, all neuropsychiatric events and symptoms were included regardless of severity.^98^ Conversely, when limited to moderate or severe neuropsychiatric events, the EAGLES trial found was no evidence of a significant increase in neuropsychiatric AEs attributable to bupropion relative to nicotine patch or placebo.^161,^ ^165^ The primary endpoint in this trial was a composite measure based on post marketing reports of neuropsychiatric AEs in smokers taking bupropion and varenicline and included 16 neuropsychiatric symptom categories. The overall incidence of neuropsychiatric AEs was similar across the bupropion (4.5%, 90 of 2006 participants), nicotine patch (3.9%, 78 of 2022 participants), and placebo (3.7%, 74 of 2014 participants) groups. For both the nonpsychiatric and psychiatric cohort, there was no significant difference in neuropsychiatric AEs in those assigned to bupropion versus placebo (risk difference [RD] −0.08 [95% CI, −1.37 to 1.21], n=1988 and RD 1.78 [95% CI, −0.24 to 3.81], n=2032), respectively. Likewise, there was no difference between the bupropion and placebo groups in rates of suicidal behavior and ideation.^161,^ ^165^

A separate moderate-credibility review by Roberts (2016) synthesized the direct and indirect evidence on pharmacologic tobacco cessation treatment among adult smokers with any form of severe mental illness, defined as any nonorganic disorder with psychotic features that results in a substantial disability including schizophrenia, schizoaffective disorder, bipolar disorder, delusional disorder or depressive psychoses.^120^ Harms were measured using a tolerability outcome which equaled the number of patients discontinuing the trial due to any adverse event. Across six trials that compared bupropion with placebo, three trials reported that no participants in either group discontinued the trials because of AEs. In the remaining three trials, two found greater rates of dropout among those in the placebo group versus bupropion group, whereas the remaining found five versus two dropouts due to AEs among the bupropion versus placebo groups, respectively. Pooling all six trials showed no statistically significant difference between groups (OR, 0.93 [95% CI, 0.18 to 4.74]; I^2^=26%; k=3; n=201) (Table 8).^120^

##### Varenicline

Harms related to varenicline use were reported in three reviews among unselected smokers, ^85,^ ^128,^ ^131^ four reviews among persons with severe mental illness,^80,^ ^101,^ ^120,^ ^142^ and one review limited to smokeless tobacco users.^123^ The most commonly reported adverse effect of varenicline was nausea, which was mostly at mild to moderate levels and usually subsided over time. Other common side effects of varenicline versus placebo with a statistically significant increase were insomnia, abnormal dreams, headache, and fatigue.^85,^ ^131^ A meta-analysis of SAEs occurring during or after active treatment suggested there may be a 25 percent increase in the chance of SAEs among people using varenicline compared with placebo (RR 1.25 [95% CI, 1.04 to 1.49]; k=29; 15,370) (Table 8); however, many of these events included comorbidities that were mostly considered by the trialists to be unrelated to the treatments. Across all reviews, very few deaths were reported in the included trials and no review found a difference in all-cause mortality between varenicline and placebo.^128,^ ^131^

Pooled analyses representing over 12,000 participants do not indicate a statistically significant increased risk of cardiovascular events (Table 8).^85,^ ^113,^ ^128^ For instance, within the Mills (2014) review, among 18 trials comparing varenicline with placebo, there was no evidence of an increased risk of cardiovascular AEs (RR 1.24 [95% CI, 0.85 to 1.81]; I2=0%; k=18; n=9072) of major cardiovascular AEs among adults (RR 1.44 [95% CI, 0.73 to 2.83]; I2=0%; k=18; n=9072).^113^ Similarly, in a more recent low-credibility review, when pooling data across 38 studies, the review by Sterling (2016) found no significant difference for cardiovascular SAEs when comparing varenicline (57 events within 7213 participants) with placebo (43 events within 5493 participants) (RR 1.03 [95% CI, 0.72 to 1.49]).^128^ Furthermore, similar results were found among patients with and without a history of cardiovascular disease.^128^

There was also no evidence of a statistically significantly higher risk of neuropsychiatric AEs for those on varenicline versus placebo (Table 8).^85,^ ^131^ In the most recent review by Cahill (2016), 23 trials representing nearly 9000 smokers found no difference in the number of people experiencing a neuropsychiatric event between those randomized to varenicline versus placebo (RR 0.82 [95% CI, 0.57 to 1.19]).^85^ Likewise, in the review by Thomas (2015), there was no evidence of an increased risk of suicide or attempted suicide (Peto OR 1.67 [95% CI 0.33 to 8.57]), suicidal ideation (Peto OR 0.58 [95% CI, 0.28 to 1.20]), or depression (Peto OR 0.96 [95% CI, 0.75 to 1.22]) associated with varenicline.^131^ There was no evidence that the risk of depression and suicidal ideation differed by age, sex, ethnicity, smoking status, the presence or absence of psychiatric illness, or study sponsorship. The effect estimates (Peto OR) for the trials in which all participants had psychiatric illnesses compared with those where none of the participants had psychiatric illness were 0.79 (95% CI, 0.32 to 1.93) versus 0.34 (95% CI, 0.09 to 1.29) for suicidal ideation and 1.49 (95% CI, 0.84 to 2.65) versus 0.91 (95% CI, 0.69 to 1.21) for depression.^131^ Four other reviews similarly found no differences in neuropsychiatric AEs or discontinuation due to AEs between smokers with severe mental illness taking or not taking varenicline (Table 8).^80,^ ^101,^ ^120,^ ^142^ Finally, no differences in the rates of nausea, sleep disturbances, or mood disorders were seen within three trials testing the effectiveness of varenicline versus placebo among smokeless tobacco users.^123^

##### Other Medications

There was insufficient evidence to indicate whether other antidepressants such as nortriptyline, SSRIs, or MAOIs increased the risk of AEs relative to placebo given too few trials for each comparison.^98^

In general, four trials of cytisine that all reported on harms did not identify more AEs or SAEs in the intervention versus control arm, but this data is limited by the few numbers of trials and lack of reporting at longer followup.^85^

#### Behavioral Interventions

Only three of the reviews on behavioral interventions included any discussion of potential harms from behavioral-based tobacco cessation interventions, including the review on internet-based interventions,^129^ the review on incentives,^116^ and the review on hypnotherapy.^82^ There was no clear harm related to any of these interventions. In the review on internet-based interventions, few trials reported AEs (6 of 67 included trials) and in those that did, AEs were rare and minor (i.e., weight gain, perceived stress, sleep disorder, fatigue).^129^ In the review on incentives for smoking cessation, one trial found no evidence of worsened psychiatric symptoms among smokers with serious mental illness. None of the other included studies reported on any harms, unintended consequences or AEs associated with the offering incentives.^116,^ ^166^ The Barnes review looked for reported AEs among participants taking part in hypnotherapy interventions and found that none of the 14 included studies reported AEs.^82^

#### Reduction-to-Quit Interventions

The review by Lindson (2019c) reported no clear evidence that the number of people reporting SAEs, or changes in withdrawal symptoms, differed between those advised to reduce their smoking versus those receiving no advice or advice for abrupt quitting; although pre-quit AEs, SAEs, and withdrawal symptoms were measured and reported variably and infrequently across studies.^105^

#### E-Cigarettes

The five RCTs that evaluated the effectiveness of e-cigarettes to aid in efforts to quit smoking conventional cigarettes at 6 months or longer,^144,^ ^145,^ ^154,^ ^155,^ ^157^ as well as four RCTs of e-cigarettes with shorter followup periods,^146–148,^ ^150^ were included in the evaluation of e-cigarettes’ harms. No cohort studies met criteria for inclusion. Characteristics of studies included for harms are described in Table 6 and Appendix F Tables 1 and 2.

None of the studies reported statistically significant differences in SAEs between intervention and control groups (Table 9).^144–148,^ ^150,^ ^154,^ ^155,^ ^157^ Four of the five trials that evaluated e-cigarette effectiveness reported nonsignificant distributions of AEs between the intervention and control groups at ≥6 months of followup (Table 9).^144,^ ^145,^ ^154,^ ^155^ The ASCEND trial, conducted by Bullen and colleagues, found no statistically significant difference in the incidence rate ratio (IRR) for AEs between these groups at 6 months’ followup (IRR 1.05 [95% CI, 0.82 to 1.34], p=0.7), despite a higher number and proportion of SAEs occurring in the nicotine e-cigarette group (27 serious events, 19.7%) than in the nicotine patch group (14 events, 11.8%).^144^ The authors deemed none of the AEs to be related to product use in any of the treatment groups.^144^ Similarly, the ECLAT study by Caponnetto and colleagues found no difference in the frequency of AEs among study groups at 12 and 52 weeks.^145^ No serious events occurred during the study.^145^ In the TEC trial, Hajek and colleagues reported that, as compared with participants assigned to NRT, those assigned to e-cigarettes had higher rates of throat and mouth irritation (e-cigarettes: 65.3% vs. NRT: 51.1%; RR 1.27 [95% CI, 1.13 to 1.43]) and lower rates of cough (e-cigarettes: 30.8% vs. NRT: 39.8%; RR 0.8 [95% CI, 0.6 to 0.9]) at 12 months of followup.^154^ SAEs occurred in both groups, but the trial clinicians determined that none of these events were attributable to study product use (Table 9).^154^ In a recent trial, SAEs occurred in 16 participants in the patch plus nicotine e-cig group, 22 people in the patch plus nicotine-free e-cig group, and 3 people in the patch only group; although the incidence rate ratios between group were not statistically significant and the authors deemed that none of the SAEs were considered treatment related.^155^ Another recent trial reported no SAEs among participants in either group but reported that the percentage of participants who experienced any adverse event was significantly lower in the e-cigarette group than in the nicotine gum group (6.7% vs 17.3% in e-cigarette group and nicotine gum group respectively)^157^ (Table 9).

Table 9 Adverse Event Results (KQ 3) for Primary Evidence on the Use of Electronic Cigarettes for Tobacco Cessation

Author, Year; Quality | System or organ class | Outcome | IG | CG | FU (mo) | IG events | IG N | IG AE rate | CG events | CG N | CG AE rate | Effect estimate (95% CI)
Bullen, 2013^144^; ASCEND; Fair | General | AE Rate | E-cig (16mg) | NRT (21mg Patch) | 6 | 137 events among 107 persons | NA | 0.8 events per person month | 119 events among 96 persons | NA | 0.8 events per person month | IRR 1.05 (0.82, 1.34) p=0.7
Bullen, 2013^144^; ASCEND; Fair | General | AE Rate | E-cig (16mg) | Placebo (0mg E-cig) | 6 | 137 events among 107 persons | NA | 0.8 events per person month | 36 events among 26 persons | NA | 0.9 events per person month | NR
Bullen, 2013^144^; ASCEND; Fair | General | Participants with AEs | E-cig (16mg) | NRT (21mg Patch) | 6 | 107 | 289 | 37.0% | 96 | 295 | 32.5% | NR
Bullen, 2013^144^; ASCEND; Fair | General | Participants with AEs | E-cig (16mg) | Placebo (0mg E-cig) | 6 | 107 | 289 | 37.0% | 26 | 73 | 35.6% | NR
Caponnetto, 2013^145^; ECLAT; Fair | General | AE Rate | E-cig (both study groups)^‡^ | Placebo (0mg E-cig) | 3 | NR | 200 | NR | NR | 100 | NR | NR; No difference was found in frequency or distribution of AEs between study groups
Caponnetto, 2013^145^; ECLAT; Fair | General | AE Rate | E-cig (both study groups)^‡^ | Placebo (0mg E-cig) | 12 | NR | 200 | NR | NR | 100 | NR | NR; No difference was found in frequency or distribution of AEs between study groups
Caponnetto, 2013^145^; ECLAT; Fair | General | Serious AEs^*^ | E-cig (both study groups)^‡^ | Placebo (0mg E-cig) | 12 | 0 | 200 | NA | 0 | 100 | NA | NA
Carpenter, 2017^147^; Fair | General | AE Rate | E-cig (16mg) | No Intv | 4 | 17 events among 9 persons | 25 | NR | 29 events among 8 persons | 22 | NR | NR
Carpenter, 2017^147^; Fair | General | AE Rate | E-cig (24mg) | No Intv | 4 | 21 events among 11 persons | 21 | NR | 29 events among 8 persons | 22 | NR | NR
Carpenter, 2017^147^; Fair | General | Participants with AEs | E-cig (16mg) | No Intv | 4 | 9 | 25 | 36% | 8 | 22 | 36% | NR
Carpenter, 2017^147^; Fair | General | Participants with AEs | E-cig (24mg) | No Intv | 4 | 11 | 21 | 52% | 8 | 22 | 36% | NR
Cravo, 2016^148^; Fair | General | AE Rate | E-cig (2.7 mg) | No Intv | 3 | 1515 events among 271 persons | 306 | NR | 225 events among 80 persons | 102 | NR | NR
Cravo, 2016^148^; Fair | General | Serious AEs | E-cig (2.7 mg) | No Intv | 3 | 5 events among 5 persons | 306 | NR | 0 | 102 | 0 | NR
Cravo, 2016^148^; Fair | Respiratory | Coughing | E-cig (2.7 mg) | No Intv | 3 | 52 | 306 | 17.0% | 8 | 102 | 7.8% | NR
Cravo, 2016^148^; Fair | Respiratory | Sore Throat | E-cig (2.7 mg) | No Intv | 3 | 85 | 306 | 27.8% | 9 | 102 | 8.8% | NR
Cravo, 2016^148^; Fair | Respiratory | Sinus Infection | E-cig (2.7 mg) | No Intv | 3 | 34 | 306 | 11.1% | 8 | 102 | 7.8% | NR
Cravo, 2016^148^; Fair | Neurologic | Headache | E-cig (2.7 mg) | No Intv | 3 | 145 | 306 | 47.4% | 34 | 102 | 33.3% | NR
Hajek, 2019^154^; TEC; Fair | General | Serious AE incidence | E-cig (any) | NRT (any) | 12 | 27 | 438 | 6.2% | 22 | 446 | 4.9% | NR
Hajek, 2019^154^; TEC; Fair | Respiratory | Coughing | E-cig (any) | NRT (any) | 12 | 97 | 314 | 30.8% | 111 | 279 | 39.8% | RR 0.8 (0.6, 0.9)
Hajek, 2019^154^; TEC; Fair | Respiratory | Shortness of breath | E-cig (any) | NRT (any) | 12 | 66 | 314 | 21.0% | 64 | 279 | 22.9% | RR 0.9 (0.7, 1.1)
Hajek, 2019^154^; TEC; Fair | Respiratory | Wheezing | E-cig (any) | NRT (any) | 12 | 74 | 314 | 23.5% | 59 | 279 | 21.1% | RR 1.1 (0.8, 1.4)
Hajek, 2019^154^; TEC; Fair | Respiratory | Throat/mouth irritation | E-cig (any) | NRT (any) | 12 | 286 | 438 | 65.3% | 221 | 432 | 51.1% | RR 1.27 (1.13, 1.43)
Hajek, 2019^154^; TEC; Fair | Respiratory | Phlegm | E-cig (any) | NRT (any) | 12 | 79 | 314 | 25.1% | 103 | 279 | 36.9% | RR 0.7 (0.6, 0.9)
Hajek, 2019^154^; TEC; Fair | Gastro-intestinal | Nausea | E-cig (any) | NRT (any) | 12 | 137 | 438 | 31.3% | 169 | 446 | 37.9% | RR 0.83 (0.69, 0.99)
Hajek, 2019^154^; TEC; Fair | Psychiatric | Disturbed Sleep | E-cig (any) | NRT (any) | 12 | 279 | 438 | 63.7% | 303 | 446 | 67.9% | RR 0.94 (0.98, 1.04)
Lee, 2019^157^; Fair | General | Number of participants with any AE | E-cig | NRT, gum | 6 | 5 | 75 | 6.7 | 13 | 75 | 17.3 | p= 0.044
Masiero, 2017^146^; Fair | Respiratory | Cough | E-cig (8mg) | Placebo (0mg E-cig) | 3 | 7 | 70 | 10.0% | 2 | 70 | 2.9% | NR
Masiero, 2017^146^; Fair | Respiratory | Dyspnea | E-cig (8mg) | Placebo (0mg E-cig) | 3 | 0 | 70 | NA | 1 | 70 | 1.4% | NR
Masiero, 2017^146^; Fair | Respiratory | Burning throat | E-cig (8mg) | Placebo (0mg E-cig) | 3 | 4 | 70 | 5.7% | 2 | 70 | 2.9% | NR
Masiero, 2017^146^; Fair | Neurologic | Headache | E-cig (8mg) | Placebo (0mg E-cig) | 3 | 0 | 70 | NA | 0 | 70 | NA | NR
Masiero, 2017^146^; Fair | Gastro-intestinal | Nausea | E-cig (8mg) | Placebo (0mg E-cig) | 3 | 1 | 70 | 1.4% | 2 | 70 | 2.9% | NR
Masiero, 2017^146^; Fair | Gastro-intestinal | Stomach-ache | E-cig (8mg) | Placebo (0mg E-cig) | 3 | 0 | 70 | NA | 0 | 70 | NA | NR
Masiero, 2017^146^; Fair | Psychiatric | Insomnia | E-cig (8mg) | Placebo (0mg E-cig) | 3 | 1 | 70 | 1.4% | 0 | 70 | NA | NR
Masiero, 2017^146^; Fair | Psychiatric | Confusion | E-cig (8mg) | Placebo (0mg E-cig) | 3 | 1 | 70 | 1.4% | 0 | 70 | NA | NR
Tseng, 2016^150^; Fair | General | Participants with AEs | E-cig | Placebo | 3 wk | 11 | 50 | 22.5% | 5 | 49 | 10.3% | p=0.14
Walker, 2019^155^; Fair | General | Serious AEs | E-cig (18mg) +NRT (21mg) | Placebo (0mg E-cig) + NRT (21mg) | 6 | 18 events in 16 people | 500 | 4.0% | 27 events in 22 people | 499 | 5.0% | IRR 0.66 (0.36, 1.20); p=0.18
Walker, 2019^155^; Fair | General | Serious AEs | E-cig (18mg) +NRT (21mg) | NRT (21mg) | 6 | 18 events in 16 people | 500 | 4.0% | 4 events in 3 people | 125 | 3.0% | IRR 0.86 (0.29, 2.53); p=0.78

Note: No intervention control groups continued smoking with conventional cigarettes and received no behavioral intervention component.

* Defined as any event requiring unscheduled visits to a physician or hospitalization.

‡ Group A=7.2 mg E-cig for 12 weeks; Group B=7.2 mg E-cig for 6 weeks and 5.4 mg E-cig for 6 weeks.

Abbreviations: AE = adverse event; E-cig = electronic cigarette; Intv = intervention; NA = not applicable; NR = not reported; NRT = nicotine replacement therapy; RR = relative risk

Among the four trials newly identified by this review with followup periods <6 months, no significant differences in the incidence of AEs overall or SAEs between intervention and control groups were reported (Table 9).^146–148,^ ^150^ At four months of followup, Carpenter and colleagues found that participants in a U.S. trial who were randomized to e-cigarettes (either 16 mg/mL or 24 mg/mL nicotine concentration), as compared with participants with ongoing conventional cigarette (CC) use, reported higher rates of cough (e-cigarettes: 32% vs. CCs: 21%), but exhibited similar rates of throat irritation (e-cigarettes: 16% vs. CCs: 17%).^147^ Although differences in the incidence of AEs between the intervention and control groups were observed, statistical comparisons were not made, and no AEs resulted in study withdrawal.^147^ Similarly, Cravo and colleagues, comparing e-cigarettes with ongoing CC use in the United Kingdom at 4 months, found higher rates of cough (e-cigarettes: 17.0% vs. CCs: 7.8%), sore throat (e-cigarettes: 27.8% vs. CCs: 8.8%), and headache (e-cigarettes: 47.4% vs. CCs: 33.3%), but no statistical comparisons were made.^148^ Compared with a nonnicotine-containing e-cigarette (placebo), Masiero and colleagues found the subjects who used nicotine-containing e-cigarettes reported higher rates of burning throat (e-cigarette: 5.7% vs. placebo: 2.9%) and cough (e-cigarette: 10.0% vs. placebo: 2.9%) at 3 months of followup, but statistical comparisons were not made.^146^ In a study by Tseng and colleagues, young adult smokers in the United States who were randomized to low-nicotine (4.5%) e-cigarettes reported almost twice the proportion of AEs (22.5%) over a 3-week followup period as participants randomized to no-nicotine placebo e-cigarettes (10.3%); however, this difference was not statistically significant (p=0.14).^150^

## Evidence for Pregnant Women

### Included Evidence

Based on a primary literature review of 64 full-text articles, we identified seven RCTs (reported in 12 publications)^167–178^ evaluating the use of NRT among pregnant women and five large observational studies (reported in six publications)^179–184^ that reported on the harms of NRT, bupropion, or varenicline use (Appendix B Figure 3).

Using the overview of reviews approach, we identified five reviews that addressed the benefits and harms of behavioral interventions for supporting women to stop smoking pregnancy (Table 2).^108,^ ^116,^ ^185–187^ The review by Chamberlain (2017) included any behavioral support intervention including counseling, health education, feedback, incentives, social support, exercise, and dissemination of cessation interventions.^185^ The included bodies of evidence within the three other reviews focused on digital interventions,^186^ incentives,^116,^ ^187^ and psychotherapy^187^ were mostly duplicative and the results were entirely consistent with those of Chamberlain. Additionally, one review on relapse prevention provided a detailed synthesis of interventions among pregnant women and is reported below.^108^

We identified no studies that met eligibility criteria that addressed the benefits or harms of the use of e-cigarettes to help pregnant women quit smoking.

### Credibility/Quality Assessment

Of the seven RCTs included that examined the benefits and harms of NRT among pregnant women, we rated two as good quality and the remaining five as fair quality (Table 10). Increased risk of bias in the fair quality studies was primarily owing to lack of allocation concealment, attrition, and study arm imbalances in baseline characteristics. Of the five observational studies included for harms, we rated four of them as good quality and one as fair quality. The fair quality study was assessed to have elevated risk of bias due to limitations in the data source for assigning individuals to the exposed and unexposed groups and insufficient adjustment for possible confounding factors.

Table 10 Primary Evidence on Pharmacotherapy Among Pregnant Individuals: Study and Population Characteristics, by Study Design

Study design | Author, Year; Trial name; Quality | Country | N rand | Brief population/cohort description | Intervention/Exposure | Comparison | Outcomes of interest
RCT | Berlin, 2014^167^; SNIPP; Good | France | 403 | Pregnant smokers aged 18 years or more with a gestational age of between nine and 20 weeks of amenorrhea who smoked at least five cigarettes a day and were motivated to quit | NRT patch (10–15 mg/day) plus behavioral support | Placebo patch plus behavioral support | - Low BW; - Mean BW; - Preterm birth; - Stillbirth; - Tobacco cessation
RCT | Coleman, 2012^168^; SNAP; Good | UK | 1051 | Pregnant smokers aged 16–50 years, between 12 and 24 weeks’ pregnant, smoked at least 10 cigarettes per day before pregnancy and continued to smoke at least five cigarettes per day | NRT patch (15 mg/ 16 hrs) plus behavioral counseling | Placebo patch plus behavioral counseling | - Low BW; - Mean BW; - Preterm birth; - Stillbirth; - Tobacco cessation
RCT | Oncken, 2008^174^; Fair | US | 194 | Pregnant smokers, ≤26 weeks pregnant and smoked ≥ 1 cpd | NRT gum (2 mg) plus behavioral counseling | Placebo gum plus behavioral counseling | - Low BW; - Mean BW; - Preterm birth; - Stillbirth; - Tobacco cessation
RCT | Oncken, 2019^175^; Fair | US | 154 | Pregnant women who smoked ≥5 cigarettes daily | NRT inhaler (10mg) plus behavioral counseling | Placebo inhaler plus behavioral counseling | - Low BW; - Mean BW; - Preterm birth; - Tobacco cessation
RCT | Wisborg, 2000^178^; Fair | Denmark | 250 | Pregnant smokers, who smoked ≥ 10 cigarettes after first trimester | NRT patch (15 mg/ 16 hrs for 8 weeks, 10 mg/16 hrs for 3 weeks) plus behavioral counseling | Placebo patch plus behavioral counseling | - Low BW; - Mean BW; - Preterm birth; - Tobacco cessation
Non-placebo control RCT | El-Mohandes, 2013^171^; Fair | US | 52 | Pregnant African American smokers ≥18 years, and <30 weeks pregnant with a desire to quit | Trans-dermal NRT, 14–21mg for 10 wks depending on cpd. Maximum of six clinical visits. | Behavioral counseling | - Low BW; - Mean BW; - Preterm birth; - Tobacco cessation
Non-placebo control RCT | Pollak, 2007^176^; Baby Steps; Fair | US | 181 | Pregnant smokers between 13 and 25 weeks pregnant and smoked ≥ 5 CPD | Choice of NRT from patch (7–12mg/16hrs depending on cpd), gum (2mg/each cpd), or lozenge (2mg/each cpd) plus behavioral counseling | Behavioral counseling | - Low BW; - Mean BW; - Preterm birth; - Tobacco cessation
Cohort | Berard, 2016^179^; Quebec Pregnancy Cohort; Good | Canada | 1288 | Quebec Pregnancy Cohort data | Bupropion alone with or without smoking or NRT patch alone with or without smoking | Smokers without bupropion or NRT patch exposure | - Preterm birth
Cohort | Dhalwani, 2018^180,^ ^181^; The Health Improvement Network (THIN); Fair | UK | 220,630 | Cohort of singleton pregnancies ending in live or stillbirth between 2001 and 2012 from The Health Improvement Network UK general practice database | NRT (any) | Smokers and non-smokers | - Stillbirth; - Major congenital anomalies
Cohort | Pedersen, 2019^182^; Good | Denmark, Sweden | 885,185 | Nationwide health and administrative registry data for cohort including live-born and stillborn infants from 1 May 2007 to 31 December 2012 | Dispensed varenicline | 1) Unexposed to varenicline, but exposed to maternal smoking in utero or 2) unexposed to varenicline and unexposed to maternal smoking in utero) | - Major congenital malformations; - Stillbirth; - Fetal growth restriction; - Preterm birth; - Sudden infant death syndrome
Cohort | Tran, 2020^183^; Smoking MUMS study; Good | Australia | 1,014,731 | Smoking MUMS cohort; perinatal and pharmaceutical dispensing data for all deliveries in New South Wales and Western Australia between 2003 and 2012. | Bupropion, varenicline or NRT during pregnancy | Women who had never been exposed to any of these medicines in pregnancy | - Any adverse perinatal event^*^; - Major congenital anomaly
Cohort | Zhu, 2014^184^; Danish National Birth Cohort (DNBC); Good | Denmark | 84,803 | Danish National Birth Cohort data | NRT (mother) plus smoker (father) or NRT (mother) plus non-smoker (father) | Nonsmoker (mother) plus nonsmoker (father) | - ADHD (child)

* Any adverse perinatal event was a composite of 10 individual birth outcomes, including preterm birth (< 37 weeks, medically indicated or spontaneous), small for gestational age (SGA, birthweight < 10th percentile sex- and gestational age-specific), Apgar score at 5 min < 7, admission to neonatal special care (NSC), severe neonatal morbidity complications, emergency caesarean section, severe maternal morbidity complications, preterm premature rupture of membranes (PPROM), placental abruption and perinatal death (stillbirth or 28-day neonatal death).

Abbreviations: ADHD = attention deficit/hyperactivity disorder; BW = birth weight; CG = control group; CPD = cigarettes per day; hr = hour(s); IG = intervention group; NRT = nicotine replacement therapy; mg = milligram(s); RCT = randomized controlled trial; UK = United Kingdom; US = United States

The review by Chamberlain (2017) was rated as having high credibility according to AMSTAR-2 criteria and had no critical weaknesses. The other reviews that included evidence for pregnant women were all rated as moderate or high credibility with only minor weaknesses in the methodology noted.

### Key Question 1 Do Tobacco Cessation Interventions Improve Mortality, Morbidity, and Other Health Outcomes in Adults Who Currently Use Tobacco, Including Pregnant Women?

#### Pharmacotherapy Interventions

##### Nicotine Replacement Therapy

All seven included RCTs were designed to test the effectiveness of NRT on smoking cessation and reported infant, child, and maternal health outcomes (Table 10).^167,^ ^168,^ ^171,^ ^174–176,^ ^178^ Most evaluated NRT patch interventions, but one gave participants a choice of patch, gum, or lozenge,^176^ one trial offered NRT gum,^174^ and one used a nicotine inhaler^175^ (Appendix G Table 2). In all cases, women were offered behavioral support in addition to NRT. Five of the seven RCTs were placebo controlled. The largest study (n=1050) was the Smoking, Nicotine, and Pregnancy trial (SNAP), which was a multisite RCT of NRT patches conducted in the United Kingdom.^168–170^ The second largest and most recent NRT trial was conducted in France at multiple sites, randomizing 402 women to nicotine patches or placebo nicotine patches.^167^ Women enrolled in the seven trials were mainly ages 18 years and older (mean ages ranged from 25.1 to 29.3 years).^167^ One trial exclusively enrolled African-American women.^171^ Study recruitment tended to be at the first antenatal visit or before the end of the second trimester of pregnancy; one small trial allowed women to enroll any time before 30 weeks gestation but the average gestation at baseline was in the early second trimester (Appendix G Table 1).^171^ In one trial^174^ women were invited to participate if they smoked one or more cigarettes per day during pregnancy and in the other trials five or more cigarettes per day. Five trials, including the two largest, reported the percentage of participants with a history of preterm birth (range 9% to 15%).^167,^ ^168,^ ^174–176^ Low adherence to NRT therapy was noted in the trials. For example, in the SNAP trial;^168–170^ only 7.2 percent of women in the NRT condition and 2.8 percent with placebo used the patch for more than one month, and in the trial offering a choice of gum, patch, or lozenge,^176^ the average use of NRT was lower than the prescribed and dispensed medications.

Five placebo-controlled trials reported on preterm birth (delivery at <37 weeks gestation). ^167,^ ^168,^ ^174,^ ^175,^ ^178^ The most recent study reported a statistically significant lower incidence of preterm delivery among those in the NRT inhaler group (3/67, 4%) compared with the placebo group (10/67, 15%) (p=0.030 after controlling for history of preterm birth).^175^ Within the other trials, one reported similar numbers of women with preterm birth in the NRT and placebo arms (14.0% vs. 13.5%, respectively),^167^ two reported only slightly fewer women with preterm birth in the NRT arm,^168,^ ^178^ and the smallest study reported reduced incidence of preterm birth with NRT compared with placebo (RR 0.39 [95% CI, 0.17 to 0.91]) (Appendix G Figure 1).^174^ The three placebo-controlled trials that did not report statistically significant differences had larger samples and estimated effects closer to null, ranging from a RR 0.85 to 1.04.^167,^ ^168,^ ^178^ Two trials without placebo controls were imprecise and estimated effects in opposite directions.^171,^ ^176^

All seven trials reported the association between the intervention and mean birthweight.^167,^ ^168,^ ^171,^ ^174–176,^ ^178^ Two placebo-controlled trials found significantly higher birthweights among women allocated to the NRT arm^174,^ ^178^ (Appendix G Figure 2), while only one of the trials^174^ reported similar effect for the proportion of infants categorized as having low birthweight (Appendix G Figure 3). The two largest, good-quality, placebo-controlled trials of NRT patch interventions, did not find evidence of increased infant birthweight with NRT treatment.^167,^ ^168^ Further, Coleman and colleagues found more low birthweight infants were reported for the NRT condition, although the result was not statistically different from null (RR 1.38 [ 95% CI, 0.90, 2.09).^168^ Four trials also reported stillbirths, but low event rates and imprecision limit inference (Appendix G Figure 4).^167,^ ^168,^ ^174,^ ^176^

The trial by Coleman and colleagues, reported 2-year followup data on child health outcomes.^168–170,^ ^173^ In this trial, just under one-third of participants in each arm completed the 2-year questionnaire. Nonrespondents’ family physicians were also surveyed. Both study trial arms reported that 88 percent of participants or clinicians completed followup at 2 years, with similar rates of withdrawal and nonresponse between arms over the time period (NRT n=445 and placebo n=446). Comparison group characteristics were similar in the original and followup cohort. This study’s authors reported composite variables based on an a priori statistical analysis plan. The main outcomes were survival with no impairment (i.e., developmental, neuromotor, and sensory) and respiratory problems (i.e., respiratory symptoms, asthma diagnosis, and admissions to hospital for respiratory problem). Group comparisons using intention-to-treat analyses with multiple imputation indicated that survival with no impairment was significantly higher among those allocated to the NRT group compared to placebo (73% versus 65%; OR 1.40 [95% CI, 1.05 to 1.86]). There was no significant difference in rates of definite developmental impairment (11% NRT, 14% placebo; OR 0.71 [95% CI, 0.47 to 1.09]) between the groups. For respiratory problems, a 5 percent observed difference between the arms (30% NRT vs. 25% placebo) was not statistically significant (OR 1.30 [95% CI 0.97 to 1.74]).^169,^ ^170^ Results from a complete case analysis that included twins were consistent with these results.^169^

##### Bupropion

We identified no trials that addressed the effectiveness of bupropion among pregnant women that met our eligibility criteria.

##### Varenicline

We identified no trials that addressed the effectiveness of varenicline among pregnant women that met our eligibility criteria.

#### Behavioral Interventions

The review by Chamberlain (2017) identified 102 trials that addressed the effects of smoking cessation interventions during pregnancy on smoking behavior and perinatal health outcomes (Tables 2 and 3).^185^ Most of the trials in this review included generally healthy women over 16 years of age, while two trials targeted women younger than 20 years of age, eight trials specifically targeted women with psychosocial risk factors, and two trials were limited to women under methadone treatment for opioid addiction (Table 4). About half the trials (k=52, 66 study arms) explicitly recruited women categorized as having low socioeconomic status, and 10 trials included mainly women belonging to an ethnic minority population. Most of the included trials recruited women during their first antenatal visit or second trimester of pregnancy and excluded women in their last trimester of pregnancy due to the limited time available to receive an intervention. There were, however, four trials that targeted women who smoked into late pregnancy.^185^

Within the trials that were included for any meta-analysis, 94 were aimed exclusively at supporting smoking cessation and 12 trials aimed to improve maternal health, which included smoking cessation.^185^ The latter studies were only included for KQ 2 (cessation outcomes) given that there is a potential for other aspects of these interventions to have impacted birth outcomes. All interventions differed substantially in their intensity, duration, and interventionists. Included trials presented many comparisons. Interventions included counseling, health education, feedback, incentives, social support, exercise, and dissemination (active dissemination of a smoking cessation intervention) and comparators included usual care, less intensive interventions, and alternative interventions (e.g., cognitive behavioral counseling versus traditional health education). The review excluded trials comparing efficacy of pharmacotherapy with equal levels of behavioral support. Of interventions categorized as counselling interventions (54 intervention arms), most involved face-to-face contact, using a variety of strategies either alone or in combination (such as motivational interviewing, cognitive behavioral therapy, stages of change). The duration and frequency of counseling varied considerably but has generally increased over time. Health education (12 intervention arms) were those interventions that provided information about the risk of smoking and advice to quit but did not give further support or advice on how to make this change. Most were provided through automated support such as self-help materials or automated text messaging. Feedback interventions (6 intervention arms) were those where the mother was provided feedback with information about the fetal health status or measurement of by-products of tobacco smoking to the mother. Incentive-based interventions (13 arms) included interventions were women received a financial incentive, contingent on their smoking cessation, including gift vouchers. Social support interventions (7 arms) were those that explicitly included the provision of support from a peer or partners.^185^

Of the 102 included trials, 26 study arms reported mean birthweight, 17 arms reported rates of low-birthweight babies (less than 2500 g) and three reported rates of very low birthweight babies (less than 1500 g), and 19 study arms reported rates of preterm births (less than 37 weeks’ gestation).^185^ Other, less commonly reported data included stillbirths (k=8), perinatal deaths (k=4), and neonatal deaths (k=5).^185^

When all 26 studies that reported mean birthweight were combined, there was evidence that infants born to women receiving behavioral smoking cessation interventions had an increase in mean birthweight of 55.60 g, compared with women in the usual care control groups (MD 55.60 g [95% CI, 29.82 to 81.38]; I^2^=31%; k=26; n=11,338) (Table 11).^185^ The magnitude and significance of the effect was similar when limited to counseling interventions (42.17 g [95% CI, 11.79 to 72.55], I^2^=0%; k=14; n=5471), and a test for subgroup differences showed no evidence of effect modification by type of intervention (p=0.11). The magnitude of the mean difference between groups for all types of interventions was modest, yet there was general consistency in the direction of effects across studies, with only six reporting effects (none statistically significant) favoring the control condition. Evidence of beneficial effects was also observed in the pooled analyses across all interventions and comparators for low birthweight (under 2500 g). The pooled effect estimate suggested a 17 percent risk reduction for delivery of a low birthweight baby (RR 0.83 [95% CI, 072 to 0.94]; I^2^=0%; k=18; n=9402) (Table 11). When restricted to specific types of interventions, while results suggested similar benefits, none of the pooled results were statistically significant. None of the three trials reporting on rates of birth to very low birthweight babies (less than 1500 g) found a beneficial effect of the behavioral intervention versus control.^185^

Table 11 Summary of Perinatal Health Outcome Results (KQ 1) of Behavioral Tobacco Cessation Interventions Among Pregnant Women, Psychosocial Interventions vs. Any Control (Within Chamberlain, 2017 Review^185^)

Outcome | Intervention | K | Total n analyzed | IG events | IG n | CG events | CG n | Risk Ratio (95% CI) | I^2^
Mean birthweight^*^ | Any psychosocial intervention | 26 | 11,338 | 3207.5 | 5756 | 3146.9 | 5582 | MD=55.60 (29.82, 81.38) | 31%
Mean birthweight^*^ | Counseling | 14 | 5471 | 3080.7 | 2698 | 3744.9 | 2733 | MD=42.17 (11.79, 72.55) | 0%
Mean birthweight^*^ | Health education | 2 | 1172 | 3330.9 | 685 | 3255.1 | 487 | MD=27.35 (−53.88, 108.58) | 33%
Mean birthweight^*^ | Feedback | 2 | 3006 | 3418.7 | 1501 | 3221.1 | 1505 | MD=79.43 (−53.05, 211.91) | 58%
Mean birthweight^*^ | Incentives | 6 | 834 | 3150.5 | 451 | 3088.2 | 383 | MD=114.01 (63.91, 164.11) | 23%
Mean birthweight^*^ | Social support | 1 | 142 | 3100 | 67 | 3072 | 75 | MD=28.0 (−152.48, 208.48) | NA
Mean birthweight^*^ | Exercise | 1 | 713 | 3132.4 | 354 | 3146.8 | 359 | MD=−14.40 (−104.15, 75.35) | NA
Low birthweight | Any psychosocial intervention | 18 | 9402 | 355 | 4743 | 429 | 4659 | 0.83 (0.72, 0.94) | 0%
Low birthweight | Counseling | 8 | 7339 | 151 | 2090 | 200 | 2249 | 0.83 (0.68, 1.01) | 0%
Low birthweight | Health education | 2 | 1172 | 40 | 685 | 37 | 487 | 0.87 (0.49, 1.55) | 40%
Low birthweight | Feedback | 1 | 2848 | 99 | 1423 | 121 | 1425 | 0.82 (0.63, 1.06) | NA
Low birthweight | Incentives | 5 | 252 | 22 | 156 | 21 | 96 | 0.63 (0.37, 1.08) | 0%
Low birthweight | Social support | 1 | 79 | 5 | 36 | 6 | 43 | 1.00 (0.33, 2.99) | NA
Low birthweight | Exercise | 1 | 712 | 38 | 353 | 44 | 359 | 0.88 (0.58, 1.32) | NA
Preterm births | Any psychosocial intervention | 19 | 9222 | 337 | 4705 | 363 | 4517 | 0.93 (0.77, 1.11) | 18%
Preterm births | Counseling | 8 | 3447 | 99 | 1672 | 117 | 1775 | 0.93 (0.71, 1.20) | 0%
Preterm births | Health education | 2 | 1170 | 29 | 684 | 25 | 486 | 0.92 (0.55, 1.56) | 40%
Preterm births | Feedback | 2 | 3111 | 115 | 1572 | 150 | 1539 | 0.60 (0.28, 1.29) | 63%
Preterm births | Exercise | 1 | 704 | 35 | 356 | 26 | 348 | 1.32 (0.81, 2.14) | NA
Preterm births | Incentives | 6 | 790 | 59 | 421 | 45 | 369 | 0.91 (0.52, 1.59) | 33%
Stillbirths | Any psychosocial intervention | 8 | 6170 | 40 | 3053 | 33 | 3117 | 1.20 (0.76, 1.90) | 0%
Stillbirths | Counseling | 5 | 2454 | 16 | 1197 | 14 | 1257 | 1.14 (0.55, 2.33) | 0%
Stillbirths | Feedback | 2 | 2960 | 22 | 1479 | 17 | 1481 | 1.28 (0.69, 2.39) | 0%
Stillbirths | Exercise | 1 | 756 | 2 | 377 | 2 | 379 | 1.01 (0.14, 7.10) | NA

* Presented as mean in grams; weighted means (g) calculated

Abbreviations: CG = control group; CI = confidence intervals; IG = intervention group; MD = mean difference; NA = not applicable

Of the 19 trials reporting the effects of the intervention on preterm birth (less than 37 weeks), results were mixed, although the majority reported a reduced risk of preterm birth among women within the behavioral interventions versus control groups.^185^ Meta-analysis of these trials resulted in uncertainty in the potential benefit of behavioral interventions compared with controls on rates of preterm birth (RR 0.93 [95% CI 0.77 to 1.11]; I^2^=18%; k=19; n=9222) (Table 11). In separate comparisons of studies, the effect was also unclear across comparisons by type of specific intervention and control groups.^185^

Among the eight trials reporting stillbirth, none of the trials found significant differences between study groups, and the pooled result was consistent with either potential benefit or harm (RR 1.20 [95% CI, 0.76 to 1.90]; I^2^=0%; k=8; n=6170) (Table 11).^185^ There were very low event rates within each group across trials, however, overall, there were slightly more stillbirths recorded in the intervention groups (40/3053) compared with the control groups (33/3117). Three trials of counseling, one trial of a feedback intervention, and one exercise trial reported on neonatal deaths, but events were too rare to inform valid conclusions. Similarly, there was no pattern of effects across four trials reporting perinatal death.^185^

#### E-Cigarettes

We identified no trials that addressed the effectiveness of e-cigarettes among pregnant women that met our eligibility criteria.

### Key Question 2 Do Tobacco Cessation Interventions Increase Tobacco Abstinence in Adults Who Currently Use Tobacco, Including Pregnant Women?

#### Pharmacotherapy Interventions

##### Nicotine Replacement Therapy

There was no evidence of differences in smoking cessation with NRT intervention across the included RCTs. Meta-analysis of five placebo-controlled trials generated a pooled effect of NRT on validated smoking cessation at followup (RR 1.11 [95% CI, 0.79 to 1.56]; I^2^ = 0%, n=2033) and low statistical heterogeneity (Appendix G Figure 5).^167,^ ^168,^ ^174,^ ^175,^ ^178^ Quit rates in these trials ranged from 5 to 28 percent in the intervention groups and 5 to 25 percent in the control groups (mean,11.8% vs. 10.6%). The results across trials for the efficacy of NRT were relatively consistent, with effect estimates ranging from 1.08 to 1.24 in the placebo-controlled trials (with the exception of one new trial that found a higher quit rate among those in the placebo group [17.9%] compared with the NRT group [10%] (RR 0.56 [95% CI, 0.23 to 1.33]).^175^ The results of the two smaller trials with no treatment controls^171,^ ^176^ were not statistically significant, and estimates of efficacy were greater than for the placebo-controlled trials. Including these studies in meta-analysis did not change the overall findings (data not shown). Low rates of adherence to the intervention were described (mean adherence rates of less than 25 percent were often observed); particularly in the trials with good reporting.^167,^ ^168,^ ^174,^ ^175,^ ^178^

The 2-year SNAP followup study found continuous smoking abstinence rates to be very low in both groups: 3 percent of mothers in the NRT group and 2 percent of mothers in the placebo group self-reported prolonged (or continuous) abstinence at two years since the quit date set in pregnancy, with no statistical difference between groups.^170^ Cessation was ascertained by clinician survey for over half of the trial participants at 2 years. Nonrespondents were assumed to be smokers and included in the denominator. While there were no significant differences between groups earlier in the postpartum period (6 months), a significant effect was observed at one year (4% NRT vs. 2% placebo) with further adjustment (site, baseline salivary cotinine, partner smoking status, and years completed education).^170^

##### Bupropion

We identified no trials that addressed the effectiveness of bupropion among pregnant women that met our eligibility criteria.

##### Varenicline

We identified no trials that addressed the effectiveness of varenicline among pregnant women that met our eligibility criteria.

#### Behavioral Interventions

##### Primary Results

The review by Chamberlain (2017) identified 102 trials with 120 study arms testing the effects of a behavioral interventions for smoking cessation among pregnant women.^185^ Of the 120 study arms included in the review, 97 arms reported the primary outcome measure of smoking abstinence in late pregnancy, up to and including the period of hospitalization for birth. In 71 of these study arms (73%), this abstinence was biochemically validated. In most trials, women were classified as “current smokers”; some other studies included women who had spontaneously quit in early pregnancy but are included here. The remaining trials did not report a measure of smoking abstinence in late pregnancy but focused on abstinence in the postpartum period only, smoking reduction, or perinatal outcome measures.^185^

Pooled analyses of all behavioral interventions (k=97), regardless of type and including self-reported outcomes, indicated a statistically significant effect on smoking cessation in late pregnancy when compared with usual care or a minimal intervention (RR 1.35 [95% CI, 1.23 to 1.48]; k=97; n=26,637), with moderate heterogeneity of estimated effects (I^2^=44%) (Table 12).^185^ While an overall Chi^2^ test for subgroup differences found no difference by the type of intervention (p=0.39), the number of studies varied considerably by intervention type (counseling [51 trials], health education [11 trials], feedback [6 trials], incentives [13 trials], social support [14 trials], exercise [1 trial], and other [1 trial]. The results were similarly beneficial when restricted to trials comparing counseling with any type of control (RR 1.31 [95% CI, 1.16 to 1.47]; I^2^=40%; k=51; n=18,2786) as well as when comparing counseling with usual care (RR 1.44 [95% CI 1.19 to 1.73]; I^2^=49%; k=30; n=12,432). Results of trials of feedback and incentives were also suggestive of a benefit; but there was no evidence of a statistically significant effect of social support interventions from analysis of 10 trials that were included in the review (RR 1.29 [95% CI, 0.97 to 1.73]). The effects of other types of interventions versus any comparator or usual care generally favored the intervention conditions, but pooled results did not rule out the possibility of no benefit. Direct comparisons between interventions of greater versus less intensity were found to be statistically significant for trials testing counseling, but not for the fewer studies of health education (4 trials), feedback (3 trials), or social support (7 trials) interventions (Table 12). There was some evidence that the positive effects of behavioral interventions on smoking cessation in late pregnancy continued into the postpartum period, up until approximately 18 months postpartum. For instance, in an examination of counseling interventions compared with usual care, the average RR was 1.59 (95% CI, 1.26 to 2.01; k=11) at 0 to 5 months postpartum, 1.33 (95% CI, 1.00 to 1.77; k=6) at 6 to 11 months postpartum, and 2.20 (95% CI, 1.23 to 3.96; k=2) at 12 to 17 months.^185^

Table 12 Summary of Tobacco Cessation Outcomes (KQ 2) of Behavioral Tobacco Cessation Interventions Among Pregnant Women (Within Chamberlain, 2017 Review^185^)

Intervention | Control | K | N analyzed | IG | IG N | IG quit rate | CG | CG N | CG quit rate | Risk ratio (95% CI) | I^2^
Any psychosocial intervention | Any control | 97 | 26,637 | 2332 | 14,192 | 16.4% | 1518 | 12,445 | 12.2% | 1.35 (1.23, 1.48) | 44%
Counseling | Any control | 51 | 18,276 | 1376 | 9510 | 14.5% | 950 | 8766 | 10.8% | 1.31 (1.16, 1.47) | 40%
Health education | Any control | 11 | 2142 | 195 | 1275 | 15.3% | 107 | 867 | 12.3% | 1.22 (0.97, 1.55) | 7%
Feedback | Any control | 6 | 859 | 94 | 513 | 18.3% | 31 | 346 | 9.0% | 1.92 (1.16, 3.17) | 7%
Incentives | Any control | 13 | 1752 | 222 | 995 | 22.3% | 89 | 757 | 11.8% | 1.88 (1.12, 3.14) | 66%
Social support | Any control | 14 | 2629 | 405 | 1409 | 28.7% | 310 | 1220 | 25.4% | 1.16 (0.96, 1.40) | 23%
Exercise | Any control | 1 | 785 | 30 | 392 | 7.7% | 25 | 393 | 6.4% | 1.20 (0.72, 2.01) | NA
Other (behavioral) | Any control | 1 | 194 | 10 | 98 | 10.2% | 6 | 96 | 6.3% | 1.63 (0.62, 4.32) | NA
Counseling | Usual care | 30 | 12,432 | 771 | 6350 | 12.1% | 546 | 6082 | 9.0% | 1.44 (1.19, 1.73) | 49%
Counseling | Less intensive intervention | 18 | 5657 | 494 | 2897 | 17.1% | 368 | 2760 | 13.3% | 1.25 (1.07, 1.47) | 28%
Counseling | Alterative intervention | 1 | 257 | 58 | 128 | 4.5% | 51 | 129 | 4.0% | 1.15 (0.86, 1.53) | NA
Health education | Usual care | 5 | 629 | 41 | 310 | 13.2% | 25 | 319 | 7.8% | 1.59 (0.99, 2.55) | 0%
Health education | Less intensive intervention | 4 | 1282 | 116 | 759 | 15.3% | 72 | 523 | 13.8% | 1.20 (0.85, 1.70) | 33%
Health education | Alterative intervention | 1 | 31 | 2 | 16 | 12.5% | 1 | 15 | 6.7% | 1.88 (0.19, 18.60) | NA
Feedback | Usual care | 2 | 355 | 33 | 198 | 16.70% | 6 | 157 | 3.80% | 4.39 (1.89, 10.21) | 0%
Feedback | Less intensive intervention | 3 | 439 | 42 | 276 | 15.2% | 19 | 163 | 11.7% | 1.29 (0.75, 2.20) | 0%
Incentives | Usual care | 5 | NR | NR | NR | NR | NR | NR | NR | NR, subtotals only | NR
Social support | Less intensive intervention | 7 | 781 | 102 | 405 | 25.2% | 73 | 376 | 19.4% | 1.21 (0.93, 1.58) | 0%
Exercise | Usual care | 1 | 785 | 30 | 392 | 7.7% | 25 | 393 | 6.4% | 1.21 (0.72, 2.01) | NA

Abbreviations: CG = control group; CI = confidence intervals; IG = intervention group; NA = not applicable; NR = not reported

##### Evidence of Effect Modification

Regarding the whole set of trials, meta regression analyses found no differences in the effects of behavioral interventions according to the specific intervention strategies, comparator, intensity (categorized according to frequency of contact), intervention duration, the provision of self-help manuals, including telephone support, the SES of the sample, newly added studies, or study design (cluster versus individually randomized trials).^185^ In general, interventions of higher intensity typically also had control groups of higher intensity, potentially explaining why no clear differences were seen with increasing intervention intensity. There was some evidence that studies with a high risk of bias related to allocation concealment had a larger pooled-effect size estimate compared with lower risk or unclear risk of bias studies. Studies with unclear and low risk of bias for equal baseline characteristics in study arms showed larger effect sizes than those at high risk of bias for this item. No other measures of risk of bias (random sequence generation, attrition bias, selective reporting bias, detection bias, blinding, contamination, or intervention fidelity) predicted larger effect estimates.^185^

Several of the individual trials provided findings of subgroup analyses based on participant characteristics.^185^ Of 13 studies that reported a sensitivity analysis by a measure of socioeconomic status with studies (such as education levels and employment), eight reported lower abstinence rates among women with lower SES, three reported no difference, and two reported higher rates of intervention success among women with low SES. Among the eleven trials that reported outcomes by ethnic status results were inconsistent: one study reported the intervention was less effective among Hispanic and African American women compared with white women, one study reported the intervention was less effective among Hispanic compared with African American women, four studies reported no difference in outcomes by race or ethnicity, and five study arms reported higher quit rates among African American and/or Hispanic women compared with women of other races and ethnicities. Four studies reported a negative association between treatment effectiveness and higher rates of depression, and of six studies that reported measures of social support, four reported a negative association with low social support and quitting.^185^

#### Interventions for Relapse Prevention

The moderate-credibility review by Livingstone-Banks (2019a) included 18 trials focused on relapse prevention among pregnant and/or postpartum ex-smokers.^108^ Pooled results from eight studies of interventions in pregnancy did not demonstrate a clear benefit on relapse prevention at the end of pregnancy (RR 1.05 [95% CI, 0.99 to 1.11]; k=8; n=1523; I^2^=0%). There was also no significant benefit seen among 15 studies that included followup into the postpartum period overall or when subgrouped according to timing of the intervention (overall RR 1.02 [95% CI, 0.94 to 1.09]; k=15; n=4606; I^2^=3%).^108^

#### E-Cigarettes

We identified no trials that addressed the use of e-cigarettes to quit smoking among pregnant women that met our eligibility criteria.

### Key Question 3 What Harms Are Associated With Tobacco Cessation Interventions in Adults, Including Pregnant Women?

#### Pharmacotherapy Interventions

##### Nicotine Replacement Therapy – Trial Evidence

Given the low number of trials and high statistical heterogeneity, we did not report pooled analyses for health outcomes that could also be evaluated as potential harms of NRT treatment (e.g., stillbirth). The available trials (Table 10) were underpowered for assessing rare harms with statistical confidence.^167,^ ^168,^ ^171,^ ^174–176,^ ^178^ As reported above, significant effects of NRT on health outcomes included beneficial effects for some individual studies, including higher birthweight in two trials^174,^ ^178^ and reduced risk of preterm birth in one.^174^ Three trials reported miscarriage by study arm, but there were too few events in the study arms to draw valid inference and no difference was evident.^167,^ ^168,^ ^175^

The two large, good-quality NRT patch trials reported detailed maternal adverse events.^167,^ ^168^ In the Berlin trial, there was insufficient statistical power to assess the statistical significance of the observed 4 percent difference in having one or more serious maternal adverse event (NRT 12%, placebo 8%).^167^ The trial did, however, report a statistically significant 0.02 mm Hg per day rise in diastolic blood pressure over time in the trial among NRT compared with placebo allocated participants (p=0.01). Reported cases of preeclampsia were few, but consistent with the differences in blood pressure, preeclampsia was diagnosed among more women in the NRT condition than the placebo control (3/203 vs. 1/199).^167^ The Coleman trial, however, did not find differences in high blood pressure readings on at least two occasions between study groups and reported slightly fewer cases of preeclampsia/eclampsia in the intervention group (3/521 versus 5/529), although again, event rates were too low to establish a valid association.^168^ The two largest trials reported that the most common adverse event was skin reaction at the patch site, with higher rates in the active NRT patches—nearly 9 percent of NRT users in the one RCT discontinued treatment due to the reaction.^167,^ ^168^

Fetal and infant harms were reported as individual outcomes and composite measures with variable definitions. In the Coleman study, a composite measure of any serious adverse event, defined as any miscarriage, stillbirth, neonatal or post neonatal death, was higher in the NRT intervention group (9/521) vs. placebo (6/529), but precision was too low to assess statistical differences.^168^ A composite outcome of any serious adverse event was also reported in the 2008 Oncken trial and included birth outcomes, miscarriage, stillbirth, and neonatal death as well as neonatal or maternal hospitalization.^174^ More serious adverse events were observed in the placebo condition than in the intervention group, and the difference approached statistical significance (NRT 24/97, placebo 33/87, p=0.06), with much of the difference attributed to lower rates of preterm birth and low birthweight in the intervention group.^174^ A similar composite outcome was reported in the Pollak trial (preterm birth, NICU admissions, small-for gestational age, placenta abruption, fetal demise), with more events found in the intervention group (NRT 30.1%, 34/113 versus placebo 17.2%, 10/58, risk difference 0.13 [95% CI, 0.00 to 0.26]).^176^ Adjustment for previous preterm birth narrowed the risk difference (RD=0.09 [95% CI, 0.05 to 0.21]).^176^

In the two larger studies reporting counts of stillbirths, nine occurred in the NRT arms and seven occurred in the placebo control groups (1.3% versus 1.0% respectively).^167,^ ^168^ Three trials reported neonatal deaths;^167,^ ^168,^ ^174^ there were a total of three cases in the intervention arms and four cases in the control arms in the trials. Congenital malformations were reported in the Berlin and Coleman trials, with fewer cases occurring in the NRT group for both studies (Berlin, NRT 4/203 versus placebo 6/203; Coleman, NRT 9/507 versus placebo 13/517).^167,^ ^168^ Between group differences were lower than 1 percent, however, and the confidence intervals crossed null.^167,^ ^168^

The 2-year followup data from the Coleman SNAP trial described for KQ1 did not find evidence of longer-term developmental or respiratory harms associated with NRT use during pregnancy compared with a placebo.^170^

##### Bupropion – Trial Evidence

We identified no trials that addressed the benefits or harms of bupropion among pregnant women that met our eligibility criteria.

##### Varenicline – Trial Evidence

We identified no trials that addressed the benefits or harms of varenicline among pregnant women that met our eligibility criteria.

##### NRT, Bupropion, and Varenicline – Observational Evidence

We included five cohort studies (4 good quality, 1 fair quality), reported in 6 publications, that evaluated the association between gestational use of a smoking cessation medication and risk of adverse fetal and maternal outcomes (Table 10).^179–184^ Two studies examined exposure to NRT only, one study examined exposure to NRT or bupropion, one study focused on varenicline, and the final study examined exposure to NRT, bupropion, or varenicline. Most studies included two compactors: women who smoked but did not use the cessation medication and non-smoking women or ex-smokers. Here we focus on those who used or were prescribed a smoking cessation medication compared with those who were current smokers. Collectively, there was no evidence of increased risk of premature delivery, small-for-gestational age, stillbirth, congenital anomalies, associated with the use of NRT, bupropion, and varenicline versus smoking.^179–184^

A good quality cohort study using the Quebec Pregnancy cohort data found a lower risk of premature delivery (<37 weeks’ gestation) with NRT (adjusted OR, 0.21 [95% CI, 0.13 to 0.34], n=316) and bupropion (adjusted OR, 0.12 [95% CI, 0.03 to 0.50], n=72) compared with women who smoked during pregnancy but did not take either medication (n=900).^179^ NRT patch use was associated with a significant reduction in the risk of small for gestational age (≤10^th^ percentile for gestational age birthweight) when compared with smoking (adjusted OR, 0.61 [0.41 to 0.90]). Gestational exposure to bupropion was not statistically significantly associated with small for gestational age when compared with smoking (adjusted OR, 0.97 [95% CI, 0.50 to 1.89]).^179^

A fair-quality cohort study conducted in the United Kingdom using the Health Improvement Network database analyzed data from 220,630 singleton pregnancies to assess whether NRT exposure during pregnancy could be associated with stillbirth.^181^ A related article reported on congenital anomalies for live-born infants (n=192,498) using the same data source and similar comparisons.^180^ Absolute risk of stillbirth was the same (5/1000 births) in women prescribed NRT (n=5221) and those continuing smoking (18,407) and there was no statistically significant difference in the relative risk of stillbirth (adjusted OR, 0.95 [95% CI 0.62 to 1.48]).^181^ Similarly, there was no difference in the risk of major congenital anomalies between women prescribed NRT during pregnancy (n=2677) and those who smoked during pregnancy (n=9980) (odds ratio, 1.07 [99% CI, 0.78 to 1.47], p=0.58).^180^ There was, however, evidence of an increased risk of respiratory anomalies in the NRT group compared with smokers (OR, 3.49 [99% CI, 1.05 to 11.62], p=0.007), however, this finding was based on only 10 NRT-exposed cases.^180^

Longer-term child health outcomes were also assessed in an included good-quality cohort study using Danish National Birth Cohort data (n=84,803).^184^ The study analyzed outcomes for children up to age 14 who were born to women who smoked and for women who used NRT during pregnancy, quit smoking during pregnancy, or did not smoke, and considering whether the father smoked. Diagnosis of attention-deficit hyperactivity disorder (ADHD) after age 5 was the primary outcome. The highest hazard ratio for the development of ADHD during followup was seen for children whose mothers reported using NRT and had nonsmoking fathers (HR 2.26 [ 95% CI 1.48 to 3.51]) with a comparison group of nonsmoking mothers and fathers. However, the results are based on small numbers, resulting in wide confidence intervals and unstable estimates. Only seven ADHD cases were identified among children in the NRT group with a smoking father and 22 ADHD cases among children in the NRT group with a nonsmoking father. The estimate was not statistically significant for children with mothers using NRT and fathers who smoked. There also were several differences between the study groups, some accounted for using statistical adjustments, and likely unmeasured confounders that could account for the differences observed.^184^

A large, good-quality cohort study (n=1,017,731) conducted in two states in Australia examined whether use of NRT, bupropion, or varenicline during pregnancy compared with a propensity score-matched unexposed group was associated with risk of adverse perinatal and major congenital anomalies.^183^ The risk of any adverse perinatal event was not significantly different between NRT-exposed and unexposed (44.8% vs. 46.3%, hazards ratio [HR] 1.02 [95% CI, 0.84 to 1.23]) and bupropion-exposed and unexposed women (39.2% versus 39.3%, HR 0.93 [95% CI, 0.73 to 1.19]), but it was significantly lower in women exposed to varenicline (36.9% vs. 40.1%, HR 0.86 [95% CI, 0.77 to 0.97]). Additionally, varenicline-exposed infants were less likely than unexposed infants to be born premature, be small for gestational age, and have severe neonatal complications. Among infants exposed to varenicline in the first trimester, 2.9% had a major congenital anomaly vs. 3.5% in unexposed infants (HR 0.91 [95% CI, 0.72 to 1.15]).^183^

Finally, a good-quality population-based cohort study in Denmark and Sweden compared the risk of congenital malformations from birth to the first year of life among infants whose mothers were dispensed varenicline during pregnancy versus infants whose mothers were unexposed to varenicline, but exposed to maternal smoking in utero.^182^ Major congenital malformations were detected among 3.6 percent of exposed infants vs. 4.3 percent of unexposed infants (adjusted OR, 0.80 [95% CI 0.545 to 1.42). Furthermore, there was no increased risk of other adverse birth outcomes such as stillbirth, fetal growth restriction, or preterm delivery.^182^

#### Behavioral Interventions

The Chamberlain review found that behavioral smoking cessation interventions have minimal adverse effects, including the possibility of a paradoxical effect (i.e., increased smoking).^185^ Four studies that measured whether women increased their smoking following exposure to the intervention showed mixed results with two studies reporting an increase in smoking behavior among women who did not quit. Thirteen trials reported postintervention psychological outcome measures, and none reported any negative psychological effects. Other potential harms of these interventions were sparsely reported, and none suggested an increase in AEs.^185^

#### E-Cigarettes

We identified no trials that addressed the harm of e-cigarettes among pregnant women that met our eligibility criteria.