# Chapter 2 Methods

## Scope and Purpose

This is an update of our 2015 review.^70,^ ^71^ Consistent with that review, we relied primarily on an overview of reviews method for this update. In general, an overview of reviews focuses on a broad condition or problem for which there are two or more potential interventions. The overview of reviews approach was the most appropriate approach for our update because of the large number of tobacco cessation trials and the availability of multiple systematic reviews on the subject. To conduct this overview of reviews, we: 1) searched for reviews; 2) selected reviews; 3) assessed the credibility of the reviews; 4) determined the use of reviews; 5) abstracted review details and findings; and 6) synthesized findings across reviews. A typical Analytic Framework, Key Questions (KQs), and inclusion/exclusion criteria are outlined as they relate to the objectives of the overview of reviews. We did not search for original research (with the exceptions noted below), replicate quality rating or data abstraction of original studies, or replicate review-specific meta-analyses.

Evidence for pregnant women was synthesized separately from evidence for the general adult population given the unique health risks of tobacco smoking for both women and children, physiological differences during pregnancy that can affect nicotine withdrawal symptoms, generally higher motivation to quit among pregnant than nonpregnant adults, and the potential different benefits and harms of various cessation treatments.

Given the 2015 USPSTF conclusions of insufficient evidence for 1) the benefits and harms of e-cigarettes for tobacco cessation and 2) the benefits and harms of pharmacologic tobacco cessation interventions among pregnant women, we decided a priori to conduct a de novo systematic review (i.e., an original search and synthesis of primary evidence) related to these specific areas. In addition, before initiating our review, we established that we would consider a search for primary research for specific interventions and/or questions if no recent (2014-present) reviews were identified for the topic.

## Key Questions and Analytic Framework

With input from the USPSTF, we developed an Analytic Framework (Figure 1) and three KQs, using the USPSTF’s methods to guide the literature search, data abstraction, and data synthesis.

Figure 1 Analytic Framework

Figure 1 is an analytic framework that depicts three Key Questions to be addressed in the systematic review. The figure illustrates how tobacco cessation interventions may result in improved mortality, morbidity, and other health outcomes in adults who currently use tobacco, including pregnant women (Key Question 1), and how tobacco cessation interventions may result in increased tobacco abstinence in adults who currently use tobacco, including pregnant women (Key Question 2). Additionally, the figure addresses how tobacco cessation interventions may be associated with any harms in adults, including pregnant women (Key Question 3).

1. Do tobacco cessation interventions improve mortality, morbidity, and other health outcomes in adults who currently use tobacco, including pregnant women?
2. Do tobacco cessation interventions increase tobacco abstinence in adults who currently use tobacco, including pregnant women?
3. What harms are associated with tobacco cessation interventions in adults, including pregnant women?

## Data Sources and Searches

We searched the following databases for relevant systematic reviews through April 2019 (with active surveillance through September 2020): PubMed, PsycINFO, the Database of Abstracts of Reviews of Effects, the Cochrane Database of Systematic Reviews (CDSR), and the Centre for Reviews and Dissemination Health Technology Assessment (Appendix A). In addition to these database searches, we searched the websites of the following organizations: AHRQ, the Canadian Agency for Drugs and Technologies in Health, CDC’s Guide to Community Preventive Services, Health and Medicine Division of the National Academies (formerly the Institute of Medicine), the NHS Health Technology Assessment Programme, and the U.S. Surgeon General. We restricted our searches to articles in the English language published since January 2014. We also examined the reference lists of all our included reviews to identify other reviews for inclusion. We supplemented our searches with suggestions from experts and reviews identified through news and table-of-contents alerts from sources such as ScienceDirect (Elsevier, Maryland Heights, MO) and Tobacco Control. We also searched for potentially relevant in-process or planned reviews as indicated by review protocols through AHRQ, CDSR, and the Centre for Reviews and Dissemination PROSPERO register.

In addition to the search for reviews, we conducted two separate searches for primary evidence.

The first search focused on studies addressing the use of e-cigarettes for tobacco cessation. We conducted searches in the following databases: CDSR, Cochrane Central Register of Controlled Clinical Trials (CENTRAL), PsycInfo, PubMed, and Scopus, from January 2014 through May 2020 (Appendix A).

The second search centered on pharmacotherapy tobacco cessation interventions among pregnant women; we conducted searches in Medline, CENTRAL, PubMed, PsycInfo from January 2014 through May 2020 (Appendix A).

We conducted ongoing surveillance for relevant primary literature through January 23, 2020 and for Cochrane systematic reviews through September 25, 2020 and have updated the review with new evidence as it is published.

We also reviewed the reference lists of related systematic or narrative reviews to identify studies for potential inclusion and searched ClinicalTrials.gov for relevant ongoing trials that were listed as “recruiting,” “active, not recruiting,” “not yet recruiting,” “completed,” or “terminated” to identify any studies underway that might be of relevance for ongoing evaluation.

We imported the literature from these sources directly into EndNote® X9.

## Study Selection

We developed criteria for inclusion and exclusion of systematic reviews based on our previous review (Appendix A Table 1). Generally, we included studies if they were systematic reviews, with or without meta-analysis, that: 1) examined the effectiveness of tobacco cessation interventions for adults and 2) were published in English from January 2014 to present. We included reviews focused on specific interventions (e.g., NRT, group counseling) and specific subpopulations (e.g., persons with serious mental illness). We considered reviews published by Cochrane as well as other non-Cochrane reviews. We excluded nonsystematic narrative reviews and other reviews of reviews. We excluded reviews that only or primarily evaluated interventions among children and adolescents and broader public health strategies. We included only the most recent version of updated reviews.

We outlined separate inclusion and exclusion criteria when considering primary evidence related to e-cigarettes and pharmacotherapy interventions among pregnant women. For primary evidence related to the benefits (KQ 1–KQ 2) and safety (KQ 3) of e-cigarettes, we included randomized controlled trials (RCTs) in which smokers were randomized to e-cigarettes or a control condition, such as a placebo/placebo device, a no-intervention condition, or another active tobacco cessation intervention (e.g., NRT, counseling). We included cohort studies with sample sizes of 1,000 participants or more. We included studies only if they reported a health outcome (KQ 1) or a measure of tobacco abstinence (KQ 2) at least 6 months after baseline assessment or adverse events (AEs) (KQ 3) at any point after treatment started. We excluded studies that only reported intermediate smoking outcomes (e.g., desire to smoke, withdrawal symptoms, quantity of cigarettes smoked). We required that studies take place in developed countries defined as “very high” on the 2015 Human Development Index (HDI) of the United Nations (http://hdr.undp.org/en/statistics).

For pharmacotherapy interventions among pregnant women, we used the criteria outlined in the review by Coleman and colleagues.^72^ Accordingly, we included RCTs that permitted assessment of the independent effects of any type of first-line pharmacotherapy on smoking cessation. Included trials also had to provide very similar (or identical) levels of behavioral support to participants in the treatment and control groups. In addition, and unique from the Coleman review, we included large cohort studies (n>1000) that compared pregnant women who were exposed versus not exposed to medications for smoking cessation. We excluded quasi-randomized, crossover, and within-participant designs, and required that studies take place in countries deemed “very high” on the Human Development Index.

Two reviewers independently screened the abstracts and titles of all records identified in the searches, using the inclusion and exclusion criteria as a guide for identifying eligible studies. Subsequently, two reviewers assessed the full text of potentially relevant systematic reviews and primary studies using a standard form outlining the eligibility criteria. We resolved disagreements through discussion, although disagreements were minimal and easily resolved. All reviews were conducted in DistillerSR (Evidence Partners, Ottawa, Canada). We kept detailed records of all included and excluded studies (and reasons for exclusion) during full-text review.

## Quality Assessment and Data Abstraction

We used the AMSTAR 2 (Assessment of Multiple Systematic Reviews) tool to rate the credibility of the systematic reviews under consideration for inclusion.^73^ The AMSTAR 2 tool contains 16 items that relate to the planning and conduct of the review (Appendix A Table 2). We rated our overall confidence in the results of each review according to published guidance: a rating of “high” reflects that the review had zero or one noncritical weakness; “moderate” indicates the review was judged to have more than one noncritical weakness; “low” means the review was judged to have one critical flaw with or without noncritical weaknesses or multiple noncritical weaknesses; and “critically low” signifies that more than one critical flaw was present. In line with USPSTF criteria for primary evidence, we excluded reviews rated as critically low because they would not provide an accurate and comprehensive summary of the available evidence. We included low credibility reviews but rarely relied on them for the main results. One reviewer completed the AMSTAR 2 tool for all provisionally included reviews, and for all reviews that were rated critically low a second reviewer provided an independent assessment with the same tool.

For individual studies, we used criteria developed by the USPSTF to assess the quality of included evidence (Appendix A Table 2).^74^ We examined potential risks of bias, including randomization and measurement procedures (including blinding and consistency between groups); comparability of the groups at baseline; overall and group-specific attrition; intervention fidelity; and the appropriateness of the statistical procedures, including methods for handling missing data. At least two independent reviewers assessed the quality of the primary evidence, and we resolved discrepancies through consultation with a third reviewer and discussion. We applied the typical USPSTF quality scores (i.e., good quality, fair quality, or poor quality) after reviewing the number and seriousness of the threats to validity. Those rated as poor quality contained a serious flaw or flaws that we felt likely biased or invalidated the results and were excluded from this review.

We abstracted data from each included review and primary study into detailed abstraction forms using DistillerSR. For all included evidence, one reviewer completed primary data abstraction, and a second reviewer checked all data for accuracy and completeness.

## Data Synthesis and Analysis

Given the large number of reviews that met our eligibility criteria and the overlapping scope and evidence between many of them, we developed a method to identify one or more reviews within each population and intervention subgroup that represented the most current and applicable evidence. These reviews serve as the basis for the main findings (called primary reviews hereafter). Box 1 describes the full set of criteria we applied to identify the primary reviews for each population and intervention. First, we categorized all included reviews according to the type of tobacco cessation intervention (i.e., distinct types of pharmacotherapy, behavioral, and/or combination interventions) and population (e.g., adults, pregnant women). Within each group, we listed the reviews in chronological order by the last search date (some reviews were listed more than once in the table if they addressed multiple populations or intervention types). Next, we compared the included studies within each review to evaluate comprehensiveness and noted concordance and discordance in the included primary literature. When we encountered highly discordant bodies of evidence, we sought an explanation for the difference by examining the inclusion and exclusion criteria. For example, if the most recent review for a given category did not appear to be the most comprehensive review in terms of the number of included studies, we examined to what extent the inclusion criteria (e.g., allowable study designs, outcomes of interest) may have influenced the discrepancy in included studies. We also looked at individual included studies as necessary to ensure that the potential primary reviews did not omit important studies. Finally, we reviewed the inclusion and exclusion criteria and data analysis procedures of each review to determine the most applicable evidence. We reviewed the remaining reviews for complementary or discordant findings. In general, the results across reviews within each population and intervention grouping were consistent with one another and thus, we do not elaborate on these consistencies within the results.

Box 1 Criteria for Choosing Primary Systematic Reviews Compared With Other Reviews for the Same Population and Intervention Group

1. The search strategy is more up to date.
2. The included studies apply inclusion/exclusion criteria that offer the most relevant and credible evidence (i.e., based on included study designs, populations, comparators, setting, followup >6 months, and outcomes).
3. There are more (or an equal number of) included studies of the ideal study design
4. Appropriately conducted pooled results are presented, with or without meta regression or subgroup analysis.
5. The quality of the review is better.

We summarized the characteristics of the primary evidence reviews in evidence tables but did not reanalyze individual study data. Instead, we reported the pooled analyses and existing point estimates presented in the included reviews. For reviews that included meta-analyses, we conducted comparisons of the pooled estimates of efficacy for each intervention versus comparator and took the definition of abstinence (continuous, point prevalence) and the length of followup into consideration. When extracting pooled estimates from the reviews, we considered the statistical validity of the available meta-analytic results. We also presented subgroup results related to the intensity or type of intervention, when available. We evaluated the appropriateness of meta-analytic procedures and used our technical judgment to interpret pooled analyses accounting for limitations or concerns from heterogeneity, statistical approaches, or other factors.

In anticipation of sparse reporting of health outcomes (KQ 1), we decided a priori to synthesize any data related to health outcomes qualitatively. The primary outcome for KQ 2 was smoking cessation at 6 months’ or longer followup using the strictest definition of abstinence available in each review. We abstracted results at both 6 and 12 months’ followup if the reviews presented both. In most cases, the reviews reported the “longest followup” result and required at least 6 months’ followup. The preferred outcome in most reviews was continuous abstinence (i.e., completely abstinent from quit date to followup allowing for up to five cigarettes) or prolonged abstinence (i.e., typically allows a “grace period” following the quit date to allow for lapses) over point prevalence abstinence (i.e., abstinent at a particular point in time such as 7 or 30 days before followup and thus includes a mix of recent and continuous quitters).^75^ Biochemical verification of self-reported abstinence was not required in most reviews, but validated outcomes were used when reported. All included reviews used analyses based on intention-to-treat principles in which participants lost to followup who could not be classified definitively as nonsmokers were counted as smokers.^75^

To evaluate health outcomes in pregnant women and neonates, we analyzed outcomes for all RCTs regardless of the control condition. Due to high statistical heterogeneity, we do not provide pooled effect estimates. Instead, we present descriptive forest plots comparing the NRT and control conditions for key reported perinatal health outcomes (preterm birth, low birthweight, stillbirth, birthweight) and narratively describe the results of the individual studies. The calculated relative risks are presented for most outcomes, but for low birthweight, the odds ratios were calculated for some trials and combined with study reported odds ratios to allow for comparisons of this outcome across all studies reporting the outcome. For some studies, data necessary for comparing health outcomes were not available in the primary studies. In such instances, we used data reported in a recent Cochrane review that directly contacted study authors for relevant data.^72,^ ^76^

For computing a pooled estimate across the included trials for pharmacotherapy smoking cessation among pregnant women, we used the DerSimonian and Laird model for pooling relative risks (RR) and used a restricted maximum likelihood model with the Knapp-Hartung correction for small samples to estimate the 95% CI interval.^77^ We used Stata version 15.1 (StataCorp LP, College Station, TX) for all analyses. All significance testing was 2-sided, and results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ as follows. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect.

For our overview of reviews method, we adopted the strength of the overall body of evidence assigned within the primary systematic review. In most cases, these grades were based on the Grading of Recommendations Assessment, Development and Evaluation (GRADE) working group definitions, which consider study limitations, consistency of effect, imprecision, indirectness and publication bias. Where strength of evidence grades were not available, including for our own primary evidence syntheses, we adapted the EPC approach – which generally aligns with GRADE methodology – to assign an overall strength of evidence grade based on consensus discussions involving at least two reviewers.^78^

## Expert Review and Public Comment

A draft Research Plan was posted on the USPSTF Web site for public comment from March 14 through April 11, 2018. In response to public comment, the USPSTF made the following changes to the research plan. First, reviews focused on relapse prevention interventions are included. Second, the USPSTF clarified that the target condition includes use of any tobacco product, as regulated by the FDA, including cigarettes, roll-your-own tobacco, smokeless tobacco, cigars, pipe tobacco, dissolvables, smoking tobacco through a hookah or waterpipe, and e-cigarettes. Reviews limited to or including cessation of any of these tobacco products are included. Third, reviews limited to specific subpopulations of adults with high prevalence of tobacco use or at risk of tobacco use-related morbidity are included, as are results from credible subgroup analyses. Last, reviews of medications that are not approved as first-line tobacco cessation medications but are used off-label and are available in the United States are included. The USPSTF made other minor modifications and clarifications as appropriate, including clarifying that any intervention that takes place in primary care or that can feasibly be referred to from primary care are included. A final research plan was posted on the USPSTF Web site on July 26, 2018. We made no deviations from the final research plan in the conduct of this review.

A draft version of this report was reviewed by content experts, representatives of Federal partners, USPSTF members, and an AHRQ Medical Officer. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report. Additionally, a draft of the full report was posted on the USPSTF Web site from June 2, 2020 to June 29, 2020. A few comments were received during this public comment period. All comments were read and considered; minor editorial changes were made to the report based on these comments, but no changes were made to the evidence or to our conclusions.

## USPSTF Involvement

We worked with four USPSTF members at key points throughout this review, particularly when determining the scope and methods and developing the Analytic Framework and KQs. The USPSTF members approved the final Analytic Framework, KQs, and inclusion and exclusion criteria after revisions reflecting the public comment period. AHRQ funded this review under a contract to support the work of the USPSTF. An AHRQ Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.