# Chapter 1 Introduction

## Purpose

The Agency for Healthcare Research and Quality (AHRQ) has requested an updated evidence report on tobacco cessation interventions for adults and pregnant women. This report will be used by the United States Preventive Services Task Force (USPSTF) to update its 2015 recommendation on behavioral and pharmacotherapy interventions for tobacco smoking cessation in adults, including pregnant women.^1^

## Condition Definition

Tobacco is a plant grown for its leaves, which are dried before being put in tobacco products. Tobacco contains nicotine, an ingredient that causes addiction, as well as many other harmful chemicals within the tobacco itself or created by burning it. Tobacco can be consumed in many combustible configurations including cigarettes, pipes, cigars, cigarillos, little cigars, bidis (tobacco wrapped in tendu or temburni leaves), kreteks (clove cigarettes), roll-your-own tobacco products, and through a hookah or waterpipe and noncombustible formats including chew, snuff including snus, nicotine pouches, nicotine gels, and dissolvable tobacco as strips, sticks, or lozenges.. Effective August 2016, the United States Food and Drug Administration (FDA) extended its regulatory authority to all other products made from or containing nicotine derived from tobacco, including electronic nicotine delivery systems (ENDS) (e.g., electronic cigarettes [e-cigarettes], e-hookah, e-cigars, vape pens, advanced refillable personal vaporizers, and electronic pipes) as well as components or parts intended or reasonably expected to be used with tobacco products or tobacco-derived nicotine. E-cigarettes intended for medical therapeutic purposes are subject to FDA regulations related to pharmaceuticals and medical devices rather than FDA regulations related to tobacco products. Companies that wish to make such claims must apply to the FDA’s Center for Drug Evaluation and Research.^2,^ ^3^ Currently, no e-cigarettes are approved for therapeutic use as smoking cessation devices. In this review, given the regulatory environment in the U.S. regarding e-cigarettes, the use of e-cigarettes is included as both a tobacco product (for which we sought evidence related to quitting e-cigarette use) and as a potential smoking cessation aid (for which we sought evidence related to using e-cigarettes to quit combustible smoking).

Electronic nicotine delivery systems are a diverse group of products that produce a heated aerosol that users inhale from a mouthpiece. Electronic cigarettes (i.e., e-cigarettes or e-cigs) range in design but share certain components: a battery, heating coil, atomizer (transforms e-liquid to an aerosol), cartridge containing the e-liquid, and a mouthpiece. Users draw on the mouthpiece, activate the heating element, and inhale the aerosol. The liquid solution (i.e., e-liquid, juice) contains propylene glycol and/or glycerol (glycerin), with various levels of nicotine (including no nicotine).^4^ Other components of the solution can include water and various additives including flavorings that vary among brands in presence and amount.^4^ Early generation devices closely resembled cigarettes and were disposable or partly disposable; second-generation devices (i.e., vape pens) are rechargeable (most have a USB charger) and have customizable looks and tip.^5^ Later designs reflect a diverse set of products that may be square or rectangular and bear little resemblance to cigarettes. Many can be customized by the user and are referred to as modified vape devices (mods).^5^ Box-style mods allow greater customization (e.g., wattage, temperature control) and are generally larger and more powerful than the previous two e-cigarette types. The more recent generation of e-cigarettes, including JUUL, Suorin and NJOY Ace, retail brands of e-cigarettes shaped like USB drives, are smaller and simpler than mods and are not refillable but use a pod that clicks onto the device to deliver the e-fluid (often referred to as pod mods). These devices typically have higher nicotine concentrations and utilize nicotine salts, which allows for higher levels of nicotine to be more palatably inhaled than free-base nicotine and can increase the rate of nicotine delivery as compared with earlier generations of e-cigarettes.^6,^ ^7^ Sales of JUULs increased markedly from 2015 to 2017, and JUUL is now the largest retail brand of e-cigarettes in the United States, accounting for more than half of the market share in tracked retail channels.^8,^ ^9^ Because e-cigarettes are developed by a variety of manufacturers, the contents vary widely and in some cases are not consistent with product labeling.^4,^ ^10–12^

Tobacco dependence refers to a psychologic state typified by tolerance and withdrawal where the body is dependent on nicotine for normal function. According to the Diagnostic and Statistical Manual of Mental Disorders (fifth edition, DSM-5), a tobacco use disorder is diagnosed when an individual uses tobacco for more than a year and a minimum of two features that relate to nicotine tolerance, withdrawal symptoms, and social and behavioral factors related to use (e.g., failure to attend to responsibilities and obligations due to tobacco use, continue use despite adverse social or interpersonal consequences).^13^ In light of the significant harm that can result from even low-level exposure to cigarette smoke, both chronic tobacco use and dependence warrant clinical intervention.^14^

## Prevalence and Burden

Tobacco smoking is the leading preventable cause of disease, disability, and death in the United States. According to a 2014 Surgeon General’s Report, cigarette smoking and exposure to tobacco smoke resulted in more than 480,000 premature deaths annually in the United States.^15^ Combustible cigarette smoking causes various forms of cancer, cardiovascular disease, respiratory disease, reproductive disorders, and other adverse consequences. Fifty years after the 1964 Surgeon General’s report was published, research continues to identify diseases caused by cigarette smoking, including diabetes mellitus, rheumatoid arthritis, colorectal cancer, erectile dysfunction, tuberculosis, and congenital defects.^15^ In addition to causing multiple diseases, cigarette smoking can cause inflammation and impair immune function.^15^ Smoking during pregnancy is known to be causally related to higher risks of miscarriage, stillbirth, preterm birth, fetal growth restriction, placental abruption, certain congenital anomalies, and impaired lung function in childhood and beyond.^15–18^

There has been progress over the past several decades in reducing the use of tobacco products by U.S. adults. In 2019, an estimated 20.8 percent (50.6 million) of adults in the United States currently used any tobacco product.^19^ Combustible tobacco products were used by 80.5 of current tobacco product users and 18.6 percent of the same population reported use of two or more tobacco products. The most commonly used tobacco product was combustible cigarettes (34.1 million; 14.0%).^19^ Estimates regarding current use of other tobacco products among adults in 2019 were: e-cigarettes, 4.5 percent (10.9 million); cigars, 3.6 percent (8.7 million); smokeless tobacco, 2.4 percent (5.9 million); and pipes, 1.0 percent (2.4 million).^19^

According to findings from the nationally representative Behavioral Risk Factor Surveillance System, the overall current e-cigarette use prevalence rose from 4.5 percent (approximately 11.2 million adults) to 5.4 percent (approximately 13.7 million adults) in 2016 and 2018 respectively.^20^ The largest increase in prevalence occurred within the younger age group (18–24 years of age), which rose from 9.2 percent to 15.0 percent in 2016 to 2018 respectively. According to the same survey data, in 2018, e-cigarette use was highest among males (6.9%), young adults ages 18 to 24 (15.0%), respondents identifying their race as “other” (6.4%) and white (5.8%), those identifying as bisexual (12.5%) or lesbian/gay (10.7%), respondents with high school and some college education (6.6%), respondents below the poverty line (6.9%) and respondents reporting current combustible cigarette us (14.7%).^20^

Despite a reduction in tobacco product use in U.S. adults, during 2017–2018, the prevalence of current us of any tobacco product increased by 38 percent among high school students (from 19.6% to 27.1%) and by 29 percent among middle school students (from 5.6% to 7.2%).^21^ The increase in tobacco use seen in this time period was driven by the considerable rise in e-cigarette use. Data from the 2011–2018 National Youth Tobacco Survey (NYTS), found that among high school students, current e-cigarette use increased from 1.5 percent in 2011 to 20.8 percent in 2018; with a 78 percent increase just between 2017 (11.7%) to 2018 (20.8%).^21^ Similarly, for young adults ages 18 to 24 years, a significant increase in self-reported e-cigarette use was seen between 2017 (5.2%) and 2018 (7.6%) (difference, 2.4% [95% CI, 0.4% to 4.4%]) whereas there was no change among adults aged 25 to 44 years and a nonsignificant decrease in those aged 45 to 64 and 65 and older.^22^

Among adults, persistent disparities in tobacco use exist by age, sex, race/ethnicity, sexual orientation, education, income level, insurance and disability status, psychological status, and region.^19^ In 2019, prevalence of current tobacco product use was higher among those ages 25 to 44 years (25.3%), 45 to 64 years (23.0%), and 18 to 24 years (18.2%) than among those age ≥65 years (11.4%), and higher among males (26.2%) than females (15.7%). By race and ethnicity, current tobacco use prevalence was highest among American Indian/Alaska Natives (29.3%), followed by non-Hispanic adults of other races (28.1%), whites (23.3%), and blacks (20.7%), Hispanic or Latino adults (13.2%), and Asians (11.0%). Prevalence of tobacco use was also higher among adults who were lesbian, gay, or bisexual (29.9%) than among heterosexual adults (20.5%). Prevalence also varied by education and income levels: It was higher among adults who had a GED (43.7%) than among those who had completed any other levels of education (ranging from 26.4% in those with 0–12 year of education (with or without a high school diploma) to 8.7% in those with a graduate degree), and higher among those who had an annual household income of <$35,000 (27.0%) than among those with higher incomes (ranging from 15.1% in those with annual household incomes ≥$100,000 to 22.0% in those with annual household incomes between $35,000 and $74,000). In 2019, there was higher prevalence of tobacco product use among those who were uninsured (30.2%), those insured by Medicaid (30.0%), or had other public insurance (25.6%) than among people covered by private health insurance (18.0%) or Medicare only (11.4%). Prevalence was also higher among those who had a disability/limitation (26.9%) than among those who did not (20.1%), as well as among those who had Generalized Anxiety Scores (GAD-7) indicating mild (30.4%), moderate (34.2%), or severe (45.3%) anxiety than among those indicating no or minimal anxiety (18.4%). Additionally, by U.S. region, the Midwest (23.7%) and South (22.9%) had higher prevalence of tobacco product use than the West (16.4%) or Northeast (18.5%).^19^

Among pregnant U.S. women who gave birth in 2016, 7.2 percent reported smoking cigarettes while pregnant.^23^ The prevalence of smoking during pregnancy was highest among women ages 20 to 24 years (10.7%), followed by women ages 15 to 19 (8.5%) and 25 to 29 years (8.2%). Additionally, prevalence of smoking during pregnancy was highest for women with a high school diploma or GED (12.2%), followed by women with less than a high school diploma (11.7%) and women with some college or an Associate degree (7.9%) while prevalence was lowest among women with a master’s degree of higher (0.4%). Similar to trends in the general adult population, Non-Hispanic American Indian or Alaska Native women had the highest prevalence of smoking during pregnancy (16.7%), followed by white women (10.5%), black (6.0%), Native Hawaiian or other Pacific Islander (4.5%), Hispanic women (1.8%) and Asian women (0.6%).^23^ Additionally, from 2014 to 2017, 3.6 percent of pregnant women ages 18 to 44 years reported current use of e-cigarettes, a proportion that was not statistically significantly different among non-pregnant women in the same age group (3.3%).^24^

According to 2016–2018 Behavioral Risk Factor Surveillance System Survey data, approximately 2.2 percent of adult pregnant women (ages 18 to 49) reported current e-cigarette use.^25^ The prevalence of current e-cigarette use among pregnant women was highest among the younger age group, aged 18 to 24 years (3.2%), followed by pregnant women ages 25 to 29 years (2.3%). In addition, the prevalence of current e-cigarette use among pregnant women was highest in those reporting white race (63.3%), single marital status (57.6%), high school and some college education (66.6%), and employed (61.7%). The prevalence of current e-cigarette use among this population almost doubled from 2016 to 2018 (1.9% and 3.8% respectively).^25^

## Etiology and Natural History

Initiation of cigarette smoking typically begins in early adolescence at an average age of 15 years.^17^ Data suggest that smoking prevalence in adolescents increases over time, peaks during young adulthood, and then declines as individuals age. This trajectory may vary, however, given differences in age at initiation of smoking, time to progress to daily smoking, and dependence symptoms. About one-third of individuals who have ever tried cigarette smoking become daily smokers.^17^ Among adolescents, symptoms of dependence have been reported at even low levels of cigarette consumption (e.g., two cigarettes once a week).^26,^ ^27^

Tobacco dependence is a chronic condition and the majority of users make multiple quit attempts before achieving lasting success.^28^ According to the NHIS, approximately two-thirds of all people who smoked cigarettes in 2015 (68%) reported they were interested in quitting smoking, and 55.4 percent of these smokers had made a quit attempt during the previous year, although less than one-third had used evidence-based cessation treatments and less than one in 10 were successful in quitting in the previous year.^29^ One study estimated that 22 percent of smokers relapsed within 3 months;^30^ however, long-term follow-up is recommended because successful quitters remain at risk of relapse for several years after smoking cessation.

Research shows that the appearance of withdrawal symptoms early in the quit-attempt period is negatively associated with the ability to remain abstinent and avoid relapse.^17^ On average, a second lapse (i.e., one instance of smoking, even a puff) occurs with 24 hours of the first lapse, and lapse to relapse (i.e., return to one’s baseline level of smoking) occurs 3 to 5 weeks after the cessation attempt.^17^ Factors associated with relapse include higher severity of nicotine dependence, daily smoking onset at younger age, higher number of prior quit attempts, being female, presence of psychiatric symptoms (mainly anxiety and depression symptoms), and higher body mass index.^17^ The rate of relapse is inversely related to the duration of continuous abstinence (i.e., the risk of relapse decreases with longer abstinence). For example, one study found the relapse rate among those who achieved up to 11 months of abstinence was consistently above 50 percent, dropping to 36 percent after 2 years of abstinence and 25 percent after 5 years of abstinence, then stabilizing at around 10 percent after 30 years of abstinence.^31^

## Tobacco Cessation Interventions

Various pharmacological and behavioral methods are available to assist adults quit tobacco use. Behavioral interventions and pharmacotherapy are believed to have complementary modes of action and independently increase the chances of maintaining long-term abstinence.^14^

### Pharmacotherapy Tobacco Cessation Interventions

Seven FDA-approved over-the-counter (OTC) and prescription medications for treating tobacco dependence are available.^32^ These include three OTC nicotine replacement therapy (NRT) products (transdermal nicotine patches, nicotine lozenges, and nicotine gum), two prescription-only nicotine replacement therapy products (nicotine inhaler and nasal spray [Nicotrol®]), and prescription-only bupropion hydrochloride sustained release (Zyban® and generic form; referred to as bupropion hereafter) and varenicline tartrate (Chantix®), neither of which contains nicotine. Although Wellbutrin SR® is not indicated for smoking cessation treatment, it contains the same active ingredient as Zyban®. Other medications are used clinically to treat tobacco dependence, including clonidine (antihypertensive) and nortriptyline (antidepressant), but these are not FDA-approved for smoking cessation.^32,^ ^33^ Cytisine, a partial agonist of nicotine acetylcholine receptors, is available both with and without a prescription in eastern and central Europe^34^ and is widely available internationally (including in the United States) through online vendors although not FDA-approved.^35^

### Behavioral Tobacco Cessation Interventions

Specific behavioral interventions include self-help materials (e.g., written materials, videos, audiotapes, computer), phone-based interventions, quitlines, brief provider-delivered interventions (e.g., advice from a physician or nurse), intensive counseling delivered on an individual basis or in a group setting, mobile phone and text-messaging interventions, biomedical risk assessment, and combinations of these approaches. Behavioral interventions generally aim to teach individuals to recognize high-risk situations and develop coping strategies to deal with them. Complementary and alternative therapies, such as acupuncture, acupressure, laser therapy, electrostimulation, hypnotherapy, and the consumption of herbals (e.g., St. John’s wort), have also been used as tobacco cessation aids alone or as adjuncts to other treatments.

## Electronic Cigarettes

There is a debate in the tobacco control community about the public health impact of e-cigarettes, how best to regulate them, and their role in tobacco cessation.^5,^ ^36^ Because e-cigarettes may offer both nicotine replacement and behavioral and sensory aspects similar to conventional cigarettes without the inhalation of tobacco smoke, they have the potential to serve as a tobacco cessation or harm reduction tool when used by smokers who transition completely to e-cigarettes.^37–39^ Conversely, when taken up by nonsmokers (generally adolescents and young adults), e-cigarettes may serve as a pathway to nicotine addiction and tobacco smoking.^15^ In addition, questions remain regarding the effectiveness of e-cigarettes for tobacco cessation as well as their impact on individual and population health, including the potential for progression to conventional tobacco use among adult nontobacco users, long-term dual use among current smokers, relapse among former smokers, and exposure to harmful or potentially harmful constituents in specific products.^14,^ ^15,^ ^40–43^

## Current Clinical Practice in the United States

In 2015, 68.0 percent of adult smokers wanted to stop smoking, 55.4 percent made a past-year quit attempt, 7.4 percent recently quit smoking, 57.2 percent had been advised by a health professional to quit, and 31.2 percent used cessation counseling and/or medication when trying to quit.^29^ Among smokers who made quit attempts, 6.8 percent reported using counseling, 29.0 percent reported using medication, and 4.7 percent reported using both. Among those who used counseling, 4.1 percent used a telephone quitline, 2.8 percent used one-on-one counseling, and 2.4 percent used a stop-smoking clinic, class, or support group. Among smokers who used a medication to quit, 16.6 percent reported using a nicotine patch, 12.5 percent used nicotine gum or lozenges, 7.9 percent used varenicline, 2.7 percent used bupropion, and 2.4 percent used a nicotine spray or inhaler.^29^

The rates of counseling and treatment vary modestly depending on patients’ age, race/ethnicity, gender, insurance status, health status, physician status, and physician specialty.^44,^ ^45^ Smokers aged 45–64 years (65.7%) and ≥65 years (65.7%) reported a higher prevalence of receiving advice to quit than did smokers aged 18–24 years (44.4%) and 25–44 years (49.8%).^45^ Lower prevalence of receiving advice to quit were reported by Asian (34.2%), American Indian/Alaska Native (38.1%), and Hispanic (42.2%) smokers than by white smokers (60.2%); and by uninsured smokers (44.1%) than by smokers with any type of insurance (range = 56.8%–69.2%). Smokers reporting a disability/limitation or serious psychological distress reported a higher prevalence of receiving advice to quit than did smokers without these conditions (71.8% and 70.2%, respectively, vs 53.6% and 55.7%).^29,^ ^45,^ ^46^ One survey found that patients were more likely to receive counseling from their primary care physician (26.9%) than from other health care providers (15.5%), and internal medicine and cardiovascular disease physicians were more likely to provide tobacco cessation counseling (32.5% and 35.4%, respectively) than family or obstetrics/gynecology physicians (23.5% and 19.7%). Psychiatrists ordered tobacco cessation prescriptions more than any other specialty (17.7%).^45^

A few physician surveys and qualitative studies suggests that physician screening for e-cigarette use is limited, but report that some physicians recommend the use of e-cigarettes as cessation devices. When surveyed in 2013, two-thirds of a sample of 787 North Carolina physicians indicated that e-cigarettes were a helpful aid for smoking cessation, 13 percent incorrectly believed that e-cigarettes were approved by the FDA for smoking cessation, and 35 percent recommended them to their patients.^47^ Conversely, a survey of Kansas family physicians published in 2017 found that 82 percent would not recommend e-cigarettes for smoking cessation.^48^ A national survey of primary care physicians, pulmonologists, surgeons, and anesthesiologists conducted in 2015 found that approximately 54.5 percent agreed with a statement that e-cigarettes could help patients quit smoking, and 37.9 percent have at some point recommended electronic cigarettes to their patients that smoke.^49^

Screening for e-cigarette use varies by practice and risk demographics. A 2012 survey of members of the American College of Obstetricians and Gynecologists (ACOG) found that 53 percent of respondents reported screening pregnant women for chewing tobacco, snuff/snus, e-cigarettes, and dissolvables all or some of the time.^50,^ ^51^ One study of patient-reported screening prevalence from the 2013–2014 National Survey on Drug Use and Health showed that patients with anxiety, depression, and substance abuse disorders were more likely to be screened for noncigarette tobacco product use (88.6%, 79.6%, and 79.4%, respectively) than respondents with no reported mental health conditions (77.8%).^52^

## Recommendations of Others

The 2015 USPSTF recommendation and 2008 Public Health Service (PHS) Guideline^53^ (the basis of the 2008 USPSTF recommendation) are endorsed by or are generally consistent with the recommendations of other national and international organizations, including those from the American College of Physicians and American Medical Association,^54,^ ^55^ American Family Physicians,^56^ and the American Dental Association.^57^ The 2020 Surgeon General’s report on Smoking Cessation similarly concluded that smoking cessation medications approved by the FDA and behavioral counseling are cost-effective cessation strategies and increase the likelihood of successfully quitting smoking, particularly when used in combination.^14^ In addition, the Community Preventive Services Task Force recommends worksite-based incentives and competitions when these efforts are combined with other individual support interventions, increasing the unit price of tobacco products, mass-reach health communication interventions, quitline interventions, and smoke-free policies to encourage tobacco cessation among adults.^58^

The World Health Organization released recommendations for the prevention of tobacco use during pregnancy in 2013^18^ that were based on an overview of reviews and a panel of experts’ ratings of the quality of the evidence. The panel made a strong recommendation for advice and psychosocial interventions for pregnant women who were smokers. It recommended against the use of bupropion or varenicline for smoking cessation, based on very low-quality evidence, but could not make a recommendation for or against NRT use during pregnancy. Accordingly, a strong recommendation for further research on pharmacotherapy for smoking cessation during pregnancy was made. ACOG recommendations for smoking cessation during pregnancy^59^ are also consistent with the 2015 USPSTF recommendations^1^ and the 2008 PHS Guideline.^53^

Several national and professional organizations have issued recent recommendations regarding screening for and use of e-cigarettes among adults.^14,^ ^43,^ ^59–64^ Many recommend that e-cigarette use should be part of tobacco screening questions and that those who smoke or vape should be advised to quit all nicotine products and be provided with tobacco cessation interventions. Recommendations regarding the use of e-cigarettes as an aid for quitting use of other tobacco products (namely combustible cigarettes) are mixed: the 2020 Surgeon General’s report on Smoking Cessation concluded that that there is presently inadequate evidence to conclude that e-cigarettes, in general, increase smoking cessation.^14^ A recent 2019 American College of Preventive Medicine guideline states that clinicians should advise patients that e-cigarettes are not considered evidence-based smoking cessation therapy; but that a shared-decision making approach may be necessary if patients have failed or refused other therapies and are more willing to try e-cigarettes to cut down or quit smoking.^63^ ACOG recommends against the use of e-cigarette products by pregnant and postpartum individuals, children and adolescents, and adults who currently do not use tobacco products.^61^ The American Cancer Society (2019) does not recommend the use of e-cigarettes as a cessation method^62^ and the American Heart Association concluded in its 2014 position paper that there was not enough evidence for clinicians to counsel their patients to use e-cigarettes as a primary cessation aid.^43^ Key policy recommendations by organizations including the AMA,^65^ Surgeon General,^66,^ ^67^ and the American Association for Cancer Research and the American Society of Clinical Oncology^65^ have also been published in support of Federal, State, and local regulation of e-cigarettes, most specifically policies aimed at restricting the sale, distributions, marketing, and advertising of e-cigarettes to youth as well as smoke-free policies that include e-cigarettes.

## Previous USPSTF Recommendation

In 2015, the USPSTF issued four recommendation statements (Table 1).^1^ Two “A” grade recommendations were given for behavioral and pharmacotherapy interventions for adults and for behavioral interventions for pregnant women, whereas two “I” statements were issued for pharmacotherapy interventions for pregnant women and the use of e-cigarettes for tobacco cessation among adults and pregnant women. The 2015 recommendation updated and was consistent with the 2009 and 2003 recommendations.^68^ In both years, the USPSTF recommended that clinicians ask all adults about tobacco use and provide interventions for smoking cessation for those who use tobacco products (A recommendation). It also recommended that clinicians ask all pregnant women about tobacco use and provide augmented, pregnancy-tailored counseling for those who smoke (A recommendation). The original USPSTF recommendation (2003) and reaffirmation (2009) were based on the 2000 and 2008 updates of the Public Health Service (PHS) Clinical Practice Guideline “Treating Tobacco Use and Dependence”.^28,^ ^69^

Table 1 U.S. Preventive Services Task Force Summary of Recommendations for Tobacco Cessation in Adults

Population | Recommendation | Grade
Adults who are not pregnant | The USPSTF recommends that clinicians ask all adults about tobacco use, advise them to stop using tobacco, and provide behavioral interventions and U.S. Food and Drug Administration (FDA)–approved pharmacotherapy for cessation to adults who use tobacco. | A
Pregnant women | The USPSTF recommends that clinicians ask all pregnant women about tobacco use, advise them to stop using tobacco, and provide behavioral interventions for cessation to pregnant women who use tobacco. | A
Pregnant women | The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of pharmacotherapy interventions for tobacco cessation in pregnant women. | I
All adults, including pregnant women | The USPSTF concludes that the current evidence is insufficient to recommend electronic nicotine delivery systems (ENDS) for tobacco cessation in adults, including pregnant women. The USPSTF recommends that clinicians direct patients who smoke tobacco to other cessation interventions with established effectiveness and safety (previously stated). | I