# Appendix I Ongoing Studies

Appendix I Table 1 Ongoing or Recently Completed Studies: Electronic Cigarettes

Study reference/ trial identifier; Primary Investigator | Study name | Location | Estimated N | Intervention Description | Relevant Outcomes | Status (Sep 2020)
NCT03453385; Matthew Carpenter | Clinical Outcomes of a Nationwide, Naturalistic E-Cig Trial (CONNECT) | USA | 660 | 2-arm smoking cessation trial for 6 months comparing (1) e-cigarettes (2) continued smoking with conventional cigarettes | 7-day PPA at 6 months | Recruiting: Est completion date July, 2022.
NCT03511001; Kim Pulvers | Effects Among Smokers Who Use and Do Not Use E-Cigarettes | USA | 187 | 2-arm smoking cessation trial comparing (1) 6 weeks of JUUL e-cigarettes vs. (2) 6 weeks of smoking as usual | Blood pressure outcomes; Respiratory symptoms | Active, but not recruiting: Est completion date December, 2019; No results published.
NCT04084210; Megan Piper | Understanding the Real-World Impact of the Use of Three Alternate Nicotine-Delivery Products on Combustible Cigarette Use | USA | 200 | 3-arm smoking cessation trial comparing: 1) Very low nicotine cigarettes (VLNCs); 2) Juul e-cigarettes; or 3) no alternative product. During two different weeks, participants will be asked to switch from their usual cigarettes and use only study products. They will also be asked to use either an active nicotine or placebo patch (the within-subjects factor), provided in double-blind fashion and counterbalanced order. | Number of conventional cigarettes smoked during each Switch Week; Number of VLNCs or JUUL pods used during each Switch Week | Not yet recruiting: Est. completion date March, 2022.
NCT03743532; Darla Kendzor | Preliminary Evaluation of Alternative Approaches to Combustible Cigarette Cessation (Exchange Project Sub-Study) | USA | 60 | 3-arm smoking cessation trial among low SES persons comparing 1) incentives for quitting smoking in addition to combination nicotine replacement therapy (patches + lozenges), 2) the provision of JUUL(device and pods) along with directions to switch over from combustible cigarettes to e-cigarettes exclusively, or 3) the combination of JUULand incentives for combustible cigarette cessation. | CO-verified 7-day PPA at 1 month | Not yet recruiting: Est. completion date December, 2020.
ACTRN12612001210864; Coral Gartner | Can using nicotine as a long-term substitute enhance smoking cessation over using it only as a cessation aid? | Australia | 1600 | Combination of varying levels of self-help materials, NRT, advice, or e-cigarettes | Continuous abstinence at 6 months; 7-day PPA at 6 months | Completed in December, 2015. No results available.
NCT02417467; Mark Eisenberg and Andréa Hébert-Losier | Evaluating the Efficacy of E-Cigarette Use for Smoking Cessation (E3) Trial | Canada | 486 | 3-arm smoking cessation trial with 12 weeks intervention and observation up to 12 months comparing (1) Nicotine e-cigarettes plus minimal behavioral counseling with (2) placebo e-cigarettes plus minimal behavioral counseling and (3) minimal behavioral counseling only | Continuous abstinence verified by exhaled-CO<11ppm at 6 and 12 months; 7-day PPA verified by exhaled-CO<11ppm at 6 and 12 months; Incidence of adverse events/serious adverse events at 3 months | Active, not recruiting: Est completion date December, 2020; Protocol (https://doi.org/10.1016/j.cjco.2020.03.006) published May 2020; Presented (https://www.acc.org/latest-in-cardiology/clinical-trials/2020/03/27/22/51/e3) by Dr. Mark J. Eisenberg at the American College of Cardiology Virtual Annual Scientific Session Together With World Congress of Cardiology (ACC 2020/WCC), March 30, 2020
NCT03249428; Smita Pakhal | E-Cigarette; Inner City RCT | Canada | 200 | 2-arm smoking cessation trial for 12 months comparing (1) NRT plus behavioral counseling with (2) e-cigarettes plus behavioral counseling | 7-day PPA (validated) at 6 and 12 months; Quality of life at 6 months | Not yet recruiting: Est completion date September, 2021
NCT03235505; Tuula Toljamo | Efficacy and Safety of E-cigarettes for Smoking Cessation in Middle-aged Heavy Smokers (EFFECT) | Finland | 450 | 3-arm smoking cessation trial with 12 weeks intervention and observation up to 12 months comparing (1) Nicotine e-cigarettes + placebo-pills + Motivational Interview (MI) with (2) Placebo e-cigarettes + varenicline + MI and (3) Placebo varenicline + placebo e-cigarettes + MI | 7-day point prevalence abstinence (PPA) verified by exhaled-CO<10ppm at 12 months | Recruiting: Est completion date December, 2020
NCT03630614; Ivan Berlin | Randomized Trial of Electronic Cigarettes with or Without Nicotine in Smoking Cessation (ECSMOKE) | France | 650 | 3-arm smoking cessation trial for 6 months comparing (1) use of nicotine e-cigarettes plus placebo varenicline tablets with (2) placebo e-cigarettes plus active varenicline and (3) placebo e-cigarettes plus placebo varenicline | 7-day PPA at 6 months; Incidence of adverse events at 6 months | Recruiting: Est completion date March, 2022
NCT01979796; Pasquale Caponnetto | Antismoking Effects of Electronic Cigarettes in Subjects with Schizophrenia and Their Potential Influence on Cognitive Functioning (SCARIS) | Italy | 153 | 3-arm smoking cessation trial among persons with schizophrenia for 3 months (1) nicotine e-cigarettes with (2) Placebo e-cigarettes and (3) no-nicotine inhalers | Continuous abstinence verified by exhaled-CO≤7ppm at 12 months | Not yet recruiting: Est completion date December, 2021
NCT02124187; Eugenio Aguglia | Smoking Cessation and Reduction in Depression (SCARID) | Italy | 129 | 3-arm smoking cessation trial among persons with depression for 3 months comparing (1) nicotine e-cigarettes with (2) Placebo e-cigarettes and (3) no-nicotine inhalers | Continuous abstinence verified by exhaled-CO≤7ppm at 12 months | Not yet recruiting: Est completion date June, 2022
NCT03589989; Reto Auer and Anna Schöni | Electronic Nicotine Delivery Systems (ENDS/Vaporizer/E-cigarette) as an Aid for Smoking Cessation (ESTxENDS) | Switzerland | 1,172 | 2-arm smoking cessation trial for 6 months comparing (1) e-cigarettes plus behavioral counseling with (2) behavioral counseling only | Continuous abstinence verified by urinalysis and exhaled-CO at 6 months; 7-day PPA at 6 months validated by urinalysis; Incidence of adverse events and withdrawal symptoms at 6 months; Chemical toxin levels at 6 months; Change in depressive symptoms, metabolism, stress levels, respiratory symptoms, and sleep quality at 6 months | Recruiting: Est completion date December, 2021
NCT04236791; Reto Auer and Anna Schöni | The ESTxENDS Trial-Electronic Nicotine Delivery Systems as an Aid for Smoking Cessation-extension of Follow-up (ESTxENDS) | Switzerland | 1,172 | 2-arm smoking cessation trial for 24 months comparing (1) e-cigarettes plus behavioral counseling with (2) behavioral counseling only | Continuous abstinence verified by urinalysis or exhaled-CO at 12, 24 months; 7-day PPA at 12, 24 months validated by urinalysis or exhaled-CO; Incidence of adverse events and withdrawal symptoms at 12, 24 months; Use of any other smoking cessation products at 12, 24 months; Health-related quality of life, including mobility, self-care, usual activities, pain/discomfort, and anxiety/depression at 12, 24 months | Recruiting: Est completion date June, 2023
NCT03061253; Markos Klonizakis | E-cigarettes and Cardiovascular Function (ISME-NRT) | England | 249 | 3-arm smoking cessation trial for 3 months comparing (1) nicotine-inclusive e-cigarettes (2) nicotine-free e-cigarettes (3) nicotine Replacement Therapy (NRT) | Intervention effect on Total Cholesterol/LDL ratio at 6 months | Active, not recruiting: Est completion date Nov 2020; No results published.
NCT04251273; Amanda L Graham | Text Message Quit Vaping Intervention for Young Adults | USA | 2900 | 2-arm vaping cessation trial for 6 months comparing (1) text message-based intervention for quit vaping support and (2) assessment only | 30-day self-reported PPA at 7 months | Active, not recruiting: Est completion date January, 2021.

Appendix I Table 2 Ongoing or Recently Completed Studies: Pharmacotherapy in Pregnant Women

Study reference/ trial identifier; Primary investigator | Study name | Location | Estimated n | Description | Status (Sep 2020)
NCT01656733; Cheryl Oncken | Nicotine Replacement for Smoking Cessation During Pregnancy | US | 154 | Pregnant smokers who smoke at least 5 cigarettes/ day will receive nurse-delivered behavioral counseling and be randomized to receive a 6-week course of treatment with either a nicotine inhaler or placebo, followed by a 6-week taper. | Completed: Results submitted to clinical trials but not publicly available. No publication available.
NCT02188459; Henry Kranzler | Placebo-controlled Trial of Bupropion for Smoking Cessation in Pregnant Women (BIBS) | US | 360 | A randomized, parallel-group, double-blinded, placebo-controlled, 10 week trial of Bupropion in 360 pregnant women who smoke daily and wish to quit smoking. | Completed: No results posted; no publication available.
NCT03819231; David Black | Mindfulness Training Plus Oxytocin (MOXY) | US | 180 | Clinical trial aimed to examine the effects of mindfulness training and a single 40 IU dose of Pitocin (oxytocin, USP; concentration = 10 IU/1 mL; PAR Pharmaceuticals, NY, USA) on smoking. | Recruiting: Est completion date Dec 2023.
NCT03480373; Cheryl Oncken | Electronic Cigarette Use During Pregnancy | US | 375 | Observational study aimed to compare overall toxicant exposure in pregnant women who use e-cigs with women who smoke conventional cigarettes. Will also compare toxicant exposure and birth outcomes among infants born to pregnant women who use e-cigs compared to women who smoke conventional cigarettes. | Suspended: Est completion date: May 2023.
NCT01290445; Pfizer | Varenicline Pregnancy Cohort Study | Denmark, Sweden | Actual enrollment: 885,185 | A prospective population-based cohort study to examine whether varenicline use during pregnancy is associated with an increased risk of major congenital malformations in infants above that associated with smoking during pregnancy. | Completed May 2016: Results available on clinicaltrials.gov; no publication available.
ACTRN12618000576224; Adrian Dunlop | Targeted antenatal smoking cessation intervention in high-risk substance dependent pregnancy: a feasibility study | Australia | 100 | This study aims to assess the feasibility and acceptability of the addition of current evidence-based smoking cessation care to routine prenatal care of women attending a substance use in pregnancy clinic. | Recruiting: Anticipated date of last data collection January, 2020. Protocol published Nov 2019.
ACTRN12615001278527; Sue Kildea | Assessment of the acceptability, feasibility and impact on smoking cessation, of an intensive smoking cessation intervention, including financial incentives, among pregnant Indigenous women reporting daily smoking and receiving maternity care through the Birthing in Our Community program. | Australia | 140 | This study will assess how effective the program is, what women think about it, and how easy it is to provide “Stop Smoking in its Tracks”. The study will involve collecting information on the care provided, whether women quit smoking and what other factors might be influencing quit attempts and successful quitting. | Recruiting: Anticipated date of last data collection Jun 2019; no results published.

Abbreviations: EST = estimated; mg = milligram(s); UK = United Kingdom; US = United States