# Appendix H Implementation Table

Appendix H Table 1 Intervention Details of Behavioral Interventions Among Adults

Intervention Type | Physician or nurse advice | Individual or group-based counseling | Telephone and mobile phone-based interventions
Primary population | Adult smokers who were typically motivated to quit, including generally healthy smokers as well as those with specific health needs such as those with smoking-related diseases and people with mental illness.
Primary outcomes measured | Smoking cessation at the longest followup (at 6 months or more) using the strictest definition of abstinence, preferring sustained over point prevalence abstinence and using biochemically validated rates where available.
Study findings | Physician and nurse advice can increase the rate of smoking cessation at 6 or more months followup (RR for physician advice 1.76 [95% CI, 1.58 to 1.96]; 26 trials; n=22,239 and for nurse advice 1.29 [95% CI, 1.21 to 1.38]; k=44; n=20,881). | Individual counseling from a smoking cessation specialist increases the rate of cessation among smokers at 6 or more months followup versus no advice, brief advice, or self-help materials (RR 1.48 [95% CI, 1.34 to 1.64]; k=33; n=13,762) and moderate quality evidence that compared with non-group self-help programs, group-based therapy interventions can increase quitting smoking (RR 1.88 [95% CI, 1.52 to 2.33]; k=13; n=4395). | Providing proactive telephone counselors after smokers have called a Quitline improves rates of smoking cessation (RR 1.38 [95% CI, 1.19 to 1.61]; k=14; n=32,484), and moderate quality evidence that proactive telephone counseling increases quit rates in smoking in other settings (RR 1.25 [95% CI, 1.15 to 1.35]; k=65; n=41,233).; Mobile phone-based interventions were less commonly studied but showed a positive benefit on smoking cessation at 6 months’ followup compared with usual care or a minimal intervention (RR 1.54 [95% CI, 1.19 to 2.00]; k=13; n=14,133) and no intervention (RR 1.59 [95% CI, 1.09 to 2.33]; k=4; n=997).
Behavior change goals and techniques | Advice was defined as verbal instructions from the provider with a “stop smoking” message irrespective of whether information was provided about the harm effects of smoking; however, the included interventions were highly variable. In most cases, advice was given verbally and was supplemented with print materials, additional advice from additional healthcare staff, or referral to a cessation clinic. | Typically included: review of smoking history and motivation to quit, help in the identification of high-risk situations, and the generation for problem-solving strategies to deal with such situations as well as non-specific support and encouragement. Many group-based sessions included cognitive behavioral therapy. Additional components such as written materials, video or audiotapes were also sometimes provided. | Telephone counseling and mobile phone-based interventions were generally tailored according to participants’ smoking history, readiness to quit and focused on increasing motivation and strategies to increase likelihood of quitting.
Duration of interventions | Most interventions took place during 1 session with followup between 1 week and 3 months. | Most interventions took place during one face-to-face session with followup consultations over 1 week to 4 months followup. | Highly variable ranging from 2 weeks to 1 year with most taking place over 3 to 4 months.
Settings of studies | Most took place in primary care or hospital settings. | Most took place in hospital or smoking cessation clinic settings. | Most interventions were delivered entirely remotely via telephone or mobile phone, with few providing any face-to-face support.
To whom is intervention targeted? | Adult smokers motivated to quit. | Adult smokers, regardless of motivation to quit. | Generally adult smokers motivated to quit. Most mobile phone-based interventions targeted younger- (mean age 18–27 years) or middle-aged adults (up to mean age of 45 years).
Mode and intensity of delivery | Most advice was given during a single consultation lasting less than 20 minutes (with or without print materials) plus up to one followup visits; although several studies compared more intense interventions (more than one session) with minimal interventions. | Most individual-based advice was given during one face-to-face session with multiple followup sessions in-person or via the telephone. Group-based sessions included smokers meeting for scheduled meetings delivered over 6 to 8 sessions, with the first few sessions devoted to discussion of motivation for quitting, health benefits, and strategies for planning a quit attempt. | Telephone counseling was typically delivered in scheduled phone calls that began after smokers had proactively called a smoking Quitline. The number of calls ranged from a single call to 12 calls. The duration of the calls was typically 10 to 20 minutes, although the first calls were often longer.; Almost all the included trials of mobile phone-based interventions used text messaging (SMS) as a central component of the intervention. The number of text messages varied considerably but often was 0 to 2 messages per day every day over the course of the intervention.
Example interventions * ^†^ | Morgan 1996^§^,^1^; Canga 2000^§^,^2^ | Fiore 2004^3^; Glasgow 2000^4^; Weissfeld 1991^§^,^5^ | Bock 2013^8^; Curry 1995^9^; Ellerbeck 2009^6^; McBride 1999^10^; McClure 2005^7^; Orleans 1991^§^,^11^; Rigotti 2006^12^
Materials provided for practice ^†^ ** | Treatment guide: Orleans CT, Rimer BK, Fleisher L. Clear horizons: a quit smoking guide especially for those 50 and over. Philadelphia: FoxChase Cancer Center, 1989 . (Morgan 1996^1^); Intervention based on protocols established in How to Help Your Patients Stop Smoking: A National Cancer Institute Manual for Physicians^13^ and followed the orientation of the Mayo Nicotine Dependence Center^14^ (Canga 2000^2^) | Office of Cancer Communications. Clearing the Air: How to Quit Smoking and Quit for Keeps. Bethesda, Md: National Cancer Institute; 1987 . (Weissfeld 1991^5^) | American Lung Association guide (https://www.ncbi.nlm.nih.gov/pubmed/2703347/) (Bock 2013^8^); Curry, S.J., Gordon, J. R., & Marlatt, G. A. (1987). Breaking Away: A guide to becoming a nonsmoker; unable to find original materials . (Curry 1995^9^); https://www.cancer.gov/publications/patient-education/clearing-the-air (McBride 1999^10^); American Lung Association maintenance manual ( American Lung Association. (1980). A lifetime of freedom from smoking. New York: Author ) (Orelans 1991^11^); Solomon L, Quinn V. Spontaneous quitting: self-initiated smoking cessation in early pregnancy. Nicotine Tob Res 2004;6 suppl:S203–16 15203822 . (Rigotti 2006^12^)
Evidence of effect modification | There was insufficient evidence to establish differences according to the intensity of the intervention. There was some evidence that physician advice interventions that provided further followup to a minimal intervention vs. those delivered in one single session were more effective, but this effect was not seen related to nurse advice. There was no evidence that the effects differed by patient group or setting. | No evidence of effect modification based on whether pharmacotherapy was offered nor on population (hospital inpatients or outpatients vs. not). Evidence was too limited to determine whether there was a dose-response effect according to number of contacts or type (face-to-face vs. remote) of followup consultations. | Some evidence that participants who were selected based on their motivation to quit may be more likely to quit smoking versus those who were not selected on their motivation in response to proactive telephone counseling. There was not enough evidence to suggest that a higher number of calls would result in a larger effect. There were minimal differences in the effectiveness of mobile phone-based interventions according to different population and intervention characteristics.
Comparison group | No advice or usual care. | No advice, brief advice, self-help materials, or usual care; non-group-based interventions. | No intervention, self-help materials, or other nontailored and noninteractive remote support.
Interventionist and training required | Physicians (e.g., general practitioners, family practice) or nursing staff with or without smoking-related duties as part of their core clinical duties. Information about training provided to staff was not synthesized and was rarely reported. In those reporting, training ranged from “brief tutorial” to a 4-hour training. | Smoking cessation specialists often with backgrounds in social work, psychology, psychiatry, health education, and nursing. Training was otherwise not described. | Telephone counseling was most often provided by professional counselors or trained health care professionals. Many text message-based interventions were developed and administered through computer expert generated systems.
Reported adherence to intervention | Adherence to intervention not synthesized or abstracted by reviews.

* Example interventions are those that demonstrated a positive direction of effect on smoking cessation, were at low risk-of-bias, and took place in the United States in primary care or a primary care-applicable setting among an unselected sample of adults (i.e., those not selected based on having smoking-related disease or other co-morbid conditions)

† Inclusion of studies and materials are for example purposes only and does not indicate endorsement by the USPSTF.

** Materials provided for practice include materials or protocols that were noted within the source study and that we were able to locate.

§ Statistically significantly effect of intervention versus control on smoking cessation at 6 months or more followup.

1 Morgan GD, Noll EL, Orleans CT, . Reaching midlife and older smokers: tailored interventions for routine medical care. Prev Med. 1996;25(3):346–54. 10.1006/pmed.1996.0065 8781013

2 Canga N, De Irala J, Vara E, . Intervention study for smoking cessation in diabetic patients: a randomized controlled trial in both clinical and primary care settings. Diabetes care. 2000;23(10):1455–60. 10.2337/diacare.23.10.1455 11023136

3 Fiore MC, McCarthy DE, Jackson TC, . Integrating smoking cessation treatment into primary care: an effectiveness study. Prev Med. 2004;38(4):412–20. 10.1016/j.ypmed.2003.11.002 15020174

4 Glasgow RE, Whitlock EP, Eakin EG, . A brief smoking cessation intervention for women in low-income planned parenthood clinics. Am J Public Health. 2000;90(5):786–9. 10.2105/ajph.90.5.786 10800431

5 Weissfeld JL, Holloway JL. Treatment for cigarette smoking in a Department of Veterans Affairs outpatient clinic. Arch Intern Med. 1991;151(5):973–7.2025147

6 Ellerbeck EF, Mahnken JD, Cupertino AP, . Effect of varying levels of disease management on smoking cessation: a randomized trial. Ann Intern Med. 2009;150(7):437–46.19349629

7 McClure JB, Westbrook E, Curry SJ, . Proactive, motivationally enhanced smoking cessation counseling among women with elevated cervical cancer risk. Nicotine Tob Res. 2005;7(6):881–9. 10.1080/14622200500266080 16298723

8 Bock B, Heron K, Jennings E, . A Text Message Delivered Smoking Cessation Intervention: The Initial Trial of TXT-2-Quit: Randomized Controlled Trial. JMIR Mhealth Uhealth. 2013;1(2):e17. 10.2196/mhealth.2522 25098502

9 Curry SJ, McBride C, Grothaus LC, . A randomized trial of self-help materials, personalized feedback, and telephone counseling with nonvolunteer smokers. J Consult Clin Psychol. 1995;63(6):1005–14.8543703

10 McBride CM, Scholes D, Grothaus LC, . Evaluation of a minimal self-help smoking cessation intervention following cervical cancer screening. Prev Med. 1999;29(2):133–8. 10.1006/pmed.1999.0514 10446040

11 Orleans CT, Schoenbach VJ, Wagner EH, . Self-help quit smoking interventions: effects of self-help materials, social support instructions, and telephone counseling. J Consult Clin Psychol. 1991;59(3):439–48.2071729

12 Rigotti NA, Park ER, Regan S, . Efficacy of telephone counseling for pregnant smokers: a randomized controlled trial. Obstet Gynecol. 2006;108(1):83–92. 10.1097/01.AOG.0000218100.05601.f8 16816060

13 Glynn TJ, Manley MW: How to Help Your Patients Stop Smoking: A National Cancer Institute Manual for Physicians. Washington, DC, U.S. Govt. Printing Office, 1998 (DHHS publ. no. 98-3064)

14 Hurt RD, Dale LC, McClain FL, Eberman KM, Offord KP, Bruce BK, Lauger GG: A comprehensive model for the treatment of nicotine dependence in a medical setting. Med Clin North Am 76:495–514, 1992 1312657

Appendix H Table 2 Intervention Details of Behavioral Interventions Among Pregnant Women

Intervention Type | Individual psychosocial interventions
Primary population | Generally healthy pregnant adult women over 16 years of age, but including those with specific health needs. About half of the included trials explicitly recruited women categorized as having low socioeconomic status.
Primary outcomes measured | Smoking cessation in late pregnancy and continued abstinence post-partum. Using the strictest definition of abstinence, preferring sustained over point prevalence abstinence and using biochemically validated rates where available.
Study findings | Psychosocial interventions among pregnant women increased the rate of smoking cessation in late pregnancy compared with control (RR 1.35 [95% CI, 1.23 to 1.48]; 97 trials; n=26,637).
Behavior change goals and techniques | Psychosocial interventions were defined as non-pharmacological strategies that use cognitive behavioral, motivational and supportive therapies to help women to quit. This included counselling, health education, feedback, financial incentives, social support from peers and/or partners, and exercise, as well as dissemination trials.
Duration of interventions | Most interventions recruited women during their first antenatal visit or second trimester of pregnancy; the duration of the intervention typically took place from this time until late pregnancy.
Settings of studies | Most interventions took place in women’s clinics or tobacco cessation clinics.
To whom is intervention targeting? | Pregnant women who are currently smoking or have recently quit smoking.
Mode and intensity of delivery | Smoking cessation interventions implemented during pregnancy differed substantially in their intensity, their duration, and the people involved in their implementation.
Example interventions * ^†^ | Bullock 2009^1^; Lee 2015^2^; Pollack 2013^3^; Stotts 2009^4^; Windsor 2011^5^
Materials provided for practice ^†^ ** | All patients (both control and experimental groups) received (Ask-Advise-Assess-Arrange) SCRIPT Procedures 1, 2, 3, 9, and 10.^6,^ ^7,^ ^8,^ ^9^ and experimental group patients also received Assist SCRIPT Procedures 4 through 8, which included a video,^10^ guide to quit smoking,^11^ and a 10 minute or less counseling session^12^
Evidence of effect modification | Meta regression analyses found no differences in the effects of behavioral interventions according to the specific intervention strategies, comparator, intensity (categorized according to frequency of contact), intervention duration, the provision of self-help manuals, including telephone support, the SES of the sample, newly added studies, or study design (cluster versus individually randomized trials).
Comparison group | Any control
Interventionist and training required | Varied
Reported adherence to intervention | Adherence to intervention not synthesized by review.

* Example interventions are those that demonstrated a positive direction of effect on smoking cessation, took place in the United States in primary care or a primary care-applicable setting, and were published in the past 10 years

† Inclusion of studies and materials are for example purposes only and does not indicate endorsement by the USPSTF.

** Materials provided for practice include materials or protocols that were noted within the source study and that we were able to locate.

1 Bullock L, Everett KD, Mullen PD, . Baby BEEP: A randomized controlled trial of nurses’ individualized social support for poor rural pregnant smokers. Matern Child Health J. 2009;13(3):395–406. 10.1007/s10995-008-0363-z 18496746

2 Lee M, Miller SM, Wen KY, . Cognitive-behavioral intervention to promote smoking cessation for pregnant and postpartum inner city women. J Behav Med. 2015;38(6):932–43. 10.1007/s10865-015-9669-7 26335312

3 Pollak KI, Lyna P, Bilheimer A, . A pilot study testing SMS text delivered scheduled gradual reduction to pregnant smokers. Nicotine Tob Res. 2013;15(10):1773–6. 10.1093/ntr/ntt045 23569007

4 Stotts AL, Groff JY, Velasquez MM, . Ultrasound feedback and motivational interviewing targeting smoking cessation in the second and third trimesters of pregnancy. Nicotine Tob Res. 2009;11(8):961–8. 10.1093/ntr/ntp095 19553282

5 Windsor R, Woodby L, Miller T, . Effectiveness of Smoking Cessation and Reduction in Pregnancy Treatment (SCRIPT) methods in Medicaid-supported prenatal care: Trial III. Health Educ Behav. 2011;38(4):412–22. 10.1177/1090198110382503 21551424

6 Fiore, M.; Bailey, W.; Cohen, S., . Smoking cessation: clinical practice guideline. Rockville, MD: AHCPR; 1996.

7 Fiore, M.; Bailey, W.; Cohen, S., . Treating tobacco use and dependence: a clinical practice guideline. Rockville, MD: AHRQ; 2008.

8 Windsor R, Cutter G, Morris J, Reese Y, Manzella B, . The effectiveness of smoking cessation methods for smokers in public health maternity clinics: A randomized trial. American Journal of Public Health. 1985; 75:1389–1392.4061709

9 Windsor R, Lowe J, Perkins L, . Health education for pregnant smokers: Its behavioral impact and cost benefit. American Journal of Public Health. 1993; 83:201–206.8427323

10 Windsor, R.; Crawford, M.; Woodby, L. Commit to quit smoking during and after pregnancy. Washington, DC: 1998. [Video]. UAB Medical Television. Edited 2004, Society for Public Health Education, www.sophe.org.

11 Windsor, R. A Pregnant Woman’s Guide to Quit Smoking. ISBN 0-935105-01-08. Washington, DC: Society for Public Health Education; 1985 &2005. www.sophe.org.

12 Laine C, Davidoff F. The patient-physician relationship: Patient-centered medicine, a professional evolution. Journal of the American Medical Association. 1996; 275:152–156.8531314