# Appendix G Additional Evidence for Smoking Cessation Interventions Among Pregnant Women

Appendix G Figure 1 NRT Interventions for Smoking Cessation During Pregnancy, Preterm Birth at <37 Weeks

This figure is a forest plot of the preterm birth at less than 37 weeks outcome for nicotine replacement therapy interventions for smoking cessation during pregnancy.

Appendix G Figure 2 NRT Interventions for Smoking Cessation During Pregnancy, Mean Birthweight in Grams

NOTE: Standard deviations for Wisborn, 2000 and El-Mohandes, 2013 abstracted from review by Claire et. al, 2020.^76^

This figure is a forest plot of the mean birthweight in grams outcome for nicotine replacement therapy interventions for smoking cessation during pregnancy.

Appendix G Figure 3 NRT Interventions for Smoking Cessation During Pregnancy, Low Birthweight (<2500 Grams)*

NOTE: Study reported odds ratios were used when reported in original publication.

This figure is a forest plot of the low birthweight (less than 2500 grams) outcome for nicotine replacement therapy interventions for smoking cessation during pregnancy.

Appendix G Figure 4 NRT Interventions for Smoking Cessation During Pregnancy, Stillbirth

This figure is a forest plot of the stillbirth outcome for nicotine replacement therapy interventions for smoking cessation during pregnancy.

Appendix G Figure 5 NRT Interventions in Placebo-Controlled Trials for Smoking Cessation During Pregnancy, Smoking Cessation (KQ 2)

NOTE: Pooled estimate from REML with Knapp-Hartung modification: RR= 1.11 (95% CI 0.79 to 1.56)

This figure is a forest plot of the smoking cessation outcome for nicotine replacement therapy interventions in placebo-controlled trials for smoking cessation during pregnancy.

Appendix G Table 1 Population Details From NRT Trials for Smoking Cessation Among Pregnant Women

Author, Year; Trial name; Quality | Mean age | Weeks’ gestation at BL, mean (range) | SES (%) | Race (%) | OB & medical Hx (%) | Median CPD and Nicotine dependence | Readiness to quit | Quit Hx
Berlin, 2014^167^; SNIPP; Good | 29.3^*^ | NR (9–12 week’s gestation) | Married^*^,^†^: 85; Edu: NR; Employment^*^:; Employed: 57; Housewife: 22; Unemployed or Student: 21; Other SES^*^: Annual household income (Euro), %; <12,000: 32.6; 12,000 – 30,000: 50.0; 30,000 – 100,000: 16.7; > 100,000: 0.7 | European: 95; African: 3 | Nulliparous^*^: 27.9; Hx of Premature birth(s)^*^: 9.5; Hx of small gestational age^*^: 10.7; Other medical:; Maternal Disorders before randomization^*^: 9.5 | 10.5^*^; Fagerstrom test (0 to 10), Median: 4.5 (IQR 3–6) | Participants were required to have scored at least a 5 on a motivational scale (range 0–10) | Previous quit attempts (≥ 1 week): 1 (IQR 0–2)
El-Mohandes, 2013^171^; Fair | 27.5^*^ | 18.5 (<30 weeks’ gestation) | Married^†^: 12; Edu:; <HS degree: 33; HS graduate^‡^: 50; At least some college: 17%; Employment:; Full time: 17; Part-time: 13; Not employed: 69; Other SES:; Medicaid (%): 96 | African American: 100 | Nulliparous: NR; Hx of Premature birth(s): NR; Hx of small gestational age: NR; Other medical:; Pregnancies (+current), mean: 5.6; Number of live births, mean: 2.4; Alcohol use during pregnancy: 16 (31%); Any depressive symptoms: 31 (60%); Marijuana during pregnancy: 12 (235) | Mean # CPD <7days: 6.0; Nicotine dependence: NR | NR | NR
Coleman, 2012^168^; SNAP; Good | 26.3^*^ | 16.3 (12–24 weeks’ gestation) | Married^*^: NR; Edu^*^: NR; Employment: NR; Other SES: NR; Mean age at leaving full-time education, yrs^*^: 16.3 | White British^*^: 97.0 | Nulliparous^*^: 0–1: 68.5; Hx of Premature birth(s)^*^: 8.8; Hx of small gestational age^*^,^§^: NR; Other medical:; Use of NRT within pregnancy and prior to enrollment^*^,^‖^ (%): 4.5 | 14; Nicotine dependence: NR | NR | NR
Oncken, 2008^174^; Fair | 25.1 | 17.1 (≤26 weeks’ gestation) | Married^†^: 30; Edu:; <HS grad: 50; HS grad: 33.5; Employment: 33; Other SES (%):; Public Insurance: 83; Private Insurance: 17 | Non-Hispanic White: 35; Non-Hispanic Black: 30; Hispanic: 54; Other: 3% | Nulliparous: 16.5; Hx of Premature birth(s): 15; Hx of small gestational age: NR; Other medical (%):; Average number of pregnancies: 3; Methadone maintenance: 6.5; Antidepressant use: 7.5%; Mental health Tx Hx: 41.5%; Substance abuse Tx Hx: 18.5% | Mean # CPD, last 7 days: 9.45; Mean Fagerstrom scores: 3.55 (IQR 1.93) | NR | Number of previous quit attempts: 2.79
Oncken, 2019^175^; Fair | 27.6 | 17.5 (13–26 weeks’ gestation) | Married: NR; Edu:; HS Grad: 19; College or post-college completed: 16; Other SES (%):; Public Insurance: 63.5; Private Insurange: 5 | White: 25.5; Black: 11.1; Hispanic: 30.4; Other: 0.5 | Nulliparous: 13; Hx of premature delivery: 10.6; Hx of SGA: NR; Other medical:; Hx of depression or anxiety: 41.6%; Substance abuse: 24.5%; Progesterone use: 5.5%; No of previous (median) pregnancies: 2 | Mean CPD: 8.4; Mean Fagerstrom test score: 4.3 | Motivation to quit (0–10): 8.4 | NR
Pollak, 2007^176^; Baby Steps; Fair | 27 | 18 (13–25 weeks’ gestation) | Married^†^: 30; Edu:; <HS grad: 28; HS grad^‡^: 31; College degree or higher: 5; Employment:; Full-time: 67; Part-time: 17; Unemployed: 67; Other SES: NR | White: 69; Black: 24; Other: 8 | Nulliparous: 16; Hx of Premature birth(s)^*^: 15; Hx of small gestational age^*^: 5; Other medical:; Number of prior pregnancies median (median, IQR): 2 (1,4); Premature rupture of membranes: 7%; High blood pressure: 19%; Prior history of miscarriage, ectopic pregnancy, or stillbirth: 50% | Mean CPD: 11 (5); Nicotine dependence mean (SD): 3 (1) | “Desire to quit” Mean: 6 (1) | Quit at least 24 hours during this pregnancy: 28%
Wisborg, 2000^178^; Fair | 28.4 | NR (<22 weeks’ gestation) | Married^*^,^†^: 76.5; Edu:; Years of schooling^*^:; <10: 18.4; ≥ 10: 66.8; Missing: 14.8; Employment:; Employed^*^: 51; Other SES: NR | NR | Nulliparous: 42.8; Hx of Premature birth(s): NR; Hx of small gestational age: NR; Other medical:; Alcohol intake (drinks/wk)^*^:; 0–2: 87.5%; ≥3: 9%; Missing: 11% | Mean CPD: 13.8; Mean Fagerstrom score: Listed but no data provided | NR | Previous attempts to quit, %^*^; 0–2: 68.8 3–15: 31.2

* Calculated

† Married includes married or cohabitating

‡ HS graduate or GED

§ Defined as any previous pregnancy which lasted from 24 to 37 week

‖ The median number of days before recruitment that women last used NRT among the 47 women who reported current or past use was 31 days for the NRT group (IQR 15 to 38 days) and 30 for the placebo group (IQR 14 to 68 days).

Abbreviations: BL = baseline; CPD = cigarettes per day; HS = high school; hx= history; IQR = interquartile range; NR = not reported; SES = socioeconomic status; Tx = treatment; yrs = years

Appendix G Table 2 Intervention Characteristics From NRT Trials for Smoking Cessation Among Pregnant Women, by Study Design

Author, Year; Trial name; Quality | NRT component | Behavioral component description | Number and length of visit(s) | Setting; Provider | Delivered intervention details | Adherence
Berlin, 2014^167^; SNIPP; Good | NRT, patch 10 mg and 15 mg; 16 hour delivery nicotine patches | Behavioral support.; Participants received behavioral support at each visit. Although the personalized, individual behavioral interventions were not specifically standardized, and the participating maternity wards could use their discretion to apply their own standard methods, these interventions were based on the national consensus document. The study’s website along with flyers in waiting rooms provided information that participants would receive personalized (not within groups) interventions by healthcare professionals specialized in smoking cessation. The core feature of the behavioral interventions included motivational interviewing, arrangement for follow-ups, behavioral counselling, establishment of good doctor-patient and midwife-patient relationships, and a clear definition of treatment aims. | Total #: 7; Initial visit 1hr, following visits at least 10min | Maternity ward; Research investigator(s) | Daily dose ranged from 10–30 mg/day Mean daily prescription dose for entire tx period IG: 18mg (SD 6.8mg), CG: 19.2 (SD 6.9mg).; Median length of prescription was: IG: 105 days (IQR 35-175), CG: 70 (IQR 35-175); In total, 21,722 nicotine patches and 19,702 placebo patches were issued to the participants | Compliance was recorded among 307 (76%) participants at 1016 visits, self-reported. Compliance assessed in 164/203 (81%) women in the nicotine patch group and 143/199 (72%) in the placebo patch group. The median self-reported compliance rate was 85% (interquartile range 56–99%) in the nicotine patch group and 83% (56–95%) in the placebo patch group.; Completed all visits: IG: 96/203 (47.3%), CG: 76/199 (38.2%)
Coleman, 2012^168^; SNAP; Good | Active nicotine patches 15 mg per 16 hours (4wk supply, additional 4wk supply if needed) | Behavioral counseling (1 face-to-face and 3 telephone sessions).; At enrollment, research midwives provided behavioral support lasting up to 1 hour. In addition to behavioral support at enrollment, research midwives provided three sessions of behavioral support by telephone to participants: one session on the quit date, one session 3 days afterward, and one at 4 weeks. The women who collected a second month’s supply of NRT or placebo also received face-to-face support from the research midwife at the time of collection. Women were offered additional support from local National Health Service smoking cessation services and were encouraged to ask for support from the research midwives or smoking cessation service staff; support was provided according to the manual. | Total #: 4 (1 initial + 3 phone); +1 additional face-to-face for women still smoking after 1mo.; Initial visit up to 1hr; phone visits NR | OBGYN, clinical; Research midwives | Gum usage ranged from about 90% usage at visit 1 to 30% usage at visit 5.; Number of days of gum use [placebo: 29.9 (SD=3.4); NRT: 37.8 (SD=3.8)]; Average number of pieces of gum used per day [placebo: 3.22 (SD=2.27); NRT: 3.04 (SD=2.43)] | At delivery, only 7.2% (35/485) of IG and 2.8% (14/496) CG reported using trial medications for over 1 month.; Rates of use of nonstudy nicotine-replacement therapy were very low.; Most participants had no additional contact, either face to face or by text message, with smoking-cessation advisors.; Median number of extra phone contacts: 2 in each group.
Oncken, 2008^174^; Fair | Nicotine gum 2mg; 6 weeks of treatment with the gum followed by a 6-week taper period. | Behavioral counseling (8 face-to-face sessions).; At BL and Visit 1, women received individualized smoking cessation counseling. Subjects received two 35-minute counseling sessions (in English or Spanish) delivered by a research assistant trained to deliver smoking cessation counseling using a motivational interviewing approach. In addition to the counseling sessions, subjects received printed educational materials that were tailored for use in pregnancy and twice-monthly telephone calls to monitor progress until delivery. | Total #: 8; 35 min (2 visits); NR for phone or other visits. | NR; Study Nurse (dispensed medication); Smoking cessation therapist; Research assistants | Initial session: lasted an average 64.7 minutes (SD15.8): CBT-only, 61.7, (16.7); and CBT+NRT, 66.1, (15.7). Sessions two through six lasted an average 25.7 minutes (SD14.1): CBTonly, Mean 23.6min, (10.7); and CBT+NRT: M27.0 min, (13.9). CBT+NRT (n=122): 72 selected the patch, 32 selected the gum, 12 selected the lozenge, and 6 opted to use no NRT.; Mean of 40 patches dispatched, however, women reported using a mean of only 23.4 patches; Gum dispensed to last the women 18 days; they reported using gum for 8 days; Lozenges dispensed to last 19 days; the women reported using lozenges for a mean of 4 days; Overall, 76% of the women in the CBT+NRT arm reported using some form of NRT; Only four women in the CBT-only arm reported using NRT | Overall, the IG was more likely to attend study visits than the placebo group (71% vs. 60%; t(10)= 3.67, p=.004).; The nicotine group participated at a significantly higher rate at visits 3 (χ2(1)= 5.26, p=.022) and 5 (χ2(1)= 4.74, p=.029) and at the postpartum visit (χ2(1)= 4.47, p=.035).
Oncken, 2019^175^; Fair | NRT, inhaler (4mg of nicotine from a porous plug containing 10mg of nicotine) Planned for 6 wks; inhaler available for additional 6wks if the participant was abstinent from smoking.; Number of inhalers used per day based on level of smoking. | Protocol consisted of nine in-person visits and a phone call one month after delivery.; After randomization, at the next two visits (baseline and one week after the quit date) participants received 35 minutes of individual smoking cessation counseling by a study nurse who was trained to deliver the counseling using a motivational interviewing approach. At the baseline visit we asked participants to pick a quit date (a date that they would completely stop smoking beginning at 12 am) sometime within the next week and to start using the inhaler on that date. We also provided written educational materials on smoking cessation during pregnancy and the package insert for the nicotine inhaler. | Total #: 10 (9 in-person, 1 phone); Length of visits: NR | NR; Study nurse | NR | Compliance with the inhaler during treatment was 69% in the placebo group and 70% in the nicotine group, which was not significant (p>0.99).
Wisborg, 2000^178^; Fair | NRT, patch (15 mg/ 16 hrs for 8 weeks, 10 mg/16 hrs for 3 weeks) planned for 11 weeks. | Behavioral counseling (4 visits).; Prenatal smoking cessation counseling with a midwife four times during pregnancy. Visits were independent of routine antenatal care visits. At first visits, which lasted 45–60 minutes, participants were interviewed about their smoking habits and previous attempts to stop smoking. Women were informed about pharmacologic and psychologic aspects of smoking and the consequences of smoking during pregnancy. Methods to stop smoking were carefully explained and the day of stopping was planned. A pamphlet on smoking and pregnancy also was distributed; pamphlets contained information about the harmful effects of smoking and gave brief advice on smoking cessation | Total #: 4; Initial visit: 45–60min; remaining 3 lasted 15–20 min | NR; Study midwife | NR | In the nicotine group 17% used all 15-mg patches and 11% used all 10-mg patches. In the placebo group 8% and 7% used all patches.
El-Mohandes, 2013^171^; Fair | Trans-dermal NRT, 14–21mg for 10 wks depending on CPD | Behavioral counseling (5 face-to-face and 1 telephone session); Delivery of an evidenced-based intervention: the Smoking Cessation or Reduction in Pregnancy Treatment (SCRIPT) Program. In addition to counseling, women were given A Pregnant Woman’s Guide to Quit Smoking, a manual to assist patients with problem-solving and coping skills, written at a 6th grade reading level. Women who continued after visit 1 received reinforcement and behavioral methods at Visits 2–5. | Total #: 6 (max); Varied: “Frequency of contact and total time with each patient was standardized” | Clinical, private room; Intervention specialists | Majority received between 31–60min (82%), 15.7% received <30min, and 2.3% received over 60min behavioral support | Sixty-five percent of patients completed the NRT protocol.; CG patients were adherent to the scheduled counseling and assessment visits. Although adherence levels in the IG and CG were comparable for Visit 1 to 4, the NRT Implementation Index was much lower for Visit 5 and 6.
Pollak, 2007^176^; Baby Steps; Fair | Choice of NRT from patch (7–21 mg/ 16 hrs depending on cpd), gum (2 mg per each cpd), or lozenge (2 mg per each cpd) Each woman’s NRT dose was based on current smoking level:; Overall encouraged to use NRT for 6wks. | All women received six one-on-one counseling sessions (five face-to-face at prenatal visits and one via telephone) designed to enhance motivation and develop skills needed to quit smoking. “Quit kit” given: a smoking cessation booklet designed for pregnant smokers (Make Yours a Fresh Start Family), water bottle, straws, hard candy, an exercise band, and a stress management tape. Support specialists helped the women devise an action plan. After the first session, each woman was mailed a card containing details of her action plan. In all sessions, support specialists attempted to increase the women’s motivation, self-efficacy, and skills. In addition to the smoking-specific content, support specialists covered a relevant content area (stress, rewards, social support, and relapse prevention). The counseling protocol was based on motivational interviewing, the transtheoretical model of behavior change, and social cognitive theory. | Total #: NR; Length: NR | Clinical (prenatal visits), 1 phone; Support specialist (Behav) | The median number of patches used was 14 (range 0–77) in the nicotine group and 7 (range 0–77) in the placebo group; Women who did not attend visits were given another appointment within the subsequent 2 weeks. If they did not attend again they were contacted by telephone. At second, third, and fourth visits, 76 (31%), 106 (44%), and 129 women (53%), respectively, were telephoned. | A greater proportion of the women in the CBT+NRT arm completed four or more sessions (four was median number of sessions) than did women in the CBT-only arm (70% vs 53%, p=0.02, RD=0.17, 95% CI0.10–0.24).

Abbreviations: BL = baseline; CBT = cognitive behavioral therapy; CG = control group; CI = confidence interval; CPD = cigarettes per day; IG = intervention group; mg = milligram; min = minute(s); NR = not reported; NRT = nicotine replacement therapy; OBGYN = obstetrics and gynecology; RCT = randomized controlled trial; RD = risk difference; SES = socioeconomic status; Tx = treatment; wks = weeks; yrs = years