# Appendix F Additional Details for Electronic Cigarette Trials

Appendix F Table 1 Population Details From Trials of Electronic Cigarettes for Tobacco Cessation

Author, Year; Trial name; Quality | Mean age | SES | Race | % Female | Median CPD | Nicotine dependence | Other smoking history | Readiness to quit | Quit history
Bullen, 2013^144^; ASCEND; Fair | 42.4 | Marital status: NR; Education: 47.3% less than high school; Employment: NR; Other SES: NR | Maori: 32.4%; Non Maori: 67.6% | 61.6 | 17.9 | FTND^†^ (0 to 10), Median: 5.5; FTND >5: 54.6% | Age of smoking initiation, mean: 15.5 years; # years smoking, mean: 24.7; Lives with smokers: 52.1% | Confidence in ability to sustain abstinence (1–5 scale), mean: 3.7; AUTOS Score, mean: 23.0 | Past year quit attempt: 55.7%
Caponnetto, 2013^145^; ECLAT; Fair | 44.0 | Marital status: NR; Education:; Low: 31%; Intermediate: 53%; High: 16%; Employment: NR; Other SES: NR | NR | 36.7 | 20.0 | FTND^†^, mean: 5.8 | Age of smoking initiation, mean: 16.8 years; Packs per year, mean: 24.9; eCO, mean: 20 ppm | NR | Ever attempted to quit: 51%; # Lifetime quit attempts, mean: 0.6
Hajek, 2019^154^; TEC; Fair | 41.0 | Marital Status:; 73.1% Single or divorced/separated; 24.9% married; 1.8% widowed; Education: 35.3% high school education or less; Employment: 69.6% employed; Other SES: NR | NR | 48.0 | 15.0 | FTND^†^, mean: 4.6 | Age of smoking initiation, median: 16 years; eCO, mean: 20 ppm; Has significant other who smokes: 39.1% | NR | Past use for cessation NRT: 74.9%; E-cig: 41.5%; Varenicline: 33.9%; Bupropion: 7.8%
Lee, 2019^157^; Fair | 42.3 | Marital status:; married: 90%; unmarried: 10%; Education:; ≤High school: 60.7; ≥College: 39.3%; Employment: 100%; Other SES: NE | NR | 0 | CPD smoked, pack: 1.01; Total smoking amount, pack-year: 21.56 | FTND, score: 4.05 | Duration of smoking, years: 21.98 | Initial confidence about quitting smoking score, 5.95 | Number of prior attempts to quit (%):; None: 10.0; 1: 20.7; ≥2: 69.3
Walker, 2019^155^; Fair | 41.6 | Marital status: NR; Education: 35.7% with less than 12 years of education; Employment: NR; Other SES: NR | Maori: 40.1%; Non Maori: 59.9% | 68.3 | 17.3 | FTND^†^, mean: 5.2; Daily smokers: 98.8% | Age of smoking initiation, mean: 15.4 years; # of years smoking, mean: 22.6 years; Lives with smokers: 41.9% | Motivation to quit,^‡^ mean score: 3.9; Reduced CPD in past year: 56.4% | Past year quit attempt: 45.1%
Carpenter, 2017^147^; Fair | 42.2 | Marital status: NR; Education: 37.1% HS education or less; Employment: 54.2% employed (full- or part-time); Other SES: 50.3% income <$25,000 | White: 54.5%; African American: 44.0% | 60.5 | 15.3 | NR | NR | Motivation to quit (1–10 scale): 4.5 | Past year quit attempt: 33.7%; Lifetime # quit attempts (mean): 4.2
Cravo, 2016^148^; Fair | 34.6 | Marital status: NR; Education: NR; Employment: NR; Other SES: NR | NR | 44.6 | 5–10 CPD: 34.6%; 11–20 CPD: 57.6%; 21–30 CPD: 7.8% | FTND^†^; Mild: 29.7%; Moderate: 55.9%; Severe: 14.5% | eCO, mean: 74.8 ppm | Subjects were excluded if they expressed current readiness to quit. | NR
Masiero, 2017^146^; Fair | 62.8 | Marital status: NR; Education: NR; Employment: NR; Other SES: NR | NR | 37.1 | 19.4 | FTND^†^, mean: 4.3 | Age of smoking initiation, mean: 17.4 years; eCO, mean: 14.8 ppm | Motivation to quit, mean score (scale 4–19)^*^: 13 | NR
Tseng, 2016^150^; Fair | 28.9 | Marital status: NR; Education: 32.7% high school or less; Employment: NR; Other SES: NR | African American: 29.2%; White: 25.0%; Other: 8.8%; Hispanic of any race: 27.1% | 32.7 | 14.8 | Smoking Dependence; Mild: 16.3%; Moderate: 51.0%; Strong to Very Strong: 32.7% | Time to first CPD; <=5 min after waking: 25.5%; 6–30 min after waking: 42.6%; 31–60 min after waking: 21.3%; >60 min after waking: 10.6% | Confidence in ability to sustain abstinence (1–10 scale), mean: 6.3; Readiness to quit (1–10 scale), mean: 5.5 | Past year quit attempt: 42.9%

* Score of 15 and above indicates high motivation to quit.

† Score of 8 or greater indicates high nicotine dependence.

‡ 1 to 5 point Likert scale where a score of 1 indicates very low motivation to quit and a score of 5 indicates very high motivation to quit.

Abbreviations: ACEND = A study of Cessation using Electronic Nicotine Devices; AUTOS = autonomy over smoking scale; CPD = cigarettes per day; e-cig = electronic cigarette; ECLAT = EffiCacy and safety of an eLectronic cigarette; eCO = expired carbon monoxide; FTND = fagerstrom test of nicotine dependence; NR = not reported; PPM = parts per million; SES = socioeconomic status; TEC = Trial of Electronic Cigarettes

Appendix F Table 2 Intervention and Control Characteristics From Trials of Electronic Cigarettes for Tobacco Cessation

Author, Year; Trial name; Quality | # of trial arms | Primary e-cig component | Additional intervention components | Behavioral support component description | Number and length of visit(s) | Setting | Delivered intervention details | Adherence
Bullen, 2013^144^; ASCEND; Fair | 3 | ARM 1; Elusion e- cigs l with 16 mg/mL nicotine cartridges for 12 weeks; Participants received a free e-cig and sufficient nicotine cartridges to last for 4–5 weeks. Participants instructed to use the device exclusively for 12 weeks | ARM 2; NRT (Habitrol 21 mg patches); Participants allocated to patches were sent exchange cards in the mail redeemable for patches from community pharmacies, with instructions to use patches daily, from 1 week before until 12 weeks after their chosen quit day, consistent with smoking cessation guidelines; ARM 3; Placebo with 0 mg Elusion e-cigs; Participants received free e-cig and cartridges containing 0 mg nicotine labelled in such a way that participants cannot detect if they contain nicotine. | All participants referred to the New Zealand smoking cessation support helpline for a standardized cessation behavioral support program delivered by trained advisors, with a mini- mum of one follow-up support telephone call over 8–12 weeks. If participants did not want to receive this support, they had access other support services such as ‘Txt2Quit’ (a mobile phone-based sup- port service), ‘QuitCoach’ (an internet-based support service), and the ‘Quitter’s community’ (an internet-based blogging forum) | Total #: 4; Baseline visit, and 3 followup visits at months 1, 3 and 6.; Visit length: NR | Academic Clinics; Research investigator(s) | Participants using both nicotine and placebo e-cigs reported having used an average of 0·7 cartridges per day at 6 months; Nicotine patches were used as instructed (an average of one 21mg patch per day); At 6 months, in both the nicotine e-cig and NRT groups, two participants had used bupropion and five had used varenicline in the past month; in the placebo e-cig group, three participants reported using varenicline. | At the 6-month followup, adherence to study treatments was significantly higher in the nicotine e-cig group as compared with the NRT group (p<0·0001) and with the placebo e-cig group (p<0·0001); 29% (71/ 241) of the nicotine e-cig group and 35% (20 of 57) of the placebo e-cig group persisted with e-cigarette use, with only 8% (17/215) of those in the NRT group still using patches.
Caponnetto, 2013^145^; ECLAT; Fair | 3 | ARM 1; Categoria e-cig (model 401) with 7.2 mg nicotine cartridges used at will for 12 weeks; ARM 2; Categoria e-cig (model 401) with two 6-week supplies of cartridges, one of the 7.2 mg nicotine cartridges and a further 6 weeks with supply of 5.4 mg nicotine cartridges; used at will for 12 weeks total | ARM 3; Placebo with Categoria e-cig (model 401) e-cigs and 12 weeks supply of no-nicotine cartridges | NA | Total #: 9; baseline visit and eight follow up visits at weeks 2, 4, 6, 8, 10, 12, 24 and 52.; Visit length: With the exception of the baseline study day, most visits took about 10–15 minutes | Academic Clinics; Research investigator(s) | Median cartridge use at 6- and 12-month followup was 0 (IQR 0–2) for the whole cohort and did not differ between study arm | NR
Hajek, 2019^154^; TEC; Fair | 2 | One Kit (Aspire) e-cigs with 18mg nicotine cartridges for 52 weeks; After the initial 4-week trial period with One Kit cartridges participants were encouraged to experiment with e-liquids of different strengths and flavors | NRT with any type of product (patch, gum, lozenge, nasal spray, inhalator, mouth spray, mouth strip, and microtabs) for 52 weeks; Use of combinations was encouraged, typically the patch and a faster-acting oral product. Participants were also free to switch product at any time during the follow-up period. | All the participants received the same multisession behavioral support as per U.K. stop-smoking service practice. This support involved weekly one-on-one sessions with local clinicians, who also monitored expired carbon monoxide levels for at least 4 weeks after the quit date | Total #: 4; Baseline visit, and 3 followup visits at weeks 4, 26, and 52.; Visit length: NR | National Health Service (NHS) stop-smoking clinics; Primary care physicians and non-clinical research investigators | Most participants in the e-cig group started to purchase their own e-liquids from the first week onwards, with only 7% requesting the second bottle. The mean nicotine content was 18mg/ml, 12mg/ml and 8mg/ml at 4, 26 and 52 weeks, respectively.; 88% of NRT arm participants used NRT combinations. This comprised mostly patch plus one of the oral products | At 12 months follow-up, 5.7% of EC arm participants reported using non-allocated NRT for at least five consecutive days in the past six months and 22.2% of NRT arm participants reported using non-allocated EC
Lee, 2019^157^; Fair | 2 | ARM 1 E-cigarette (distributed in 12wk supply); ARM 2: Nicotine, gum (distributed in 12wk supply) | e-cigarette (eGO-C Ovale, nicotine 0.01 mg/mL; Janty-Korea Co., Janty-Asia Co., Seoul, Republic of Korea); Nicotine gum (Nicoman, nicotine 2 mg/tablet; Daewoong Pharmaceuticals, Seongnam, Republic of Korea) | 50min edu sessions on smoking cessation and the use of smoking-cessation aids were conducted in the medical office where the e-cigarette and nicotine gum were distributed.; subjects were instructed to visit the medical office every 4 weeks for evaluation and counseling by an independent health practitioner | Total #: 7; 1 50min session at BL; 1 medical office visit (length NR) every 4 wks for 24 wks | Medical (not specified); Subjects were recruited from a motor company | 4 (Arm 1) and 14 (Arm 2) withdrew before treatment | NR
Walker, 2019^155^; Fair | 3 | ARM 1; eVOD e-cigarette (2^nd^ gen) starter pack with a supply of 18mg/mL nicotine e-liquid cartridges used ad libitum for 14 weeks + NRT (as described in Arm 3) | ARM 2; eVOD e-cigarette (2^nd^ gen) starter pack with a supply of placebo (no nicotine) e-liquid cartridges used ad libitum for 14 weeks + NRT (as described in Arm 3); Participants randomized to e-cigs were allowed to choose between two preselected flavors of e-liquid in the starter packs, after which both e-cigarette groups were free to seek out new e-cigs and other e-liquids at will; ARM 3; NRT with a 21mg, 24-hour nicotine patch (Habitrol); one patch per day for 14 weeks | All groups received moderate-intensity, withdrawal-oriented behavioral support directly following randomization, then once a week for 6 weeks | Total #: 5; Baseline visit, and 3 followup visits at weeks 4, 12, 24, and 52.; Visit length: NR | Community-based intervention. Patients were recruited from the general population using national advertising | Use of allocated treatments decreased over time. At 3 months followup, only 50% of participants in all three groups were still using the patch and only 33% of participants randomized to e-cigs were still using their assigned product.; At 6 months, only 40% of participants in the patches only group were still using patches and 11% an 13% of participants were using both their allocated patches and ecigs in the nicotine e-cig and no nictotine e-cig groups respectively.; Participants only received a median of 3 of the 6 scheduled support calls with participants in ARM 1 receiving more calls than those in ARM 3. | In the patch-only group, 15% of the participants crossed over and used e-cigarettes and 11% in the placebo e-cig group reported using nicotine e-cigs
Carpenter, 2017^147^; Fair | 3 | ARM 1; BluCig Starter Pack, with 16 mg/mL nicotine used at will (with minimal instruction) for 4 months.; ARM 2; Midway through the study, the manufacturer of Blu altered the product and discontinued availability of the device, replaced with BluPlus+, with 24 mg/mL nicotine, again offered in both tobacco and menthol flavorings | ARM 3; Control group continued smoking with conventional cigarettes | NA | Total #: 7; Baseline visit and 6 follow up visits at weeks 2, 3, 4, 8, 12, and 16.; Visit length: NR | Academic Clinics; Research investigator(s) | 44/46 participants randomized to the e-cig group used the e-cig at least once. Most participants reported a high frequency of use during the sampling period (>5 days per week), which decreased to about 3 days per week during follow-up. Over the 21-day sampling period, average duration of e-cig use was 15.4 days among 16 mg e-cig participants and 17.0 days among the 24 mg e-cig group. Just under half (48%) of 24 mg e-cig participants used product all 21 days of the sampling period, versus 30% of 16 mg e-cig participants. | Overall compliance was modest but no different across groups: 58% of all sessions completed.
Cravo, 2016^148^; Fair | 2 | Prototype e-cig, developed by Fontem Ventures, with 2.7 mg nicotine capsules (menthol or tobacco flavor) for 12 weeks; Participants were provided with the e-cig and with sufficient capsules to last for the duration of the study; Each capsule expected to provide 40 to 60 puffs | Control group continued smoking with their own usual conventional cigarette brand for 12 weeks; mean ISO nicotine yield 0.81 mg and mean ISO tar yield 9.2 mg | NA | Total #: 8; Baseline visit and 7 followup visits at weeks 1, 2, 4, 6, 8, 10, and 12.; Visit length: NR | Ambulatory care settings; Research investigator(s) | Subjects in the e-cig arm used a mean of 3.29 to 4.15 capsules per day over the study weeks.; The mean daily CC use in the CC group over the 12 study weeks ranged from 12.33 to 14.1 CPD. | A total of 123 subjects (40.2%) were classified as “EVP- compliant” and 183 (59.8%) were classified as “less-EVP-compliant”. The proportion of EVP-compliant subjects was highest in the subgroup of subjects with lowest CPD consumption at baseline and decreased with increasing CPD at baseline. EVP-compliant subjects did not use more EVP capsules than less-compliant subjects.
Masiero, 2017^146^; Fair | 3 | ARM 1; VP5 e-cig with 8mg nicotine cartridges for 3 months.; Each participant received an e-cig kit and 12 10-mL liquid cartridges (8 mg/mL nicotine concentration) free of charge. Participants were asked to consume no more than 1 ml of the liquid a day. | ARM 2; Placebo e-cig with VP5 e-cig; Each participant received an e-cig kit and 12 10-mL liquid that did not contain nicotine free of charge. Participants were asked to consume no more than 1 ml of the liquid a day.; ARM 3; Behavioral support only | Participants in all arms also received a low-intensity telephone counseling; The counselor provided information, supported participants’ motivation, and helped them coping with possible roadblocks. The counseling was provided by trained psychologists. | Total #: 4; Baseline visit, and 3 followup visits at months 1, 2, and 3.; Visit length: behavioral counseling was delivered via a 10 min monthly telephone interview. Otherwise NR. | Oncology Clinics | Participants in Arm 3 reported smoking an average of 10.034 cigarettes/day, while participants in Arm 1 and Arm 2 showed a lower consumption (7.671 and 9.091, respectively). | Usage of the e-cig was assessed via a monthly telephone interview; Participants in Arm 1 and Arm 2 had a similar compliance in the use of e-cigs. And there was no significant difference, though the placebo group used on average less liquid (Arm 1 M = 10.9 empty flacons; Arm 2 M = 9.8 empty flacons).
Tseng, 2016^150^; Fair | 2 | ARM 1; NJOY, King Bold disposable e-cigs with 4.5% nicotine (tobacco flavor only) for 3 weeks; ARM 2; Placebo with no-nicotine NJOY, King Bold disposable e-cigarettes (tobacco flavor only) for 3 weeks; Minimum EC use instruction was provided | NR | Prior to receiving the ECs, subjects were required to complete a counseling session with a trained tobacco cessation counselor to review current smoking patterns and offer behavioral change strategies. These included specific smoking reduction options and other strategies to manage urges | Total #: 3; Baseline visit, and 2 followup visits at weeks 1 and 3.; Visit length: NR, but counseling visit was 20–30 min in length | Ambulatory care settings; Research investigator(s) | NR | NR

Abbreviations: ACEND = A study of Cessation using Electronic Nicotine Devices; CC = conventional cigarettes; CPD = cigarettes per day; e-cigs = electronic cigarettes; ECLAT = EffiCacy and safety of an eLectronic cigarette; NR = not reported; TEC = Trial of Electronic Cigarettes