# Appendix E Excluded Studies Lists

## Appendix E List 2 Excluded Studies List, Tobacco Cessation in Adults: Electronic Cigarettes

Exclusion Code | Definition
E1 | ESR aim not relevant
E2a | Not a systematic review
E2b | Does not describe search dates AND search databases AND search string
E2c | Does not indicate criteria used to select studies for inclusion
E2d | ESR among pharmacotherapy interventions among pregnant women (not included study design)
E3a | Population: ≥50% of studies included focus on children and adolescents, and stratified results not presented
E3b | Population: > 50% of the included studies focus on groups not generalizable to primary care (e.g., COPD), and stratified results not presented
E4 | Intervention: Not a relevant intervention (e.g., systems-level, broad public health intervention, harm reduction, second-line or off-label medications, relapse prevention)
E5 | Setting: > 50% of the included studies take place in settings not applicable to primary care (e.g., worksites, specialty care), and stratified results not presented
E6 | Outcomes: No relevant outcomes (exclude reviews that only report tobacco reduction; reduction in withdrawal symptoms; attitudes, knowledge, beliefs; intentions; etc.)
E7 | Outcome Assessment: > 50% of the included studies report outcomes at < 6 months follow up, and stratified results not presented (does not apply for KQ3/harms data)
E8 | Country: > 50% of included studies take place in countries not on the “Very High” list for Human Development
E9 | Review published in language other than English
E10 | Previous Review: Primary ESR that has been updated
E11 | Previous Review: Non-primary ESR that will not move forward
E12 | Poor Quality

1 [No authors listed]. Cardiac adverse effects of nicotine replacement therapy. Prescrire Int. 2015;24(166):292–3. PMID: 26788573. KQ1E2a, KQ2E2a, KQ3E2a.26788573
2 Afshin A, Babalola D, McLean M, . Information technology and lifestyle: a systematic evaluation of internet and mobile interventions for improving diet, physical activity, obesity, tobacco, and alcohol use. J Am Heart Assoc. 2016;5(9):e003058. PMID: 27581172. 10.1161/jaha.115.003058 KQ1E6, KQ2E12, KQ3E6.27581172
3 Aldi GA, Bertoli G, Ferraro F, . Effectiveness of pharmacological or psychological interventions for smoking cessation in smokers with major depression or depressive symptoms: a systematic review of the literature. Subst Abus. 2018;39(3):289–306. PMID: 29436984. 10.1080/08897077.2018.1439802 KQ1E6, KQ2E12, KQ3E12.29436984
4 Ali A, Kaplan CM, Derefinko KJ, . Smoking cessation for smokers not ready to quit: meta-analysis and cost-effectiveness analysis. Am J Prev Med. 2018;55(2):253–62. PMID: 29903568. 10.1016/j.amepre.2018.04.021 KQ1E6, KQ2E12, KQ3E6.29903568
5 Aubin HJ, Luquiens A, Berlin I. Pharmacotherapy for smoking cessation: pharmacological principles and clinical practice. Br J Clin Pharmacol. 2014;77(2):324–36. PMID: 23488726. 10.1111/bcp.12116 KQ1E2a, KQ2E2a, KQ3E2a.23488726
6 Banham L, Gilbody S. Smoking cessation in severe mental illness: what works? Addiction. 2010;105(7):1176–89. PMID: 20491721. KQ1E11, KQ2E11, KQ3E11.20491721
7 Bar-Zeev Y, Bonevski B, Lim LL, . Improving health providers smoking cessation care in pregnancy: a systematic review and meta-analysis. Addict Behav. 2019;93:29–38. PMID: 30684819. 10.1016/j.addbeh.2019.01.002 KQ1E6, KQ2E1, KQ3E6.30684819
8 Barnes J, Dong CY, McRobbie H, . Hypnotherapy for smoking cessation. Cochrane Database Syst Rev. 2010;10:CD001008. PMID: 20927723. KQ1E6, KQ2E10, KQ3E10.20927723
9 Barry K, Finke J. Nicotine replacement therapy for tobacco cessation. 2020;102(1):17–18. Am Fam Physician. KQ1E2a, KQ2E2a, KQ3E2a
10 Berger I, Mooney-Somers J. Smoking cessation programs for lesbian, gay, bisexual, transgender, and intersex people: a content-based systematic review. Nicotine Tob Res. 2017;19(12):1408–17. PMID: 27613909. 10.1093/ntr/ntw216 KQ1E6, KQ2E7, KQ3E6.27613909
11 Bize R, Burnand B, Mueller Y, . Biomedical risk assessment as an aid for smoking cessation. Cochrane Database Syst Rev. 2012;12:CD004705. PMID: 23235615. KQ1E6, KQ2E10, KQ3E6.23235615
12 Bodner ME, Dean E. Advice as a smoking cessation strategy: a systematic review and implications for physical therapists. Physiother Theory Pract. 2009;25(5–6):369–407. PMID: 19842864. KQ1E6, KQ2E11, KQ3E6.19842864
13 Brose LS, Simonavicius E, McNeill A. Maintaining abstinence from smoking after a period of enforced abstinence - systematic review, meta-analysis and analysis of behaviour change techniques with a focus on mental health. Psychol Med. 2018;48(4):669–678. PMID: 28780913. 10.1017/s0033291717002021 KQ1E1, KQ2E1, KQ3E1.28780913
14 Brown J. A review of the evidence on technology-based interventions for the treatment of tobacco dependence in college health. Worldviews Evid Based Nurs. 2013;10(3):150–62. PMID: 23421669. KQ1E6, KQ2E11, KQ3E6.23421669
15 Brown TJ, Hardeman W, Bauld L, . A systematic review of behaviour change techniques within interventions to prevent return to smoking postpartum. Addict Behav. 2019;92:236–43. PMID: 30731328. 10.1016/j.addbeh.2018.12.031 KQ1E6, KQ2E12, KQ3E6.30731328
16 Bull ER, McCleary N, Li X, . Interventions to promote healthy eating, physical activity and smoking in low-income groups: a systematic review with meta-analysis of behavior change techniques and delivery/context. Int J Behav Med. 2018;25(6):605–16. PMID: 30003476. 10.1007/s12529-018-9734-z KQ1E1, KQ2E1, KQ3E1.30003476
17 Bush T, Lovejoy JC, Deprey M, . The effect of tobacco cessation on weight gain, obesity, and diabetes risk. Obesity. 2016;24(9):1834–41. PMID: 27569117. 10.1002/oby.21582 KQ1E2a, KQ2E2a, KQ3E2a.27569117
18 Cahill K, Hartmann-Boyce J, Perera R. Incentives for smoking cessation. Cochrane Database Syst Rev. 2015;5:CD004307. PMID: 25983287. 10.1002/14651858.CD004307.pub5 KQ1E6, KQ2E10, KQ3E10.25983287
19 Cahill K, Lancaster T, Green N. Stage-based interventions for smoking cessation. Cochrane Database Sys Rev. 2010;11:CD004492. PMID: 21069681. KQ1E6, KQ2E11, KQ3E6.21069681
20 Cahill K, Stead LF, Lancaster T. Nicotine receptor partial agonists for smoking cessation. Cochrane Database Syst Rev. 2012;4:CD006103. PMID: 22513936. KQ1E6, KQ2E10, KQ3E10.22513936
21 Canadian Agency for Drugs and Technologies in Health. Nicotine Replacement Therapy for Smoking Cessation or Reduction: A Review of the Clinical Evidence. Ottawa, ON Canada: Canadian Agency for Drugs and Technologies in Health; 2014. PMID: 2474173024741730. KQ1E2a, KQ2E2a, KQ3E2a.
22 Canadian Agency for Drugs and Technologies in Health. Smoking Cessation Aids for Patients in Treatment for Substance Abuse: Clinical Effectiveness, Cost-Effectiveness and Guidelines. Ottawa, ON Canada: Canadian Agency for Drugs and Technologies in Health; 2015. KQ1E2a, KQ2E2a, KQ3E2a.
23 Canadian Agency for Drugs and Technologies in Health. Telehealth Delivery of Group Smoking Cessation Programs for Adolescents and Young Adults: Clinical Effectiveness. Ottawa, ON Canada: Canadian Agency for Drugs and Technologies in Health; 2015. KQ1E2a, KQ2E2a, KQ3E2a.
24 Canadian Agency for Drugs and Technologies in Health. Nicotine Replacement Therapy, Bupropion and Varenicline for Tobacco Cessation: A Review of Clinical Effectiveness. Ottawa, ON Canada: Canadian Agency for Drugs and Technologies in Health; 2016. KQ1E2a, KQ2E2a, KQ3E2a.
25 Canadian Agency for Drugs and Technologies in Health. Smoking Cessation Interventions for Patients With Severe Mental Illnesses: Clinical Effectiveness and Guidelines. Ottawa, ON Canada: Canadian Agency for Drugs and Technologies in Health; 2016. KQ1E2a, KQ2E2a, KQ3E2a.
26 Canadian Agency for Drugs and Technologies in Health. Pharmacological agents for smoking cessation: clinical effectiveness and cost-effectiveness (CADTH rapid response report: reference list). Ottawa, ON Canada: Canadian Agency for Drugs and Technologies in Health; 2017. KQ1E2a, KQ2E2a, KQ3E2a.
27 Canadian Agency for Drugs and Technologies in Health. Cytisine for Smoking Cessation: Clinical Effectiveness and Cost-Effectiveness. Ottawa, ON Canada: Canadian Agency for Drugs and Technologies in Health; 2017. KQ1E2a, KQ2E2a, KQ3E2a.
28 Carr AB, Ebbert J. Interventions for tobacco cessation in the dental setting. Cochrane Database Syst Rev. 2012;6:CD005084. PMID: 22696348. KQ1E6, KQ2E11, KQ3E6.22696348
29 Cawkwell PB, Blaum C, Sherman SE. Pharmacological smoking cessation therapies in older adults: a review of the evidence. Drugs Aging. 2015;32(6):443–51. PMID: 26025119. 10.1007/s40266-015-0274-9 KQ1E6, KQ2E12, KQ3E6.26025119
30 Chamberlain C, O’Mara-Eves A, Oliver S, . Psychosocial interventions for supporting women to stop smoking in pregnancy. Cochrane Database Syst Rev. 2013;10:CD001055. PMID: 24154953. KQ1E10, KQ2E10, KQ3E10.24154953
31 Chebli JL, Blaszczynski A, Gainsbury SM. Internet-based interventions for addictive behaviours: a systematic review. J Gambl Stud. 2016;32(4):1279–304. PMID: 27002522. 10.1007/s10899-016-9599-5 KQ1E6, KQ2E12, KQ3E6.27002522
32 Chen D, Wu LT. Smoking cessation interventions for adults aged 50 or older: a systematic review and meta-analysis. Drug Alcohol Depend. 2015;154:14–24. PMID: 26094185. 10.1016/j.drugalcdep.2015.06.004 KQ1E6, KQ2E12, KQ3E6.26094185
33 Chen YF, Madan J, Welton N, . Effectiveness and cost-effectiveness of computer and other electronic aids for smoking cessation: a systematic review and network meta-analysis. Health Technol Assess. 2012;16(38):1–v. PMID: 23046909. KQ1E6, KQ2E11, KQ3E6.23046909
34 Cheng HM, Chung YC, Chen HH, . Systematic review and meta-analysis of the effects of acupoint stimulation on smoking cessation. Am J Chin Med. 2012;40(3):429–42. PMID: 22745061. KQ1E6, KQ2E11, KQ3E6.22745061
35 Civljak M, Stead LF, Hartmann-Boyce J, . Internet-based interventions for smoking cessation. Cochrane Database Syst Rev. 2013;7:CD007078. PMID: 23839868. KQ1E6, KQ2E10, KQ3E6.23839868
36 Claire R, Chamberlain C, Davey MA, . Pharmacological interventions for promoting smoking cessation during pregnancy. Cochrane Database Syst Rev. 2020;3:CD010078. PMID: 32129504. 10.1002/14651858.CD010078.pub3 KQ1E2d, KQ2E2d, KQ3E2d.32129504
37 Coleman T, Chamberlain C, Davey MA, . Pharmacological interventions for promoting smoking cessation during pregnancy. Cochrane Database Syst Rev. 2012;9:CD010078. PMID: 22972148. KQ1E2d, KQ2E2d, KQ3E2d.22972148
38 Coleman T, Chamberlain C, Davey MA, . Pharmacological interventions for promoting smoking cessation during pregnancy. Cochrane Database Syst Rev. 2015;12:CD010078. PMID: 26690977. 10.1002/14651858.CD010078.pub2 KQ1E2d, KQ2E2d, KQ3E2d.26690977
39 de Souza IC, de Barros VV, Gomide HP, . Mindfulness-based interventions for the treatment of smoking: a systematic literature review. J Altern Complement Med. 2015;21(3):129–40. PMID: 25710798. 10.1089/acm.2013.0471 KQ1E6, KQ2E7, KQ3E6.25710798
40 Di YM, May BH, Zhang AL, . A meta-analysis of ear-acupuncture, ear-acupressure and auriculotherapy for cigarette smoking cessation. Drug Alcohol Depend. 2014;142:14–23. PMID: 25064021. KQ1E6, KQ2E11, KQ3E11.25064021
41 Drabkin A. Treatment for tobacco use. https://www.dynamed.com/management/treatment-for-tobacco-use-19/. Accessed Dec 20, 2017. KQ1E2a, KQ2E2a, KQ3E2a
42 Drovandi AD, Chen CC, Glass BD. Adverse effects cause varenicline discontinuation: a meta-analysis. Curr Drug Saf. 2016;11(1):78–85. PMID: 26412667. KQ1E6, KQ2E6, KQ3E12.26412667
43 DynaMed. Counseling for tobacco cessation. https://www.dynamed.com/management/counseling-for-tobacco-cessation. Accessed Dec 20, 2017. KQ1E2a, KQ2E2a, KQ3E2a.
44 DynaMed. Varenicline. https://www.dynamed.com/drug-monograph/varenicline. Accessed Dec 20, 2017. KQ1E2a, KQ2E2a, KQ3E2a.
45 Ebbert J, Montori VM, Erwin PJ, . Interventions for smokeless tobacco use cessation. Cochrane Database Syst Rev. 2011;2:CD004306. PMID: 21328266. KQ1E6, KQ2E11, KQ3E6.21328266
46 Evins AE, Cather C, Laffer A. Treatment of tobacco use disorders in smokers with serious mental illness: toward clinical best practices. Harv Rev Psychiatry. 2015;23(2):90–8. PMID: 25747922. 10.1097/hrp.0000000000000063 KQ1E2a, KQ2E2a, KQ3E2a.25747922
47 Fanshawe TR, Hartmann-Boyce J, Perera R, . Competitions for smoking cessation. Cochrane Database Syst Rev. 2019;2:CD013272. PMID: 30784046. 10.1002/14651858.Cd013272 KQ1E4, KQ2E4, KQ3E4.30784046
48 Filion KB, Abenhaim HA, Mottillo S, . The effect of smoking cessation counselling in pregnant women: a meta-analysis of randomised controlled trials. BJOG. 2011;118(12):1422–8. PMID: 21880109. KQ1E6, KQ2E11, KQ3E6.21880109
49 Garcia-Gomez L, Hernandez-Perez A, Noe-Diaz V, . Smoking cessation treatments: current psychological and pharmacological options. Rev Invest Clin. 2019;71(1):7–16. PMID: 30810545. 10.24875/ric.18002629 KQ1E2a, KQ2E2a, KQ3E2a.30810545
50 Gardner K, Kearns R, Woodland L, . A scoping review of the evidence on health promotion interventions for reducing waterpipe smoking: implications for practice. Front Public Health. 2018;6:308. PMID: 30456210. 10.3389/fpubh.2018.00308 KQ1E4, KQ2E4, KQ3E4.30456210
51 Ghorai K, Akter S, Khatun F, . mHealth for smoking cessation programs: a systematic review. J Pers Med. 2014;4:412–23. PMID: 25563359. 10.3390/jpm4030412 KQ1E6, KQ2E6, KQ3E6.25563359
52 Gierisch JM, Bastian LA, Calhoun PS, . Comparative Effectiveness of Smoking Cessation Treatments for Patients With Depression: A Systematic Review and Meta-Analysis of the Evidence. Washington, DC: Department of Veterans Affairs; 2010. PMID: 2129064021290640. KQ1E6, KQ2E11, KQ3E11.
53 Gomez-Coronado N, Walker AJ, Berk M, . Current and emerging pharmacotherapies for cessation of tobacco smoking. Pharmacotherapy. 2018;38(2):235–58. PMID: 29250815. 10.1002/phar.2073 KQ1E2a, KQ2E2a, KQ3E2a.29250815
54 Gould GS, Lim LL, Mattes J. Prevention and treatment of smoking and tobacco use during pregnancy in selected Indigenous communities in high-income countries of the United States, Canada, Australia, and New Zealand: an evidence-based review. Chest. 2017;152(4):853–66. PMID: 28694200. 10.1016/j.chest.2017.06.033 KQ1E2a, KQ2E2a, KQ3E2a.28694200
55 Gulliver A, Farrer L, Chan JK, . Technology-based interventions for tobacco and other drug use in university and college students: a systematic review and meta-analysis. Addict Sci Clin Pract. 2015;10:5. PMID: 25928221. 10.1186/s13722-015-0027-4 KQ1E6, KQ2E7, KQ3E6.25928221
56 Hartmann-Boyce J, Lancaster T, Stead LF. Print-based self-help interventions for smoking cessation. Cochrane Database Syst Rev. 2014;6:CD001118. PMID: 24888233. KQ1E6, KQ2E10, KQ3E6.24888233
57 Haskins BL, Lesperance D, Gibbons P, . A systematic review of smartphone applications for smoking cessation. Transl Behav Med. 2017;7(2):292–9. PMID: 28527027. 10.1007/s13142-017-0492-2 KQ1E6, KQ2E6, KQ3E6.28527027
58 Hendrick V, Suri R, Gitlin MJ, . Bupropion use during pregnancy: a systematic review. Prim Care Companion CNS Disord. 2017;19(5):21. PMID: 28973846. 10.4088/PCC.17r02160 KQ1E2d, KQ2E2d, KQ3E2d.28973846
59 Hettema JE, Hendricks PS. Motivational interviewing for smoking cessation: a meta-analytic review. J Consult Clin Psychol. 2010;78(6):868–84. PMID: 21114344. KQ1E6, KQ2E11, KQ3E6.21114344
60 Hickson C, Lewis S, Campbell KA, . Comparison of nicotine exposure during pregnancy when smoking and abstinent with nicotine replacement therapy: systematic review and meta-analysis. Addiction. 2019;114(3):406–24. PMID: 30315598. 10.1111/add.14473 KQ1E2d, KQ2E2d, KQ3E2d.30315598
61 Hollands GJ, McDermott MS, Lindson-Hawley N, . Interventions to increase adherence to medications for tobacco dependence. Cochrane Database Syst Rev. 2015(2):CD009164. PMID: 25914910. 10.1002/14651858.CD009164.pub2 KQ1E6, KQ2E10, KQ3E10.25914910
62 Hsieh MT, Tseng PT, Wu YC, . Effects of different pharmacologic smoking cessation treatments on body weight changes and success rates in patients with nicotine dependence: a network meta-analysis. Obes Rev. 2019;20(6):895–905. PMID: 30816006. 10.1111/obr.12835 KQ1E6, KQ2E6, KQ3E6.30816006
63 Huang Y, Li W, Yang L, . Long-term efficacy and safety of varenicline for smoking cessation: a systematic review and meta-analysis of randomized controlled trials. J Public Health. 2012;20(4):355–65. KQ1E6, KQ2E11, KQ3E11.
64 Hubbard G, Gorely T, Ozakinci G, . A systematic review and narrative summary of family-based smoking cessation interventions to help adults quit smoking. BMC Fam Pract. 2016;17:73. PMID: 27342987. 10.1186/s12875-016-0457-4 KQ1E6, KQ2E4, KQ3E6.27342987
65 Hughes JR. Varenicline as a cause of suicidal outcomes. Nicotine Tob Res. 2016;18(1):2–9. PMID: 25572451. 10.1093/ntr/ntu275 KQ1E2a, KQ2E2a, KQ3E2a.25572451
66 Hughes JR, Stead LF, Hartmann BJ, . Antidepressants for smoking cessation. Cochrane Database Syst Rev. 2014;1:CD000031. PMID: 24402784. KQ1E6, KQ2E10, KQ3E10.24402784
67 Hurst D. Nicotine lozenges and behavioural interventions may help smokeless tobacco users to quit. Evid Based Dent. 2015;16(4):104–5. PMID: 26680516. 10.1038/sj.ebd.6401129 KQ1E2a, KQ2E2a, KQ3E2a.26680516
68 Hutton HE, Wilson LM, Apelberg BJ, . A systematic review of randomized controlled trials: web-based interventions for smoking cessation among adolescents, college students, and adults. Nicotine Tob Res. 2011;13(4):227–38. PMID: 21350042. KQ1E6, KQ2E11, KQ3E6.21350042
69 Jahagirdar D, Kaunelis D. Smoking Cessation Interventions for Patients With Severe Mental Illnesses: A Review of Clinical Effectiveness and Guidelines. Ottawa, ON Canada: Canadian Agency for Drugs and Technologies in Health; 2017. KQ1E2a, KQ2E2a, KQ3E2a.
70 Jawad M, Jawad S, Waziry RK, . Interventions for waterpipe tobacco smoking prevention and cessation: a systematic review. Sci Rep. 2016;6:25872. PMID: 27167891. 10.1038/srep25872 KQ1E6, KQ2E7, KQ3E6.27167891
71 Kittle J, Lopes RD, Huang M, . Cardiovascular adverse events in the drug-development program of bupropion for smoking cessation: a systematic retrospective adjudication effort. Clin Cardiol. 2017;40(10):899–906. PMID: 28605035. 10.1002/clc.22744 KQ1E6, KQ2E6, KQ3E2a.28605035
72 Lai Douglas TC, Cahill K, Qin Y, . Motivational interviewing for smoking cessation. Cochrane Database Syst Rev. 2010;1:CD006936. PMID: 20091612. KQ1E6, KQ2E11, KQ3E6.20091612
73 Lee EB, An W, Levin ME, . An initial meta-analysis of acceptance and commitment therapy for treating substance use disorders. Drug Alcohol Depend. 2015;155:1–7. PMID: 26298552. 10.1016/j.drugalcdep.2015.08.004 KQ1E6, KQ2E12, KQ3E6.26298552
74 Lee J, Matthews A, McCullen C, . Promotion of tobacco use cessation for lesbian, gay, bisexual, and transgender people: a systematic review. Am J Prev Med. 2014;47(6):823–31. PMID: 25455123. 10.1016/j.amepre.2014.07.051 KQ1E6, KQ2E7, KQ3E6.25455123
75 Lee PN, Fariss MW. A systematic review of possible serious adverse health effects of nicotine replacement therapy. Arch Toxicol. 2017;91(4):1565–94. PMID: 27699443. 10.1007/s00204-016-1856-y KQ1E6, KQ2E6, KQ3E2d.27699443
76 Lemhoefer C, Rabe GL, Wellmann J, . Emergency department-initiated tobacco control: update of a systematic review and meta-analysis of randomized controlled trials. Prev Chronic Dis. 2017;14:E89. PMID: 28981403. 10.5888/pcd14.160434 KQ1E6, KQ2E7, KQ3E6.28981403
77 Leung LW, Davies GA. Smoking cessation strategies in pregnancy. J Obstet Gynaecol Can. 2015;37(9):791–7. PMID: 26605448. 10.1016/S1701-2163(15)30149-3 KQ1E2a, KQ2E2a, KQ3E2a.26605448
78 Likis F, Andrews J, Fonnesbeck C, . Smoking Cessation Interventions in Pregnancy and Postpartum Care. Rockville, MD: 2014. KQ1E11, KQ2E11, KQ3E11.
79 Lindson-Hawley N, Thompson TP, Begh R. Motivational interviewing for smoking cessation. Cochrane Database Syst Rev. 2015;3:CD006936. 10.1002/14651858.CD006936.pub3 KQ1E6, KQ2E10, KQ3E6.
80 Lumley J, Chamberlain C, Dowswell T, . Interventions for promoting smoking cessation during pregnancy. Cochrane Database Syst Rev. 2009;3:CD001055. PMID: 19588322. KQ1E11, KQ2E11, KQ3E11.19588322
81 Maglione MA, Maher AR, Ewing B, . Efficacy of mindfulness meditation for smoking cessation: a systematic review and meta-analysis. Addict Behav. 2017;69:27–34. PMID: 28126511. 10.1016/j.addbeh.2017.01.022 KQ1E6, KQ2E7, KQ3E6.28126511
82 Martin Cantera C, Puigdomenech E, Ballve JL, . Effectiveness of multicomponent interventions in primary healthcare settings to promote continuous smoking cessation in adults: a systematic review. BMJ Open. 2015;5(10):e008807. PMID: 26428333. 10.1136/bmjopen-2015-008807 KQ1E6, KQ2E12, KQ3E6.26428333
83 Maziak W, Jawad M, Jawad S, . Interventions for waterpipe smoking cessation. Cochrane Database Syst Rev. 2015;7:CD005549. PMID: 26228266. 10.1002/14651858.CD005549.pub3 KQ1E8, KQ2E8, KQ3E8.26228266
84 Merriel S, Andrews V, Salisbury C. Telehealth interventions for primary prevention of cardiovascular disease: a systematic review and meta-analysis. Prev Med. 2014;64:88–95. PMID: 24726502. 10.1016/j.ypmed.2014.04.001 KQ1E1, KQ2E1, KQ3E1.24726502
85 Mills EJ, Wu P, Lockhart I, . Comparisons of high-dose and combination nicotine replacement therapy, varenicline, and bupropion for smoking cessation: a systematic review and multiple treatment meta-analysis. Ann Med. 2012;44(6):588–97. PMID: 22860882. KQ1E6, KQ2E11, KQ3E6.22860882
86 Momin B, Neri A, McCausland K, . Traditional and innovative promotional strategies of tobacco cessation services: a review of the literature. J Community Health. 2014;39(4):800–9. PMID: 24515948. 10.1007/s10900-014-9825-y KQ1E1, KQ2E1, KQ3E1.24515948
87 Montgomery L, Robinson C, Seaman EL, . A scoping review and meta-analysis of psychosocial and pharmacological treatments for cannabis and tobacco use among African Americans. Psychol Addict Behav. 2017;31(8):922–43. PMID: 29199844. 10.1037/adb0000326 KQ1E6, KQ2E12, KQ3E6.29199844
88 Morales-Rosado JA, Cousin MA, Ebbert JO, . A critical review of repurposing apomorphine for smoking cessation. Assay Drug Dev Technol. 2015;13(10):612–22. PMID: 26690764. 10.1089/adt.2015.680 KQ1E2a, KQ2E2a, KQ3E2a.26690764
89 Morozova M, Rabin RA, George TP. Co-morbid tobacco use disorder and depression: a re-evaluation of smoking cessation therapy in depressed smokers. Am J Addict. 2015;24(8):687–94. PMID: 26354720. 10.1111/ajad.12277 KQ1E12, KQ2E12, KQ3E12.26354720
90 Mottillo S, Filion KB, Belisle P, . Behavioural interventions for smoking cessation: a meta-analysis of randomized controlled trials. Eur Heart J. 2009;30(6):718–30. PMID: 19109354. KQ1E6, KQ2E11, KQ3E6.19109354
91 Muhlig S, Paulick J, Lindenmeyer J, . Applying the ‘cognitive bias modification’ concept to smoking cessation-a systematic review. Sucht. 2016;62(6):333–54. 10.1024/0939-5911/a000454 KQ1E6, KQ2E6, KQ3E6.
92 Myung SK, Ju W, Jung HS, . Efficacy and safety of pharmacotherapy for smoking cessation among pregnant smokers: a meta-analysis. BJOG. 2012;119(9):1029–39. PMID: 22780818. KQ1E2d, KQ2E2d, KQ3E2d.22780818
93 Myung SK, McDonnell DD, Kazinets G, . Effects of Web- and computer-based smoking cessation programs. Arch Intern Med. 2009;169(10):929–37. PMID: 19468084. KQ1E6, KQ2E11, KQ3E6.19468084
94 Naslund JA, Kim SJ, Aschbrenner KA, . Systematic review of social media interventions for smoking cessation. Addict Behav. 2017;73:81–93. PMID: 28499259. 10.1016/j.addbeh.2017.05.002 KQ1E6, KQ2E7, KQ3E6.28499259
95 Nethan ST, Sinha DN, Chandan K, . Smokeless tobacco cessation interventions: a systematic review. Indian J Med Res. 2018;148(4):396–410. PMID: 30666002. 10.4103/ijmr.IJMR_1983_17 KQ1E6, KQ2E12, KQ3E6.30666002
96 Nierkens V, Hartman MA, Nicolaou M, . Effectiveness of cultural adaptations of interventions aimed at smoking cessation, diet, and/or physical activity in ethnic minorities. a systematic review. PLoS One. 2013;8(10):e73373. PMID: 24116000. KQ1E6, KQ2E11, KQ3E6.24116000
97 Norris AR, Miller JE. Motivational interviewing or counseling, medical therapies or no intervention to improve tobacco cessation in adults and adolescents. J Okla State Med Assoc. 2017;110(3):142–3. PMID: 29298020. KQ1E2a, KQ2E2a, KQ3E2a.29298020
98 Oikonomou MT, Arvanitis M, Sokolove RL. Mindfulness training for smoking cessation: a meta-analysis of randomized-controlled trials. J Health Psychol. 2017;22(14):1841–50. PMID: 27044630. 10.1177/1359105316637667 KQ1E6, KQ2E7, KQ3E6.27044630
99 Omana-Cepeda C, Jane-Salas E, Estrugo-Devesa A, . Effectiveness of dentist’s intervention in smoking cessation: a review. J Clin Exp Dent. 2016;8(1):e78–83. PMID: 26855711. 10.4317/jced.52693 KQ1E6, KQ2E12, KQ3E6.26855711
100 Oosterveen E, Tzelepis F, Ashton L, . A systematic review of eHealth behavioral interventions targeting smoking, nutrition, alcohol, physical activity and/or obesity for young adults. Prev Med. 2017;99:197–206. PMID: 28130046. 10.1016/j.ypmed.2017.01.009 KQ1E6, KQ2E7, KQ3E6.28130046
101 Park E. Behavioral approaches to smoking cessation. https://www.uptodate.com/contents/behavioral-approaches-to-smoking-cessation. Accessed Dec 13, 2017. KQ1E2a, KQ2E2a, KQ3E2a.
102 Peletidi A, Nabhani-Gebara S, Kayyali R. Smoking cessation support services at community pharmacies in the UK: a systematic review. Hellenic J Cardiol. 2016;57(1):7–15. PMID: 26856195. KQ1E4, KQ2E4, KQ3E4.26856195
103 Posadzki P, Choi J, Lee M, . Yoga for addictions: a systematic review of randomised clinical trials (Provisional abstract). Focus Altern Complement Ther. 2014;19(1):1–8. KQ1E6, KQ2E6, KQ3E6.
104 Prochaska JJ, Hilton JF. Risk of cardiovascular serious adverse events associated with varenicline use for tobacco cessation: systematic review and meta-analysis. BMJ. 2012;344:e2856. PMID: 22563098. KQ1E6, KQ2E6, KQ3E10.22563098
105 Ramseier CA, Suvan JE. Behaviour change counselling for tobacco use cessation and promotion of healthy lifestyles: a systematic review. J Clin Periodontol. 2015;42(Suppl 16):S47–58. PMID: 25496370. 10.1111/jcpe.12351 KQ1E6, KQ2E2a, KQ3E6.25496370
106 Rice VH, Hartmann-Boyce J, Stead LF. Nursing interventions for smoking cessation. Cochrane Database Syst Rev. 2013;8:CD001188. PMID: 23939719. KQ1E6, KQ2E10, KQ3E6.23939719
107 Rigotti N. Benefits and risks of smoking cessation. https://www.uptodate.com/contents/benefits-and-risks-of-smoking-cessation. Accessed Dec 13, 2017. KQ1E2a, KQ2E2a, KQ3E2a.
108 Rigotti NA. Overview of smoking cessation management in adults. https://www.uptodate.com/contents/overview-of-smoking-cessation-management-in-adults. Accessed Dec 13, 2017. KQ1E2a, KQ2E2a, KQ3E2a.
109 Rigotti NA. Pharmacotherapy for smoking cessations in adults. https://www.uptodate.com/contents/pharmacotherapy-for-smoking-cessation-in-adults. Accessed Dec 13, 2017. KQ1E2a, KQ2E2a, KQ3E2a.
110 Schwindt R, Hudmon KS, Knisely M, . Impact of tobacco quitlines on smoking cessation in persons with mental illness: a systematic review. J Drug Educ. 2017;47(1–2):68–81. PMID: 29534595. 10.1177/0047237918762104 KQ1E12, KQ2E12, KQ3E6.29534595
111 Scott-Sheldon LA, Lantini R, Jennings EG, . Text messaging-based interventions for smoking cessation: a systematic review and meta-analysis. JMIR mHealth uHealth. 2016;4(2):e49. PMID: 27207211. 10.2196/mhealth.5436 KQ1E6, KQ2E7, KQ3E6.27207211
112 Secades-Villa R, Gonzalez-Roz A, Garcia-Perez A, . Psychological, pharmacological, and combined smoking cessation interventions for smokers with current depression: a systematic review and meta-analysis. PLoS One. 2017;12(12):e0188849. PMID: 29206852. 10.1371/journal.pone.0188849 KQ1E6, KQ2E12, KQ3E12.29206852
113 Shahab L, McEwen A. Online support for smoking cessation: a systematic review of the literature. Addiction. 2009;104(11):1792–804. PMID: 19832783. KQ1E6, KQ2E11, KQ3E6.19832783
114 Si S, Moss J, Sullivan T, . Effectiveness of general practice-based health checks: a systematic review and meta-analysis (Structured abstract). Br J Gen Pract. 2014;64(618):e47–e53. KQ1E1, KQ2E1, KQ3E1.24567582
115 Spohr SA, Nandy R, Gandhiraj D, . Efficacy of SMS text message interventions for smoking cessation: a meta-analysis. J Subst Abuse Treat. 2015;56:1–10. PMID: 25720333. 10.1016/j.jsat.2015.01.011 KQ1E6, KQ2E12, KQ3E6.25720333
116 Stead LF, Hartmann BJ, Perera R, . Telephone counselling for smoking cessation. Cochrane Database Syst Rev. 2013;8:CD002850. PMID: 23934971. KQ1E6, KQ2E10, KQ3E6.23934971
117 Stead LF, Koilpillai P, Lancaster T. Additional behavioural support as an adjunct to pharmacotherapy for smoking cessation. Cochrane Database Syst Rev. 2015;10:CD009670. PMID: 26457723. 10.1002/14651858.CD009670.pub3 KQ1E6, KQ2E10, KQ3E6.26457723
118 Stead LF, Lancaster T. Combined pharmacotherapy and behavioural interventions for smoking cessation. Cochrane Database Syst Rev. 2012;10:CD008286. PMID: 23076944. KQ1E6, KQ2E10, KQ3E6.23076944
119 Stead LF, Lancaster T. Behavioural interventions as adjuncts to pharmacotherapy for smoking cessation. Cochrane Database Syst Rev. 2013;12:CD009670. PMID: 23235680. KQ1E6, KQ2E10, KQ3E6.23235680
120 Stead LF, Perera R, Bullen C, . Nicotine replacement therapy for smoking cessation. Cochrane Database Syst Rev. 2012;11:CD000146. PMID: 23152200. KQ1E6, KQ2E10, KQ3E10.23152200
121 Stubbs B, Vancampfort D, Bobes J, . How can we promote smoking cessation in people with schizophrenia in practice? A clinical overview. Acta Psychiatr Scand. 2015;132(2):122–30. PMID: 25754402. 10.1111/acps.12412 KQ1E2a, KQ2E2a, KQ3E2a.25754402
122 Su A, Buttenheim AM. Maintenance of smoking cessation in the postpartum period: which interventions work best in the long-term? Matern Child Health J. 2014;18(3):714–28. PMID: 23812798. KQ1E6, KQ2E11, KQ3E6.23812798
123 Sun Y, Duan W, Meng X, . Varenicline is associated with a modest limitation in weight gain in smokers after smoking cessation: a meta-analysis. J Public Health (Oxf). 2018;40(2):e126–e132. PMID: 28505296. 10.1093/pubmed/fdx056 KQ1E6, KQ2E6, KQ3E12.28505296
124 Tahiri M, Mottillo S, Joseph L, . Alternative smoking cessation aids: a meta-analysis of randomized controlled trials. Am J Med. 2012;125(6):576–84. PMID: 22502956. KQ1E6, KQ2E11, KQ3E6.22502956
125 Thomas KH, Caldwell D, Dalili MN, . How do smoking cessation medicines compare with respect to their neuropsychiatric safety? A protocol for a systematic review, network meta-analysis and cost-effectiveness analysis. BMJ Open. 2017;7(6):e015414. PMID: 28624760. 10.1136/bmjopen-2016-015414 KQ1E2a, KQ2E2a, KQ3E2a.28624760
126 Tran K, Argáez C. Smoking Reduction and Cessation Interventions for Pregnant Women and Mothers of Infants: A Review of the Clinical Effectiveness. Ottawa: CADTH; 2017. KQ1E2a, KQ2E2a, KQ3E2a.
127 Tran K, Asakawa K, Cimon K, . Pharmacologic-based strategies for smoking cessation: clinical and cost-effectiveness analyses. CADTH Technol Overv. 2012;2(3):e2303. KQ1E6, KQ2E11, KQ3E11.23002381
128 Turner E, Jones M, Vaz LR, . Systematic review and meta-analysis to assess the safety of buproprion and varenicline in pregnancy. Nicotine Tob Res. 2019;21(8):1001–1010. PMID: 29579233. 10.1093/ntr/nty055 KQ1E2d, KQ2E2d, KQ3E2d.29579233
129 Tutka P, Vinnikov D, Courtney RJ, . Cytisine for nicotine addiction treatment: a review of pharmacology, therapeutics and an update of clinical trial evidence for smoking cessation. Addiction. 2019;[Epub ahead of print]. PMID: 31240783. 10.1111/add.14721 KQ1E6, KQ2E12, KQ3E12.31240783
130 Tzelepis F, Paul CL, Walsh RA, . Proactive telephone counseling for smoking cessation: meta-analyses by recruitment channel and methodological quality. J Natl Cancer Inst. 2011;103(12):922–41. PMID: 21666098. KQ1E6, KQ2E11, KQ3E6.21666098
131 Tzelepis F, Paul CL, Williams CM, . Real-time video counselling for smoking cessation. Cochrane Database Syst Rev. 2019;10:CD012659. 10.1002/14651858.CD012659 KQ1E2a, KQ2E2a, KQ3E2a.
132 Ussher MH, Taylor AH, Faulkner GE. Exercise interventions for smoking cessation. Cochrane Database Syst Rev. 2014;8:CD002295. PMID: 25170798. KQ1E6, KQ2E10, KQ3E6.25170798
133 Veisani Y, Jenabi E, Delpisheh A, . Effect of prenatal smoking cessation interventions on birth weight: meta-analysis. J Matern Fetal Neonatal Med. 2019;32(2):332–8. PMID: 28889768. 10.1080/14767058.2017.1378335 KQ1E12, KQ2E12, KQ3E6.28889768
134 Villanti AC, McKay HS, Abrams DB, . Smoking-cessation interventions for U.S. young adults: a systematic review. Am J Prev Med. 2010;39(6):564–74. PMID: 21084078. KQ1E6, KQ2E12, KQ3E6.21084078
135 Vogeler T, McClain C, Evoy KE. Combination bupropion SR and varenicline for smoking cessation: a systematic review. Am J Drug Alcohol Abuse. 2016;42(2):129–39. PMID: 26809272. 10.3109/00952990.2015.1117480 KQ1E6, KQ2E12, KQ3E12.26809272
136 Ward KD, Siddiqi K, Ahluwalia JS, . Waterpipe tobacco smoking: the critical need for cessation treatment. Drug Alcohol Depend. 2015;153:14–21. PMID: 26054945. 10.1016/j.drugalcdep.2015.05.029 KQ1E2a, KQ2E2a, KQ3E2a.26054945
137 Washio Y, Cassey H. Systematic review of interventions for racial/ethnic-minority pregnant smokers. J Smok Cessat. 2016;11(1):12–27. PMID: 26925170. 10.1017/jsc.2014.12 KQ1E12, KQ2E12, KQ3E6.26925170
138 Whittaker R, McRobbie H, Bullen C, . Mobile phone-based interventions for smoking cessation. Cochrane Database Syst Rev. 2012;11:CD006611. PMID: 23152238. KQ1E6, KQ2E10, KQ3E6.23152238
139 Whittaker R, McRobbie H, Bullen C, . Mobile phone-based interventions for smoking cessation. Cochrane Database Syst Rev. 2016;4:CD006611. PMID: 27060875. 10.1002/14651858.CD006611.pub4 KQ1E6, KQ2E10, KQ3E6.27060875
140 Wray JM, Funderburk JS, Acker JD, . A meta-analysis of brief tobacco interventions for use in integrated primary care. Nicotine Tob Res. 2018;20(12):1418–1426. PMID: 29059419. 10.1093/ntr/ntx212 KQ1E6, KQ2E12, KQ3E6.29059419
141 Ybarra ML, Jiang Y, Free C, . Participant-level meta-analysis of mobile phone-based interventions for smoking cessation across different countries. Prev Med. 2016;89:90–7. PMID: 27154349. 10.1016/j.ypmed.2016.05.002 KQ1E2a, KQ2E2a, KQ3E2a.27154349
142 Zbikowski SM, Magnusson B, Pockey JR, . A review of smoking cessation interventions for smokers aged 50 and older. Maturitas. 2012;71(2):131–41. PMID: 22209349. KQ1E6, KQ2E12, KQ3E6.22209349

Exclusion Code | Definition
E1 | Study aim not relevant
E2 | Study design
E3 | Population
E4 | Outcomes: No relevant outcomes (exclude trials that only report tobacco reduction; reduction in withdrawal symptoms; attitudes, knowledge, beliefs; intentions; etc.)
E5 | Setting
E6 | Poor Quality
E7 | Publication Type

1 [No author listed]. Correction to: Electronic cigarette use and myocardial infarction among adults in the US population: assessment of tobacco and health (J Am Heart Assoc, (2019), 8, 12, 10.1161/JAHA.119.012317). J Am Heart Assoc. 8(21). 2019. KQ1E2, KQ2E2, KQ3E2
2 [No author listed]. Retraction to: Electronic cigarette use and myocardial infarction among adults in the US population: assessment of tobacco and health. J Am Heart Assoc. 2020;9(4):e014519. KQ1E2, KQ2E2, KQ3E232066313
3 Brownson EG, Thompson CM, . Explosion injuries from e-cigarettes. N Engl J Med. 2016;375(14):1400–1402. PMID: 27705271. 10.1056/NEJMc1608478 KQ1E2, KQ2E2, KQ3E227705271
4 Baldassarri SR, Bernstein SL, . Electronic cigarettes for adults with tobacco dependence undergoing a tobacco treatment program: a pilot prospective study. Am J Respir Crit Care Med. 2016;193(Meeting Abstracts):A6511. KQ1E4, KQ2E6, KQ3E4
5 Baldassarri SR, Bernstein SL, . Electronic cigarettes for adults with tobacco dependence enrolled in a tobacco treatment program: a pilot study. Addict Behav. 2018;80:1–5. PMID: 29304395. 10.1016/j.addbeh.2017.11.033 KQ1E4, KQ2E6, KQ3E429304395
6 Barkat SS, Tellier SM, . Varenicline for cessation from nicotine-containing electronic cigarettes. Am J Health Syst Pharm. 2019;76(23):1894–1895. KQ1E2, KQ2E2, KQ3E231586415
7 Beard E, Brown J, . Is prevalence of e-cigarette and nicotine replacement therapy use among smokers associated with average cigarette consumption in England? A time-series analysis. BMJ Open. 2018;8(6):e016046. PMID: 29921676. 10.1136/bmjopen-2017-016046 KQ1E4, KQ2E2, KQ3E429921676
8 Benmarhnia T, Pierce JP, . Can e-cigarettes and pharmaceutical aids increase smoking cessation and reduce cigarette consumption? Findings from a nationally representative cohort of American smokers. Am J Epidemiol. 2018;187(11):2397–2404. PMID: 29955810. 10.1093/aje/kwy129 KQ1E4, KQ2E2, KQ3E429955810
9 Bhatta DN, Glantz SA. Association of e-cigarette use with respiratory disease among adults: a longitudinal analysis. Am J Prev Med. 2020;58(2):182–90. KQ1E2, KQ2E4, KQ3E431859175
10 Bhatta DN, Glantz SA. Electronic cigarette use and myocardial infarction among adults in the US population assessment of tobacco and health. J Am Heart Assoc. 2019;8(12):e012317. KQ1E2, KQ2E2, KQ3E231165662
11 Blagev DP, Harris D, . Clinical presentation, treatment, and short-term outcomes of lung injury associated with e-cigarettes or vaping: a prospective observational cohort study. Lancet. 2019;394(10214):2073–2083. KQ1E2, KQ2E2, KQ3E231711629
12 Borrelli B, O’Connor GT. E-cigarettes to assist with smoking cessation. N Engl J Med. 2019;380(7):678–679. PMID: 30699299. 10.1056/NEJMe1816406 KQ1E2, KQ2E2, KQ3E230699299
13 Brady BR, Crane TE, . Electronic cigarette use and tobacco cessation in a state-based quitline. J Smok Cessat. 2019;14(3):176–185. 10.1017/jsc.2019.2 KQ1E4, KQ2E2, KQ3E4
14 Campagna D, Cibella F, . Changes in breathomics from a 1-year randomized smoking cessation trial of electronic cigarettes. Eur J Clin Invest. 2016;46(8):698–706. PMID: 27322745. 10.1111/eci.12651 KQ1E4, KQ2E4, KQ3E427322745
15 Cibella F, Campagna D, . Lung function and respiratory symptoms in a randomized smoking cessation trial of electronic cigarettes. Clin Sci (Lond). 2016;130(21):1929–37. PMID: 27543458. 10.1042/cs20160268 KQ1E4, KQ2E4, KQ3E427543458
16 Coleman BN, Rostron B, . Electronic cigarette use among US adults in the Population Assessment of Tobacco and Health (PATH) Study, 2013–2014. Tob Control. 2017;26(e2):e117–e126. PMID: 28624763. 10.1136/tobaccocontrol-2016-053462 KQ1E2, KQ2E2, KQ3E428624763
17 Collins SE, Nelson LA, . Harm reduction treatment for smoking (HaRT-S): findings from a single-arm pilot study with smokers experiencing chronic homelessness. Subst Abus. 2019;40(2):229–239. PMID: 30924732. 10.1080/08897077.2019.1572049 KQ1E2, KQ2E2, KQ3E430924732
18 Dahal R, Adhikari K, . Smoking cessation and improvement in mental health outcomes: do people who quit smoking by switching to electronic cigarettes experience improvement in mental health? Can J Psychiatry. 2020;65(7):512–514. KQ1E2, KQ2E2, KQ3E232242744
19 Dobbie F, Hiscock R, . Evaluating Long-term Outcomes of NHS Stop Smoking Services (ELONS): a prospective cohort study. Health Technol Assess. 2015;19(95):1–156. PMID: 26565129. 10.3310/hta19950 KQ1E1, KQ2E1, KQ3E126565129
20 Eisenhofer J, Makanjuola T, . Efficacy of electronic cigarettes for smoking cessation in veterans. Drug Alcohol Depend. 2015;156:e63–e64. 10.1016/j.drugalcdep.2015.07.1091 KQ1E7, KQ2E7, KQ3E7
21 Ely J. Evaluation of the Use of Electric Cigarettes in a Rural Smoking Cessation Program. College of Natural and Health Sciences. Doctor of Nursing Practice. 2013. KQ1E2, KQ2E2, KQ3E2
22 Fairchild AL, Lee JS, . E-cigarettes and the harm-reduction continuum. N Engl J Med. 2018;378(3):216–219. PMID: 29342380. 10.1056/NEJMp1711991 KQ1E1, KQ2E1, KQ3E129342380
23 Farsalinos K, Niaura R. E-cigarettes and smoking cessation in the United States according to frequency of e-cigarette use and quitting duration: analysis of the 2016 and 2017 National Health Interview Surveys. Nicotine Tob Res. 2020;22(5):655–662. PMID: 30768136. 10.1093/ntr/ntz025 KQ1E4, KQ2E2, KQ3E430768136
24 Felicione NJ, Enlow P, . A pilot investigation of the effect of electronic cigarettes on smoking behavior among opioid-dependent smokers. Addict Behav. 2019;91:45–50. PMID: 30006020. 10.1016/j.addbeh.2018.07.003 KQ1E2, KQ2E2, KQ3E430006020
25 Ferrari M, Zanasi A, . Short-term physiological effects of the e-cigarette compared to regular cigarette. Eur Respir J. 2014;44:3436. KQ1E2, KQ2E2, KQ3E2
26 Franco T, Trapasso S, . Electronic cigarette: role in the primary prevention of oral cavity cancer. Clin Med Insights Ear Nose Throat. 2016;9:7–12. PMID: 27773997. 10.4137/cment.s40364 KQ1E2, KQ2E2, KQ3E227773997
27 Goniewicz ML, Gawron M, . Exposure to nicotine and selected toxicants in cigarette smokers who switched to electronic cigarettes: a longitudinal within-subjects observational study. Nicotine Tob Res. 2017;19(2):160–167. PMID: 27613896. 10.1093/ntr/ntw160 KQ1E2, KQ2E2, KQ3E227613896
28 Goniewicz ML, Smith DM, . Comparison of nicotine and toxicant exposure in users of electronic cigarettes and combustible cigarettes. JAMA Netw Open. 2018;1(8):e185937. PMID: 30646298. 10.1001/jamanetworkopen.2018.5937 KQ1E1, KQ2E1, KQ3E430646298
29 Halpern SD, Harhay MO, . A pragmatic trial of e-cigarettes, incentives, and drugs for smoking cessation. N Engl J Med. 2018;378(24):2302–2310. PMID: 29791259. 10.1056/NEJMsa1715757 KQ1E4, KQ2E1, KQ3E429791259
30 Ikonomidis I, Vlastos D, . Electronic cigarette smoking increases arterial stiffness and oxidative stress to a lesser extent than a single conventional cigarette: an acute and chronic study. Circulation. 2018;137(3):303–306. PMID: 29335291. 10.1161/circulationaha.117.029153 KQ1E2, KQ2E2, KQ3E429335291
31 Johnson L, Ma Y, . E-cigarette usage is associated with increased past-12-month quit attempts and successful smoking cessation in two US population-based surveys. Nicotine Tob Res. 2019;21(10):1331–1338. PMID: 30304476. 10.1093/ntr/nty211 KQ1E4, KQ2E2, KQ3E430304476
32 King JL, Reboussin BA, . Tobacco product use and mental health status among young adults. Addict Behav. 2018;77:67–72. 10.1016/j.addbeh.2017.09.012 KQ1E1, KQ2E1, KQ3E128965069
33 King JL, Reboussin BA, . Adverse symptoms users attribute to e-cigarettes: results from a national survey of US adults. Drug Alcohol Depend. 2019;196:9–13. PMID: 30658221. 10.1016/j.drugalcdep.2018.11.030 KQ1E4, KQ2E4, KQ3E230658221
34 Lee SM, Tenney R, . The end perioperative smoking pilot study: a randomized trial comparing e-cigarettes versus nicotine patch. Can J Anesthesia. 2017;64(1 Supplement 1):S48–s49. 10.1007/s12630-017-1003-0 KQ1E7, KQ2E7, KQ3E7
35 Manzoli L, Flacco ME, . Cohort study of electronic cigarette use: effectiveness and safety at 24 months. Tob Control. 2017;26(3):284–292. PMID: 27272748. 10.1136/tobaccocontrol-2015-052822 KQ1E2, KQ2E2, KQ3E227272748
36 Martinez U, Martinez-Loredo V, . How does smoking and nicotine dependence change after onset of vaping? A retrospective analysis of dual users. Nicotine Tob Res. 2020;22(5):764–770. PMID: 30883640. 10.1093/ntr/ntz043 KQ1E4, KQ2E2, KQ3E430883640
37 Meier E, Wahlquist AE, . A pilot randomized crossover trial of electronic cigarette sampling among smokers. Nicotine Tob Res. 2017;19(2):176–182. PMID: 27613880. 10.1093/ntr/ntw157 KQ1E4, KQ2E4, KQ3E427613880
38 Motooka Y, Matsui T, . Adverse events of smoking cessation treatments (nicotine replacement therapy and non-nicotine prescription medication) and electronic cigarettes in the Food and Drug Administration Adverse Event Reporting System, 2004–2016. SAGE Open Med. 2018;6:2050312118777953. PMID: 29844912. 10.1177/2050312118777953 KQ1E1, KQ2E1, KQ3E229844912
39 Nolan M, Leischow S, . Feasibility of electronic nicotine delivery systems in surgical patients. Nicotine Tob Res. 2016;18(8):1757–62. PMID: 26834051. 10.1093/ntr/ntw003 KQ1E4, KQ2E4, KQ3E426834051
40 Nowariak EN, Lien RK, . E-cigarette use among treatment-seeking smokers: moderation of abstinence by use frequency. Addict Behav. 2018;77:137–142. 10.1016/j.addbeh.2017.09.023 KQ1E2, KQ2E2, KQ3E428992579
41 Osei AD, Mirbolouk M, . The association between e-cigarette use and cardiovascular disease among never and current combustible cigarette smokers: BRFSS 2016 & 2017. Am J Med. 2019;132(8):949–954.e2. PMID: 30853474. 10.1016/j.amjmed.2019.02.016 KQ1E2, KQ2E2, KQ3E430853474
42 Papaseit E, Perez-Mana C, . Pharmacodynamics of nicotine from secondgeneration electronic cigarette. Basic Clin Pharmacol Toxicol. 2014;115:13. 10.1111/bcpt.12300 KQ1E2, KQ2E2, KQ3E2
43 Park SH, Lee L, . Patterns of electronic cigarette use and level of psychological distress. PLoS One. 2017;12(3):e0173625. PMID: 28278239. 10.1371/journal.pone.0173625 KQ1E1, KQ2E1, KQ3E128278239
44 Pepper JK, Gilkey MB, . Physicians’ counseling of adolescents regarding e-cigarette use. J Adolesc Health. 2015;57(6):580–586. PMID: 26297135. 10.1016/j.jadohealth.2015.06.017 KQ1E3, KQ2E3, KQ3E326297135
45 Perkins KA, Karelitz JL, . Effects of nicotine versus placebo e-cigarette use on symptom relief during initial tobacco abstinence. Exp Clin Psychopharmacol. 2017;25(4):249–254. PMID: 28650184. 10.1037/pha0000134 KQ1E1, KQ2E1, KQ3E128650184
46 Pravettoni G, Masiero M, . The role of electronic cigarettes in smoking cessation among heavy smokers undergoing a lung cancer screening program: preliminary results of a randomized controlled study. Psychooncology. 2016;25:72. 10.1002/pon.4082 KQ1E2, KQ2E2, KQ3E4
47 Rossheim ME, Livingston MD, . Electronic cigarette explosion and burn injuries, US emergency departments 2015–2017. Tob Control. 2019;28(4):472–474. PMID: 30219795. 10.1136/tobaccocontrol-2018-054518 KQ1E4, KQ2E4, KQ3E230219795
48 Russo C, Cibella F, . Evaluation of post cessation weight gain in a 1-year randomized smoking cessation trial of electronic cigarettes. Sci Rep. 2016;6:18763. PMID: 26729619. 10.1038/srep18763 KQ1E4, KQ2E4, KQ3E426729619
49 Salloum RG, Lee J, . Evidence-based tobacco treatment utilization among dual users of cigarettes and E-cigarettes. Prev Med. 2018;114:193–199. PMID: 30026117. 10.1016/j.ypmed.2018.07.010 KQ1E4, KQ2E4, KQ3E430026117
50 Shahab L, Goniewicz ML, . Nicotine, carcinogen, and toxin exposure in long-term e-cigarette and nicotine replacement therapy users: a cross-sectional study. Ann Intern Med. 2017;166(6):390–400. PMID: 28166548. 10.7326/m16-1107 KQ1E2, KQ2E4, KQ3E428166548
51 Sharma R, Gartner CE, . The challenge of reducing smoking in people with serious mental illness. Lancet Respir Med. 2016;4(10):835–844. PMID: 27707462. 10.1016/s2213-2600(16)30228-4 KQ1E1, KQ2E1, KQ3E127707462
52 Soneji S. Errors in data input in meta-analysis on association between initial use of e-cigarettes and subsequent cigarette smoking among adolescents and young adults. JAMA Pediatr. 2018;172(1):92–93. PMID: 29131876. 10.1001/jamapediatrics.2017.4200 KQ1E1, KQ2E1, KQ3E129131876
53 Soule EK, Nasim A, . Adverse effects of electronic cigarette use: a concept mapping approach. Nicotine Tob Res. 2016;18(5):678–85. PMID: 26563262. 10.1093/ntr/ntv246 KQ1E2, KQ2E2, KQ3E226563262
54 Soule EK, Plunk AD, . Longitudinal analysis of associations between reasons for electronic cigarette use and change in smoking status among adults in the Population Assessment of Tobacco and Health Study. Nicotine Tob Res. 2020;22(5):663–671. PMID: 30698815. 10.1093/ntr/ntz005 KQ1E4, KQ2E2, KQ3E430698815
55 Veldheer S, Yingst J, . Pulmonary and other health effects of electronic cigarette use among adult smokers participating in a randomized controlled smoking reduction trial. Addict Behav. 2019;91:95–101. PMID: 30393015. 10.1016/j.addbeh.2018.10.041 KQ1E2, KQ2E2, KQ3E430393015
56 Vlachopoulos C, Ioakeimidis N, . Electronic cigarette smoking increases aortic stiffness and blood pressure in young smokers. J Am Coll Cardiol. 2016;67(23):2802–2803. PMID: 27282901. 10.1016/j.jacc.2016.03.569 KQ1E2, KQ2E2, KQ3E227282901
57 Walele T, Sharma G, . A randomised, crossover study on an electronic vapour product, a nicotine inhalator and a conventional cigarette. Part B: safety and subjective effects. Regul Toxicol Pharmacol. 2016;74:193–9. PMID: 26702788. 10.1016/j.yrtph.2015.12.004 KQ1E4, KQ2E4, KQ3E226702788
58 Wang JB, Olgin JE, . Cigarette and e-cigarette dual use and risk of cardiopulmonary symptoms in the Health eHeart Study. PLoS One. 2018;13(7):e0198681. PMID: 30044773. 10.1371/journal.pone.0198681 KQ1E2, KQ2E2, KQ3E230044773
59 Weaver SR, Huang J, . Are electronic nicotine delivery systems helping cigarette smokers quit? Evidence from a prospective cohort study of U.S. adult smokers, 2015–2016. PLoS One. 2018;13(7):e0198047. PMID: 29985948. 10.1371/journal.pone.0198047 KQ1E4, KQ2E2, KQ3E429985948

## Appendix E List 3 Excluded Studies List, Tobacco Cessation in Adults: Pharmacotherapy in Pregnant Women

Exclusion Code | Definition
E1 | Study aim not relevant
E2 | Study design
E3 | Population
E4 | Outcomes: No relevant outcomes (exclude trials that only report tobacco reduction; reduction in withdrawal symptoms; attitudes, knowledge, beliefs; intentions; etc.)
E5 | Setting
E6 | Poor Quality
E7 | Publication Type
E8 | Intervention Type

1 Alwan S, Reefhuis J, . Maternal use of bupropion and risk for congenital heart defects. Am J Obstet Gynecol. 2010;203(1):52e1–6. PMID: 20417496. 10.1016/j.ajog.2010.02.015 KQ1E2, KQ2E2, KQ3E220417496
2 Anonymous. Smoking cessation during pregnancy. Prescrire Int. 2015;24(161):157–9. PMID: 26436173. KQ1E2, KQ2E2, KQ3E226436173
3 Bar-Zeev Y, Bovill M, . Improving smoking cessation care in pregnancy at Aboriginal Medical Services: ‘ICAN QUIT in Pregnancy’ step-wedge cluster randomised study. BMJ Open. 2019;9(6):e025293. KQ1E4, KQ2E4, KQ3
4 Bar-Zeev Y, Bovill M, . The indigenous counselling and nicotine (ICAN) quit in pregnancy intervention-preliminary findings of changes in health providers’ knowledge and practices. Asia-pacific journal of clinical oncology. Conference: hunter cancer research symposium 2017. Australia. 2017;13(Supplement 5):30–31. 10.1111/ajco.12813 KQ1E7, KQ2E7, KQ3E7
5 Boshier A, Wilton LV, . Evaluation of the safety of bupropion (Zyban) for smoking cessation from experience gained in general practice use in England in 2000. Eur J Clin Pharmacol. 2003;59(10):767–73. PMID: 14615857. 10.1007/s00228-003-0693-0 KQ1E2, KQ2E2, KQ3E214615857
6 Braillon A, Bewley S. Behavioral counseling and pharmacotherapy interventions for tobacco cessation in pregnant women. Ann Intern Med. 2016;164(9):637. PMID: 27136221. 10.7326/L15-0625 KQ1E2, KQ2E2, KQ3E627136221
7 Brose LS. Helping pregnant smokers to quit. BMJ. 2014;348:g1808. PMID: 24620362. 10.1136/bmj.g1808 KQ1E2, KQ2E2, KQ3E224620362
8 Chan B, Einarson A, . Effectiveness of bupropion for smoking cessation during pregnancy. J Addict Dis. 2005;24(2):19–23.. PMID: 15784520. 10.1300/J069v24n02_02 KQ1E2, KQ2E2, KQ3E215784520
9 Chen LS, Baker TB, . Interplay of genetic risk (CHRNA5) and environmental risk (partner smoking) on cigarette smoking reduction. Drug Alcohol Depend. 2014;143:36–43. PMID: 25073833. 10.1016/j.drugalcdep.2014.06.027 KQ1E2, KQ2E2, KQ3E225073833
10 Chun-Fai-Chan B, Koren G, . Pregnancy outcome of women exposed to bupropion during pregnancy: a prospective comparative study. Am J Obstet Gynecol. 2005;192(3):932–6. PMID: 15746694. 10.1016/j.ajog.2004.09.027 KQ1E2, KQ2E2, KQ3E215746694
11 Cole JA, Modell JG, . Bupropion in pregnancy and the prevalence of congenital malformations. Pharmacoepidemiol Drug Saf. 2007;16(5):474–84. PMID: 16897811. 10.1002/pds.1296 KQ1E2, KQ2E2, KQ3E216897811
12 Crawford P, Cieslak D. Varenicline for smoking cessation. Am Fam Physician. 2017;96(5):Online. KQ1E2, KQ2E2, KQ3E7
13 Einarson A, Choi J, . Incidence of major malformations in infants following antidepressant exposure in pregnancy: results of a large prospective cohort study. Can J Psychiatry. 2009;54(4):242–6. PMID: 19321030. 10.1177/070674370905400405 KQ1E2, KQ2E2, KQ3E219321030
14 Fokina VM, Wang X, . Determination of cotinine in the urine of pregnant patients enrolled in a clinical trial for the use of bupropion sustained-release as an aid for smoking cessation. Drug Alcohol Depend. 2015;146:e280. 10.1016/j.drugalcdep.2014.09.227 KQ1E7, KQ2E7, KQ3E3
15 Gisslen T, Nathan B, . Hyperinsulinism associated with gestational exposure to bupropion in a newborn infant. J Pediatr Endocrinol Metab. 2011;24(9–10):819–22. PMID: 22145484. KQ1E2, KQ2E2, KQ3E222145484
16 GlaxoSmithKline. The Bupropion Pregnancy Registry: Final Report. 2008. KQ1E2, KQ2E2, KQ3E2
17 Gould G, Bovill M, . Feasibility and acceptability of ican quit in pregnancy multicomponent implementation intervention and research design for australian indigenous pregnant women: a pilot cluster randomized step-wedge trial. Asia-pacific journal of clinical oncology. Conference: hunter cancer research symposium 2018. Australia. 2018;14(Supplement 6):26–27. 10.1111/ajco.13071 KQ1E7, KQ2E7, KQ3E4
18 Gould Gillian S, Bovill Michelle, . Feasibility and acceptability of Indigenous Counselling and Nicotine (ICAN) QUIT in pregnancy multicomponent implementation intervention and study design for Australian Indigenous pregnant women: a pilot cluster randomised step-wedge trial. Addict Behav. 2019;90:176–190. 10.1016/j.addbeh.2018.10.036 KQ1E4, KQ2E4, KQ3E430412909
19 Haddad A, Davis AM. Tobacco smoking cessation in adults and pregnant women: behavioral and pharmacotherapy interventions. JAMA. 2016;315(18):2011–2. PMID: 27163990. 10.1001/jama.2016.2535 KQ1E2, KQ2E2, KQ3E727163990
20 Harrison-Woolrych M, Paterson H, . Exposure to the smoking cessation medicine varenicline during pregnancy: a prospective nationwide cohort study. Pharmacoepidemiol Drug Saf. 2013;22(10):1086–92. PMID: 23926076. 10.1002/pds.3489 KQ1E2, KQ2E2, KQ3E223926076
21 Hartmann-Boyce J, Aveyard P. Drugs for smoking cessation. BMJ. 2016;352:i571. PMID: 26907501. 10.1136/bmj.i571 KQ1E2, KQ2E2, KQ3E126907501
22 Hegaard HK, Kjaergaard H, . Multimodal intervention raises smoking cessation rate during pregnancy. Acta Obstet Gynecol Scand. 2003;82(9):813–9. PMID: 12911442. KQ1E2, KQ2E2, KQ3E412911442
23 Hotham ED, Gilbert AL, . A randomised-controlled pilot study using nicotine patches with pregnant women. Addict Behav. 2006;31(4):641–648. PMID: 15985339. KQ1E6, KQ2E4, KQ3E615985339
24 Janssen R, Oudijk MA. Concerns about the safety of nicotine replacement therapy during pregnancy on lung development in children. Am J Obstet Gynecol. 2017;216(3):327–328. PMID: 27780705. 10.1016/j.ajog.2016.10.023 KQ1E2, KQ2E2, KQ3E227780705
25 Kaplan YC, Olgac Dundar N, . Pregnancy outcome after varenicline exposure in the first trimester. Case Rep Obstet Gynecol. 2014;2014:263981. PMID: 24639907. 10.1155/2014/263981 KQ1E2, KQ2E2, KQ3E224639907
26 Kapur B, Hackman R, . Randomized, double-blind, placebo-controlled trial of nicotine replacement therapy in pregnancy. Curr Ther Res Clin Exp. 2001;62(4):274–278. KQ1E4, KQ2E4, KQ3E2
27 Lancaster T. ACP Journal Club. In pregnant smokers, the nicotine patch did not increase abstinence or birthweight more than placebo. Ann Intern Med. 2014;160(12):JC11. PMID: 24935505. 10.7326/0003-4819-160-12-201406170-02011 KQ1E2, KQ2E2, KQ3E224935505
28 Leventhal K, Byatt N, . Fetal cardiac arrhythmia during bupropion use. Acta Obstet Gynecol Scand. 2010;89(7):980–1. PMID: 20583941. 10.3109/00016349.2010.485632 KQ1E2, KQ2E2, KQ3E220583941
29 Louik C, Kerr S, . First-trimester exposure to bupropion and risk of cardiac malformations. Pharmacoepidemiol Drug Saf. 2014;23(10):1066–75. PMID: 24920293. 10.1002/pds.3661 KQ1E2, KQ2E2, KQ3E624920293
30 Lusskin SI, Khan SJ, . Pharmacotherapy for perinatal depression. Clin Obstet Gynecol. 2018;61(3):544–561. PMID: 29561284. 10.1097/grf.0000000000000365 KQ1E2, KQ2E2, KQ3E229561284
31 Mendelsohn CP. The evidence supports prequit use of nicotine patches. BMJ. 2016;353:i2176. PMID: 27090572. 10.1136/bmj.i2176 KQ1E2, KQ2E2, KQ3E227090572
32 Nanovskaya TN, Oncken C, . Bupropion sustained release for pregnant smokers: a randomized, placebo-controlled trial. Am J Obstet Gynecol. 2017;216(4):420.e1–420.e9. PMID: 27890648. 10.1016/j.ajog.2016.11.1036 KQ1E6, KQ2E6, KQ3E227890648
33 Noonan D, Lyna P, . Unintended effects of a smoking cessation intervention on Latino fathers’ binge drinking in early postpartum. Ann Behav Med. 2016;50(4):622–7. 10.1007/s12160-016-9781-0 KQ1E8, KQ2E8, KQ3E226868270
34 O’Dowd A. Only a tenth of pregnant smokers are prescribed nicotine replacement therapy. BMJ. 2014;349:g5405. PMID: 25183700. 10.1136/bmj.g5405 KQ1E2, KQ2E2, KQ3E225183700
35 Olsen M, Petronis KR, . Maternal use of varenicline and risk of congenital malformations. Pharmacoepidemiol Drug Saf. 2015;24(244). KQ1E7, KQ2E7, KQ3E2
36 Palmsten K, Huybrechts KF, . Antidepressant use and risk for preeclampsia. Epidemiology. 2013;24(5):682–91. PMID: 23873072. 10.1097/EDE.0b013e31829e0aaa KQ1E2, KQ2E2, KQ3E723873072
37 Passey ME, Stirling JM. Evaluation of ‘Stop Smoking in its Tracks’: an intensive smoking cessation program for pregnant Aboriginal women incorporating contingency-based financial rewards. Public Health Res Pract. 2018;28(2):14. 10.17061/phrp28011804 KQ1E2, KQ2E2, KQ3E8
38 Richardson JL, Stephens S, . Pregnancy outcomes after maternal varenicline use; analysis of surveillance data collected by the European Network of Teratology Information Services. Reprod Toxicol. 2017;67:26–34. PMID: 27851994. 10.1016/j.reprotox.2016.11.010 KQ1E2, KQ2E2, KQ3E227851994
39 Roper L, Tran DT, . Algorithm for resolving discrepancies between claims for smoking cessation pharmacotherapies during pregnancy and smoking status in delivery records: the impact on estimates of utilisation. PLoS One. 2018;13(8):e0202999. 10.1371/journal.pone.0202999 KQ1E2, KQ2E2, KQ3E430161203
40 Sedgwick P. Controlled trials: allocation concealment, random allocation, and blinding. BMJ. 2015;350:h2633. PMID: 25979365. 10.1136/bmj.h2633 KQ1E2, KQ2E2, KQ3E225979365
41 Sedgwick P. Measuring the detriment of treatment: number needed to harm. BMJ. 2015;350:h2763. PMID: 26002193. 10.1136/bmj.h2763 KQ1E2, KQ2E2, KQ3E226002193
42 Spindel ER, McEvoy CT. The role of nicotine in the effects of maternal smoking during pregnancy on lung development and childhood respiratory disease. Implications for dangers of e-cigarettes. Am J Respir Crit Care Med. 2016;193(5):486–94. PMID: 26756937. 10.1164/rccm.201510-2013PP KQ1E2, KQ2E2, KQ3E226756937
43 Stotts AL, Northrup TF, . Randomized, controlled pilot trial of bupropion for pregnant smokers: challenges and future directions. Am J Perinatol. 2015;32(4):351–6. PMID: 25111040. 10.1055/s-0034-1386635 KQ1E2, KQ2E2, KQ3E225111040
44 Tappin D, Bauld L, . Financial incentives for smoking cessation in pregnancy: randomised controlled trial. BMJ. 2015;350:h134. PMID: 25627664. 10.1136/bmj.h134 KQ1E1, KQ2E1, KQ3E225627664
45 Thyagarajan V, Robin Clifford C, . Bupropion therapy in pregnancy and the occurrence of cardiovascular malformations in infants. Pharmacoepidemiol Drug Saf. 2012;21(11):1240–2. PMID: 23109236. 10.1002/pds.3271 KQ1E2, KQ2E2, KQ3E223109236
46 Wong MK, Barra NG, . Adverse effects of perinatal nicotine exposure on reproductive outcomes. Reproduction. 2015;150(6):R185–93. PMID: 26432348. 10.1530/REP-15-0295 KQ1E2, KQ2E2, KQ3E226432348