# Appendix D Included Studies Lists

## Appendix D List 1 Included ESRs, by Author

### Ancillary publication(s) indented under primary article

- Agboola SA, Coleman T, McNeill A, . Abstinence and relapse among smokers who use varenicline in a quit attempt-a pooled analysis of randomized controlled trials. Addiction. 2015;110(7):1182–93. PMID: 25846123. 10.1111/add.12941 25846123
- Ahmed S, Virani S, Kotapati VP, . Efficacy and safety of varenicline for smoking cessation in schizophrenia: a meta-analysis. Front Psychiatry. 2018;9:428. PMID: 30283363. 10.3389/fpsyt.2018.00428 30283363
- Apollonio D, Philipps R, Bero L. Interventions for tobacco use cessation in people in treatment for or recovery from substance use disorders. Cochrane Database Syst Rev. 2016;11:CD010274. PMID: 27878808. 10.1002/14651858.CD010274.pub2 27878808
- Barnes J, McRobbie H, Dong CY, . Hypnotherapy for smoking cessation. Cochrane Database Syst Rev. 2019;6:CD001008. PMID: 31198991. 10.1002/14651858.CD001008.pub3 31198991
- Boland VC, Stockings EA, Mattick RP, . The methodological quality and effectiveness of technology-based smoking cessation interventions for disadvantaged groups: a systematic review and meta-analysis. Nicotine Tob Res. 2018;20(3):276–285. PMID: 28034998. 10.1093/ntr/ntw391 28034998
- Boyle R, Solberg L, Fiore M. Use of electronic health records to support smoking cessation. Cochrane Database Syst Rev. 2014;12:CD008743. PMID: 25547090. 10.1002/14651858.CD008743.pub3 25547090
- Cahill K, Lindson-Hawley N, Thomas KH, . Nicotine receptor partial agonists for smoking cessation. Cochrane Database Syst Rev. 2016;5:CD006103. PMID: 27158893. 10.1002/14651858.CD006103.pub7 27158893
- Carson K, V, Brinn MP, Peters M, . Interventions for smoking cessation in Indigenous populations. Cochrane Database Syst Rev. 2012;1:CD009046 PMID: 22258998. 10.1002/14651858.CD009046.pub2 22258998
- Chamberlain C, O’Mara-Eves A, Porter J, . Psychosocial interventions for supporting women to stop smoking in pregnancy. Cochrane Database Syst Rev. 2017;2:CD001055. PMID: 28196405. 10.1002/14651858.CD001055.pub5 28196405
- Chang PH, Chiang CH, Ho WC, . Combination therapy of varenicline with nicotine replacement therapy is better than varenicline alone: a systematic review and meta-analysis of randomized controlled trials. BMC Public Health. 2015;15:689. PMID: 26198192. 10.1186/s12889-015-2055-0 26198192
- Clair C, Mueller Y, Livingstone-Banks J, . Biomedical risk assessment as an aid for smoking cessation. Cochrane Database Syst Rev. 2019;3:CD004705. PMID: 30912847. 10.1002/14651858.CD004705.pub5 30912847
- Danielsson AK, Eriksson AK, Allebeck P. Technology-based support via telephone or web: a systematic review of the effects on smoking, alcohol use and gambling. Addict Behav. 2014;39(12):1846–68. PMID: 25128637. 10.1016/j.addbeh.2014.06.007 25128637
- Denison E, Underland V, Mosdol A, . Cognitive Therapies for Smoking Cessation: A Systematic Review. Oslo, Norway: Knowledge Centre for the Health Services at The Norwegian Institute of Public Health (NIPH); 2017.
- Do HP, Tran BX, Le Pham Q, . Which eHealth interventions are most effective for smoking cessation? A systematic review. Patient Pref Adherence. 2018;12:2065–84. PMID: 30349201. 10.2147/ppa.S169397 30349201
- Ebbert JO, Elrashidi MY, Stead LF. Interventions for smokeless tobacco use cessation. Cochrane Database Syst Rev. 2015;10:CD004306. PMID: 26501380. 10.1002/14651858.CD004306.pub5 26501380
- Giles E, Robalino S, McColl E, . The effectiveness of financial incentives for health behaviour change: systematic review and meta-analysis (Structured abstract). Plos One. 2014;9(3):e90347. PMID: 24618584. 10.1371/journal.pone.0090347 24618584
- Graham AL, Carpenter KM, Cha S, . Systematic review and meta-analysis of Internet interventions for smoking cessation among adults. Subst Abuse Rehabil. 2016;7:55–69. PMID: 27274333. 10.2147/sar.s101660 27274333
- Griffiths SE, Parsons J, Naughton F, . Are digital interventions for smoking cessation in pregnancy effective? A systematic review and meta-analysis. Health Psychol Rev. 2018;12(4):333–56. PMID: 29912621. 10.1080/17437199.2018.1488602 29912621
- Hartmann-Boyce J, Chepkin SC, Ye W, . Nicotine replacement therapy versus control for smoking cessation. Cochrane Database Syst Rev. 2018;5:CD000146. PMID: 29852054. 10.1002/14651858.CD000146.pub5 29852054
- Hartmann-Boyce J, Hong B, Livingstone-Banks J, . Additional behavioural support as an adjunct to pharmacotherapy for smoking cessation. Cochrane Database Syst Rev. 2019;6:CD009670. PMID: 31166007. 10.1002/14651858.CD009670.pub4 31166007
- Hollands GJ, Naughton F, Farley A, . Interventions to increase adherence to medications for tobacco dependence. Cochrane Database Syst Rev. 2019;8:CD009164. PMID: 31425618. 10.1002/14651858.CD009164.pub3 31425618
- Howes S, Hartmann-Boyce J, Livingstone-Banks J, . Antidepressants for smoking cessation. Cochrane Database Syst Rev. 2020;4:CD000031. PMID: 32319681. 10.1002/14651858.CD000031.pub5 32319681
- Johnston V, Westphal DW, Glover M, . Reducing smoking among indigenous populations: new evidence from a review of trials. Nicotine Tob Res. 2013;15(8):1329–38. PMID: 23519776. 10.1093/ntr/ntt022 23519776
- Khanna P, Clifton AV, Banks D, . Smoking cessation advice for people with serious mental illness. Cochrane Database Syst Rev. 2016;1:CD009704. PMID: 26816385. 10.1002/14651858.CD009704.pub2 26816385
- Kishi T, Iwata N. Varenicline for smoking cessation in people with schizophrenia: systematic review and meta-analysis. Eur Arch Psychiatry Clin Neurosci. 2015;265(3):259–68. PMID: 25283510. 10.1007/s00406-014-0551-3 25283510
- Klinsophon T, Thaveeratitham P, Sitthipornvorakul E, . Effect of exercise type on smoking cessation: a meta-analysis of randomized controlled trials. BMC Res Notes. 2017;10(1):442. PMID: 28874175. 10.1186/s13104-017-2762-y 28874175
- Lancaster T, Stead LF. Individual behavioural counselling for smoking cessation. Cochrane Database Syst Rev. 2017;3:CD001292. PMID: 28361496. 10.1002/14651858.CD001292.pub3 28361496
- Lindson N, Chepkin S, Ye W, . Different doses, durations and modes of delivery of nicotine replacement therapy for smoking cessation. Cochrane Database Syst Rev. 2019;4:CD013308. 10.1002/14651858.CD013308 30997928
- Lindson N, Klemperer E, Hong B, . Smoking reduction interventions for smoking cessation. Cochrane Database Syst Rev. 2019;9:CD013183. PMID: 31565800. 10.1002/14651858.CD013183.pub2 31565800
- Lindson N, Thompson TP, Ferrey A, . Motivational interviewing for smoking cessation. Cochrane Database Syst Rev. 2019;7:CD006936. PMID: 31425622. 10.1002/14651858.CD006936.pub4 31425622
- Liu JJ, Wabnitz C, Davidson E, . Smoking cessation interventions for ethnic minority groups: a systematic review of adapted interventions. Prev Med. 2013;57(6):765–75. PMID: 24076130.24076130
- Livingstone-Banks J, Norris E, Hartmann-Boyce J, . Relapse prevention interventions for smoking cessation. Cochrane Database Syst Rev. 2019;2:CD003999. PMID: 30758045. 10.1002/14651858.CD003999.pub5 30758045
- Livingstone-Banks J, Ordonez-Mena JM, Hartmann-Boyce J. Print-based self-help interventions for smoking cessation. Cochrane Database Syst Rev. 2019;1:CD001118. PMID: 30623970. 10.1002/14651858.CD001118.pub4 30623970
- Matkin W, Ordonez-Mena JM, Hartmann-Boyce J. Telephone counselling for smoking cessation. Cochrane Database Syst Rev. 2019;5:CD002850. PMID: 31045250. 10.1002/14651858.CD002850.pub4 31045250
- McCrabb S, Baker AL, Attia J, . Internet-based programs incorporating behavior change techniques are associated with increased smoking cessation in the general population: a systematic review and meta-analysis. Ann Behav Med. 2019;53(2):180–95. PMID: 29750240. 10.1093/abm/kay026 29750240
- McKee SA, Smith PH, Kaufman M, . Sex differences in varenicline efficacy for smoking cessation: a meta-analysis. Nicotine Tob Res. 2016;18(5):1002–11. PMID: 26446070. 10.1093/ntr/ntv207 26446070
- Mills EJ, Thorlund K, Eapen S, . Cardiovascular events associated with smoking cessation pharmacotherapies: a network meta-analysis. Circulation. 2014;129(1):28–41. PMID: 24323793. 10.1161/CIRCULATIONAHA.113.003961 24323793
- Mills EJ, Wu P, Lockhart I, . Adverse events associated with nicotine replacement therapy (NRT) for smoking cessation. A systematic review and meta-analysis of one hundred and twenty studies involving 177,390 individuals. Tob Induc Dis. 2010;8:8. PMID: 20626883. 10.1186/1617-9625-8-8 20626883
- Moyo F, Archibald E, Slyer JT. Effectiveness of decision aids for smoking cessation in adults: a quantitative systematic review. JBI Database System Rev Implement Rep. 2018;16(9):1791–822. PMID: 30204670. 10.11124/jbisrir-2017-003698 30204670
- Notley C, Gentry S, Livingstone-Banks J, . Incentives for smoking cessation. Cochrane Database Syst Rev. 2019;7:CD004307. PMID: 31313293. 10.1002/14651858.CD004307.pub6 31313293
- Palmer M, Sutherland J, Barnard S, . The effectiveness of smoking cessation, physical activity/diet and alcohol reduction interventions delivered by mobile phones for the prevention of non-communicable diseases: a systematic review of randomised controlled trials. PLoS One. 2018;13(1):e0189801. PMID: 29304148. 10.1371/journal.pone.0189801 29304148
- Peckham E, Brabyn S, Cook L, . Smoking cessation in severe mental ill health: what works? an updated systematic review and meta-analysis. BMC Psychiatry. 2017;17(1):252. PMID: 28705244. 10.1186/s12888-017-1419-7 28705244
- Rice VH, Heath L, Livingstone-Banks J, . Nursing interventions for smoking cessation. Cochrane Database Syst Rev. 2017;12:CD001188. PMID: 29243221. 10.1002/14651858.CD001188.pub5 29243221
- Roberts E, Evins A, McNeill A, . Efficacy and tolerability of pharmacotherapy for smoking cessation in adults with serious mental illness: a systematic review and network meta-analysis. Addiction. 2016;111(4):599–612. PMID: 26594837. 10.1111/add.13236 26594837
- Rosen LJ, Galili T, Kott J, . Diminishing benefit of smoking cessation medications during the first year: a meta-analysis of randomized controlled trials. Addiction. 2018;113(5):805–16. PMID: 29377409. 10.1111/add.14134 29377409
- Schuit E, Panagiotou OA, Munafo MR, . Pharmacotherapy for smoking cessation: effects by subgroup defined by genetically informed biomarkers. Cochrane Database Syst Rev. 2017;9:CD011823. PMID: 28884473. 10.1002/14651858.CD011823.pub2 28884473
  - Panagiotou OA, Schuit E, Munafo MR, . Smoking cessation pharmacotherapy based on genetically-informed biomarkers: what is the evidence? Nicotine Tob Res. 2019;21(9):1289–1293. PMID: 30690475. 10.1093/ntr/ntz009 30690475
- Schwartz J, Fadahunsi O, Hingorani R, . Use of varenicline in smokeless tobacco cessation: a systematic review and meta-analysis. Nicotine Tob Res. 2016;18(1):10–6. PMID: 25646351. 10.1093/ntr/ntv010 25646351
- Smith PH, Weinberger AH, Zhang J, . Sex differences in smoking cessation pharmacotherapy comparative efficacy: a network meta-analysis. Nicotine Tob Res. 2016;[Epub ahead of print]. 10.1093/ntr/ntw144
- Stead LF, Buitrago D, Preciado N, . Physician advice for smoking cessation. Cochrane Database Syst Rev. 2013;5:CD000165. PMID: 23728631. 10.1002/14651858.CD000165.pub4 23728631
- Stead LF, Carroll AJ, Lancaster T. Group behaviour therapy programmes for smoking cessation. Cochrane Database Syst Rev. 2017;3:CD001007. PMID: 28361497. 10.1002/14651858.CD001007.pub3 28361497
- Stead LF, Koilpillai P, Fanshawe TR, . Combined pharmacotherapy and behavioural interventions for smoking cessation. Cochrane Database Syst Rev. 2016;3:CD008286. PMID: 27009521. 10.1002/14651858.CD008286.pub3 27009521
- Sterling LH, Windle SB, Filion KB, . Varenicline and adverse cardiovascular events: a systematic review and meta-analysis of randomized controlled trials. J Am Heart Assoc. 2016;5(2):e002849. PMID: 26903004. 10.1161/jaha.115.002849 26903004
- Taylor GMJ, Dalili MN, Semwal M, . Internet-based interventions for smoking cessation. Cochrane Database Syst Rev. 2017;9:CD007078. PMID: 28869775. 10.1002/14651858.CD007078.pub5 28869775
- Thomas D, Abramson MJ, Bonevski B, . System change interventions for smoking cessation. Cochrane Database Syst Rev. 2017;2:CD010742. PMID: 28185257. 10.1002/14651858.CD010742.pub2 28185257
- Thomas KH, Martin RM, Knipe DW, . Risk of neuropsychiatric adverse events associated with varenicline: systematic review and meta-analysis. BMJ. 2015;350:h1109. PMID: 25767129.25767129
- Thurgood SL, McNeill A, Clark-Carter D, . A systematic review of smoking cessation interventions for adults in substance abuse treatment or recovery. Nicotine Tob Res. 2016;18(5):993–1001. PMID: 26069036. 10.1093/ntr/ntv127 26069036
- Tsoi DT, Porwal M, Webster AC. Interventions for smoking cessation and reduction in individuals with schizophrenia. Cochrane Database Syst Rev. 2013;2:CD007253. PMID: 23450574. 10.1002/14651858.CD007253.pub3 23450574
- Tzelepis F, Paul CL, Williams CM, . Real-time video counselling for smoking cessation. Cochrane Database Syst Rev. 2019;2019;10:CD012659. PMID: 31684699. 10.1002/14651858.CD012659.pub2 31684699
- Ussher MH, Faulkner GEJ, Angus K, . Exercise interventions for smoking cessation. Cochrane Database Syst Rev. 2019;2019;10:CD002295. PMID: 31684691. 10.1002/14651858.CD002295.pub6 31684691
- van der Meer RM, Willemsen MC, Smit F, . Smoking cessation interventions for smokers with current or past depression. Cochrane Database Syst Rev. 2013;8:CD006102. PMID: 23963776. 10.1002/14651858.CD006102.pub2 23963776
- White AR, Rampes H, Liu JP, . Acupuncture and related interventions for smoking cessation. Cochrane Database Syst Rev. 2014;1:CD000009. PMID: 24459016. 10.1002/14651858.CD000009.pub4 24459016
- Whittaker R, McRobbie H, Bullen C, . Mobile phone text messaging and app-based interventions for smoking cessation. Cochrane Database Syst Rev. 2019;10:CD006611. PMID: 31638271. 10.1002/14651858.CD006611.pub5 31638271
- Wilson A, Guillaumier A, George J, . A systematic narrative review of the effectiveness of behavioural smoking cessation interventions in selected disadvantaged groups (2010–2017). Expert Rev Respir Med. 2017;11(8):617–30. PMID: 28608758. 10.1080/17476348.2017.1340836 28608758
- Wilson SM, Newins AR, Medenblik AM, . Contingency management versus psychotherapy for prenatal smoking cessation: a meta-analysis of randomized controlled trials. Womens Health. 2018;28(6):514–23. PMID: 30061033. 10.1016/j.whi.2018.05.002 30061033
- Windle SB, Filion KB, Mancini JG, . Combination therapies for smoking cessation: a hierarchical Bayesian meta-analysis. Am J Prev Med. 2016;51(6):1060–71. PMID: 27617367. 10.1016/j.amepre.2016.07.011 27617367
- Wu L, Sun S, He Y, . Effect of smoking reduction therapy on smoking cessation for smokers without an intention to quit: an updated systematic review and meta-analysis of randomized controlled. Int J Environ Res Public Health. 2015;12(9):10235–53. PMID: 26308034. 10.3390/ijerph120910235 26308034
- Wu Q, Gilbody S, Peckham E, . Varenicline for smoking cessation and reduction in people with severe mental illnesses: systematic review and meta-analysis. Addiction. 2016;111(9):1554–67. PMID: 27043328. 10.1111/add.13415 27043328

## Appendix D List 2 Included Trials for Electronic Cigarettes, by Author

### Ancillary publication(s) indented under primary article

- Bullen C, Howe C, Laugesen M, . Electronic cigarettes for smoking cessation: a randomised controlled trial. Lancet. 2013;382(9905):1629–37. PMID: 24029165. 10.1016/S0140-6736(13)61842-5 24029165
  - Bullen C, Howe C, Laugesen M. Electronic cigarettes for smoking cessation: a randomised controlled trial. J Vasc Surg. 2014;59(3):872. PMID: 24029165 10.1016/j.jvs.2014.01.028 24029165
  - Bullen C, Williman J, Howe C, . Study protocol for a randomised controlled trial of electronic cigarettes versus nicotine patch for smoking cessation. BMC Public Health. 2013;13:210. PMID: 23496861. 10.1186/1471-2458-13-210 23496861
  - O’Brien B, Knight-West O, Walker N, . E-cigarettes versus NRT for smoking reduction or cessation in people with mental illness: secondary analysis of data from the ASCEND trial. Tob Induc Dis. 2015;13(1):5. PMID: 25814920. 10.1186/s12971-015-0030-2 25814920
- Caponnetto P, Campagna D, Cibella F, . EffiCiency and Safety of an eLectronic cigAreTte (ECLAT) as tobacco cigarettes substitute: a prospective 12-month randomized control design study. PLoS One. 2013;8(6):e66317. PMID: 23826093. 10.1371/journal.pone.0066317 23826093
  - Caponnetto P, Campagna D, Cibella F, . Erratum: EffiCiency and Safety of an eLectronic cigAreTte (ECLAT) as tobacco cigarettes substitute: a prospective 12-month randomized control design study. PLoS One. 2014;9(1). 10.1371/annotation/e12c22d3-a42b-455d-9100-6c7ee45d58d0
- Carpenter MJ, Heckman BW, Wahlquist AE, . A naturalistic, randomized pilot trial of e-cigarettes: uptake, exposure, and behavioral effects. Cancer Epidemiol Biomarkers Prev. 2017;26(12):1795–803. PMID: 29127080. 10.1158/1055-9965.epi-17-0460 29127080
- Cravo AS, Bush J, Sharma G, . A randomised, parallel group study to evaluate the safety profile of an electronic vapour product over 12 weeks. Regul Toxicol Pharmacol. 2016;81(Suppl 1):S1–S14. PMID: 27769828. 10.1016/j.yrtph.2016.10.003 27769828
- Hajek P, Phillips-Waller A, Przulji D, . A randomized trial of e-cigarettes versus nicotine-replacement therapy. N Engl J Med. 2019;380:629–37. PMID: 30699054. 10.1056/NEJMoa1808779 30699054
  - Hajek P, Phillips-Waller A, Przulj D, . E-cigarettes compared with nicotine replacement therapy within the UK Stop Smoking Services: the TEC RCT. Health Technol Assess. 2019;23(43):1–82. PMID: 31434605. 10.3310/hta23430 31434605
- Lee SH, Ahn SH, Cheong YS. Effect of electronic cigarettes on smoking reduction and cessation in Korean male smokers: a randomized controlled study. J Am Board Fam Med. 2019;32(4):567–74. PMID: 31300577. 10.3122/jabfm.2019.04.180384 31300577
- Masiero M, Lucchiari C, Mazzocco K, . E-cigarettes may support smokers with high smoking-related risk awareness to stop smoking in the short run: preliminary results by randomized controlled trial. Nicotine Tob Res. 2018;21(1):119–26. PMID: 29660034. 10.1093/ntr/nty047 29660034
  - Masiero M, Lucchiari C, Mazzocco K, . Corrigendum: E-cigarettes may support smokers with high smoking-related risk awareness to stop smoking in the short run: preliminary results by randomized controlled trial. Nicotine Tob Res. 2020;22(4):594–5. 10.1093/ntr/nty175 30239904
  - Lucchiari C, Masiero M, Veronesi G, . Benefits of e-cigarettes among heavy smokers undergoing a lung cancer screening program: randomized controlled trial protocol. JMIR Res Protocols. 2016;5(1):e21. PMID: 26842790. 10.2196/resprot.4805 26842790
- Tseng TY, Ostroff JS, Campo A, . A randomized trial comparing the effect of nicotine versus placebo electronic cigarettes on smoking reduction among young adult smokers. Nicotine Tob Res. 2016;18(10):1937–43. PMID: 26783292. 10.1093/ntr/ntw017 26783292
- Walker N, Parag V, Verbiest M, . Nicotine patches used in combination with e-cigarettes (with and without nicotine) for smoking cessation: a pragmatic, randomised trial. Lancet Respir Med. 2019;[Epub ahead of print]. PMID: 31515173. 10.1016/S2213-2600(19)30269-3 31515173

## Appendix D List 3 Included Studies for Pharmacotherapy Interventions Among Pregnant Women, by Author

### Ancillary publication(s) indented under primary article

- Berard A, Zhao JP, Sheehy O. Success of smoking cessation interventions during pregnancy. Am J Obstet Gynecol. 2016;215(5):611.e1–.e8. PMID: 27402053. 10.1016/j.ajog.2016.06.059 27402053
- Berlin I, Grange G, Jacob N, . Nicotine patches in pregnant smokers: randomised, placebo controlled, multicentre trial of efficacy. BMJ. 2014;348:g1622. PMID: 24627552.24627552
- Coleman T, Cooper S, Thornton JG, . A randomized trial of nicotine-replacement therapy patches in pregnancy. New Engl J Med. 2012;366(9):808–18. PMID: 22375972.22375972
  - Cooper S, Lewis S, Thornton JG, . The SNAP trial: a randomised placebo-controlled trial of nicotine replacement therapy in pregnancy-clinical effectiveness and safety until 2 years after delivery, with economic evaluation. Health Technol Assess. 2014;18(54):1–128. PMID: 25158081. 10.3310/hta18540 25158081
  - Cooper S, Taggar J, Lewis S, . Effect of nicotine patches in pregnancy on infant and maternal outcomes at 2 years: follow-up from the randomised, double-blind, placebo-controlled SNAP trial. Lancet Respir Med. 2014(9):728–37. PMID: 25127405.25127405
  - Essex HN, Parrott S, Wu Q, . Cost-effectiveness of nicotine patches for smoking cessation in pregnancy: a placebo randomized controlled trial (SNAP). Nicotine Tob Res. 2015;17(6):636–42. PMID: 25481916. 10.1093/ntr/ntu258 25481916
  - Iyen B, Vaz LR, Taggar J, . Is the apparently protective effect of maternal nicotine replacement therapy (NRT) used in pregnancy on infant development explained by smoking cessation? Secondary analyses of a randomised controlled trial. BMJ Open. 2019;9(7):e024923. PMID: 31300493. 10.1136/bmjopen-2018-024923 31300493
  - Vaz LR, Coleman T, Cooper S, . The nicotine metabolite ratio in pregnancy measured by trans-3’-hydroxycotinine to cotinine ratio: characteristics and relationship with smoking cessation. Nicotine Tob Res. 2015;17(11):1318–23. PMID: 25589677. 10.1093/ntr/ntu342 25589677
- Dhalwani NN, Szatkowski L, Coleman T, . Stillbirth among women prescribed nicotine replacement therapy in pregnancy: analysis of a large UK pregnancy cohort. Nicotine Tob Res. 2019;21(4):409–415. PMID: 29394405. 10.1093/ntr/nty019 29394405
  - Dhalwani NN, Szatkowski L, Coleman T, . Nicotine replacement therapy in pregnancy and major congenital anomalies in offspring. Pediatrics. 2015;135(5):859–67. PMID: 25847803. 10.1542/peds.2014-2560 25847803
- El-Mohandes AA, Windsor R, Tan S, . A randomized clinical trial of trans-dermal nicotine replacement in pregnant African-American smokers. Matern Child Health J. 2013;17(5):897–906. PMID: 22761006.22761006
- Oncken C, Dornelas E, Greene J, . Nicotine gum for pregnant smokers: a randomized controlled trial. Obstet Gynecol. 2008;112(4):859–67. PMID: 18827129. 10.1097/AOG.0b013e318187e1ec 18827129
- Oncken C, Dornelas EA, Kuo CL, . Randomized trial of nicotine inhaler for pregnant smokers. Am J Obstet Gynecol MFM. 2019;1(1):10–8. PMID: 31380506. 10.1016/j.ajogmf.2019.03.006 31380506
- Pedersen L, Petronis KR, Norgaard M, . Risk of adverse birth outcomes after maternal varenicline use: a population-based observational study in Denmark and Sweden. Pharmacoepidemiol Drug Saf. 2020;29(1):94–102. PMID: 31713302. 10.1002/pds.4894 31713302
- Pollak KI, Oncken CA, Lipkus IM, . Nicotine replacement and behavioral therapy for smoking cessation in pregnancy. Am J Prev Med. 2007;33(4):297–305. PMID: 17888856. 10.1016/j.amepre.2007.05.006 17888856
- Tran DT, Preen DB, Einarsdottir K, . Use of smoking cessation pharmacotherapies during pregnancy is not associated with increased risk of adverse pregnancy outcomes: a population-based cohort study. BMC Med. 2020;18(1):15. PMID: 32019533. 10.1186/s12916-019-1472-9 32019533
- Wisborg K, Henriksen TB, Jespersen LB, . Nicotine patches for pregnant smokers: a randomized controlled study. Obstet Gynecol. 2000;96(6):967–71. PMID: 11084187. 10.1016/s0029-7844(00)01071-1 11084187
- Zhu JL, Olsen J, Liew Z, . Parental smoking during pregnancy and ADHD in children: the Danish national birth cohort. Pediatrics. 2014;134(2):e382–8. PMID: 25049343. 10.1542/peds.2014-0213 25049343