# Appendix C Characteristics of Ancillary Reviews

Appendix C Table 1 Inclusion Criteria of Ancillary Systematic Reviews on the Effectiveness and Adverse Events of Tobacco Cessation Interventions Among Adults, by Author

Author, Year | Last search date | Population | Specific Intervention | Intervention criteria | Comparison | Outcomes | Setting | Followup | Study design
Agboola, 2015^79^ | Sept-2013 | Adult smokers | Varenicline | Varenicline | NR | Smoking abstinence | NR | ≥3 months | RCTs
Ahmed, 2018^80^ | July-2018 | Smokers with schizophrenia, schizophreniform, schizoaffective, or delusional disorder | Varenicline | Varenicline | Placebo | Smoking abstinence, AEs | NR | NR | RCTs
Appolonio, 2016^81^ | Aug-2016 | Adult smokers aged 15 years or older with alcohol or other drug dependence | Any tobacco cessation intervention | Any pharmacologic, behavioral, or combination tobacco cessation intervention | Usual tobacco cessation therapies provided in alcohol and drug treatment; delayed treatment; lower treatment level; no tobacco-related cessation therapy | Smoking abstinence | Inpatient or outpatient treatment | Any followup | RCTs
Boland, 2016^83^ | May-2016 | Smokers (excluding smokeless tobacco or e-cig users) of any age, of low-socioeconomic status, disadvantaged groups (e.g. homeless persons, Indigenous and native persons, prisoners, at-risk-youth, persons with a mental illness, persons using substances or diagnosed with a substance use disorder, persons with a disability or chronic illness such as HIV-positive persons), including pregnant women | Mobile phone- or internet-based support | Technology-based intervention, including those delivered via mobile phone or internet | NR | Smoking abstinence | NR | Any followup | RCTs or quasi-RCTs
Carson, 2012^86^ | April-2011 | Indigenous smokers of any age | Any tobacco cessation intervention | Any pharmacologic, behavioral, or combination tobacco cessation intervention | Usual care, minimal or no intervention, placebo | Smoking abstinence | Any | ≥6 months | RCTs or quasi-RCTs
Danielsson, 2014^89^ | May-2013 | Adult smokers, excluding pregnant persons | Telephone- or internet-based support | Telephone or web-based interventions, focused on pure telephone or internet-based self-help | NR | Smoking abstinence | NR | ≥3 months | RCTs or quasi-RCTs
Denison, 2017^90^ | Nov-2016 | Adults smokers | Cognitive therapy | Cognitive therapies promoting smoking cessation | No intervention; usual care; other behavioral intervention | Smoking abstinence; physiological or clinical outcomes related to smoking | NR | NR | RCTs or systematic reviews
Do, 2018^91^ | Mar-2017 | Smokers of any age, excluding smokeless tobacco users | eHealth smoking cessation intervention | Web-based intervention, computer-generated programs, mobile-based interventions, and other electronic platforms | Usual practice or other smoking cessation methods | Smoking abstinence | NR | ≥1 month | RCTs, quasi-RCTs, interrupted time series, and controlled before-after
Ebbert, 2015^92^ | June-2015 | Users of any age of any tobacco product that is placed in the mouth and not burned | Any tobacco cessation intervention | Any pharmacologic, behavioral, or combination tobacco cessation intervention | Placebo; less intensive intervention; usual care | Smoking abstinence | NR | ≥6 months | RCTs or quasi-RCTs
Giles, 2014^93^ | Apr-2012 | Non-clinical, adult (at least 50% of the sample aged 18 years or above) populations, living in high-income economies | Financial-based incentives | Financial incentives: cash, cash-like rewards, or penalties contingent on behavior change | Usual care; no intervention | Smoking abstinence | NR | ≥6 months | RCTs
Graham, 2016^94^ | Apr-2015 | Adult smokers | Internet-based interventions | Internet-based interventions | NR | Smoking abstinence | NR | ≥1 month | RCTs
Griffiths, 2018^186^ | May-2017 | Pregnant smokers aged 16 years and older | Digital interventions | Any intervention delivered through computer, video or DVD, mobile phone or handheld device | Usual care; other intervention | Smoking abstinence | NR | End of pregnancy | RCTs or quasi-RCTs
Johnston, 2013^99^ | May-2012 | Nonindigenous and indigenous smokers of any age from Australia, New Zealand, United States, or Canada | Any tobacco cessation intervention | Any tailored or nontailored pharmacologic, behavioral, or combination tobacco cessation intervention | Nontailored tobacco control intervention or usual care | Smoking abstinence | NR | NR | RCTs, CCTs
Khanna, 2016^100^ | Apr-2015 | Smokers aged 18 to 65 years and suffering from serious mental illness (e.g. schizophrenia, schizophrenia-like disorders, bipolar disorder, serious affective disorders) | Advice | Tobacco cessation advice, defined as “preventive information or counsel that leaves the recipient to make the final decision”. | Usual care | Smoking abstinence; AEs; quality of life; smoking cessation awareness | NR | Any followup | RCTs
Kishi, 2014^101^ | Aug-2014 | Smokers of any age, including pregnant women, with schizophrenia, schizoaffective disorder, schizophreniform disorder, or delusional disorder | Varenicline (Harms only) | Varenicline | Placebo | AEs | NR | ≥8 weeks | RCTs
Klinsophon, 2017^102^ | Nov-2016 | Smokers of any age who wished to quit or who were recent quitters, excluding pregnant persons | Exercise | Exercise alone or as an adjunct program to smoking cessation | Any control, including another smoking cessation intervention that did not include exercise | Smoking abstinence | NR | ≥6 months | RCTs
Lindson-Hawley, 2015^213^ | Aug-2014 | Adult tobacco users, excluding pregnant persons | Motivational interviewing | Behavioral intervention using motivational interviewing | Brief advice; low-intensity intervention; routine care | Smoking abstinence | NR | ≥6 months | RCTs
Liu, 2013^107^ | Apr-2013 | Children and adults of African-, Chinese- or South Asian-origin | Adapted interventions for ethnic minorities | Adapted behavioral tobacco cessation interventions for ethnic minorities | Usual care or nonadapted intervention | Smoking abstinence | Any | NR | Any
McCabb. 2019^111^ | Sept-2018 | Adult smokers, excluding pregnant persons and smokeless tobacco users | Internet-based interventions | Internet-based intervention with or without additional support such as medication or other behavioral support | No treatment or other smoking cessation intervention | Smoking abstinence | Any | Any | RCTs
McKee, 2016^112^ | Dec-2014 | Tobacco users of any age | Varenicline | Varenicline | Placebo | Smoking abstinence | NR | ≥3 months | RCTs
Notley, 2019^116^ | July-2018 | Pregnant smokers | Incentives | Incentive schemes, lotteries, raffles, and contingent or non-contingent payments, to reward cessation and abstinence in smoking cessation programs | Usual care, other smoking cessation intervention without incentives, another incentive-based intervention differing by incentive type or amount | Smoking abstinence, AEs | Any | End of pregnancy | RCTs
Palmer, 2018^117^ | Jan-2016 | Smokers of any age | Mobile phone-based support | Mobile phone-based support | NR | Smoking abstinence | NR | Any followup | RCTs
Peckham, 2017^118^ | Sept-2016 | Adults smokers with severe mental illness | Any tobacco cessation intervention | Any pharmacologic, behavioral, or combination tobacco cessation intervention or the use of e-cigarettes as a smoking cessation aid | Placebo; comparative effectiveness; usual care; no intervention | Smoking abstinence; AEs; change in psychiatric symptoms; change in body weight | Either in-patient or outpatient settings | Any followup | RCTs
Roberts, 2016^120^ | Dec-2014 | Adult smokers with severe mental illness motivated to attempt to quit or reduce smoking | NRT, bupropion, varenicline | NRT, bupropion, varenicline | Placebo; alternative pharm | Smoking abstinence; AEs | NR | ≥6 months | RCTs
Rosen, 2018^121^ | Dec-11, July-12, July-13 (used 3 Cochrane reviews) | Adult smokers, excluding pregnant persons | NRT, bupropion, varenicline | NRT, bupropion, varenicline | No active medication | Smoking abstinence | NR | 6 months and 12 months | RCTs
Schuit, 2018^122^ | Aug-2016 | Adult smokers | NRT, bupropion, varenicline | NRT, bupropion, varenicline | Placebo; usual care; alternative pharm; non-pharm intervention; no-intervention control; different doses or durations of pharm; different NRT formats; combinations of pharm; different types or intensities of behavioral support as adjunct to pharm | Smoking abstinence | Any | Any followup | RCTs or quasi-RCTs
Schwartz, 2015^123^ | Feb-2014 | Smokeless tobacco users of any age | Varenicline | Varenicline | Placebo | Smoking abstinence; AEs | NR | 12 weeks; 6 months | RCTs
Smith, 2016^124^ | Dec-2015 | Adult smokers | NRT, bupropion, varenicline | NRT, bupropion, varenicline | Placebo | Smoking abstinence | NR | ≥6 months | RCTs
Thurgood, 2016^132^ | Aug-2014 | Adult smokers in substance abuse treatment or recovery | Any tobacco cessation intervention | Any pharmacologic, behavioral, or combination tobacco cessation intervention | Placebo; usual care | Smoking abstinence | NR | ≥6 months | RCTs
Tsoi, 2013^133^ | Oct-2012 | Adult smokers with schizophrenia or schizoaffective disorder | Any tobacco cessation intervention | Any pharmacologic, behavioral, or combination tobacco cessation intervention | Another intervention, placebo or usual care | Smoking abstinence; AEs; change in mental state | NR | ≥6 months | RCTs or quasi-RCTs
van der Meer, 2013^136^ | Apr-2013 | Adult smokers with current or past depression | Any tobacco cessation intervention | Any pharmacologic, behavioral, or combination tobacco cessation intervention | Usual care or placebo | Smoking abstinence | Any | ≥6 months | RCTs
Wilson, 2017^139^ | Jan-2017 | Smokers in selected disadvantaged groups (e.g. homeless, prisoners, indigenous populations, at-risk youth, people on low income, those with mental illness) | Any behavioral support | Any behavioral tobacco cessation intervention | Another behavioral intervention; usual care | Smoking abstinence | Only studies conducted in full OECD countries (US, Canada, Australia, New Zealand, United Kingdom, and Western Europe) | ≥3 months | RCTs
Wilson, 2018^187^ | July-2017 | Pregnant smokers of any age | Psychotherapy or incentive-based interventions | Psychotherapy delivered in at least 2 sessions or incentives to be earned contingent on abstinence | Usual care or any smoking cessation intervention not including incentives | Smoking abstinence | NR | ≥3 months | RCTs
Windle, 2016^140^ | July-2015 | Cigarette smokers of any age motivated to quit | NRT, bupropion, varenicline | NRT, bupropion, varenicline | Placebo or alternative pharm | Smoking abstinence; AEs; SAEs | NR | ≥12 months | RCTs
Wu, 2015^141^ | Apr-2015 | Adults smokers not motivated to quit | Any tobacco cessation intervention | Any pharmacologic, behavioral, or combination tobacco cessation intervention | Placebo; no intervention; other behavioral support except for reduction support | Smoking abstinence; AEs | NR | ≥6 months | RCTs
Wu, 2016^142^ | Sept-2015 | Adult smokers with a severe mental illness | Varenicline (Harms only) | Varenicline | Placebo; alternative pharm | Psychiatric AEs | In- and out-patient settings in any country | NR | RCTs or quasi-RCT

Abbreviations: AE = Adverse event; CCT = Controlled clinical trial; NR = Not reported; NRT = Nicotine replacement therapy; OECD = Organization for Economic Cooperation and Development; RCT = Randomized controlled trial; SAE = Serious adverse event

Appendix C Table 2 Descriptive Characteristics of Included Studies Within the Ancillary Reviews on the Efficacy and Adverse Events of Tobacco Cessation Interventions Among Adults, by Author

Author, Year | Intervention | Total # of included studies | Sample size (range) | Average age (range) | Average CPD at BL (range) | Intervention description | Setting | Providers
Agboola, 2015^79^ | Varenicline | 19 | 32 - 1210 | 39 - 57 | NR | All trials used a regimen of 0.5 mg for the first week of treatment followed by 1-mg tablets of varenicline administered twice daily for a n additional 11 weeks except three; one in which varenicline was administered for 7 weeks, another in which participants received varenicline for 52 weeks, and a third study in which varenicline was administered for an additional 12 weeks as maintenance treatment following a 12 week treatment period. All trials provided brief support (behavioral counseling delivered face-to-face or via telephone) throughout the treatment phase, except one study in which participants received a personalized quit message and a printed information sheet at baseline only. All trials continued brief counseling during the non-treatment follow-up phase, either face-to-face or via telephone, except two studies in which participants received a quit message at baseline only and supplies of varenicline at follow-up visits and access to quitlne counseling during the treatment phase only. Only two studies documented the use of specific relapse prevention counseling indicating that, in most of the included studies, relapse prevention may not have been a major feature of support provided. | NR | NR
Ahmed, 2018^80^ | Varenicline | 4 | 9 – 127 | 41 – 42 | NR | Varenicline treatment for 12 weeks | NR | NR
Appolonio, 2016^81^ | Any tobacco cessation intervention | 34 | 36 - 575 | NR | NR | Counseling (k=11) included one-time or multi-session individual counseling or motivational interviewing sessions, cognitive behavioral therapy, and group counseling sessions. Pharmacotherapy (k=11) included naltrexone or topiramate, nicotine gum, nicotine patches + gum, bupropion, and varenicline. Combination therapy (k=12) included combined counseling and pharmacotherapy (NRT or bupropion) versus usual care. | Inpatient and outpatient | NR
Boland, 2016^83^ | Mobile phone- or internet-based support | 13 | 100 - 2142 | 22 - 47.4 | Average, 16.9 (range NR) | Websites to deliver cessation support targeted at low-income smokers and HIV positive smokers (k=5); Computer program to deliver cessation advice and support to substance dependent smokers, smokers with a mental illness, and predominantly African American pregnant smokers (k=5); 60-minute culturally specific cessation DVD for African American smokers (k=1); Integrated video-telephony for rural low-SES smokers (k=1); Mobile phone text-message cessation support for Indigenous smokers (k=1); Tailored intervention and study materials to respective disadvantaged group with the aim of reducing health inequalities (k=9) | NR | NR
Carson, 2012^86^ | Any tobacco cessation intervention | 4 | 111 - 601 | 24.5 - 39.9 | NR | Intervention durations ranged from seven weeks to six months. One study had two days of training for doctors and clinical staff with no data provided on intervention duration received by patients. | Remote locations; health clinics | NR
Danielsson, 2014^89^ | Telephone- or internet-based support | 74 | 38 - 73,000 | 20.1 - 57.4 | NR | Internet intervention vs. control (k=21); Helpline intervention vs. control (k=12); Remaining studies focused on alcohol use or gambling | NR | NR
Denison, 2017^90^ | Cognitive therapy | 21 | 25 - 677 | 21 - 60 | NR | Most interventions included one or more of the following cognitive or cognitive-behavioral content, in order of frequency: relapse prevention, coping skills, self-management, self-efficacy, social support, cognitive restructuring, problem solving, motivational interview, stress management, and rearrangement of environment-per- son interaction. One study evaluated interventions based on an acceptance and commitment approach, and one study focused on environment-person interactions. Most studies used individual counselling. | NR | NR
Do, 2018^91^ | eHealth smoking cessation intervention | 108 | 2 – 23,213 | NR | NR | Majority of studies used web-based programs followed by wireless and mobile phone-based programs, and computer-assisted interventions. Few studies investigated social media, virtual chat rooms, or other electronic aids. | NR | NR
Ebbert, 2015^92^ | Any tobacco cessation intervention | 34 | 42 - 2523 | 17 - 44 | Two studies reported the average number of dips per day, ranging from 7.9 to 11 dips per day at baseline. One study only enrolled participants consuming 3 cans or pouches of smokeless tobacco per week. All other studies required participants to be current ST users at enrollment. | Pharmacologic: Bupropion SR was sustained release; NRT included patches, lozenges, and gum. In all cases, both the treatment and control groups received the same behavioral interventions.; Behavioral: stratified on the basis of whether the intervention targeted individuals or organizations and included oral screening, counseling (telephone or group (peer-led or nursing-led)), mailings, posters, videos, in-person feedback, manuals, informational websites, and quitlines. | Any setting, including dental offices, community settings, school, military | NR
Giles, 2014^93^ | Financial-based incentives | 8 | 141 - 11,281 | NR | NR | Most interventions offered cash rewards and/or vouchers exchangeable for a specific range of goods or services; two studies used deposit contracts where participants made cash deposits at the start of the intervention which were only returned in the event of successful behavior change - resulting in potential financial penalties. Two studies also included additional uncertain rewards contingent on behavior change in addition to certain rewards. The total value of incentives, over and above any payments for study participants, ranged from $5.16 to $786 (in 2011 US$). Intervention periods ranged from two weeks to 24 months. | NR | NR
Graham, 2016^94^ | Internet-based interventions | 40 | 122 - 23,213 | 19.8 - 49.5 | NR | Static web interventions: Ten trials included stand-alone static web components as part of the intervention condition. Static content was generally informational and non-tailored and contained content comparable to a printed cessation guide. Included in this category are static interventions in which the intervention is fully available and those that deliver intervention components over time. In some studies, static content was paired with additional features such as tailored feedback reports, text messaging, and/or social support. Tailored feedback: Tailored feedback consists of advice or information provided to users based on responses to one or more assessments. Eight studies examined interventions consisting largely of a feedback report. Tailoring was often performed on the basis of participants’ responses to an initial assessment and/or on the basis of participants’ stage of quitting. The form of tailored messages, however, varied greatly. In one study, participants could receive up to 150 tailored emails over 6–12 months with tailoring on multiple factors. In contrast, another study provided participants with a single tailored letter, six to nine pages in length, based on a 62-item questionnaire. Interactive/tailored web intervention: The majority of studies evaluated the effectiveness of interactive web interventions. Interactivity was defined as any part of a web intervention that solicited/required user input and included features such as exercises, quizzes, cost calculators, tailored messages, quit planning tools, training in coping strategies, and self-monitoring. A minority of the interactive interventions offered tailored content and/or guided users through the intervention based on information provided by the participant. Coaching analogs and social support: A number of trials included social support resources such as peers, coaches, or counselors. The most common form of social support was the provision of an asynchronous discussion forum. Eight trials included a discussion forum, either moderated by a peer or an expert, in at least some of the study arms. Seven trials included access to live coaching or counseling either via telephone, face-to-face counseling, or SMS text or email. Two studies evaluated other methods of accessing social support. Other adjunctive components: Four trials described the use of SMS text messaging as part of the intervention. Two trials also included interactive voice response calls. Two other studies included an online eight module cognitive-behavioral mood management component in some arms. Another study included videos and the ability to create video content. Medication: Several studies provided pharmacotherapy along with the web-based intervention. Nicotine replacement therapy (NRT) was the most common form of pharmacotherapy and was included in seven trials. Medication treatment ranged from a 2-week starter kit used in one study to a 10-week starter kit used in another study. Two trials included 12 weeks of varenicline. One study included a 9-week course of bupropion. | Varied | NR
Griffiths, 2018^186^ | Digital interventions | 12 | 17 – 918 | 23 – 30.5 | NR | Four studies delivered digital content through text messages. Three studies used videotapes, and one study used telephone Interactive Voice Response Technology (IVR). Two trials used websites, including a contingency management program, and an interactive and personalized website. The remaining two trials were computer programs. | Home, clinical setting | NR
Johnston, 2013^99^ | Any tobacco cessation intervention | 5 | 226 - 1705 | NR | NR | Three studies were pragmatic trials that recruited participants through New Zealand’s Quitline service with the aim of testing the effectiveness of enhanced protocols, specifically (a) precessation nicotine replacement therapy (NRT), (b) familiarization and choice of NRT product, and (c) very low nicotine content cigarettes (VLNC) compared with usual care. The other two studies trialed a smoking cessation counseling intervention using mobile phone technology. | Recruited from Quitline service (k=3) | NR
Khanna, 2016^100^ | Advice | 0 | NA | NA | NA | NA | NA | NA
Kishi, 2015^101^ | Varenicline (Harms only) | 7 | 9 - 128 | 39.9 - 51.4 | NR | All trials provided varenicline at 1–2mg/day plus psychotherapy | Outpatient | NR
Klinsophon, 2017^102^ | Exercise | 19 | 20 - 2318 | NR | NR | Details of interventions not synthesized.; Aerobic exercise (k=14); Resistance training (k=1); Yoga (k=1); Combined aerobic and resistance exercise program (k=1); Did not specify the precise type of exercise and were classified as “physical activity” (k=2); Supervised, group-based exercise at the research setting plus home-based exercise (k=8); Supervised, group-based exercise at the research setting (k=7); Home-based exercise (k=3); Remaining provided home-based exercise or supervised, group-based exercise in each group | NR | NR
Liu, 2013^107^ | Adapted interventions for ethnic minorities | 28 | NR | NR | NR | Most interventions were adapted for African American smokers (k=23) and the remaining were adapted for Chinese Americans (k=5). The most frequency used adaptations were to develop materials specifically for the target population, followed by the use of materials that reflected the target population’s reading and literacy level, material that depicted individuals from the target population, appropriate graphics and scenarios, and intervention content that targeted the population’s social and cultural values. | NR | Physicians, lay health educators, lay counselors, neighborhood health advocates, nurses
McCrabb, 2019^111^ | Internet-based interventions | 45 | 35–16,430 | 20–50 | NR | Internet-based interventions with or without additional interventions components such as phone calls, medication, group support. | NR | NR
McKee, 2016^112^ | Varenicline | 16 | 79 - 703 | NR | NR | Majority of studies delivered 1mg bid. Varenicline duration was mostly 12 weeks (14/16 trial) with 1 study at 6weeks and 1 lasting 52wks. Study duration ranged from 24 to 52; majority 52 wks (9/16 trials) while 7 were 24 or 26wks in duration. | Hospitalized adults (k=1) | NR
Notley, 2019^*^,^116^ | Incentives | 10 | 17–1014 | 24–30.7 | NR | Largest trial provided cash payments as the incentive. In all other cases the rewards were vouchers for goods or services. All the trials offered a program of practical cessation support, in addition to usual care. | Antenatal programs, substance misuse treatment clinics | NR
Palmer, 2018^117^ | Mobile phone-based support | 18 | 31 - 5800 | 19 - 43 | NR | Twelve interventions were delivered by SMS, three were delivered by voice calls, one by interactive voice response, one by a combination of SMS and video messages, and one by a mobile application with voice calls. | Recruited from internet, quitline, lung cancer screening, local newspaper, cancer network membership, mail, emergency department, electronic health record, and phone recruitment | NR
Peckham, 2017^118^ | Any tobacco cessation intervention | 26 | 5 - 298 | NR | NR | The varenicline studies all followed a standard dosing schedule whereas the dose in the Bupropion SR studies ranged from 150 mg once per day to 150 mg twice per day. Smoking cessation counselling, whether part of the intervention being tested or part of the control arm, consisted of a range of behavior change techniques delivered in a variety of formats e.g. face-to-face one-to-one sessions, face-to-face group sessions or one-to-one sessions delivered via telephone. It is important to note that in the trials of varenicline and bupropion, where smoking cessation counselling was delivered, the same program was delivered in both the medication (varenicline or bupropion) arm of the trial as in the usual care arm of the trial. In the majority of the trials the exact content, in terms of the behavior change techniques employed in the smoking cessation counselling, was insufficiently described. | Outpatients (k=20), inpatient (k=1) | NR
Roberts, 2016^120^ | NRT, bupropion, varenicline | 14 | 5 - 128 | NR | NR | Number of CBT sessions varied by study | NR | NR
Rosen, 2018^121^ | NRT, bupropion, varenicline | 61 | 36 - 3575 | NR | NR | For comparators: “Some studies included more than two treatment groups. For 2 × 2 factorial designs that included a medical and a non-medical (behavioral/ psychological) intervention, two separate comparisons were performed: one for the active non-medical intervention and one for the inactive non-medical intervention. In cases where high- and low- dependent smoker subgroups were randomized separately to intervention and control arms, each subgroup was treated in the meta-analysis as a separate study. In studies with multiple doses and a single control, participants assigned any non-zero dose were combined into a single intervention group. For trials with multiple intervention arms which did not have a clear 2 × 2 design, we compared the two groups that were identical on all aspects of the intervention except for provision of medication. | NR | NR
Schuit, 2017^122^ | NRT, bupropion, varenicline | 18 | 61 - 1686 | 41 - 46 | NR | NRT vs. placebo (k=4); Bupropion SR vs. placebo (k=6); NRT vs. bupropion SR vs. NRT + Bupropion SR (k=1); NRT vs. varenicline (k=1); Bupropion SR vs. NRT + Bupropion SR (k=1); Basic support + NRT vs. weekly support + NRT (k=1); No intervention vs. extended NRT vs. extended NRT + CBT vs. extended NRT vs. extended counselling (k=1); NRT, patch vs. NRT, nasal spray with group counseling provided to all participants (k=1); NRT oral dose (tailored by DNA analysis) vs. NRT oral dose (tailored by nicotine dependence questionnaire) (k=1); Varenicline + telephone counselling vs. varenicline + web intervention vs. varenicline + telephone counselling + web intervention (k=1) | Community and healthcare | NR
Schwartz, 2016^123^ | Varenicline | 3 | 76 - 431 | 34.2 - 43.9 | NR | All trials included behavioral counseling (details not specified); 2 trials assessed at both timepoints: Varenicline at a dose of 0.5mg once daily on Days 1–3, increased to 0.5mg twice daily on Days 4–7, and further increased to a target dose of 1mg twice daily for 11 weeks; for a total of 12 weeks of treatment.; The 3rd trial with only 12wk FU: Varenicline at a dose of 0.5mg once daily on Days 1–3, increased to 0.5mg twice daily on Days 4–7, and further increased to a target dose of 1mg once daily for 11 weeks in participants weighing <55kg, and a target dose of 1mg twice daily in participants weighing ≥55kg; for a total of 12 weeks of treatment. | NR | NR
Smith, 2016^124^ | NRT, bupropion, varenicline | 28 | 56 - 842 | NR | NR | All NRT trials included transdermal nicotine patches ranging from 14mg to 42mg per day for 6 to 18 weeks with varying levels of counseling. All Bupropion SR trials provided 150mg 2/day for 6 to 10 weeks with varying levels of counseling. Varenicline doses ranges from 0.3 mg 1/day to 1mg 2/day for 12 weeks with varying levels of counseling. | Primary care (k=4), community volunteers (k=26), smoking cessation clinic (k=2), community health center (k=1) | NR
Thurgood, 2016^132^ | Any tobacco cessation intervention | 17 | 64 - 383 | 34 - 50 | 16 - 32 | The main intervention categories included counseling only; counseling and NRT; NRT only; CBT only; CBT and NRT; motivational interviewing; contingency management; bupropion; and varenicline. | Inpatient substance abuse treatment (k=4); 21-day inpatient alcohol detox (k=1); Outpatient substance abuse treatment (k=1); Outpatient methadone treatment (k=1) | Masters and doctoral level clinicians, trained therapists, counselors, graduate students, psychologists trained in CBT, research physicians, first author provided counseling, interventionists
Tsoi, 2013^133^ | Any tobacco cessation intervention | 34 | 9 - 298 | 34 - 48.7 | 7 – 41 | The duration of drug treatment varied from 7 hours to 6 months. | “Most trials recruited participants from the community”; inpatient units, the community, or outpatient psychiatric treatment sites | NR
van der Meer, 2013^136^ | Any tobacco cessation intervention | 49 | 14 - 5046 | 24 - 57 | 7.9 – 32.3 | In most trials, the psychosocial mood management component of the experimental intervention consisted of a format of (cognitive) behavioral therapy for depression. In one trial the psychosocial mood management component consisted of a cognitive behavioral analysis system of psychotherapy, in one trial of hypnosis skills, and in one trial of exercise counselling. The interventions of all of four of Muñoz’s trials had a self-help format, one trial had a group counselling format, two trials had an individual counselling format, two trials had an individual plus telephone counselling format, one trial had a telephone counselling format, one had a telephone counselling plus self-help format, and one had a group plus self-help format. All trials except the four conducted by Muñoz had interventions with multi-session behavioral support. Seven trials had time-matched comparisons. Three trials had additional pharmacotherapy in both arms, and six trials had no additional pharmacotherapy in both arms. | Trials conducted in community, university, and clinical settings including hospitals | NR
Wilson, 2017^139^ | Any behavioral support | 24 | 30 - 4613 | 21.9 - 54.8 | NR | NRT (k=9), Bupropion SR (k=2), nortriptyline (k=1), behavioral therapy varied, included motivational interviewing, smoking cessation counselling, group therapy, CBT, weekly classes, financial incentives, exercise, computer-delivered programs, phone counselling, contingency management, motivational enhancement, and educational videos | Community or health centers | NR
Wilson, 2018^187^ | Incentives | 22 | 54 – 941 | 23 – 31 | Mean: 10 | Sixteen trials provided psychotherapy to smokers with total session time ranging from 50 min to 480 min over 2 or more sessions. Six trials provided incentive-based interventions ranging from a maximum of $250 to $1180 contingent upon abstinence. | Public prenatal clinic, WIC clinic, community, prenatal clinic, HMO, army medical center, women’s hospital, MIC clinic, maternity hospital, addiction program | NR
Windle, 2016^140^ | NRT, bupropion, varenicline | 123 | 51 - 3684 | 16 - 63 | 7 - 38 | NRT patch + BT vs. BT (k=15); Short-acting NRT + BT vs. BT (k=29 ); NRT + BT vs. BT (k=44); Bupropion SR + BT vs. BT (k=20); Varenicline + BT vs. BT (k=14); Nicotine patch + BT vs. Nicotine Patch (k=4); NRT + BT vs. NRT (k=6); Pharmacotherapy + BT vs. Pharmacotherapy (k=7); Pharmacotherapy + Intensive BT vs. Pharmacotherapy + Minimal BT (k=5); Pharmacotherapy combinations NRT + NRT vs. NRT monotherapy (k=7); Nicotine patch + Short-acting NRT vs. Nicotine Patch (k=5); Bupropion SR + NRT vs. Monotherapy (k=4); Pharmacotherapy + Pharmacotherapy vs. Pharmacotherapy (k=12) | NR | NR
Wu, 2015^141^ | Any tobacco cessation intervention | 14 | 67 - 1410 | 38.5 - 55.4 | NR | Reduction support + medication vs. reduction support + placebo (k=9); Reduction support + medication vs.no intervention (k=5); Reduction support + medication vs. reduction support vs.no intervention (k=1) | NR | NR
Wu, 2016^142^ | Varenicline (Harms only) | 8 | 5 - 127 | NR | NR | The selected randomized trials all compared varenicline with placebo. Three studies explored the effectiveness of varenicline alone, and the remaining studies evaluated varenicline in combination with individual behavioral interventions. The duration of the varenicline treatment varied between 8 and 12 weeks; 81% of participants treated with varenicline completed the treatment, compared with 82% in placebo groups. | NR | NR

* Evidence for pregnant persons only

Abbreviations: bid = Two times a day; BL = Baseline; BT = Behavioral therapy; CBT = Cognitive behavioral therapy; CPD = Cigarettes per day; DNA = Deoxyribonucleic acid; DVD = Digital versatile disc; FU = Followup; HIV = Human immunodeficiency virus; kg = kilogram; mg = milligram; NA = Not applicable; NR = Not reported; NRT = Nicotine replacement therapy; SES = Socioeconomic status; SMS = Short message service; ST = Smokeless tobacco; wks = weeks; US = United States; VLNC = Very low nicotine content cigarettes