# Appendix B Literature Flow Diagrams

Appendix B Figure 1 Literature Flow Diagram, Tobacco Cessation in Adults: Overview of Reviews

* Articles may appear under more than one Key Question

Abbreviations: ESRs = existing systematic reviews

This figure is a flow chart that summarizes the search and selection of articles in the review of reviews portions of Tobacco Cessation in Adults. There were 1095 citations identified through literature databases. An additional 24 citations were identified from outside sources, and 54 citations were identified from the 2015 USPSTF review. After duplicates were removed, 1173 unique citations were screened at the title/abstract stage. The full text of 210 citations were examined for inclusion for one or more of the Key Questions. The following number of articles were included for Key Question 1 (k=3), Key question 2 (k=61), and Key Question 3 (k=27). Reasons for excluding the other articles are available in Appendix E.

Appendix B Figure 2 Literature Flow Diagram, Tobacco Cessation in Adults: Electronic Cigarettes

* Articles may appear under more than one Key Question

This figure is a flow chart that summarizes the search and selection of articles in the electronic cigarettes portion of Tobacco Cessation in Adults. There were 7044 citations identified through literature databases. An additional 7 citations were identified from outside sources, and 3 citations were identified from the 2015 USPSTF Review. After duplicates were removed, 7054 unique citations were screened at the title/abstract stage. The full-text of 75 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=0), Key question 2 (k=5), and Key Question 3 (k=9). Reasons for excluding the other articles are available in Appendix E.

Appendix B Figure 3 Literature Flow Diagram, Tobacco Cessation in Adults: Pharmacotherapy Interventions Among Pregnant Women

* Articles may appear under more than one Key Question

This figure is a flow chart that summarizes the search and selection of articles in the pharmacotherapy interventions among pregnant women portion of Tobacco Cessation in Adults. There were 481 citations identified through literature databases. An additional 14 citations were identified from outside sources, and 11 citations were identified from the 2015 USPSTF review. After duplicates were removed, 203 unique citations were screened at the title/abstract stage. The full text of 64 citations were examined for inclusion for one or more of the Key Questions. The following number of articles were included for Key Question 1 (k=7), Key Question 2 (k=7), and Key Question 3 (k=12). Reasons for excluding the other articles are available in Appendix E.