# Appendix A Detailed Methods

## Literature search strategies for overview of reviews: Tobacco cessation in adults

Sources searched (2014-present):

Agency for Healthcare Research and Quality

Canadian Agency for Drugs and Technologies in Health

Cochrane Database of Systematic Reviews

Community Guide

Database of Abstracts of Reviews of Effects

Health Technology Assessment

Health and Medicine Division (HMD) of the National Academies of Sciences, Engineering, and Medicine (formerly Institute of Medicine)

NHS Health Technology Assessment Programme

PsycINFO

PubMed

Surgeon General

### Canadian Agency for Drugs and Technologies in Health

Pharmacological based strategies for Smoking Cessation (2016)

https://cadth.ca/pharmacologic-based-strategies-smoking-cessation

Integrated cessation program for adults who smoke cannabis and tobacco: Clinical effectiveness and guidelines (2017)

https://cadth.ca/sites/default/files/pdf/htis/2017/RA0934%20Interventions%20for%20Cannabis%20Use%20Disorder%20and%20Co-smokers%20Final.pdf

Smoking cessation interventions for patients with severe mental illnesses: A review of clinical effectiveness and guidelines (2017)

https://cadth.ca/sites/default/files/pdf/htis/2017/RC0922%20Smoking%20Cessation%20in%20Mental%20Illness%20Final.pdf

### Cochrane Database of Systematic Reviews

Issue 5 of 12, May 2019

#1 tobacco:ti 1800
#2 smoking:ti 8736
#3 smoker*:ti 3237
#4 smokeless:ti 167
#5 nicotine:ti 2830
#6 cigar*:ti 1822
#7 (vape or vaping or vapour):ti 148
#8 #1 or #2 or #3 or #4 or #5 or #6 or #7 with Cochrane Library publication date Between Jan 2014 and Dec 2019, in Cochrane Reviews, Cochrane Protocols 67

### NHS HTA Programme

Pharmacological interventions for promoting smoking cessation during pregnancy 2018 [in progress]

https://www.journalslibrary.nihr.ac.uk/programmes/sr/NIHR128783/#/

Relapse prevention interventions for smoking cessation (2019) [waiting to start]

https://www.journalslibrary.nihr.ac.uk/programmes/sr/NIHR128787/#/

The Filter FE Challenge: pilot trial and process evaluation of a multi-level smoking prevention intervention in further education settings (2017)

https://www.journalslibrary.nihr.ac.uk/programmes/phr/134202/#/

A multi-centred Trial of physical Activity assisted Reduction of Smoking (TARS) (2017)

https://www.journalslibrary.nihr.ac.uk/programmes/hta/1511101/#/

Evaluating Long-term Outcomes of NHS Stop Smoking Services (ELONS) (2015)

https://www.journalslibrary.nihr.ac.uk/programmes/hta/0916101/#/

Helping pregnant smokers quit: Multi-centre RCT of electronic cigarettes vs usual care. (2017)[in progress]

https://www.journalslibrary.nihr.ac.uk/programmes/hta/155785/#/

A randomised controlled trial to examine the efficacy of e-cigarettes compared with nicotine replacement therapy, when used within the UK stop smoking service (2014) [waiting to publish]

https://www.journalslibrary.nihr.ac.uk/programmes/hta/12167135/#/

A randomised trial to increase the uptake of smoking cessation services using Personal Targeted risk information and Taster Sessions (2017)

https://www.journalslibrary.nihr.ac.uk/programmes/hta/085802/#/

Barriers and facilitators to smoking cessation in pregnancy and following childbirth: literature review and qualitative study (2017)

https://www.journalslibrary.nihr.ac.uk/programmes/hta/119301/#/

Exploring the uptake and use of electronic cigarettes provided to smokers accessing homeless centres: a feasibility study (2018) [in progress]

https://www.journalslibrary.nihr.ac.uk/programmes/phr/174429/#/

A pragmatic randomised controlled trial of physical activity as an aid to smoking cessation during pregnancy. (2015)

https://www.journalslibrary.nihr.ac.uk/programmes/hta/070114/#/

Feasibility randomised controlled trial of a smoking cessation smartphone app that delivers ‘context aware’ behavioural support in real time (2019)

https://www.journalslibrary.nihr.ac.uk/programmes/phr/179231/#/

The London Exercise And Pregnant smokers (LEAP) trial: a randomised controlled trial of physical activity for smoking cessation in pregnancy with an economic evaluation (2015)

https://www.journalslibrary.nihr.ac.uk/hta/hta19840/#/abstract

Nicotine preloading for smoking cessation: the Preloading RCT (2018)

https://www.journalslibrary.nihr.ac.uk/hta/hta22410/#/abstract

Smoking Cessation Intervention for Severe Mental Ill Health Trial (SCIMITAR): a definitive randomised evaluation of a bespoke smoking cessation service (2015)

https://www.journalslibrary.nihr.ac.uk/programmes/hta/1113652/#/

Mixed methods systematic review to identify the determinants of nicotine replacement therapy use and of vaping in pregnancy (2018)

https://www.journalslibrary.nihr.ac.uk/programmes/sr/NIHR128785/#/

### PubMed search strategy

Search | Query
#11 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #8 OR #10
#10 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #7 AND #9 AND (“2014”[Date - Publication] : “3000”[Date - Publication]) AND English[Language]
#9 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (systematic review [ti] OR meta-analysis [pt] OR meta-analysis [ti] OR systematic literature review [ti] OR this systematic review [tw] OR pooling project [tw] OR (systematic review [tiab] AND review [pt]) OR meta synthesis [ti] OR meta-analy*[ti] OR integrative review [tw] OR integrative research review [tw] OR rapid review [tw] OR umbrella review [tw] OR consensus development conference [pt] OR practice guideline [pt] OR drug class reviews [ti] OR cochrane database syst rev [ta] OR acp journal club [ta] OR health technol assess [ta] OR evid rep technol assess summ [ta] OR jbi database system rev implement rep [ta]) OR (clinical guideline [tw] AND management [tw]) OR ((evidence based[ti] OR evidence-based medicine [mh] OR best practice* [ti] OR evidence synthesis [tiab]) AND (review [pt] OR diseases category[mh] OR behavior and behavior mechanisms [mh] OR therapeutics [mh] OR evaluation studies[pt] OR validation studies[pt] OR guideline [pt] OR pmcbook)) OR ((systematic [tw] OR systematically [tw] OR critical [tiab] OR (study selection [tw]) OR (predetermined [tw] OR inclusion [tw] AND criteri* [tw]) OR exclusion criteri* [tw] OR main outcome measures [tw] OR standard of care [tw] OR standards of care [tw]) AND (survey [tiab] OR surveys [tiab] OR overview* [tw] OR review [tiab] OR reviews [tiab] OR search* [tw] OR handsearch [tw] OR analysis [ti] OR critique [tiab] OR appraisal [tw] OR (reduction [tw]AND (risk [mh] OR risk [tw]) AND (death OR recurrence))) AND (literature [tiab] OR articles [tiab] OR publications [tiab] OR publication [tiab] OR bibliography [tiab] OR bibliographies [tiab] OR published [tiab] OR pooled data [tw] OR unpublished [tw] OR citation [tw] OR citations [tw] OR database [tiab] OR internet [tiab] OR textbooks [tiab] OR references [tw] OR scales [tw] OR papers [tw] OR datasets [tw] OR trials [tiab] OR meta-analy* [tw] OR (clinical [tiab] AND studies [tiab]) OR treatment outcome [mh] OR treatment outcome [tw] OR pmcbook)) NOT (letter [pt] OR newspaper article [pt])
#8 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #7 AND systematic[sb] AND (“2014”[Date - Publication] : “3000”[Date - Publication]) AND English[Language]
#7 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #4 NOT #6
#6 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Child”[Mesh] OR “Adolescent”[Mesh]) NOT #5
#5 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Adult”[Mesh]) AND (“Child”[Mesh] OR “Adolescent”[Mesh])
#4 (https://www.ncbi.nlm.nih.gov/pubmed) | Search #1 OR (#2 AND #3)
#3 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (cessat*[tiab] OR stop*[tiab] OR quit*[tiab] OR reduce*[tiab] OR reduction[tiab] OR relapse*[tiab])
#2 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (smoking[ti] OR smoker*[ti] OR tobacco[ti] OR nicotine[ti] OR cigar*[ti] OR vape[ti] OR vaping[ti] OR vapour[ti] OR smokeless[ti])
#1 (https://www.ncbi.nlm.nih.gov/pubmed) | Search “Tobacco Use Disorder”[Mesh:NoExp] OR “Smoking Cessation”[Mesh:NoExp] OR “Tobacco Use Cessation”[Mesh:NoExp] OR “Smoking/prevention and control”[Mesh] OR “Tobacco Use Cessation Products”[Mesh:NoExp] OR “Nicotinic Agonists”[Mesh:NoExp] OR “Tobacco, Smokeless”[Mesh:NoExp] OR “Nicotine Chewing Gum”[Mesh:NoExp] OR “Electronic Nicotine Delivery Systems”[Mesh:NoExp] OR “Smoking Prevention”[Mesh:NoExp]

### PsycINFO <1806 to April Week 4 2019>

1. exp Tobacco Smoking/ (29913)
2. exp Smoking Cessation/ (12420)
3. exp Smokeless Tobacco/ (792)
4. exp Electronic Cigarettes/ (909)
5. (smoking or smoker* or tobacco or nicotine or cigar* or vape or vaping or vapour or smokeless).ti. (34380)
6. 1 or 2 or 3 or 4 or 5 (39898)
7. limit 6 to “300 adulthood <age 18 yrs and older>” (22887)
8. limit 7 to (“0830 systematic review” or 1200 meta analysis) (95)
9. limit 8 to (english language and yr=“2014 -Current”) (46)

## Literature search strategies for primary literature. Tobacco cessation in adults: Electronic Cigarettes

Sources searched:

Cochrane CDSR Trials, via Wiley

PsycInfo, via Ovid

PubMed

Scopus 2020 and 2019

Key:

- * = truncation
- ab = word in abstract
- id = keyword
- kf = keyword heading [word not phrase indexed]
- kw = keyword
- ti = word in title

### Cochrane

Issue 6 of 12, May 2020

#1 (electronic next cigarette*):ti,ab,kw 379
#2 (e next cigarette*):ti,ab,kw 432
#3 “electronic nicotine”:ti,ab,kw 157
#4 (e next liquid):ti,ab,kw 57
#5 (vape or vaping):ti,ab,kw 129
#6 (vaporizer* or vapourizer*):ti,ab,kw 2042
#7 (nicotine or tobacco or cigar*):ti,ab,kw 15956
#8 #6 and #7 62
#9 #1 or #2 or #3 or #4 or #5 or #8 with Publication Year from 2013 to 2020, with Cochrane Library publication date Between May 2019 and Dec 2020 193

### PsycINFO

Datatabase: APA PsycInfo <1806 to June Week 3 2020>

Search Strategy:

------------------------------------------------------------

1. exp Electronic Cigarettes/ (1332)
2. electronic cigarette*.ti,ab,id. (1097)
3. e-cigarette*.ti,ab,id. (1601)
4. electronic nicotine.ti,ab,id. (215)
5. e-liquid*.ti,ab,id. (114)
6. (vape or vaping).ti,ab,id. (417)
7. (vaporizer* or vapourizer*).ti,ab,id. (64)
8. 1 or 2 or 3 or 4 or 5 or 6 or 7 (2057)
9. limit 8 to (english language and yr=“2013 -Current”) (1874)
10. (201905* or 201906* or 201907* or 201908* or 201909* or 201910* or 201911* or 201912* or 2020*).up. (191834)
11. 9 and 10 (456)

### PubMed

((((((((“Electronic Nicotine Delivery Systems”[MeSH Terms:noexp] OR “Vaping”[MeSH Terms:noexp]) OR ((((“e-cigarette”[Title/Abstract] OR “e-cigarettes”[Title/Abstract]) OR “electronic cigarette”[Title/Abstract]) OR “electronic cigarettes”[Title/Abstract]) OR “electronic nicotine”[Title/Abstract])) OR “e-liquid”[Title/Abstract]) OR (“vape”[Title/Abstract] OR “Vaping”[Title/Abstract])) OR ((“vaporizer*”[Title/Abstract] OR “vapourizer*”[Title/Abstract]) AND ((“nicotine”[Title/Abstract] OR “tobacco”[Title/Abstract]) OR “cigar*”[Title/Abstract]))) NOT (“Animals”[MeSH Terms] NOT (“Animals”[MeSH Terms] AND “Humans”[MeSH Terms]))) AND “English”[Language]) AND 2013/1/1:2020/12/31[Date - Publication]) AND 2019/5/1:2020/6/22[Date - Entry]

### Scopus

6 #1 OR #2 OR #3 OR #4 OR #5 AND ( LIMIT-TO ( PUBYEAR , 2020) OR LIMIT-TO ( PUBYEAR , 2019)) AND LIMIT-TO ( LANGUAGE , “English” )
5 ( TITLE-ABS-KEY ( vaporizer* OR vapourizer* ) AND TITLE-ABS-KEY ( nicotine OR tobacco OR cigar* ) )
4 TITLE-ABS-KEY (( vape OR vaping )
3 TITLE-ABS-KEY ( “electronic nicotine” )
2 TITLE-ABS-KEY ( “electronic cigarette*” )
1 TITLE-ABS-KEY ( “e cigarette*” )

## Literature search strategies for primary literature. Tobacco cessation in adults: Pharmacologic interventions in pregnant women

Sources searched:

Cochrane Central Register of Controlled Clinical Trials, via Wiley

MEDLINE, via Ovid

PsycInfo, via Ovid

PubMed, publisher-supplied

Key:

- * = truncation
- $ = truncation
- ab = word in abstract
- exp = explode
- id = keyword
- kf = keyword heading [word not phrase indexed]
- kw = keyword
- sb=subset
- ti = word in title

### COCHRANE

Issue 6 of 12, June 2020

#1 (pregnan* or prenatal or “pre natal” or perinatal or “peri natal” or antenatal or “ante natal” or antepartum or “ante partum” or postnatal or “post natal” or postpartum or “post partum” or puerperal):ti,ab,kw 70929
#2 nicotine:ti,ab,kw next replacement*:ti,ab,kw 1741
#3 nicotine:ti,ab,kw near/3 (transdermal or intravenous* or patch* or gum* or spray* or inhaler* or lozenge*):ti,ab,kw 2338
#4 (Nicotrol or Nicoderm or Habitrol or Prostep or Nicorette):ti,ab,kw 131
#5 (Bupropion or Wellbutrin or Zyban or Varenicline or Chantix or Champix):ti,ab,kw 2477
#6 pharm*:ti and (smoking or smoker* or tobacco or nicotine or cigarette*):ti,ab,kw 875
#7 #2 or #3 or #4 or #5 or #6 6091
#8 #1 and #7 with Publication Year from 2014 to 2020, with Cochrane Library publication date Between May 2019 and Dec 2020 34

### Medline Non-Indexed

Database: Ovid MEDLINE(R) Epub Ahead of Print <June 19, 2020>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <1946 to June 19, 2020>

Search Strategy:

------------------------------------------------------------

1. Pregnancy/ (0)
2. Pregnant women/ (0)
3. Prenatal care/ (0)
4. Perinatal care/ (0)
5. Postnatal care/ (0)
6. Postpartum period/ (0)
7. Peripartum period/ (0)
8. Maternal Health Services/ (0)
9. Pregnancy complications/ (0)
10. Puerperal Disorders/ (0)
11. pregnan$.ti,ab,kf. (51260)
12. prenatal.ti,ab,kf. (10184)
13. pre natal.ti,ab,kf. (140)
14. perinatal.ti,ab,kf. (7292)
15. peri natal.ti,ab,kf. (25)
16. antenatal.ti,ab,kf. (4824)
17. ante natal.ti,ab,kf. (131)
18. antepartum.ti,ab,kf. (544)
19. ante partum.ti,ab,kf. (75)
20. postnatal.ti,ab,kf. (8795)
21. post natal.ti,ab,kf. (805)
22. postpartum.ti,ab,kf. (6998)
23. post partum.ti,ab,kf. (1365)
24. new mother$.ti,ab,kf. (256)
25. puerperal.ti,ab,kf. (977)
26. or/1–25 (71058)
27. “Tobacco Use Cessation Products”/ (0)
28. Nicotinic Agonists/ (0)
29. Bupropion/ (0)
30. Varenicline/ (0)
31. nicotine replacement$.ti,ab,kf. (445)
32. (nicotine adj3 (transdermal or intravenous$ or patch$ or gum$ or nasal spray$ or inhaler$ or lozenge$)).ti,ab,kf. (230)
33. (Nicotrol or Nicoderm or Habitrol or Prostep or Nicorette).ti,ab,kf. (6)
34. (Bupropion or Wellbutrin).ti,ab,kf. (505)
35. Zyban.ti,ab,kf. (11)
36. Varenicline.ti,ab,kf. (273)
37. Chantix.ti,ab,kf. (11)
38. Champix.ti,ab,kf. (12)
39. pharm$.ti. and (smoking or smoker$ or tobacco or nicotine or cigarette$).ti,ab,kf. (258)
40. stop smoking med$.ti,ab,kf. (10)
41. “Tobacco Use Disorder”/dt or smoking/dt or cigarette smoking/dt or “tobacco use”/dt (0)
42. or/27–41 (1369)
43. 26 and 42 (66)
44. Animals/ not (Humans/ and Animals/) (1)
45. 43 not 44 (66)
46. limit 45 to (english language and yr=“2014 -Current”) (47)
47. remove duplicates from 46 (45)

### Medline Indexed

Database: Ovid MEDLINE(R) <1946 to June Week 2 2020>, Ovid MEDLINE(R) Daily Update <June 19, 2020>

Search Strategy:

------------------------------------------------------------

1. Pregnancy/ (873141)
2. Pregnant women/ (8225)
3. Prenatal care/ (27513)
4. Perinatal care/ (4574)
5. Postnatal care/ (5607)
6. Postpartum period/ (25355)
7. Peripartum period/ (1159)
8. Maternal Health Services/ (13798)
9. Pregnancy complications/ (90581)
10. Puerperal Disorders/ (11242)
11. pregnan$.ti,ab,kf. (470582)
12. prenatal.ti,ab,kf. (86283)
13. pre natal.ti,ab,kf. (1045)
14. perinatal.ti,ab,kf. (64796)
15. peri natal.ti,ab,kf. (166)
16. antenatal.ti,ab,kf. (30838)
17. ante natal.ti,ab,kf. (424)
18. antepartum.ti,ab,kf. (5276)
19. ante partum.ti,ab,kf. (376)
20. postnatal.ti,ab,kf. (95526)
21. post natal.ti,ab,kf. (6547)
22. postpartum.ti,ab,kf. (47023)
23. post partum.ti,ab,kf. (10555)
24. new mother$.ti,ab,kf. (1505)
25. puerperal.ti,ab,kf. (5840)
26. or/1–25 (1069952)
27. “Tobacco Use Cessation Products”/ (1786)
28. Nicotinic Agonists/ (7272)
29. Bupropion/ (3025)
30. Varenicline/ (1280)
31. nicotine replacement$.ti,ab,kf. (2991)
32. (nicotine adj3 (transdermal or intravenous$ or patch$ or gum$ or nasal spray$ or inhaler$ or lozenge$)).ti,ab,kf. (3118)
33. (Nicotrol or Nicoderm or Habitrol or Prostep or Nicorette).ti,ab,kf. (131)
34. (Bupropion or Wellbutrin).ti,ab,kf. (3824)
35. Zyban.ti,ab,kf. (119)
36. Varenicline.ti,ab,kf. (1480)
37. Chantix.ti,ab,kf. (72)
38. Champix.ti,ab,kf. (43)
39. pharm$.ti. and (smoking or smoker$ or tobacco or nicotine or cigarette$).ti,ab,kf. (2476)
40. stop smoking med$.ti,ab,kf. (45)
41. “Tobacco Use Disorder”/dt or smoking/dt or cigarette smoking/dt or “tobacco use”/dt (1952)
42. or/27–41 (18199)
43. 26 and 42 (953)
44. Animals/ not (Humans/ and Animals/) (4675588)
45. 43 not 44 (574)
46. limit 45 to (english language and yr=“2014 -Current”) (181)
47. remove duplicates from 46 (181)
48. Smoking Cessation Agents/ (147)
49. 48 not 43 (138)
50. limit 49 to (english language and yr=“2014 -Current”) (132)
51. 50 not 44 (122)
52. (201905* or 201906* or 201907* or 201908* or 201909* or 201910* or 201911* or 201912* or 2020*).ed. (1095231)
53. 47 and 52 (39)
54. 51 or 53 (161)

### PsycInfo

Database: APA PsycInfo <1806 to June Week 3 2020>

Search Strategy:

------------------------------------------------------------

1. exp Pregnancy/ (41840)
2. exp Expectant Mothers/ (710)
3. exp Prenatal Care/ (2070)
4. exp Perinatal Period/ (2836)
5. exp Postnatal Period/ (4650)
6. pregnan*.ti,ab,id. (47446)
7. prenatal.ti,ab,id. (19454)
8. pre natal.ti,ab,id. (251)
9. perinatal.ti,ab,id. (10625)
10. peri natal.ti,ab,id. (66)
11. antenatal.ti,ab,id. (3565)
12. ante natal.ti,ab,id. (57)
13. antepartum.ti,ab,id. (351)
14. ante partum.ti,ab,id. (12)
15. postnatal.ti,ab,id. (20144)
16. post natal.ti,ab,id. (1112)
17. postpartum.ti,ab,id. (12024)
18. post partum.ti,ab,id. (1240)
19. puerperal.ti,ab,id. (509)
20. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 (96764)
21. exp Tobacco Smoking/ (32427)
22. exp Smoking Cessation/ (13149)
23. exp Smokeless Tobacco/ (850)
24. nicotine.ti,ab,id. (16823)
25. (smoking or smoker* or tobacco or nicotine or cigarette*).ti,ab,id. (69408)
26. 21 or 22 or 23 or 24 or 25 (69649)
27. Drug Therapy/ or pharm*.ti. (145315)
28. 26 and 27 (3410)
29. exp Bupropion/ (966)
30. nicotine replacement*.ti,ab,id. (1727)
31. (nicotine adj3 (transdermal or intravenous* or patch* or gum* or nasal spray* or inhaler* or lozenge*)).ti,ab,id. (1789)
32. (nicotrol or nicoderm or habitrol or prostep or nicorette).ti,ab,id. (48)
33. (bupropion or wellbutrin).ti,ab,id. (2178)
34. zyban.ti,ab,id. (44)
35. varenicline.ti,ab,id. (832)
36. chantix.ti,ab,id. (43)
37. champix.ti,ab,id. (17)
38. 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 (7581)
39. 20 and 38 (247)
40. limit 39 to (english language and yr=“2014 -Current”) (82)
41. (201905* or 201906* or 201907* or 201908* or 201909* or 201910* or 201911* or 201912* or 2020*).up. (191834)
42. 40 and 41 (10)

### PubMed, publisher-supplied records

((pregnan*[tiab] OR prenatal[tiab] OR “pre natal”[tiab] OR perinatal[tiab] OR “peri natal”[tiab] OR antenatal[tiab] OR “ante natal”[tiab] OR antepartum[tiab] OR “ante partum”[tiab] OR postnatal[tiab] OR “post natal”[tiab] OR postpartum[tiab] OR “post partum”[tiab] OR puerperal[tiab]) AND ((“nicotine replacement”[tiab]) OR (nicotine[tiab] AND (transdermal[tiab] OR intravenous*[tiab] OR patch*[tiab] OR gum[tiab] OR gums[tiab] OR spray*[tiab] OR inhaler*[tiab] OR lozenge*[tiab])) OR (nicotra[tiab] OR nikodem[tiab] OR habitual[tiab] OR prostej[tiab] OR Nicorette[tiab]) OR (Bupropion[tiab] OR Wellbutrin[tiab] OR Zyban[tiab] OR Varenicline[tiab] OR Chantix[tiab] OR Champix[tiab]) OR (pharm*[ti] AND (smoking[tiab] OR smoker*[tiab] OR tobacco[tiab] OR nicotine[tiab] OR cigarette*[tiab])))) AND publisher[sb] Filters: from 2014 – 2020 [21 results]

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | Include | Exclude
Aim | Tobacco cessation in adults who currently use tobacco, regardless of readiness to quit, including relapse prevention | - Primary prevention of tobacco use; - Tobacco harm–reduction strategies
Condition | Current use of any tobacco product, including but not limited to: cigarettes, e-cigarettes and other electronic nicotine delivery systems (ENDS), cigars, cigarillos and filtered cigars, smokeless tobacco (including snus pouches), pipe tobacco, dissolvable tobacco in the form of strips, sticks, or lozenges, or smoking tobacco through a hookah or waterpipe
Population | Adults (age ≥18 years), including pregnant women who currently use tobacco | Reviews limited to:; - Children and adolescents; - Persons with other comorbid health conditions (e.g., chronic obstructive pulmonary disease, cardiovascular conditions, cancer, HIV)
Interventions | Primary care–relevant tobacco cessation interventions that can be provided in primary care or are feasible to refer to from primary care, including pharmacotherapy, behavioral interventions, and e-cigarettes or ENDS, alone or in combination. | Broad public health initiatives (e.g., mass media, communitywide campaigns)
Setting | Any setting applicable to primary care, including interventions that take place in settings that can be referred to from primary care | Reviews limited to studies that take place in worksites, churches, or other settings where participants have existing social connections
Comparators | - No intervention; - Usual care; - Waitlist; - Attention control (e.g., intervention is similar in format and intensity but on a different content area); - Minimal intervention (no more than a single brief contact [i.e., <5 minutes] per year, brief written materials, such as pamphlets, or self-help materials); - Active intervention (i.e., more than a single brief contact per year or brief written materials)
Outcome assessment | Based on self-report or biochemically validated reports (e.g., expired carbon monoxide; cotinine measured in saliva, urine, or blood; cotinine–creatinine ratio; thiocyanate) | Population-based smoking rates (i.e., not based on study sample but on underlying population)
Outcomes | KQ 1 (health and other outcomes):; Health outcomes:; - All-cause mortality; - Tobacco-related mortality; - Tobacco-related morbidity (including, but not limited to: cancer, asthma, cardiovascular disease, chronic bronchitis, or other respiratory disorders); - Maternal and perinatal morbidity/mortality; - Dental/oral health; - Quality of life; Other outcomes:; - Health care utilization; KQ 2 (behavioral outcomes): Tobacco cessation/tobacco abstinence (continuous or point prevalence abstinence); KQ 3 (harms): Serious treatment-related harms at any time point after the intervention began | Reviews that only report:; - Reduction in smoking/tobacco (based on frequency/quantity only); - Reduction in withdrawal symptoms; - Attitudes, knowledge, or beliefs related to tobacco use; - Intentions to change behavior; - Intervention participation/compliance
Outcome assessment timing | KQs 1, 2: ≥6-month followup after quit date/start of intervention; KQ 3: Harms reported at any point after quit date | <6-month followup after quit date or start of intervention
Study design | Pharmacotherapy and behavioral interventions in adults and behavioral interventions in pregnant women (review-of-reviews):; All KQs: Systematic reviews, including review-of-reviews, with or without meta-analysis. A review will be considered “systematic” if it: 1) includes a clear statement of the purpose of the review; 2) describes the search strategy; 3) indicates the criteria used to select studies for inclusion; and 4) presents the findings relevant to the main purpose of the review, including those that did not favor the intervention. Systematic reviews that include experimental and/or observational study designs will be included.; Pharmacotherapy in pregnant women; e-cigarette or ENDS interventions; All KQs: Randomized and nonrandomized controlled trials; KQ 3: The above, plus observational cohort studies (n≥1,000)
Study geography | Reviews and primary studies that primarily take place in countries categorized as “Very High” on the Human Development Index (as defined by the United Nations Development Programme) | Reviews in which >50% of included studies take place in countries not categorized as “Very High” on the Human Development Index
Publication language | English | Any language other than English
Quality rating | Fair- or good-quality studies | Poor-quality studies

Appendix A Table 2 Study-Design Quality Rating Criteria

Study Design | Adapted Quality Criteria
Cohort studies^*^, adapted from Newcastle-Ottawa Scale^212^ | Bias arising in randomization process or due to confounding; - Balance in baseline characteristics; - No baseline confounding; - No time-varying confounding; Bias in selecting participants into the study; - No evidence of biased selection of sample; - Start of followup and start of intervention coincide; Bias due to departures form intended interventions; - Participant intervention status is clearly and explicitly defined and measured; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome; Bias in classifying interventions; - Fidelity to intervention protocol; - Participants were analyzed as originally allocated; Bias from missing data; - Outcome data are reasonably complete and comparable between groups; - Confounding variables that are controlled for in analysis are reasonably complete; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported
Randomized clinical trials^*^, adapted from U.S. Preventive Services Task Force Manual^74^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported
Systematic review^†^, AMSTAR 2^73^ | - Research questions and inclusion criteria for the review included components of PICO; - Report of the review contained an explicit statement that the review methods were established prior to the conduct of the review and the report justified any significant deviations from the protocol; - The selection of the study designs for inclusion in the review was explained; - A comprehensive literature search strategy was used; - Study selection was performed in duplicate; - Data extraction in was performed duplicate; - A list of excluded studies and justifications for the exclusions were provided; - The included studies were described in adequate detail; - A satisfactory technique for assessing the risk of bias (RoB) in individual studies that were included in the review was used; - Sources of funding for the studies included were reported; - If meta-analysis was performed, appropriate methods for statistical combination of results were performed; - If meta-analysis was performed, the potential impact of RoB in the individual studies on the results on the MA or other evidence synthesis were assessed.; - RoB in individual studies were accounted for when interpreting/discussing the results of the review; - A satisfactory explanation for, and discussion of, any heterogeneity observed itn the results to the review was provided; - If a quantitative synthesis was performed, an adequate investigation of publication bias (small study bias) was performed and its likely impact on the results of the review was discussed; - Any potential sources of conflict of interest, included any funding authors received for conducting the review was reported

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.

† Overall confidence in the results of each review was rated according to published guidance: a rating of “high” reflects that the review had zero or one noncritical weakness; “moderate” indicates the review was judged to have more than one noncritical weakness; “low” means the review was judged to have one critical flaw with or without noncritical weaknesses or multiple noncritical weaknesses; and “critically low” signifies that more than one critical flaw was present.