# References

1 LeFevre ML. Behavioral counseling to promote a healthful diet and physical activity for cardiovascular disease prevention in adults with cardiovascular risk factors: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2014;161(8):587–93. PMID: 25155419. 10.7326/m14-1796 25155419
2 US Department of Health and Human Services, US Department of Agriculture. 2015-2020 Dietary Guidelines for Americans. 8th edition. http://health.gov/dietaryguidelines/2015/guidelines/. Accessed: August 7, 2019.
3 Arnett DK, Blumenthal RS, Albert MA, . 2019 ACC/AHA Guideline on the Primary Prevention of Cardiovascular Disease. Circulation. 2019:CIR0000000000000678. PMID: 30879355. 10.1161/CIR.0000000000000678 30879355
4 Artinian NT, Fletcher GF, Mozaffarian D, . Interventions to Promote Physical Activity and Dietary Lifestyle Changes for Cardiovascular Risk Factor Reduction in Adults. A Scientific Statement From the American Heart Association. 2010;122(4):406–41. PMID: 20625115. 10.1161/CIR.0b013e3181e8edf1 20625115
5 Jellinger PS, Handelsman Y, Rosenblit PD, . American Association of Clinical Endocrinologists and American College of Endocrinology Guidelines for Management of Dyslipidemia and Prevention of Cardiovascular Disease. Endocr Pract. 2017;23:(Suppl 2):1–87. PMID: 28437620. 10.4158/EP171764.APPGL 28437620
6 Garvey WT, Mechanick JI, Brett EM, . American Association of Clinical Endocrinologists and American College of Endocrinology Comprehensive Clinical Practice Guidelines for Medical Care of Patients with Obesity. Endocr Pract. 2016;22: Suppl 3:1–203. PMID: 27219496. 10.4158/EP161365.GL 27219496
7 American Academy of Physicians. Clinical Practice Guidelines. Lifestyle Management to Reduce Cardiovascular Risk (2014). https://www.aafp.org/patient-care/clinical-recommendations/all/cardiovascular-risk.html. Accessed: June 4, 2019.
8 Grundy SM, Stone NJ, Bailey AL, . 2018 AHA/ACC/AACVPR/AAPA/ABC/ACPM/ADA/AGS/APhA/ASPC/NLA/PCNA Guideline on the Management of Blood Cholesterol. Circulation. 2018:CIR0000000000000625 PMID: 30586774. 10.1161/CIR.0000000000000625 30586774
9 US Department of Health and Human Services. Physical Activity Guidelines for Americans. 2nd ed. Wasington, DC: US Dept of Health and Human Services; 2018. https://health.gov/paguidelines/second-edition/pdf/Physical_Activity_Guidelines_2nd_edition.pdf. Accessed: May 25, 2019.
10 Centers for Disease Control and Prevention. Heart Disease Facts. https://www.cdc.gov/heartdisease/facts.htm. Accessed: 20 February, 2017.
11 Benjamin EJ, Blaha MJ, Chiuve SE, . Heart Disease and Stroke Statistics—2017 Update: A Report From the American Heart Association. Circulation. 2017. PMID. 10.1161/cir.0000000000000485
12 Benjamin EJ, Muntner P, Alonso A, . Heart Disease and Stroke Statistics-2019 Update: A Report From the American Heart Association. Circulation. 2019;139(10):e56–e528. PMID. 10.1161/CIR.0000000000000659 30700139
13 Benjamin EJ, Virani SS, Callaway CW, . Heart Disease and Stroke Statistics—2018 Update: A Report From the American Heart Association. Circulation. 2018. PMID. 10.1161/cir.0000000000000558
14 D’Agostino RB, Sr., Vasan RS, Pencina MJ, . General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation. 2008;117(6):743–53. PMID: 18212285. 10.1161/circulationaha.107.699579 18212285
15 Wilson PW, D’Agostino RB, Levy D, . Prediction of coronary heart disease using risk factor categories. Circulation. 1998;97(18):1837–47. PMID.9603539
16 Yusuf S, Hawken S, Ounpuu S, . Effect of potentially modifiable risk factors associated with myocardial infarction in 52 countries (the INTERHEART study): case-control study. Lancet. 2004;364(9438):937–52. PMID: 15364185. 10.1016/s0140-6736(04)17018-9 15364185
17 Goff DC, Jr., Lloyd-Jones DM, Bennett G, . 2013 ACC/AHA guideline on the assessment of cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2014;63(25 Pt B):2935–59. PMID: 24239921. 10.1016/j.jacc.2013.11.005 24239921
18 U.S. Preventive Services Task Force, Bibbins-Domingo K, Grossman DC, . Statin Use for the Primary Prevention of Cardiovascular Disease in Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;316(19):1997–2007. PMID: 27838723. 10.1001/jama.2016.15450 27838723
19 Whelton PK, Carey RM, Aronow WS, . 2017 ACC/AHA/AAPA/ABC/ACPM/AGS/APhA/ASH/ASPC/NMA/PCNA Guideline for the Prevention, Detection, Evaluation, and Management of High Blood Pressure in Adults: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Hypertension. 2017. PMID: 29133356. 10.1161/HYP.0000000000000065 29133356
20 Wang X, Ouyang Y, Liu J, . Fruit and vegetable consumption and mortality from all causes, cardiovascular disease, and cancer: systematic review and dose-response meta-analysis of prospective cohort studies. BMJ. 2014;349:g4490. PMID: 25073782. 10.1136/bmj.g4490 25073782
21 Li Y, Hruby A, Bernstein AM, . Saturated Fats Compared With Unsaturated Fats and Sources of Carbohydrates in Relation to Risk of Coronary Heart Disease: A Prospective Cohort Study. J Am Coll Cardiol. 2015;66(14):1538–48. PMID: 26429077. 10.1016/j.jacc.2015.07.055 26429077
22 Wang DD, Li Y, Chiuve SE, . Improvements In US Diet Helped Reduce Disease Burden And Lower Premature Deaths, 1999-2012; Overall Diet Remains Poor. Health Aff (Millwood). 2015;34(11):1916–22. 10.1377/hlthaff.2015.0640 26526250
23 Arem H, Moore SC, Patel A, . Leisure time physical activity and mortality: a detailed pooled analysis of the dose-response relationship. JAMA Intern Med. 2015;175(6):959–67. PMID: 25844730. 10.1001/jamainternmed.2015.0533 25844730
24 Wen CP, Wai JP, Tsai MK, . Minimum amount of physical activity for reduced mortality and extended life expectancy: a prospective cohort study. Lancet. 2011;378(9798):1244–53. PMID: 21846575. 10.1016/S0140-6736(11)60749-6 21846575
25 U. S. Burden of Disease Collaborators, Mokdad AH, Ballestros K, . The State of US Health, 1990-2016: Burden of Diseases, Injuries, and Risk Factors Among US States. JAMA. 2018;319(14):1444–72. PMID: 29634829. 10.1001/jama.2018.0158 29634829
26 Micha R, Penalvo JL, Cudhea F, . Association Between Dietary Factors and Mortality From Heart Disease, Stroke, and Type 2 Diabetes in the United States. JAMA. 2017;317(9):912–24. PMID: 28267855. 10.1001/jama.2017.0947 28267855
27 Shan Z, Rehm CD, Rogers G, . Trends in Dietary Carbohydrate, Protein, and Fat Intake and Diet Quality Among US Adults, 1999-2016. JAMA. 2019;322(12):1178–87. PMID: 31550032. 10.1001/jama.2019.13771 31550032
28 Omura JD, Carlson SA, Paul P, . Adults Eligible for Cardiovascular Disease Prevention Counseling and Participation in Aerobic Physical Activity - United States, 2013. MMWR Morb Mortal Wkly Rep. 2015;64(37):1047–51. PMID: 26401758. 10.15585/mmwr.mm6437a4 26401758
29 Rehm CD, Penalvo JL, Afshin A, . Dietary Intake Among US Adults, 1999-2012. JAMA. 2016;315(23):2542–53. PMID: 27327801. 10.1001/jama.2016.7491 27327801
30 Clarke TC, Norris T, Schiller JS. Early Release of Selected Estimates Based on Data From the 2016 National Health Interview Survey. Division of Health Interview Statistics, National Center for Health Statistics: 2017. Available from: https://www.cdc.gov/nchs/nhis/.
31 Centers for Disease Control and Prevention. 2008 Physical Activity Guidelines for Americans. https://www.cdc.gov/physicalactivity/downloads/trends-in-the-prevalence-of-physical-activity-508.pdf. Accessed: 26 February, 2020.
32 Promotion OoDPaH. Physical Activity. https://www.healthypeople.gov/2020/topics-objectives/topic/physical-activity. Accessed: 26 February, 2020.
33 Omura JD, Bellissimo MP, Watson KB, . Primary care providers’ physical activity counseling and referral practices and barriers for cardiovascular disease prevention. Prev Med. 2017;108:115–22. PMID: 29288783. 10.1016/j.ypmed.2017.12.030 29288783
34 Sherson EA, Yakes Jimenez E, Katalanos N. A review of the use of the 5 A’s model for weight loss counselling: differences between physician practice and patient demand. Fam Pract. 2014;31(4):389–98. PMID: 24891472. 10.1093/fampra/cmu020 24891472
35 van Dillen SM, van Binsbergen JJ, Koelen MA, . Nutrition and physical activity guidance practices in general practice: a critical review. Patient Educ Couns. 2013;90(2):155–69. PMID: 23246149. 10.1016/j.pec.2012.10.022 23246149
36 Hanson C, Staskiewicz A, Woscyna G, . Frequency and Confidence of Healthcare Practitioners in Encountering and Addressing Nutrition-Related Issues. J Allied Health. 2016;45(1):54–61. PMID: 26937883.26937883
37 U.S. Preventive Services Task Force. Using nontraditional risk factors in coronary heart disease risk assessment: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;151(7):474–82. PMID: 19805770.19805770
38 Balk EM, Earley A, Raman G, . Combined Diet and Physical Activity Promotion Programs to Prevent Type 2 Diabetes Among Persons at Increased Risk: A Systematic Review for the Community Preventive Services Task Force. Ann Intern Med. 2015;163(6):437–51. PMID: 26167912. 10.7326/m15-0452 26167912
39 LeFevre ML. Screening for asymptomatic carotid artery stenosis: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;161(5):356–62. PMID: 25003392. 10.7326/m14-1333 25003392
40 Moyer VA. Screening for and management of obesity in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;157(5):373–8. PMID: 22733087. 10.7326/0003-4819-157-5-201209040-00475 22733087
41 Moyer VA. Screening for peripheral artery disease and cardiovascular disease risk assessment with the ankle-brachial index in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013;159(5):342–8. PMID: 24026320. 10.7326/0003-4819-159-5-201309030-00008 24026320
42 Siu AL. Behavioral and Pharmacotherapy Interventions for Tobacco Smoking Cessation in Adults, Including Pregnant Women: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2015;163(8):622–34. PMID: 26389730. 10.7326/m15-2023 26389730
43 Siu AL. Screening for Abnormal Blood Glucose and Type 2 Diabetes Mellitus: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2015;163(11):861–8. PMID: 26501513. 10.7326/m15-2345 26501513
44 Lin JS, O’Connor E, Evans CV, . Behavioral counseling to promote a healthy lifestyle in persons with cardiovascular risk factors: A systematic review for the U.S. Preventive Services Task Force. Annals of Internal Medicine. 2014;161(8):568–78. PMID: 25155549. 10.7326/m14-0130 25155549
45 U.S. Preventive Services Task Force. Final Research Plan: Abnormal Blood Glucose and Type 2 Diabetes Mellitus: Screening. November 2018. https://www.uspreventiveservicestaskforce.org/Page/Document/final-research-plan/abnormal-blood-glucose-and-type-2-diabetes-mellitus-screening. Accessed: April 11, 2019.
46 Patnode CD, Evans CV, Senger CA, . Behavioral Counseling to Promote a Healthful Diet and Physical Activity for Cardiovascular Disease Prevention in Adults Without Known Cardiovascular Disease Risk Factors: Updated Systematic Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2017 Jul. Report No.: 15-05222-EF-1. Agency for Healthcare Research and Quality. 2017:07. PMID: 2936462029364620.
47 LeBlanc ES, Patnode CD, Webber EM, . Behavioral and Pharmacotherapy Weight Loss Interventions to Prevent Obesity-Related Morbidity and Mortality in Adults: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2018;320(11):1172–91. PMID: 30326501. 10.1001/jama.2018.7777 30326501
48 United Nations Development Programme. Human Development Report 2015: Work for Human Development. http://hdr.undp.org/sites/default/files/2015_human_development_report.pdf. Accessed: April 11, 2019.
49 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force: 2015.
50 Raudenbush SW. Analyzing effect sizes: Random-effects models. In: Cooper H, Hedges LV, Valentine JC, editors. The Handbook of Research Synthesis and Meta-Analysis. 2nd ed. New York, New York: Russell Sage Foundation; 2009. p. 296–314.
51 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693–710. PMID: 12939780. 10.1002/sim.1482 12939780
52 Veroniki AA, Jackson D, Bender R, . Methods to calculate uncertainty in the estimated overall effect size from a random-effects meta-analysis. Res Synth Methods. 2019;10(1):23–43. PMID. 10.1002/jrsm.1319 30129707
53 Egger M, Davey Smith G, Schneider M, . Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629–34. PMID: 9310563.9310563
54 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID.
55 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
56 Ammerman AS, Keyserling TC, Atwood JR, . A randomized controlled trial of a public health nurse directed treatment program for rural patients with high blood cholesterol. Prev Med. 2003;36(3):340–51. PMID: 12634025.12634025
57 Anderson JW, Garrity TF, Wood CL, . Prospective, randomized, controlled comparison of the effects of low-fat and low-fat plus high-fiber diets on serum lipid concentrations. Am J Clin Nutr. 1992;56(5):887–94. PMID: 1329482.1329482
58 Anderssen SAH, A.; Hjerman, I.; Urdal, P.; Gjesdal, K.; Holme, I. Oslo diet and exercise study: a one year randomized intervention trial. Efect on Haemostatic variables and other coronary risk factors. Nutrition, Metabolism & Cardiovascular Diseases. 1995;5:189–200. PMID: 8339552. 10.1016/0197-2456(93)90005-X 8339552
59 Appel LJ, Champagne CM, Harsha DW, . Effects of comprehensive lifestyle modification on blood pressure control: main results of the PREMIER clinical trial. JAMA : the journal of the American Medical Association. 2003;289(16):2083–93. PMID: 12709466. 10.1001/jama.289.16.2083 12709466
60 Applegate WB, Miller ST, Elam JT, . Nonpharmacologic intervention to reduce blood pressure in older patients with mild hypertension. Arch Intern Med. 1992;152(6):1162–6. PMID: 1599343. 10.1001/archinte.1992.00400180034005 1599343
61 Arroll B, Beaglehole R. Salt restriction and physical activity in treated hypertensives. N Z Med J. 1995;108(1003):266–8. PMID: 7637923.7637923
62 Babazono A, Kame C, Ishihara R, . Patient-motivated prevention of lifestyle-related disease in Japan: A randomized, controlled clinical trial. Disease Management & Health Outcomes. 2007;15(2):119–26. PMID: None. 10.2165/00115677-200715020-00007
63 Beckmann SL, Os I, Kjeldsen SE, . Effect of dietary counselling on blood pressure and arterial plasma catecholamines in primary hypertension. Am J Hypertens. 1995;8(7):704–11. PMID: 7546496.7546496
64 Bloemberg BP, Kromhout D, Goddijn HE, . The impact of the Guidelines for a Healthy Diet of The Netherlands Nutrition Council on total and high density lipoprotein cholesterol in hypercholesterolemic free-living men. Am J Epidemiol. 1991;134(1):39–48. PMID: 1853859.1853859
65 Bo S, Ciccone G, Baldi C, . Effectiveness of a lifestyle intervention on metabolic syndrome. A randomized controlled trial. J Gen Intern Med. 2007;22(12):1695–703. PMID: 17922167. 10.1007/s11606-007-0399-6 17922167
66 Bosworth HB, Olsen MK, Grubber JM, . Two self-management interventions to improve hypertension control: a randomized trial. Ann Intern Med. 2009;151(10):687–95. PMID: 19920269. 10.7326/0003-4819-151-10-200911170-00148 19920269
67 Broekhuizen K, van Poppel MN, Koppes LL, . Can multiple lifestyle behaviours be improved in people with familial hypercholesterolemia? Results of a parallel randomised controlled trial. PLoS ONE. 2012;7(12):e50032. PMID: 23251355. 10.1371/journal.pone.0050032 23251355
68 Bruckert E, Giral P, Paillard F, . Effect of an educational program (PEGASE) on cardiovascular risk in hypercholesterolaemic patients. Cardiovascular Drugs & Therapy. 2008;22(6):495–505. PMID: 18830810. 10.1007/s10557-008-6137-4 18830810
69 Burke V, Beilin L, Cutt H, . A lifestyle program for treated hypertensives improves cardiovascular risk factors: A randomized controlled trial. Atherosclerosis Supplements. 2006;7:386. PMID: 17208119. 10.1016/j.jclinepi.2006.05.012 17208119
70 Cochrane T, Davey R, Iqbal Z, . NHS health checks through general practice: randomised trial of population cardiovascular risk reduction. BMC Public Health. 2012;12:944. PMID: 23116213. 10.1186/1471-2458-12-944 23116213
71 Coleman KJ, Farrell MA, Rocha DA, . Readiness to be physically active and self-reported physical activity in low-income Latinas, California WISEWOMAN, 2006-2007. Preventing Chronic Disease. 2012;9:E87. PMID: 22515969. 10.5888/pcd9.110190 22515969
72 Delahanty LM, Sonnenberg LM, Hayden D, . Clinical and cost outcomes of medical nutrition therapy for hypercholesterolemia: a controlled trial. Journal of the American Dietetic Association. 2001;101(9):1012–23. PMID: 11573752. 10.1016/S0002-8223(01)00250-4 11573752
73 Eakin E, Reeves M, Lawler S, . Telephone counseling for physical activity and diet in primary care patients. American Journal of Preventive Medicine. 2009;36(2):142–9. PMID: 19062240. 10.1016/j.amepre.2008.09.042 19062240
74 Edelman D, Oddone EZ, Liebowitz RS, . A Multidimensional Integrative Medicine Intervention to Improve Cardiovascular Risk. Journal of General Internal Medicine. 2006;21(7):728–34. PMID: 16808774. 10.1111/j.1525-1497.2006.00495.x 16808774
75 Fagerberg B, Wikstrand J, Berglund G, . Mortality rates in treated hypertensive men with additional risk factors are high but can be reduced: a randomized intervention study. Am J Hypertens. 1998;11(1 Pt 1):14–22. PMID: None. 10.1016/S0895-7061(97)00363-4 9504445
76 Hardcastle S, Taylor A, Bailey M, . A randomised controlled trial on the effectiveness of a primary health care based counselling intervention on physical activity, diet and CHD risk factors. Patient Education and Counseling. 2008;70(1):31–9. PMID: 17997263. 10.1016/j.pec.2007.09.014 17997263
77 Harris MF, Fanaian M, Jayasinghe UW, . A cluster randomised controlled trial of vascular risk factor management in general practice. Med J Aust. 2012;197(7):387–93. PMID: 23025735. 10.5694/mja12.10313 23025735
78 Hyman DJ, Ho KS, Dunn JK, . Dietary intervention for cholesterol reduction in public clinic patients. Am J Prev Med. 1998;15(2):139–45. PMID: 9713670. 10.1016/S0749-3797(98)00038-5 9713670
79 Hyman DJ, Pavlik VN, Taylor WC, . Simultaneous vs sequential counseling for multiple behavior change. Archives of Internal Medicine. 2007;167(11):1152–8. PMID: 17563023. 10.1001/archinte.167.11.1152 17563023
80 Ives DG, Kuller LH, Traven ND. Use and outcomes of a cholesterol-lowering intervention for rural elderly subjects. Am J Prev Med. 1993;9(5):274–81. PMID: 8257616.8257616
81 Johnston HJ, Jones M, Ridler-Dutton G, . Diet modification in lowering plasma cholesterol levels. A randomised trial of three types of intervention. Med J Aust. 1995;162(10):524–6. PMID: 7776913. 10.5694/j.1326-5377.1995.tb138510.x 7776913
82 Kastarinen MJ, Puska PM, Korhonen MH, . Non-pharmacological treatment of hypertension in primary health care: a 2-year open randomized controlled trial of lifestyle intervention against hypertension in eastern Finland. J Hypertens. 2002;20(12):2505–12. PMID: 12473876. 10.1097/01.hjh.0000042893.24999.db 12473876
83 Keyserling TC, Ammerman AS, Davis CE, . A randomized controlled trial of a physician-directed treatment program for low-income patients with high blood cholesterol: the Southeast Cholesterol Project. Arch Fam Med. 1997;6(2):135–45. PMID: 9075448.9075448
84 Koelewijn-van Loon MS, van der Weijden T, van Steenkiste B, . Involving patients in cardiovascular risk management with nurse-led clinics: a cluster randomized controlled trial. CMAJ Canadian Medical Association Journal. 2009;181(12):E267–E74. PMID: 19948811. 10.1503/cmaj.081591 19948811
85 Lakerveld J, Bot SD, Chinapaw MJ, . Motivational interviewing and problem solving treatment to reduce type 2 diabetes and cardiovascular disease risk in real life: a randomized controlled trial. Int J Behav Nutr Phys Act. 2013;10:47. PMID: 23597082. 10.1186/1479-5868-10-47 23597082
86 Migneault JP, Dedier JJ, Wright JA, . A culturally adapted telecommunication system to improve physical activity, diet quality, and medication adherence among hypertensive African-Americans: a randomized controlled trial. Annals of Behavioral Medicine. 2012;43(1):62–73. PMID: 22246660. 10.1007/s12160-011-9319-4 22246660
87 Moreau KL, Degarmo R, Langley J, . Increasing daily walking lowers blood pressure in postmenopausal women. Medicine and Science in Sports and Exercise. 2001;33(11):1825–31. PMID: 11689731.11689731
88 Moy TF, Yanek LR, Raqueño JV, . Dietary counseling for high blood cholesterol in families at risk of coronary disease. Preventive Cardiology. 2001;4(4):158–64. PMID: 11832672. 10.1111/j.1520-037X.2001.00543.x 11832672
89 Muhlhauser I, Sawicki PT, Didjurgeit U, . Evaluation of a structured treatment and teaching programme on hypertension in general practice. Clin Exp Hypertens. 1993;15(1):125–42. PMID: 8467308.8467308
90 Murphy SM, Edwards RT, Williams N, . An evaluation of the effectiveness and cost effectiveness of the National Exercise Referral Scheme in Wales, UK: a randomised controlled trial of a public health policy initiative. Journal of Epidemiology & Community Health. 2012;66(8):745–53. PMID: 22577180. 10.1136/jech-2011-200689 22577180
91 Neil HA, Roe L, Godlee RJ, . Randomised trial of lipid lowering dietary advice in general practice: the effects on serum lipids, lipoproteins, and antioxidants. BMJ. 1995;310(6979):569–73. PMID: 7888933. 10.1136/bmj.310.6979.569 7888933
92 Rodriguez Cristobal JJ, Alonso-Villaverde Grote C, Trave Mercade P, . Randomised clinical trial of an intensive intervention in the primary care setting of patients with high plasma fibrinogen in the primary prevention of cardiovascular disease. BMC Res Notes. 2012;5:126. PMID: 22381072. 10.1186/1756-0500-5-126 22381072
93 Rodriguez MA. Is behavior change sustainable for diet, exercise, and medication adherence? 2012;73(3-B):1860. PMID: None.
94 van Sluijs EM, van Poppel MN, Twisk JW, . Effect of a tailored physical activity intervention delivered in general practice settings: results of a randomized controlled trial. Am J Public Health. 2005;95(10):1825–31. PMID: 16186461. 10.2105/AJPH.2004.044537 16186461
95 Stefanick ML, Mackey S, Sheehan M, . Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med. 1998;339(1):12–20. PMID: 9647874. 10.1056/NEJM199807023390103 9647874
96 Stevens VJ, Glasgow RE, Toobert DJ, . One-year results from a brief, computer-assisted intervention to decrease consumption of fat and increase consumption of fruits and vegetables. Preventive Medicine. 2003;36(5):594–600. PMID: 12689805. 10.1016/S0091-7435(03)00019-7 12689805
97 Svetkey LP, Pollak KI, Yancy WS, Jr., . Hypertension improvement project: randomized trial of quality improvement for physicians and lifestyle modification for patients. Hypertension. 2009;54(6):1226–33. PMID: 19920081. 10.1161/HYPERTENSIONAHA.109.134874 19920081
98 Ter Bogt NC, Bemelmans WJ, Beltman FW, . Preventing weight gain: one-year results of a randomized lifestyle intervention. Am J Prev Med. 2009;37(4):270–7. PMID: 19765497. 10.1016/j.amepre.2009.06.011 19765497
99 Tiessen AH, Smit AJ, Broer J, . Randomized controlled trial on cardiovascular risk management by practice nurses supported by self-monitoring in primary care. BMC Family Practice. 2012;13:90. PMID: 22947269. 10.1186/1471-2296-13-90 22947269
100 Toft U, Kristoffersen L, Ladelund S, . The effect of adding group-based counselling to individual lifestyle counselling on changes in dietary intake. The Inter99 study - a randomized controlled trial. International Journal of Behavioral Nutrition & Physical Activity. 2008;5:59. PMID: 19025583. 10.1186/1479-5868-5-59 19025583
101 Tomson Y, Johannesson M, Aberg H. The costs and effects of two different lipid intervention programmes in primary health care. J Intern Med. 1995;237(1):13–7. PMID: 7830025. 10.1111/j.1365-2796.1995.tb01134.x 7830025
102 van der Veen J, Bakx C, van den Hoogen H, . Stage-matched nutrition guidance for patients at elevated risk for cardiovascular disease: a randomized intervention study in family practice. J Fam Pract. 2002;51(9):751–8. PMID: 12366892.12366892
103 van Keulen HM, Mesters I, Ausems M, . Tailored print communication and telephone motivational interviewing are equally successful in improving multiple lifestyle behaviors in a randomized controlled trial. Annals of Behavioral Medicine. 2011;41(1):104–18. PMID: 20878293. 10.1007/s12160-010-9231-3 20878293
104 Voils CI, Coffman CJ, Yancy WS, Jr., . A randomized controlled trial to evaluate the effectiveness of CouPLES: a spouse-assisted lifestyle change intervention to improve low-density lipoprotein cholesterol. Prev Med. 2013;56(1):46–52. PMID: 23146744. 10.1016/j.ypmed.2012.11.001 23146744
105 Whelton PK, Appel LJ, Espeland MA, . Sodium reduction and weight loss in the treatment of hypertension in older persons: a randomized controlled trial of nonpharmacologic interventions in the elderly (TONE). TONE Collaborative Research Group. JAMA. 1998;279(11):839–46. PMID: 9515998. 10.1001/jama.279.11.839 9515998
106 Wister A, Loewen N, Kennedy-Symonds H, . One-year follow-up of a therapeutic lifestyle intervention targeting cardiovascular disease risk.[see comment]. CMAJ Canadian Medical Association Journal. 2007;177(8):859–65. PMID: 17923653. 10.1503/cmaj.061059 17923653
107 Wood DA, Kotseva K, Connolly S, . Nurse-coordinated multidisciplinary, family-based cardiovascular disease prevention programme (EUROACTION) for patients with coronary heart disease and asymptomatic individuals at high risk of cardiovascular disease: a paired, cluster-randomised controlled trial. Lancet. 2008;371:1999–2012. PMID: 18555911. 10.1016/S0140-6736(08)60868-5 18555911
108 Beune EJ, Moll van Charante EP, Beem L, . Culturally adapted hypertension education (CAHE) to improve blood pressure control and treatment adherence in patients of African origin with uncontrolled hypertension: cluster-randomized trial. PLoS One. 2014;9(3):e90103. PMID: 24598584. 10.1371/journal.pone.0090103 24598584
109 Greaves C, Gillison F, Stathi A, . Waste the waist: a pilot randomised controlled trial of a primary care based intervention to support lifestyle change in people with high cardiovascular risk. Int J Behav Nutr Phys Act. 2015;12:1. PMID: 25592201. 10.1186/s12966-014-0159-z 25592201
110 Kandula NR, Dave S, De Chavez PJ, . Translating a heart disease lifestyle intervention into the community: the South Asian Heart Lifestyle Intervention (SAHELI) study; a randomized control trial. BMC Public Health. 2015;15:1064. PMID: 26475629. 10.1186/s12889-015-2401-2 26475629
111 Niiranen TJ, Leino K, Puukka P, . Lack of impact of a comprehensive intervention on hypertension in the primary care setting. Am J Hypertens. 2014;27(3):489–96. PMID: 24186848. 10.1093/ajh/hpt204 24186848
112 Ogedegbe G, Tobin JN, Fernandez S, . Counseling African Americans to Control Hypertension: cluster-randomized clinical trial main effects. Circulation. 2014;129(20):2044–51. PMID: 24657991. 10.1161/circulationaha.113.006650 24657991
113 Reid RD, McDonnell LA, Riley DL, . Effect of an intervention to improve the cardiovascular health of family members of patients with coronary artery disease: a randomized trial. CMAJ Canadian Medical Association Journal. 2014;186(1):23–30. PMID: 24246588. 10.1503/cmaj.130550 24246588
114 Salisbury C, O’Cathain A, Thomas C, . Telehealth for patients at high risk of cardiovascular disease: pragmatic randomised controlled trial. BMJ. 2016;353:i2647. PMID: 27252245. 10.1136/bmj.i2647 27252245
115 Schoenthaler A, Luerassi L, Silver S, . Comparative Effectiveness of a Practice-Based Comprehensive Lifestyle Intervention vs. Single Session Counseling in Hypertensive Blacks. Am J Hypertens. 2016;29(2):280–7. PMID: 26135553. 10.1093/ajh/hpv100 26135553
116 Bennett GG, Warner ET, Glasgow RE, . Obesity treatment for socioeconomically disadvantaged patients in primary care practice. Arch Intern Med. 2012;172(7):565–74. PMID: 22412073 10.1001/archinternmed.2012.1 22412073
117 Liira H, Engberg E, Leppavuori J, . Exercise intervention and health checks for middle-aged men with elevated cardiovascular risk: a randomized controlled trial. Scand J Prim Health Care. 2014;32(4):156–62. PMID: 25434409. 10.3109/02813432.2014.984967 25434409
118 Cicolini G, Simonetti V, Comparcini D, . Efficacy of a nurse-led email reminder program for cardiovascular prevention risk reduction in hypertensive patients: a randomized controlled trial. Int J Nurs Stud. 2014;51(6):833–43. PMID: 24225325. 10.1016/j.ijnurstu.2013.10.010 24225325
119 Cohen MD, D’Amico FJ, Merenstein JH. Weight reduction in obese hypertensive patients. Fam Med. 1991;23(1):25–8. PMID: 2001777.2001777
120 The Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels. Results of the Trials of Hypertension Prevention, Phase I. JAMA. 1992;267(9):1213–20. PMID: 1586398. 10.1001/jama.1992.03480090061028 1586398
121 Hinderliter AL, Sherwood A, Craighead LW, . The long-term effects of lifestyle change on blood pressure: One-year follow-up of the ENCORE study. Am J Hypertens. 2014;27(5):734–41. PMID: 24084586. 10.1093/ajh/hpt183 24084586
122 Hypertension Prevention Trial Research Group. The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Hypertension Prevention Trial Research Group. Arch Intern Med. 1990;150(1):153–62. PMID: 2404477. 10.1001/archinte.1990.00390130131021 2404477
123 Svetkey LP, Stevens VJ, Brantley PJ, . Comparison of strategies for sustaining weight loss: the weight loss maintenance randomized controlled trial. JAMA. 2008;299(10):1139–48. PMID: 18334689. 10.1001/jama.299.10.1139 18334689
124 Jones DW, Miller ME, Wofford MR, . The effect of weight loss intervention on antihypertensive medication requirements in the hypertension Optimal Treatment (HOT) study. Am J Hypertens. 1999;12(12 Pt 1-2):1175–80. PMID: 10619579. 10.1016/S0895-7061(99)00123-5 10619579
125 Wadden T, Volger S, Sarwer D, . A two-year randomized trial of obesity treatment in primary care practice. N Engl J Med. 2011;365(21):1969–79. PMID: 22082239 10.1056/NEJMoa1109220 22082239
126 Appel L, Clark J, Yeh H, . Comparative effectiveness of weight-loss interventions in clinical practice. N Engl J Med. 2011;365(21):1959–68. PMID: 22085317 10.1056/NEJMoa1108660 22085317
127 Rosas LG, Thiyagarajan S, Goldstein BA, . The effectiveness of two community-based weight loss strategies among obese, low-income US Latinos. Journal of the Academy of Nutrition & Dietetics. 2015;115(4):537–50.e2. PMID: 25578925. 10.1016/j.jand.2014.10.020 25578925
128 Kanke S, Kawai T, Takasawa N, . Interventions for body weight reduction in obese patients during short consultations: an open-label randomized controlled trial in the Japanese primary care setting. Asia Pacific Family Medicine. 2015;14(1):5. PMID: 26015773. 10.1186/s12930-015-0022-7 26015773
129 Christian JG, Byers TE, Christian KK, . A computer support program that helps clinicians provide patients with metabolic syndrome tailored counseling to promote weight loss. Journal of the American Dietetic Association. 2011;111(1):75–83. PMID: 21185968. 10.1016/j.jada.2010.10.006 21185968
130 Chirinos DA, Goldberg RB, Llabre MM, . Lifestyle modification and weight reduction among low-income patients with the metabolic syndrome: the CHARMS randomized controlled trial. Journal of Behavioral Medicine. 2016;39(3):483–92. PMID: 26846133. 10.1007/s10865-016-9721-2 26846133
131 Estruch R, Ros E, Salas-Salvado J, . Primary Prevention of Cardiovascular Disease with a Mediterranean Diet Supplemented with Extra-Virgin Olive Oil or Nuts. N Engl J Med. 2018;378(25):e34. PMID: 29897866. 10.1056/NEJMoa1800389 29897866
132 Scott SE, Breckon JD, Copeland RJ. An integrated motivational interviewing and cognitive-behavioural intervention promoting physical activity maintenance for adults with chronic health conditions: A feasibility study. Chronic Illness. 2018:1742395318769370. PMID: 29642707. 10.1177/1742395318769370 29642707
133 Rubinstein A, Miranda JJ, Beratarrechea A, . Effectiveness of an mHealth intervention to improve the cardiometabolic profile of people with prehypertension in low-resource urban settings in Latin America: a randomised controlled trial. The Lancet Diabetes & Endocrinology. 2016;4(1):52–63. PMID: 26653067. 10.1016/S2213-8587(15)00381-2 26653067
134 Kramer MK, Vanderwood KK, Arena VC, . Evaluation of a Diabetes Prevention Program Lifestyle Intervention in Older Adults: A Randomized Controlled Study in Three Senior/Community Centers of Varying Socioeconomic Status. Diabetes Educator. 2018;44(2):118–29. PMID: 29514568. 10.1177/0145721718759982 29514568
135 Blackford K, Jancey J, Lee AH, . Home-based lifestyle intervention for rural adults improves metabolic syndrome parameters and cardiovascular risk factors: A randomised controlled trial. Preventive Medicine. 2016;89:15–22. PMID: 27196148. 10.1016/j.ypmed.2016.05.012 27196148
136 Ellsworth DL, Costantino NS, Blackburn HL, . Lifestyle modification interventions differing in intensity and dietary stringency improve insulin resistance through changes in lipoprotein profiles. Obesity Science & Practice. 2016;2(3):282–92. PMID: 27708845. 10.1002/osp4.54 27708845
137 Soto RA, García SJ, Toro SM, . Benefits of an educational intervention on diet and anthropometric profile of women with one cardiovascular risk factor. Medicina clinica. 2016;146(10):436–9. PMID: 26897504. 10.1016/j.medcli.2015.12.013 26897504
138 The Trials of Hypertension Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. The Trials of Hypertension Prevention, phase II. The Trials of Hypertension Prevention Collaborative Research Group. Arch Intern Med. 1997;157(6):657–67. PMID: 9080920.9080920
139 Groeneveld IF, Proper KI, van der Beek AJ, . Sustained body weight reduction by an individual-based lifestyle intervention for workers in the construction industry at risk for cardiovascular disease: results of a randomized controlled trial. Prev Med. 2010;51(3–4):240–6. PMID: 20692282. 10.1016/j.ypmed.2010.07.021 20692282
140 Lee LL, Arthur A, Avis M. Evaluating a community-based walking intervention for hypertensive older people in Taiwan: a randomized controlled trial. Prev Med. 2007;44(2):160–6. PMID: 17055561. 10.1016/j.ypmed.2006.09.001 17055561
141 Bennett GG, Steinberg D, Askew S, . Effectiveness of an App and Provider Counseling for Obesity Treatment in Primary Care. Am J Prev Med. 2018. PMID: 30361140. 10.1016/j.amepre.2018.07.005 30361140
142 Nolan RP, Feldman R, Dawes M, . Randomized Controlled Trial of E-Counseling for Hypertension: REACH. Circ Cardiovasc Qual Outcomes. 2018;11(7):e004420. PMID: 30006474. 10.1161/CIRCOUTCOMES.117.004420 30006474
143 Wong MC, Wang HH, Kwan MW, . Dietary counselling has no effect on cardiovascular risk factors among Chinese Grade 1 hypertensive patients: a randomized controlled trial. Eur Heart J. 2015;36(38):2598–607. PMID: 26264550. 10.1093/eurheartj/ehv329 26264550
144 Langford HG, Davis BR, Blaufox D, . Effect of drug and diet treatment of mild hypertension on diastolic blood pressure. The TAIM Research Group. Hypertension. 1991;17(2):210–7. PMID: 1671380. 10.1161/01.HYP.17.2.210 1671380
145 Viglione C, Bouwman D, Rahman N, . A technology-assisted health coaching intervention vs. enhanced usual care for Primary Care-Based Obesity Treatment: a randomized controlled trial. BMC Obesity. 2019;6:4. PMID: 30766686. 10.1186/s40608-018-0226-0 30766686
146 Gill R, Superko HR, McCarthy MM, . Cardiovascular Risk Factor Reduction in First Responders Resulting From an Individualized Lifestyle and Blood Test Program: A Randomized Controlled Trial. J Occup Environ Med. 2019;61(3):183–9. PMID: 30475306. 10.1097/JOM.0000000000001490 30475306
147 Yousuf H, Reintjens R, Slipszenko E, . Effectiveness of web-based personalised e-Coaching lifestyle interventions. Netherlands Heart Journal. 2019;27(1):24–9. PMID: 30488381. 10.1007/s12471-018-1200-7 30488381
148 Haufe S, Kerling A, Protte G, . Telemonitoring-supported exercise training, metabolic syndrome severity, and work ability in company employees: a randomised controlled trial. The lancet Public Health. 2019;4(7):e343–e52. PMID: 31204284. 10.1016/S2468-2667(19)30075-1 31204284
149 Gill DP, Blunt W, Boa Sorte Silva NC, . The HealtheStepsTM lifestyle prescription program to improve physical activity and modifiable risk factors for chronic disease: a pragmatic randomized controlled trial. BMC Public Health. 2019;19(1):841. PMID: 31253112. 10.1186/s12889-019-7141-2 31253112
150 Aadahl M, Huth SL, Toft U, . Does a population-based multifactorial lifestyle intervention increase social inequality in physical activity? The Inter99 study. British Journal of Sports Medicine. 2011;45:209–15. PMID: 19850570. 10.1136/bjsm.2009.064840 19850570
151 Agewall S, Fagerberg B, Berglund G, . Multiple risk intervention trial in high risk hypertensive men: comparison of ultrasound intima-media thickness and clinical outcome during 6 years of follow-up. J Intern Med. 2001;249(4):305–14. PMID: 11298850. 10.1046/j.1365-2796.2001.00818.x 11298850
152 Agewall S, Fagerberg B, Samuelsson O, . Multiple cardiovascular risk factor intervention in treated hypertensive men: what can be achieved? Nutr Metab Cardiovasc Dis. 1993;3:128–35. PMID: None. 10.1111/j.1365-2796.1994.tb00858.x
153 Agewall S, Wikstrand J, Dahlof C, . A randomized study of quality of life during multiple risk factor intervention in treated hypertensive men at high cardiovascular risk. J Hypertens. 1995;13(12 Pt 1):1471–7. PMID.8866910
154 Agewall S, Wikstrand J, Samuelsson O, . The efficacy of multiple risk factor intervention in treated hypertensive men during long-term follow up. Risk Factor Intervention Study Group. J Intern Med. 1994;236(6):651–9. PMID: 7989900.7989900
155 Anderssen S, Holme I, Urdal P, . Diet and exercise intervention have favourable effects on blood pressure in mild hypertensives: the Oslo Diet and Exercise Study (ODES). Blood Press. 1995;4(6):343–9. PMID: None. 10.1111/j.1365-2796.1994.tb00858.x 8746601
156 Anderssen SA, Carroll S, Urdal P, . Combined diet and exercise intervention reverses the metabolic syndrome in middle-aged males: results from the Oslo Diet and Exercise Study. Scandinavian Journal of Medicine & Science in Sports. 2007;17(6):687–95. PMID: 17331082. 10.1111/j.1600-0838.2006.00631.x 17331082
157 Anderssen SA, Hjermann I, Urdal P, . Improved carbohydrate metabolism after physical training and dietary intervention in individuals with the “atherothrombogenic syndrome’. Oslo Diet and Exercise Study (ODES). A randomized trial. J Intern Med. 1996;240(4):203–9. PMID: None. 10.1046/j.1365-2796.1996.22848000.x 8918511
158 Appel LJ, Espeland M, Whelton PK, . Trial of Nonpharmacologic Intervention in the Elderly (TONE). Design and rationale of a blood pressure control trial. Ann Epidemiol. 1995;5(2):119–29. PMID: 7795830. 10.1016/1047-2797(94)00056-Y 7795830
159 Appel LJ, Espeland MA, Easter L, . Effects of reduced sodium intake on hypertension control in older individuals: results from the Trial of Nonpharmacologic Interventions in the Elderly (TONE). Arch Intern Med. 2001;161(5):685–93. PMID: 11231700. 10.1001/archinte.161.5.685 11231700
160 Babio N, Toledo E, Estruch R, . Mediterranean diets and metabolic syndrome status in the PREDIMED randomized trial. CMAJ Canadian Medical Association Journal. 2014;186(17):E649–57. PMID: 25316904. 10.1503/cmaj.140764 25316904
161 Bahnson JL, Whelton PK, Appel LJ, . Baseline characteristics of randomized participants in the Trial of Nonpharmacologic Intervention in the Elderly (TONE). Disease Management and Clinical Outcomes. 1997;1(2):61–8. PMID: None. 10.1016/S1088-3371(97)00005-3
162 Blackford K, Jancey J, Lee AH, . Effects of a home-based intervention on diet and physical activity behaviours for rural adults with or at risk of metabolic syndrome: a randomised controlled trial. International Journal of Behavioral Nutrition & Physical Activity. 2016;13:13. PMID: 26830197. 10.1186/s12966-016-0337-2 26830197
163 Blackford K, Jancey J, Lee AH, . A randomised controlled trial of a physical activity and nutrition program targeting middle-aged adults at risk of metabolic syndrome in a disadvantaged rural community. BMC Public Health. 2015;15:284. PMID: 25885657. 10.1186/s12889-015-1613-9 25885657
164 Blackford K, Lee A, James AP, . Process evaluation of the Albany Physical Activity and Nutrition (APAN) program, a home-based intervention for metabolic syndrome and associated chronic disease risk in rural Australian adults. Health Promot J Austr. 2017;28(1):8–14. PMID: 27426475. 10.1071/HE16027 27426475
165 Blumenthal JA, Babyak MA, Hinderliter A, . Effects of the DASH diet alone and in combination with exercise and weight loss on blood pressure and cardiovascular biomarkers in men and women with high blood pressure: the ENCORE study. Arch Intern Med. 2010;170(2):126–35. PMID: 20101007. 10.1001/archinternmed.2009.470 20101007
166 Brantley PJ, Stewart DW, Myers VH, . Psychosocial predictors of weight regain in the weight loss maintenance trial. J Behav Med. 2014;37(6):1155–68. PMID: 24722826. 10.1007/s10865-014-9565-6 24722826
167 Broekhuizen K, Jelsma JG, van Poppel MN, . Is the process of delivery of an individually tailored lifestyle intervention associated with improvements in LDL cholesterol and multiple lifestyle behaviours in people with familial hypercholesterolemia? BMC Public Health. 2012;12:348. PMID: 22583789. 10.1186/1471-2458-12-348 22583789
168 Broekhuizen K, van Poppel MN, Koppes LL, . A tailored lifestyle intervention to reduce the cardiovascular disease risk of individuals with Familial Hypercholesterolemia (FH): design of the PRO-FIT randomised controlled trial. BMC Public Health. 2010;10:69. PMID: 20156339. 10.1186/1471-2458-10-69 20156339
169 Broekhuizen K, van Poppel MN, Koppes LL, . No significant improvement of cardiovascular disease risk indicators by a lifestyle intervention in people with familial hypercholesterolemia compared to usual care: results of a randomised controlled trial. BMC Res Notes. 2012;5:181. PMID: 22490761. 10.1186/1756-0500-5-181 22490761
170 Burke V, Beilin LJ, Cutt HE, . Moderators and mediators of behaviour change in a lifestyle program for treated hypertensives: a randomized controlled trial (ADAPT). Health Education Research. 2008;23(4):583–91. PMID: 17890759. 10.1093/her/cym047 17890759
171 Burke V, Beilin LJ, Cutt HE, . Effects of a lifestyle programme on ambulatory blood pressure and drug dosage in treated hypertensive patients: a randomized controlled trial. Journal of Hypertension. 2005;23(6):1241–9. PMID: 15894901. 10.1097/01.hjh.0000170388.61579.4f 15894901
172 Burke V, Mansour J, Beilin LJ, . Long-term follow-up of participants in a health promotion program for treated hypertensives (ADAPT). Nutr Metab Cardiovasc Dis. 2008;18(3):198–206. PMID: 17327140. 10.1016/j.numecd.2006.10.004 17327140
173 Camhi SM, Stefanick ML, Katzmarzyk PT, . Metabolic syndrome and changes in body fat from a low-fat diet and/or exercise randomized controlled trial. Obesity. 2010;18(3):548–54. PMID: 19798074. 10.1038/oby.2009.304 19798074
174 Champagne CM, Broyles ST, Moran LD, . Dietary intakes associated with successful weight loss and maintenance during the Weight Loss Maintenance trial. J Am Diet Assoc. 2011;111(12):1826–35. PMID: 22117658. 10.1016/j.jada.2011.09.014 22117658
175 Cook NR, Cutler JA, Obarzanek E, . Long term effects of dietary sodium reduction on cardiovascular disease outcomes: observational follow-up of the trials of hypertension prevention (TOHP). BMJ. 2007;334(7599):885–8. PMID: 17449506. 10.1136/bmj.39147.604896.55 17449506
176 Coughlin JW, Brantley PJ, Champagne CM, . The impact of continued intervention on weight: Five-year results from the weight loss maintenance trial. Obesity. 2016;24(5):1046–53. PMID: 26991814. 10.1002/oby.21454 26991814
177 Crist LA, Champagne CM, Corsino L, . Influence of change in aerobic fitness and weight on prevalence of metabolic syndrome. Preventing Chronic Disease. 2012;9:E68. PMID: 22405475. 10.5888/pcd9.110171 22405475
178 Davey R, Cochrane T, Iqbal Z, . Randomised controlled trial of additional lifestyle support for the reduction of cardiovascular disease risk through primary care in Stoke-on-Trent, UK. Contemporary Clinical Trials. 2010;31(4):345–54. PMID: None. 10.1016/j.cct.2010.04.002 20430115
179 Davis BR, Blaufox MD, Hawkins CM, . Trial of antihypertensive interventions and management. Design, methods, and selected baseline results. Control Clin Trials. 1989;10(1):11–30. PMID: 2649308. 10.1016/0197-2456(89)90016-0 2649308
180 Dolor RJ, Yancy WS, Jr., Owen WF, . Hypertension Improvement Project (HIP): study protocol and implementation challenges. Trials [Electronic Resource]. 2009;10:13. PMID: 19245692. 10.1186/1745-6215-10-13 19245692
181 Domenech M, Roman P, Lapetra J, . Mediterranean diet reduces 24-hour ambulatory blood pressure, blood glucose, and lipids: one-year randomized, clinical trial. Hypertension. 2014;64(1):69–76. PMID: 24799608. 10.1161/HYPERTENSIONAHA.113.03353 24799608
182 Downer MK, Gea A, Stampfer M, . Predictors of short- and long-term adherence with a Mediterranean-type diet intervention: the PREDIMED randomized trial. International Journal of Behavioral Nutrition & Physical Activity. 2016;13:67. PMID: 27297426. 10.1186/s12966-016-0394-6 27297426
183 Driehuis F, Barte JC, Ter Bogt NC, . Maintenance of lifestyle changes: 3-year results of the Groningen Overweight and Lifestyle study. Patient Education & Counseling. 2012;88(2):249–55. PMID: 22560253. 10.1016/j.pec.2012.03.017 22560253
184 Drieling RL, Ma J, Stafford RS. Evaluating clinic and community-based lifestyle interventions for obesity reduction in a low-income Latino neighborhood: Vivamos Activos Fair Oaks Program. BMC Public Health. 2011;11:98. PMID: 21320331. 10.1186/1471-2458-11-98 21320331
185 Eaglehouse YL, Rockette-Wagner B, Kramer MK, . Physical Activity Levels in a Community Lifestyle Intervention: A Randomized Trial. Transl J Am Coll Sports Med. 2016;1(5):45–51. PMID: 27551690. 10.1249/TJX.0000000000000004 27551690
186 Eakin E, Reeves M, Winkler E, . Maintenance of physical activity and dietary change following a telephone-delivered intervention. Health Psychology. 2010;29(6):566–73. PMID: 20954778. 10.1037/a0021359 20954778
187 Eakin EG, Reeves MM, Lawler SP, . The Logan Healthy Living Program: a cluster randomized trial of a telephone-delivered physical activity and dietary behavior intervention for primary care patients with type 2 diabetes or hypertension from a socially disadvantaged community-rationale, design and recruitment. Contemporary Clinical Trials. 2008;29:439–54. PMID: 18055274. 10.1016/j.cct.2007.10.005 18055274
188 Edwards RT, Linck P, Hounsome N, . Cost-effectiveness of a national exercise referral programme for primary care patients in Wales: results of a randomised controlled trial. BMC Public Health. 2013;13:1021. PMID: 24164697. 10.1186/1471-2458-13-1021 24164697
189 Elmer PJ, Obarzanek E, Vollmer WM, . Effects of comprehensive lifestyle modification on diet, weight, physical fitness, and blood pressure control: 18-month results of a randomized trial. Annals of Internal Medicine. 2006;144(7):485–95. PMID: 16585662. 10.7326/ACPJC-2006-145-2-042 16585662
190 Espeland MA, Whelton PK, Kostis JB, . Predictors and mediators of successful long-term withdrawal from antihypertensive medications. TONE Cooperative Research Group. Trial of Nonpharmacologic Interventions in the Elderly. Arch Fam Med. 1999;8(3):228–36. PMID: 10333818.10333818
191 Estruch R, Martinez-Gonzalez MA, Corella D, . Effect of a high-fat Mediterranean diet on bodyweight and waist circumference: a prespecified secondary outcomes analysis of the PREDIMED randomised controlled trial. The Lancet Diabetes & Endocrinology. 2016;4(8):666–76. PMID: 27283479. 10.1016/S2213-8587(16)30085-7 27283479
192 Estruch R, Martinez-Gonzalez MA, Corella D, . Effect of a high-fat Mediterranean diet on bodyweight and waist circumference: a prespecified secondary outcomes analysis of the PREDIMED randomised controlled trial. The Lancet Diabetes & Endocrinology. 2019;7(5):e6–e17. PMID: 31003626. 10.1016/S2213-8587(19)30074-9 31003626
193 Estruch R, Ros E, Salas-Salvado J, . Primary prevention of cardiovascular disease with a Mediterranean diet.[Erratum appears in N Engl J Med. 2014 Feb 27;370(9):886]. New England Journal of Medicine. 2013;368(14):1279–90. PMID: 23432189. 10.1056/NEJMoa1200303 23432189
194 Fanaian M, Laws RA, Passey M, . Health improvement and prevention study (HIPS) - evaluation of an intervention to prevent vascular disease in general practice. BMC Family Practice. 2010;11:57. PMID: 20687956. 10.1186/1471-2296-11-57 20687956
195 Farrell MA, Hayashi T, Loo RK, . Clinic-based nutrition and lifestyle counseling for hispanic women delivered by community health workers: design of the California WISEWOMAN Study. Journal of Women’s Health. 2009;18(5):733–9. PMID: 19445619. 10.1089/jwh.2008.0871 19445619
196 Fernandez S, Tobin JN, Cassells A, . The counseling African Americans to Control Hypertension (CAATCH) Trial: baseline demographic, clinical, psychosocial, and behavioral characteristics. Implement Sci. 2011;6:100. PMID: 21884616. 10.1186/1748-5908-6-100 21884616
197 Foley P, Steinberg D, Levine E, . Track: A randomized controlled trial of a digital health obesity treatment intervention for medically vulnerable primary care patients. Contemporary Clinical Trials. 2016;48:12–20. PMID: 26995281. 10.1016/j.cct.2016.03.006 26995281
198 Forsyth JM, Schoenthaler A, Ogedegbe G, . Perceived racial discrimination and adoption of health behaviors in hypertensive Black Americans: The CAATCH trial. Journal of Health Care for the Poor and Underserved. 2014;25(1):276–91. PMID: 24509026. 10.1353/hpu.2014.0053 24509026
199 Friedberg JP, Rodriguez MA, Watsula ME, . Effectiveness of a tailored behavioral intervention to improve hypertension control: primary outcomes of a randomized controlled trial. Hypertension. 2015;65(2):440–6. PMID: 25403606. 10.1161/HYPERTENSIONAHA.114.03483 25403606
200 From S, Liira H, Leppavuori J, . Effectiveness of exercise intervention and health promotion on cardiovascular risk factors in middle-aged men: a protocol of a randomized controlled trial. BMC Public Health. 2013;13:125. PMID: 23398957. 10.1186/1471-2458-13-125 23398957
201 Funk KL, Elmer PJ, Stevens VJ, . PREMIER-a trial of lifestyle interventions for blood pressure control: intervention design and rationale. Health Promot Pract. 2008;9(3):271–80. PMID: 16803935. 10.1177/1524839906289035 16803935
202 Funk KL, Stevens VJ, Appel LJ, . Associations of internet website use with weight change in a long-term weight loss maintenance program. J Med Internet Res. 2010;12(3):e29. PMID: 20663751. 10.2196/jmir.1504 20663751
203 Gill DP, Blunt W, Bartol C, . HealtheStepsTM Study Protocol: a pragmatic randomized controlled trial promoting active living and healthy lifestyles in at-risk Canadian adults delivered in primary care and community-based clinics. BMC Public Health. 2017;17(1):173. PMID: 28173782. 10.1186/s12889-017-4047-8 28173782
204 Gillison F, Greaves C, Stathi A, . ‘Waste the Waist’: the development of an intervention to promote changes in diet and physical activity for people with high cardiovascular risk. Br J Health Psychol. 2012;17(2):327–45. PMID: 22107451. 10.1111/j.2044-8287.2011.02040.x 22107451
205 Gillison F, Stathi A, Reddy P, . Processes of behavior change and weight loss in a theory-based weight loss intervention program: A test of the process model for lifestyle behavior change. Int J Behav Nutr Phys Act. 2015;12(2). PMID: 25592314. 10.1186/s12966-014-0160-6 25592314
206 Greaney ML, Quintiliani LM, Warner ET, . Weight Management Among Patients at Community Health Centers: The “Be Fit, Be Well” Study. Obesity and Weight Management. 2009;5(5):222–8. PMID: None. 10.1089/obe.2009.0507
207 Groeneveld IF, Proper KI, Absalah S, . An individually based lifestyle intervention for workers at risk for cardiovascular disease: a process evaluation. Am J Health Promot. 2011;25(6):396–401. PMID: 21721966. 10.4278/ajhp.091001-QUAN-319 21721966
208 Groeneveld IF, Proper KI, van der Beek AJ, . Design of a RCT evaluating the (cost-) effectiveness of a lifestyle intervention for male construction workers at risk for cardiovascular disease: the health under construction study. BMC Public Health. 2008;8:1. PMID: 18173844. 10.1186/1471-2458-8-1 18173844
209 Haafkens JA, Beune EJ, Moll van Charante EP, . A cluster-randomized controlled trial evaluating the effect of culturally-appropriate hypertension education among Afro-Surinamese and Ghanaian patients in Dutch general practice: study protocol. BMC Health Serv Res. 2009;9:193. PMID: 19849857. 10.1186/1472-6963-9-193 19849857
210 Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study-patient characteristics: randomization, risk profiles, and early blood pressure results. Blood Press. 1994;3(5):322–7. PMID: 7866597.7866597
211 Hardcastle SJ, Taylor AH, Bailey MP, . Effectiveness of a motivational interviewing intervention on weight loss, physical activity and cardiovascular disease risk factors: a randomised controlled trial with a 12-month post-intervention follow-up. International Journal of Behavioral Nutrition & Physical Activity. 2013;10:40. PMID: 23537492. 10.1186/1479-5868-10-40 23537492
212 Hayashi T, Farrell MA, Chaput LA, . Lifestyle intervention, behavioral changes, and improvement in cardiovascular risk profiles in the California WISEWOMAN project. J Womens Health (Larchmt). 2010;19(6):1129–38. PMID: 20509780. 10.1089/jwh.2009.1631 20509780
213 Hebert PR, Bolt RJ, Borhani NO, . Design of a multicenter trial to evaluate long-term life-style intervention in adults with high-normal blood pressure levels. Trials of Hypertension Prevention (phase II). Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):130–9. PMID: 7795831. 10.1016/1047-2797(94)00057-Z 7795831
214 Hollis JF, Satterfield S, Smith F, . Recruitment for phase II of the Trials of Hypertension Prevention. Effective strategies and predictors of randomization. Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):140–8. PMID: 7795832. 10.1016/1047-2797(94)00058-2 7795832
215 Huth SL, Ladelund S, Borch JK, . A randomized multifactorial intervention study for prevention of ischaemic heart disease (Inter99): the long-term effect on physical activity. Scandinavian Journal of Public Health. 2008;36:380–8. PMID: 18539692. 10.1177/1403494807085313 18539692
216 Ives DG, Kuller LH, Schulz R, . Comparison of recruitment strategies and associated disease prevalence for health promotion in rural elderly. Prev Med. 1992;21(5):582–91. PMID: 1438108.1438108
217 Ives DG, Traven ND, Kuller LH, . Selection bias and nonresponse to health promotion in older adults. Epidemiology. 1994;5(4):456–61. PMID: 7918817.7918817
218 Jacobs DR, Jr., Sluik D, Rokling-Andersen MH, . Association of 1-y changes in diet pattern with cardiovascular disease risk factors and adipokines: results from the 1-y randomized Oslo Diet and Exercise Study. American Journal of Clinical Nutrition. 2009;89(2):509–17. PMID: 19116328. 10.3945/ajcn.2008.26371 19116328
219 Jerome GJ, Dalcin A, Coughlin JW, . Longitudinal accuracy of web-based self-reported weights: results from the Hopkins POWER Trial. J Med Internet Res. 2014;16(7):e173. PMID: 25042773. 10.2196/jmir.3332 25042773
220 Jorgensen T, Borch-Johnsen K, Thomsen TF, . A randomized non-pharmacological intervention study for prevention of ischaemic heart disease: baseline results Inter99. European Journal of Cardiovascular Prevention & Rehabilitation. 2003;10(5):377–86. PMID: 14663300. 10.1097/01.hjr.0000096541.30533.82 14663300
221 Jørgensen T, Jacobsen RK, Toft U, . Effect of screening and lifestyle counselling on incidence of ischaemic heart disease in general population: Inter99 randomised trial. BMJ : British Medical Journal. 2014;348:g3617. PMID: 24912589. 10.1136/bmj.g3617 24912589
222 Kandula NR, Patel Y, Dave S, . The South Asian Heart Lifestyle Intervention (SAHELI) study to improve cardiovascular risk factors in a community setting: design and methods. Contemporary Clinical Trials. 2013;36(2):479–87. PMID: 24060673. 10.1016/j.cct.2013.09.007 24060673
223 Keyserling TC, Ammerman AS, Atwood JR, . A cholesterol intervention program for public health nurses in the rural southeast: description of the intervention, study design, and baseline results. Public Health Nurs. 1999;16(3):156–67. PMID: 10388332. 10.1046/j.1525-1446.1999.00156.x 10388332
224 Khanji MY, Balawon A, Boubertakh R, . Personalized E-Coaching in Cardiovascular Risk Reduction: A Randomized Controlled Trial. Ann Glob Health. 2019;85(1). PMID: 31298823. 10.5334/aogh.2496 31298823
225 Koelewijn-van Loon MS, van SB, Ronda G, . Improving patient adherence to lifestyle advice (IMPALA): a cluster-randomised controlled trial on the implementation of a nurse-led intervention for cardiovascular risk management in primary care (protocol). BMC Health Serv Res. 2008;8:9. PMID: 18194522. 10.1186/1472-6963-8-9 18194522
226 Korhonen M, Kastarinen M, Uusitupa M, . The effect of intensified diet counseling on the diet of hypertensive subjects in primary health care: a 2-year open randomized controlled trial of lifestyle intervention against hypertension in eastern Finland. Preventive Medicine. 2003;36(1):8–16. PMID: 12473420. 10.1006/pmed.2002.1120 12473420
227 Kumanyika SK, Cook NR, Cutler JA, . Sodium reduction for hypertension prevention in overweight adults: further results from the Trials of Hypertension Prevention Phase II. J Hum Hypertens. 2005;19(1):33–45. PMID: 15372064. 10.1038/sj.jhh.1001774 15372064
228 Kumanyika SK, Hebert PR, Cutler JA, . Feasibility and efficacy of sodium reduction in the Trials of Hypertension Prevention, phase I. Trials of Hypertension Prevention Collaborative Research Group. Hypertension. 1993;22(4):502–12. PMID: 8406655.8406655
229 Lakerveld J, Bot SD, Chinapaw MJ, . Primary prevention of diabetes mellitus type 2 and cardiovascular diseases using a cognitive behavior program aimed at lifestyle changes in people at risk: Design of a randomized controlled trial. BMC Endocr Disord. 2008;8:6. PMID: 18573221. 10.1186/1472-6823-8-6 18573221
230 Lakerveld J, Bot SD, van der Ploeg HP, . The effects of a lifestyle intervention on leisure-time sedentary behaviors in adults at risk: the Hoorn Prevention Study, a randomized controlled trial. Prev Med. 2013;57(4):351–6. PMID: 23777672. 10.1016/j.ypmed.2013.06.011 23777672
231 Lasser VI, Raczynski JM, Stevens VJ, . Trials of Hypertension Prevention, phase II. Structure and content of the weight loss and dietary sodium reduction interventions. Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):156–64. PMID: 7795834. 10.1016/1047-2797(94)00060-7 7795834
232 Lau C, Vistisen D, Toft U, . The effects of adding group-based lifestyle counselling to individual counselling on changes in plasma glucose levels in a randomized controlled trial: the Inter99 study. Diabetes & Metabolism. 2011;37(6):546–52. PMID: 21900030. 10.1016/j.diabet.2011.06.001 21900030
233 Lau CJ, Pisinger C, Husemoen LLN, . Effect of general health screening and lifestyle counselling on incidence of diabetes in general population: Inter99 randomised trial. Preventive Medicine. 2016;91:172–9. PMID: 27514243. 10.1016/j.ypmed.2016.08.016 27514243
234 Lawler SP, Winkler EA, Goode AD, . Moderators of health behavior initiation and maintenance in a randomized telephone counseling trial. Preventive Medicine. 2014;61:34–41. PMID: 24412896. 10.1016/j.ypmed.2014.01.002 24412896
235 Lien LF, Brown AJ, Ard JD, . Effects of PREMIER lifestyle modifications on participants with and without the metabolic syndrome. Hypertension. 2007;50(4):609–16. PMID: 17698724. 10.1161/HYPERTENSIONAHA.107.089458 17698724
236 Lin PH, Appel LJ, Funk K, . The PREMIER intervention helps participants follow the Dietary Approaches to Stop Hypertension dietary pattern and the current Dietary Reference Intakes recommendations. Journal of the American Dietetic Association. 2007;107(9):1541–51. PMID: 17761231. 10.1016/j.jada.2007.06.019 17761231
237 Lin PH, Yancy WS, Jr., Pollak KI, . The Influence of a Physician and Patient Intervention Program on Dietary Intake. J Acad Nutr Diet. 2013;113(11):1465–75. PMID: 23999279. 10.1016/j.jand.2013.06.343 23999279
238 Littlecott HJ, Moore GF, Moore L, . Psychosocial mediators of change in physical activity in the Welsh national exercise referral scheme: secondary analysis of a randomised controlled trial. International Journal of Behavioral Nutrition & Physical Activity. 2014;11:109. PMID: 25209188. 10.1186/s12966-014-0109-9 25209188
239 Martinez-Gonzalez MA, Salas-Salvado J, Estruch R, . Benefits of the Mediterranean Diet: Insights From the PREDIMED Study. Progress in Cardiovascular Diseases. 2015;58(1):50–60. PMID: 25940230. 10.1016/j.pcad.2015.04.003 25940230
240 Martinez-Gonzalez MA, Toledo E, Aros F, . Extravirgin olive oil consumption reduces risk of atrial fibrillation: the PREDIMED (Prevencion con Dieta Mediterranea) trial. Circulation. 2014;130(1):18–26. PMID: 24787471. 10.1161/CIRCULATIONAHA.113.006921 24787471
241 Maruthur NM, Wang NY, Appel LJ. Lifestyle interventions reduce coronary heart disease risk: results from the PREMIER Trial. Circulation. 2009;119(15):2026–31. PMID: 19349322. 10.1161/CIRCULATIONAHA.108.809491 19349322
242 McVay MA, King HA, Jeffreys AS, . Mechanisms of patient health behavior change in a randomized controlled trial of a spouse-assisted intervention. Psychol Health Med. 2015;20(7):753–66. PMID: 25774698. 10.1080/13548506.2015.1020817 25774698
243 Meinert CL, Borhani NO, Langford HG. Design, methods, and rationale in the Hypertension Prevention Trial. Hypertension Prevention Trial Research Group. Control Clin Trials. 1989;10:(3 Suppl):1S–29S. PMID: 2680271.2680271
244 Mitjavila MT, Fandos M, Salas-Salvado J, . The Mediterranean diet improves the systemic lipid and DNA oxidative damage in metabolic syndrome individuals. A randomized, controlled, trial. Clinical Nutrition. 2013;32(2):172–8. PMID: 22999065. 10.1016/j.clnu.2012.08.002 22999065
245 Murphy S, Raisanen L, Moore G, . A pragmatic randomised controlled trial of the Welsh National Exercise Referral Scheme: protocol for trial and integrated economic and process evaluation. BMC Public Health. 2010;10:352. PMID: 20565846. 10.1186/1471-2458-10-352 20565846
246 Nolan RP, Liu S, Feldman R, . Reducing risk with e-based support for adherence to lifestyle change in hypertension (REACH): protocol for a multicentred randomised controlled trial. BMJ Open. 2013;3(8):e003547. PMID: 23965936. 10.1136/bmjopen-2013-003547 23965936
247 Oberman A, Wassertheil-Smoller S, Langford HG, . Pharmacologic and nutritional treatment of mild hypertension: changes in cardiovascular risk status. Ann Intern Med. 1990;112(2):89–95. PMID: 1967210. 10.1016/1047-2797(94)00060-7 1967210
248 Odes Investigators. The Oslo Diet and Exercise Study (ODES): design and objectives. Control Clin Trials. 1993;14(3):229–43. PMID: 8339552. 10.1016/0197-2456(93)90005-X 8339552
249 Ogedegbe G, Tobin JN, Fernandez S, . Counseling African Americans to Control Hypertension (CAATCH) trial: a multi-level intervention to improve blood pressure control in hypertensive blacks. Circ Cardiovasc Qual Outcomes. 2009;2(3):249–56. PMID: 20031845. 10.1161/CIRCOUTCOMES.109.849976 20031845
250 Ponzo V, Gentile L, Gambino R, . Incidence of diabetes mellitus, cardiovascular outcomes and mortality after a 12-month lifestyle intervention: A 9-year follow-up. Diabetes & Metabolism. 2018;44(5):449–51. PMID: 29773350. 10.1016/j.diabet.2018.04.008 29773350
251 Reseland JE, Anderssen SA, Solvoll K, . Effect of long-term changes in diet and exercise on plasma leptin concentrations. American Journal of Clinical Nutrition. 2001;73(2):240–5. PMID: 11157319. 10.1093/ajcn/73.2.240 11157319
252 Rubin RR, Peyrot M, Wang NY, . Patient-reported outcomes in the practice-based opportunities for weight reduction (POWER) trial. Qual Life Res. 2013;22(9):2389–98. PMID: 23515902. 10.1007/s11136-013-0363-3 23515902
253 Ruiz-Canela M, Estruch R, Corella D, . Association of Mediterranean diet with peripheral artery disease: The PREDIMED randomized trial. JAMA - Journal of the American Medical Association. 2014;311(4):415–7. PMID: 24449321. 10.1001/jama.2013.280618 24449321
254 Salas-Salvado J, Bullo M, Babio N, . Erratum. Reduction in the Incidence of Type 2 Diabetes With the Mediterranean Diet: Results of the PREDIMED-Reus nutrition intervention randomized trial. Diabetes Care 2011;34:14-19. Diabetes Care. 2018;41(10):2259–60. PMID: 30104300. 10.2337/dc18-er10 30104300
255 Salas-Salvado J, Bullo M, Estruch R, . Prevention of diabetes with Mediterranean diets: a subgroup analysis of a randomized trial. Annals of Internal Medicine. 2014;160(1):1–10. PMID: 24573661. 10.7326/M13-1725 24573661
256 Sarwer DB, Moore RH, Diewald LK, . The impact of a primary care-based weight loss intervention on the quality of life. Int J Obes (Lond). 2013;37: Suppl 1:S25–30. PMID: 23921778. 10.1038/ijo.2013.93 23921778
257 Satterfield S, Cutler JA, Langford HG, . Trials of hypertension prevention. Phase I design. Ann Epidemiol. 1991;1(5):455–71. PMID: 1669525. 10.1016/1047-2797(91)90014-4 1669525
258 Schoenthaler A, Luerassi L, Teresi JA, . A practice-based trial of blood pressure control in African Americans (TLC-Clinic): study protocol for a randomized controlled trial. Trials. 2011;12:265. PMID: 22192273. 10.1186/1745-6215-12-265 22192273
259 Shah M, Jeffery RW, Laing B, . Hypertension Prevention Trial (HPT): food pattern changes resulting from intervention on sodium, potassium, and energy intake. Hypertension Prevention Trial Research Group. J Am Diet Assoc. 1990;90(1):69–76. PMID: 2404050.2404050
260 Stevens VJ, Corrigan SA, Obarzanek E, . Weight loss intervention in phase 1 of the Trials of Hypertension Prevention. The TOHP Collaborative Research Group. Arch Intern Med. 1993;153(7):849–58. PMID: 8466377. 10.1001/archinte.1993.00410070039006 8466377
261 Stevens VJ, Obarzanek E, Cook NR, . Long-term weight loss and changes in blood pressure: results of the Trials of Hypertension Prevention, phase II. Ann Intern Med. 2001;134(1):1–11. PMID: 11187414. 10.7326/0003-4819-134-1-200101020-00007 11187414
262 Svetkey LP, Ard JD, Stevens VJ, . Predictors of long-term weight loss in adults with modest initial weight loss, by sex and race. Obesity (Silver Spring). 2012;20(9):1820–8. PMID: 21527896. 10.1038/oby.2011.88 21527896
263 Svetkey LP, Clark JM, Funk K, . Greater weight loss with increasing age in the weight loss maintenance trial. Obesity (Silver Spring). 2014;22(1):39–44. PMID: 23640912. 10.1002/oby.20506 23640912
264 Svetkey LP, Erlinger TP, Vollmer WM, . Effect of lifestyle modifications on blood pressure by race, sex, hypertension status, and age. Journal of Human Hypertension. 2005;19(1):21–31. PMID: 15385946. 10.1038/sj.jhh.1001770 15385946
265 Ter Bogt NC, Milder IE, Bemelmans WJ, . Changes in lifestyle habits after counselling by nurse practitioners: 1-year results of the Groningen Overweight and Lifestyle study. Public Health Nutrition. 2011;14(6):995–1000. PMID: 21272417. 10.1017/S1368980010003708 21272417
266 The H.O.T. Study Group. The Hypertension Optimal Treatment Study (the HOT Study). Blood Press. 1993;2(1):62–8. PMID: 8193735.8193735
267 Thomas CL, Man MS, O’Cathain A, . Effectiveness and cost-effectiveness of a telehealth intervention to support the management of long-term conditions: study protocol for two linked randomized controlled trials. Trials. 2014;15:36. PMID: 24460845. 10.1186/1745-6215-15-36 24460845
268 Toft U, Kristoffersen L, Ladelund S, . The impact of a population-based multi-factorial lifestyle intervention on changes in long-term dietary habits The Inter99 study. Preventive Medicine. 2008;47(4):378–83. PMID: 18590758. 10.1016/j.ypmed.2008.05.013 18590758
269 Tomson Y, Aberg H. Risk factors for cardiovascular disease-a comparison between Swedes and immigrants. Scand J Prim Health Care. 1994;12(3):147–54. PMID: 7997691. 10.3109/02813439409003691 7997691
270 Torjesen PA, Birkeland KI, Anderssen SA, . Lifestyle changes may reverse development of the insulin resistance syndrome. The Oslo Diet and Exercise Study: a randomized trial. Diabetes Care. 1997;20(1):26–31. PMID: 9028689.9028689
271 van Keulen HM, Bosmans JE, van Tulder MW, . “Cost-effectiveness of tailored print communication, telephone motivational interviewing, and a combination of the two: Results of an economic evaluation alongside the Vitalum randomized controlled trial”: Correction.. The International Journal of Behavioral Nutrition and Physical Activity. 2011:ArtID. PMID: 20815869. 10.1186/1479-5868-7-64 20815869
272 van Keulen HM, Mesters I, Ausems M, . Tailored print communication and telephone motivational interviewing are equally successful in improving multiple lifestyle behaviors in a randomized controlled trial. Annals of behavioral medicine : a publication of the Society of Behavioral Medicine. 2011;41(1):104–18. PMID: 20878293. 10.1007/s12160-010-9231-3 20878293
273 van Keulen HM, Mesters I, Brug J, . Vitalum study design: RCT evaluating the efficacy of tailored print communication and telephone motivational interviewing on multiple health behaviors. BMC Public Health. 2008;8:216. PMID: 18565222. 10.1186/1471-2458-8-216 18565222
274 Van Sluijs EM, Van Poppel MN, Twisk JW, . The positive effect on determinants of physical activity of a tailored, general practice-based physical activity intervention. Health Educ Res. 2005;20(3):345–56. PMID: 15479705. 10.1093/her/cyg129 15479705
275 Verheijden MW, van dV, Bakx JC, . Stage-matched nutrition guidance: stages of change and fat consumption in Dutch patients at elevated cardiovascular risk. J Nutr Educ Behav. 2004;36(5):228–37. PMID: 15707545. 10.1016/S1499-4046(06)60385-0 15707545
276 Vetter ML, Wadden TA, Chittams J, . Effect of lifestyle intervention on cardiometabolic risk factors: results of the POWER-UP trial. Int J Obes (Lond). 2013;37: Suppl 1:S19–24. PMID: 23921777. 10.1038/ijo.2013.92 23921777
277 Voils CI, Yancy WS, Jr., Kovac S, . Study protocol: Couples Partnering for Lipid Enhancing Strategies (CouPLES) - a randomized, controlled trial. Trials [Electronic Resource]. 2009;10:10. PMID: 19200384. 10.1186/1745-6215-10-10 19200384
278 Volger S, Wadden TA, Sarwer DB, . Changes in eating, physical activity and related behaviors in a primary care-based weight loss intervention. Int J Obes (Lond). 2013;37: Suppl 1:S12–8. PMID: 23921776. 10.1038/ijo.2013.91 23921776
279 Whelton PK, Hebert PR, Cutler J, . Baseline characteristics of participants in phase I of the Trials of Hypertension Prevention. Ann Epidemiol. 1992;2(3):295–310. PMID: 1342280. 10.1016/1047-2797(92)90062-U 1342280
280 Wong MC, Wang HH, Kwan MW, . The effectiveness of Dietary Approaches to Stop Hypertension (DASH) counselling on estimated 10-year cardiovascular risk among patients with newly diagnosed grade 1 hypertension: A randomised clinical trial. International Journal of Cardiology. 2016;224:79–87. PMID: 27631719. 10.1016/j.ijcard.2016.08.334 27631719
281 Young DR, Coughlin J, Jerome GJ, . Effects of the PREMIER interventions on health-related quality of life. Annals of behavioral medicine : a publication of the Society of Behavioral Medicine. 2010;40(3):302–12. PMID: 20799005. 10.1007/s12160-010-9220-6 20799005
282 Young DR, Vollmer WM, King AC, . Can individuals meet multiple physical activity and dietary behavior goals? American Journal of Health Behavior. 2009;33(3):277–86. PMID: 19063649. 10.5993/AJHB.33.3.6 19063649
283 American Heart Association. How much sodium should I eat per day? https://www.heart.org/en/healthy-living/healthy-eating/eat-smart/sodium/how-much-sodium-should-i-eat-per-day. Accessed: August 20, 2019.
284 Appel L, Van Horn L. Did the PREDIMED trial test a Mediterranean diet? N Engl J Med. 2013;4(368):1353–4. PMID: None. 10.1056/NEJMe1301582
285 Gittelsohn J, Trude ACB, Kim H. Pricing Strategies to Encourage Availability, Purchase, and Consumption of Healthy Foods and Beverages: A Systematic Review. Prev Chronic Dis. 2017;14:E107. PMID: 29101767. 10.5888/pcd14.170213 29101767
286 Olsho LE, Klerman JA, Wilde PE, . Financial incentives increase fruit and vegetable intake among Supplemental Nutrition Assistance Program participants: a randomized controlled trial of the USDA Healthy Incentives Pilot. American Journal of Clinical Nutrition. 2016;104(2):423–35. PMID: 27334234. 10.3945/ajcn.115.129320 27334234
287 Jacobs DR, Jr., Petersen KS, Svendsen K, . Considerations to facilitate a US study that replicates PREDIMED. Metabolism: Clinical & Experimental. 2018;05:05. PMID: 29733820. 10.1016/j.metabol.2018.05.001 29733820
288 de Ridder D, Kroese F, Evers C, . Healthy diet: Health impact, prevalence, correlates, and interventions. Psychology & Health. 2017;32(8):907–41. PMID: 28447854. 10.1080/08870446.2017.1316849 28447854
289 Odutayo A, Gill P, Shepherd S, . Income Disparities in Absolute Cardiovascular Risk and Cardiovascular Risk Factors in the United States, 1999-2014. JAMA Cardiol. 2017;2(7):782–90. PMID. 10.1001/jamacardio.2017.1658 28593301
290 Bull ER, McCleary N, Li X, . Interventions to Promote Healthy Eating, Physical Activity and Smoking in Low-Income Groups: a Systematic Review with Meta-Analysis of Behavior Change Techniques and Delivery/Context. International Journal of Behavioral Medicine. 2018;12:12. PMID: 30003476. 10.1007/s12529-018-9734-z 30003476
291 Sisti LG, Dajko M, Campanella P, . The effect of multifactorial lifestyle interventions on cardiovascular risk factors: a systematic review and meta-analysis of trials conducted in the general population and high risk groups. Preventive Medicine. 2018;109:82–97. PMID: 29291422. 10.1016/j.ypmed.2017.12.027 29291422
292 Leblanc ES, O’Connor E, Whitlock EP, . Effectiveness of primary care-relevant treatments for obesity in adults: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2011;155(7):434–47. PMID: 21969342. 10.7326/0003-4819-155-7-201110040-00006 21969342
293 Patnode CD, Evans CV, Senger CA, . Behavioral Counseling to Promote a Healthful Diet and Physical Activity for Cardiovascular Disease Prevention in Adults Without Known Cardiovascular Disease Risk Factors: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2017;318(2):175–93. PMID: 28697259. 10.1001/jama.2017.3303 28697259
294 Jackson SL, Safo S, Staimez LR, . Reduced Cardiovascular Disease Incidence With a National Lifestyle Change Program. Am J Prev Med. 2017;52(4):459–68. PMID: 27939239. 10.1016/j.amepre.2016.10.013 27939239
295 Avanzini F, Marzona I, Baviera M, . Improving cardiovascular prevention in general practice: Results of a comprehensive personalized strategy in subjects at high risk. European Journal of Preventive Cardiology. 2016;23(9):947–55. PMID: 26525065. 10.1177/2047487315613664 26525065
296 Budzowski AR, Parkinson MD, Silfee VJ. An Evaluation of Lifestyle Health Coaching Programs Using Trained Health Coaches and Evidence-Based Curricula at 6 Months Over 6 Years. Am J Health Promot. 2019;33(6):912–5. PMID: 30669850. 10.1177/0890117118824252 30669850
297 Willett W, Rockstrom J, Loken B, . Food in the Anthropocene: the EAT-Lancet Commission on healthy diets from sustainable food systems. Lancet. 2019;393(10170):447–92. PMID: 30660336. 10.1016/S0140-6736(18)31788-4 30660336
298 Bassi N, Karagodin I, Wang S, . Lifestyle modification for metabolic syndrome: a systematic review. Am J Med. 2014;127(12):1242.e1–10. PMID: 25004456. 10.1016/j.amjmed.2014.06.035 25004456
299 Borek AJ, Abraham C, Greaves CJ, . Group-Based Diet and Physical Activity Weight-Loss Interventions: A Systematic Review and Meta-Analysis of Randomised Controlled Trials. Applied Psychology Health and Well-being. 2018;10(1):62–86. PMID: 29446541. 10.1111/aphw.12121 29446541
300 Mensinger JL, Calogero RM, Stranges S, . A weight-neutral versus weight-loss approach for health promotion in women with high BMI: A randomized-controlled trial. Appetite. 2016;105:364–74. PMID: 27289009. 10.1016/j.appet.2016.06.006 27289009
301 Veronese N, Li Y, Manson JE, . Combined associations of body weight and lifestyle factors with all cause and cause specific mortality in men and women: prospective cohort study. BMJ. 2016;355:i5855. PMID: 27884868. 10.1136/bmj.i5855 27884868
302 Pescatello LS, Buchner DM, Jakicic JM, . Physical Activity to Prevent and Treat Hypertension: A Systematic Review. Med Sci Sports Exerc. 2019;51(6):1314–23. PMID: 31095088. 10.1249/MSS.0000000000001943 31095088
303 Herrod PJJ, Doleman B, Blackwell JEM, . Exercise and other nonpharmacological strategies to reduce blood pressure in older adults: a systematic review and meta-analysis. Journal of the American Society of Hypertension. 2018;12(4):248–67. PMID: 29496468. 10.1016/j.jash.2018.01.008 29496468
304 Normansell R, Holmes R, Victor C, . Exploring non-participation in primary care physical activity interventions: PACE-UP trial interview findings. Trials. 2016;17:178. PMID: 27039181. 10.1186/s13063-016-1299-z 27039181
305 Lewington S, Clarke R, Qizilbash N, . Age-specific relevance of usual blood pressure to vascular mortality: a meta-analysis of individual data for one million adults in 61 prospective studies. Lancet. 2002;360(9349):1903–13. PMID: 12493255. 10.1016/s0140-6736(02)11911-8 12493255
306 Prospective Studies Collaboration, Lewington S, Whitlock G, . Blood cholesterol and vascular mortality by age, sex, and blood pressure: a meta-analysis of individual data from 61 prospective studies with 55,000 vascular deaths. Lancet. 2007;370(9602):1829–39. PMID: 18061058. 10.1016/S0140-6736(07)61778-4 18061058
307 Prospective Studies Collaboration, Whitlock G, Lewington S, . Body-mass index and cause-specific mortality in 900 000 adults: collaborative analyses of 57 prospective studies. Lancet. 2009;373(9669):1083–96. PMID: 19299006. 10.1016/S0140-6736(09)60318-4 19299006
308 Flint AC, Conell C, Ren X, . Effect of Systolic and Diastolic Blood Pressure on Cardiovascular Outcomes. N Engl J Med. 2019;381(3):243–51. PMID: 31314968. 10.1056/NEJMoa1803180 31314968
309 Emerging Risk Factors Collaboration, Sarwar N, Gao P, . Diabetes mellitus, fasting blood glucose concentration, and risk of vascular disease: a collaborative meta-analysis of 102 prospective studies. Lancet. 2010;375(9733):2215–22. PMID: 20609967. 10.1016/S0140-6736(10)60484-9 20609967
310 Rao Kondapally Seshasai S, Kaptoge S, Thompson A, . Diabetes mellitus, fasting glucose, and risk of cause-specific death. N Engl J Med. 2011;364(9):829–41. PMID: 21366474. 10.1056/NEJMoa1008862 21366474
311 Asia Pacific Cohort Studies Collaboration. Central obesity and risk of cardiovascular disease in the Asia Pacific Region. Asia Pac J Clin Nutr. 2006;15(3):287–92. PMID: 16837418.16837418
312 Cerhan JR, Moore SC, Jacobs EJ, . A pooled analysis of waist circumference and mortality in 650,000 adults. Mayo Clin Proc. 2014;89(3):335–45. PMID: 24582192. 10.1016/j.mayocp.2013.11.011 24582192
313 Aburto NJ, Ziolkovska A, Hooper L, . Effect of lower sodium intake on health: systematic review and meta-analyses. BMJ. 2013;346:f1326. PMID: 23558163. 10.1136/bmj.f1326 23558163
314 Beresford SA, Johnson KC, Ritenbaugh C, . Low-fat dietary pattern and risk of colorectal cancer: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):643–54. PMID: 16467233. 10.1001/jama.295.6.643 16467233
315 Howard BV, Manson JE, Stefanick ML, . Low-fat dietary pattern and weight change over 7 years: the Women’s Health Initiative Dietary Modification Trial. JAMA. 2006;295(1):39–49. PMID: 16391215. 10.1001/jama.295.1.39 16391215
316 Howard BV, Van Horn L, Hsia J, . Low-fat dietary pattern and risk of cardiovascular disease: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):655–66. PMID: 16467234. 10.1001/jama.295.6.655 16467234
317 Prentice RL, Caan B, Chlebowski RT, . Low-fat dietary pattern and risk of invasive breast cancer: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):629–42. PMID: 16467232. 10.1001/jama.295.6.629 16467232
318 Harcombe Z. Dietary fat guidelines have no evidence base: where next for public health nutritional advice? British Journal of Sports Medicine. 2017;51(10):769–74. PMID: 27797736. 10.1136/bjsports-2016-096734 27797736
319 Chowdhury R, Warnakula S, Kunutsor S, . Association of dietary, circulating, and supplement fatty acids with coronary risk: a systematic review and meta-analysis. Ann Intern Med. 2014;160(6):398–406. PMID: 24723079. 10.7326/M13-1788 24723079
320 Zhu Y, Bo Y, Liu Y. Dietary total fat, fatty acids intake, and risk of cardiovascular disease: a dose-response meta-analysis of cohort studies. Lipids Health Dis. 2019;18(1):91. PMID: 30954077. 10.1186/s12944-019-1035-2 30954077
321 Shrank WH, Patrick AR, Brookhart MA. Healthy user and related biases in observational studies of preventive interventions: a primer for physicians. J Gen Intern Med. 2011;26(5):546–50. PMID: 21203857. 10.1007/s11606-010-1609-1 21203857
322 LeBlanc EL, Patnode CD, Webber EM, . Behavioral and Pharmacotherapy Weight Loss Interventions to Prevent Obesity-Related Morbidity and Mortality in Adults: An Updated Systematic Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2018 Sep. Report No.: 18-05239-EF-1. 2018. PMID: 3035404230354042.
323 Spong CY, Bianchi DW. Improving public health requires inclusion of underrepresented populations in research. JAMA - Journal of the American Medical Association. 2018;319(4):337–8. PMID. 10.1001/jama.2017.19138 29285540
324 Lin JS, O’Connor EA, Evans CV, . Behavioral Counseling to Promote a Healthy Lifestyle for Cardiovascular Disease Prevention in Persons With Cardiovascular Risk Factors: An Updated Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2014. Available from: https://www.ncbi.nlm.nih.gov/pubmed/25232633.
325 Sacks FM, Lichtenstein AH, Wu JHY, . Dietary Fats and Cardiovascular Disease: A Presidential Advisory From the American Heart Association. Circulation. 2017;136(3):e1–e23. PMID: 28620111. 10.1161/CIR.0000000000000510 28620111
326 Panizza CE, Shvetsov YB, Harmon BE, . Testing the Predictive Validity of the Healthy Eating Index-2015 in the Multiethnic Cohort: Is the Score Associated with a Reduced Risk of All-Cause and Cause-Specific Mortality? Nutrients. 2018;10(4). PMID: 29621192. 10.3390/nu10040452 29621192
327 Mercer K, Giangregorio L, Schneider E, . Acceptance of Commercially Available Wearable Activity Trackers Among Adults Aged Over 50 and With Chronic Illness: A Mixed-Methods Evaluation. JMIR MHealth and UHealth. 2016;4(1):e7. PMID: 26818775. 10.2196/mhealth.4225 26818775
328 Khan N, Bacon SL, Khan S, . Hypertension management research priorities from patients, caregivers, and healthcare providers: A report from the Hypertension Canada Priority Setting Partnership Group. Journal of Clinical Hypertension. 2017;19(11):1063–9. PMID: 28944609. 10.1111/jch.13091 28944609
329 Grundy SM, Stone NJ, Bailey AL, . 2018 AHA/ACC/AACVPR/AAPA/ABC/ACPM/ADA/AGS/APhA/ASPC/NLA/PCNA Guideline on the Management of Blood Cholesterol: Executive Summary: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. J Am Coll Cardiol. 2019;73(24):3168–209. PMID. 10.1016/j.jacc.2018.11.002 30423391
330 Academy of Nutrition and Dietetics. Hypertension evidence-based nutrition practice guideline. Chicago: Academy of Nutrition and Dietetics; 2015.
331 US Department of Veterans Affairs, US Department of Defense. VA/DoD Clinical Practice Guidelines, Management of Hypertension (HTN) in Primary Care (2014). https://www.healthquality.va.gov/guidelines/CD/htn/. Accessed: June 4, 2019.
332 United States Department of Veterans Affairs, United States Department of Defense, United States Dyslipidemia Working Group, . VA/DoD clinical practice guideline for the management of dyslipidemia for cardiovascular risk reduction. Washington, D.C.: Department of Veterans Affairs Department of Defense; 2014. PMID.
333 Eckel RH, Jakicic JM, Ard JD, . 2013 AHA/ACC Guideline on Lifestyle Management to Reduce Cardiovascular Risk. A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. 2013. PMID. 10.1161/01.cir.0000437740.48606.d1
334 U. S. Preventive Services Task Force, Grossman DC, Bibbins-Domingo K, . Behavioral Counseling to Promote a Healthful Diet and Physical Activity for Cardiovascular Disease Prevention in Adults Without Cardiovascular Risk Factors: US Preventive Services Task Force Recommendation Statement. JAMA. 2017;318(2):167–74. PMID: 28697260. 10.1001/jama.2017.7171 28697260
335 U. S. Preventive Services Task Force, Curry SJ, Krist AH, . Behavioral Weight Loss Interventions to Prevent Obesity-Related Morbidity and Mortality in Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2018;320(11):1163–71. PMID. 10.1001/jama.2018.13022 30326502
336 National Institutes of Health. DASH Eating Plan. https://www.nhlbi.nih.gov/health-topics/dash-eating-plan. Accessed: August 20, 2019.
337 Banegas JR, Ruilope LM, de la Sierra A, . Relationship between Clinic and Ambulatory Blood-Pressure Measurements and Mortality. N Engl J Med. 2018;378(16):1509–20. PMID: 29669232. 10.1056/NEJMoa1712231 29669232