# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Justin A. Mills, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; the National Center for Chronic Disease Prevention and Health Promotion, National Institute on Minority Health and Health Disparities, National Heart, Lung, and Blood Institute, National Institute of Nursing Research, and National Institute of Child Health and Human Development for providing federal partner review of the draft report; Alice H. Lichtenstein, DSc, PhD, Penny M. Kris-Etherton, PhD, and Crystal Tyson, MD, who provided expert review of the draft report; and Andy Zhu, BS, for assistance with contextual questions, Smyth Lai, MLS, and Katherine Essick, BS, for technical and editorial assistance at the Kaiser Permanente Center for Health Research.