# Chapter 4 Discussion

## Summary of Evidence

Consistent with our prior review to support the previous recommendation, this review found that medium- and high-contact behavioral counseling interventions to improve diet and physical activity in people with cardiovascular risk factors was associated with improvements spanning a range of intermediate and behavioral outcomes, including blood pressure; lipids; adiposity; blood glucose; and intake of saturated fat, fruits and vegetables, fiber, and sodium. We found very similar effect sizes for most of these outcomes compared with the previous review (Table 15), despite the change in the composition of the evidence. Unlike the previous review, the current review included weight loss trials (as long as the trial was limited to people with CVD risk factors) and trials in people with elevated blood pressure and lipids (rather than requiring participants to meet criteria for hypertension or dyslipidemia), and excluded diabetes prevention trials that required all or most participants to have impaired fasting glucose. Thus, the current review was more heavily weighted toward populations with hypertension, dyslipidemia, and obesity, and de-emphasized diabetes prevention, which is addressed in a separate, concurrent USPSTF review.

Unlike the previous review, the current review found that behavioral counseling interventions were associated with a lower likelihood of CVD events, based on 12 trials reporting CVD event outcomes. Nine of these trials were new in this update. The overall pooled effect showed a 20 percent lower risk of CVD events with behavioral counseling interventions (pooled RR=0.80 [95% CI, 0.73 to 0.87], 9 RCTs [n=12,551]). This translates to a number needed to treat (NNT) of 100 (95% CI, 74 to 154) to prevent one CVD event, assuming a baseline rate of 5 percent. Population risks of 7.5 percent and 10 percent translate to NNTs of 67 (95% CI, 49 to 103) and 50 (95% CI, 37 to 77), respectively. This evidence is based largely on the strength of PREDIMED, a recently completed large trial conducted in Spain that was not included in the previous review.^131^ The PREDIMED study reduced stroke, PAD, and total CVD events. Total CVD events were reduced from 4.4 percent in the control group to 3.6 percent in the intervention group after 5 years. The PREDIMED findings were supported by a number of additional trials targeting patients with hypertension or selected based on having any of multiple CVD risk factors, and the effect was still statistically significant in a sensitivity analysis excluding PREDIMED (pooled RR=0.79 [95% CI, 0.70 to 0.90], 8 RCTs [n=5,104]) (Table 9).

## Applicability of Findings

We considered this evidence to generally have good applicability to most U.S. primary care settings. Many of the trials were conducted in or recruited from primary care settings or other related healthcare settings (e.g., enrollment records from health clinics or systems), and almost half were conducted in the United States. Although data were very limited for persons age 75 years and older, PREDIMED had an average age of 67, supporting the benefits of dietary counseling adults age 65 and older. Most interventions were delivered by professionals of the type embedded in large health systems (e.g., registered dieticians, nurses, health educators) and 25 (22%) of the included trials involved the primary care provider or their staff directly. However, we acknowledge that access to these professionals may not be widely available in all primary care settings, and there may be more opportunities in large healthcare delivery systems. Additionally, recruitment from most studies (63%) was not self-selected or volunteer-based, improving the generalizability to primary care.

While PREDIMED was conducted in primary care settings, two factors limit the generalizability of its results: first, it excluded patients who were not ready to change according to the Stages of Change model, and second, it provided nuts or olive oil to all participants on a weekly basis. Indeed, some commenters have suggested that the results of PREDIMED might largely reflect the impact of supplemental food rather than overall dietary pattern.^284^ Given evidence to support the benefits of food subsidies for low-income families,^285,^ ^286^ food provision may be a powerful intervention that could reduce socioeconomic health disparities. However, it does likely limit generalizability since most primary care settings are unlikely to distribute food directly. An additional limitation to the generalizability of PREDIMED is that it was conducted in Spain, where the typical diet already has Mediterranean elements. One group has noted that the typical U.S. diet would probably score 1 to 2 on the MEDAS, based largely on NHANES data,^287^ in contrast to the baseline score in PREDIMED of approximately 8.5. The typical diet in the United States includes a substantial quantity of prepared and processed foods, and cooking from scratch is relatively rare. Thus, a 2-point increase on the MEDAS from 8.5, as was seen in the PREDIMED study, may not have the same health impact as a 2-point increase from a score of 1.5. It is plausible that the effect could be larger from such a different starting point.

Importantly, we found that behavioral counseling interventions appear to be effective in low-SES populations as well as those with more ample resources, which may provide an opportunity to help reduce income-related health disparities. There is a body of literature demonstrating an association between low socioeconomic status and unhealthy diet, which relates to the relatively higher burden of obesity and other cardiovascular risk factors among low-income individuals.^288,289^ These groups therefore have the potential for substantial benefit from these interventions. A number of mechanisms have been suggested as reasons economically disadvantaged individuals have poorer quality diets: such diets cost less per calorie and people with very limited funds may need to prioritize price over healthfulness; knowledge is lacking about what constitutes a healthy diet and how to prepare foods to maximize their healthful qualities; and environmental factors may play a role, including limited access to fresh fruits and vegetables and greater access to fast-food outlets.^288^ A systematic review of 35 RCTs examined factors associated with greater effectiveness of healthy lifestyle behavioral interventions in low-income individuals.^290^ It found that self-monitoring, targeting multiple behaviors, and delivery through personal contact were all associated with greater improvement in healthy eating for people with low incomes. Features that were associated with more limited benefits included providing feedback on their eating, providing information about the emotional consequences of an unhealthy diet, and encouraging participants to use prompts and cues to be meeting dietary goals. They also found that physical activity interventions that included behavioral practice or instruction on how to perform the activity tended to report larger improvements in physical activity in low-income individuals.^290^

## Comparisons with Other Reviews and Implementation Studies

Our findings were consistent with another recent review of 36 trials of multifactorial (primarily diet and physical activity) lifestyle interventions.^291^ At 12-month followup among trials it categorized as being in “moderate” risk populations (generally meaning participants had one or more CVD risk factors but not CVD), it reported findings that were very similar to ours for blood pressure, (−2.48 mm Hg [95% CI, −4.34 to −0.62]/−1.66 mm Hg [95% CI, −2.17 to −1.14], SBP/DBP change), and slightly larger for lipids (total cholesterol=−8.8 mg/dL [95% CI, −17.0 to −0.1], LDL=−4.2 mg/dL [95% CI, −8.5 to −0.0]) and adiposity (BMI=−0.8 kg/m^2^ [95% CI, −1.8 to 0.2], waist circumference=−2.4 cm [95% CI, −5.4 to 0.6]). However, unlike our review, this review included trials with supervised physical activity. Similarly, USPSTF reviews^47,^ ^292^ on adult obesity also found larger mean differences between groups in adiposity-related outcomes (e.g., BMI: −1.0 [95% CI, −1.2 to −0.7], Table 15), and LDL (−4.9 [95% CI, −7.3 to −2.6]), but had similar SBP results (SBP=−2.0 [95% CI, −2.9 to −1.2]), with 13 trials appearing in both reviews.^109,^ ^116,^ ^119,^ ^120,^ ^123–130,^ ^138^ The USPSTF review on diet and physical activity counseling in people who do not have CVD risk factors reported slightly smaller pooled effects for most intermediate outcomes and minimal evidence on the impact in CVD events but larger increases in physical activity than our review.^293^ It found approximately 35 more minutes per week of physical activity with lifestyle counseling interventions, and that USPSTF review included 43 trials of interventions that only addressed physical activity, many of which recruited adults with low levels of physical activity.^293^ Indeed, studies whose primary inclusion criterion was suboptimal physical activity (without reference to CVD risk factors) were included in that review and not the present review.

Large implementation trials may provide insight into how well review results will generalize to real-life settings. A retrospective cohort study of the Veterans Administration MOVE! weight loss program included 1,463,003 veterans with obesity or overweight with weight-related health conditions and no baseline CVD, of whom 169,248 participated in the MOVE! program.^294^ The MOVE! program involves group-based educational sessions on nutrition, physical activity, and goal-setting. After a mean of 4.9 years of followup, participants in the MOVE! program had lower incidence of total CVD (hazard ratio [HR]=0.83 [95% CI, 0.80 to 0.86]), coronary artery disease (HR=0.81 [95% CI=0.77, 0.86]), cerebrovascular disease (HR=0.87 [95% CI, 0.82 0.92]), peripheral vascular disease (HR=0.89 [95% CI, 0.83 to 0.94]), and heart failure (HR=0.78 [95% CI, 0.74 to 0.83]), all controlling for age, race, sex, BMI, statin use, and baseline comorbidities. These results held up when examined for the categories of race/ethnicity, BMI, diabetes, hypertension, smoking status, and statin use. These effect sizes are consistent with our observed 19 percent reduction in CVD events. In this study, 49 percent had hypertension, 19 percent had diabetes, and 41 percent had dyslipidemia at baseline.

Another implementation study included 12,513 patients with multiple cardiovascular risk factors or history of atherosclerotic disease who were followed for 5 years in primary care clinics in Italy that implemented a program of annual screening and counseling by primary care providers for cardiovascular risk factors, including hypertension, hypercholesterolemia, diabetes, obesity, smoking, unhealthy diet, and physical inactivity.^295^ If control of any major modifiable cardiovascular risk factors was suboptimal, general practitioners use a brief checklist to develop action plans to improve the patients’ global risk profile. From the first to the last year of the program, control of all major modifiable risk factors except physical inactivity improved (p<0.0001). The improvement in the global cardiovascular risk profile during the first year was associated with a lower rate of major cardiovascular events in the following years (HR=0.94 [95% CI, 0.88 to 0.99]).

## Intervention Approach

We identified no single optimal or representative intervention, but rather found that a wide range of approaches improve health profiles (Table 16). A number of effective trials used group-based counseling, and almost all of these also provided at least one individual support or assessment session as well. Quite a few interventions only provided individual contact, either in person or over the phone. Interestingly, an evaluation of participation in a health coaching program in a large integrated delivery system found that 80 percent of patients who participated in their program opted to receive one-on-one counseling over the phone rather than in-person individual or group sessions.^296^

In the included trials, the intervention contact time required to show a benefit was as low as 1 hour over two sessions, although not all interventions with this level of contact were beneficial. In addition, weight loss interventions tended to offer more contact time than general diet and physical activity interventions. Most effective group-based programs offered five to 12 sessions over 4 to 12 months, or if weight loss was a primary focus, 20 to 30 sessions over 24 months. One-on-one interventions were generally briefer, typically four to 17 sessions over 6 to 16 months, and up to 32 or more sessions over 24 months for interventions focusing on weight loss. Medium contact interventions were typically delivered individually while high contact trials usually involved groups, often in addition to individual contact. Two trials included interventions both with and without human contact, using technology^123^ or print-based^103^ approaches for one of the intervention groups. Compared with a high-contact intervention, an online-only intervention resulted in less weight loss but no clear differences in diet composition or physical activity,^123^ and the four-session medium contact intervention showed comparable levels of behavior change as four tailored letters.^103^

In general, the interventions involved both physical activity and dietary counseling, which typically advised participants to reduce saturated fat; reduce sodium intake to below 1,500 or 2,300 mg/day for hypertension prevention and management; increase consumption of fruits, vegetable, whole grains, healthy fats, and fish; and reduce consumption of sweets and added sugar. The DASH diet and the Mediterranean diet were both employed by multiple interventions. A recently published diet described as optimal for both human and planetary health similarly emphasizes fish, vegetables, fruit, legumes, whole grains, and nuts.^297^

Among interventions showing a benefit, common behavior-change techniques included goal setting, active use of self-monitoring, and addressing barriers related to diet, physical activity, or weight change. Some of the interventions offered smoking cessation support to smokers. Motivational interviewing was commonly employed. The most common type of provider to deliver the bulk of the interventions was a registered dietician, but a wide range of providers were employed, such as health educators, nurses, lifestyle coaches, psychologists or psychology graduate students, and exercise physiologists. Few of the included interventions were primarily or wholly delivered through the computer or other electronic means, and a systematic review of lifestyle counseling to improve components of metabolic syndrome found that while technology could be a useful tool, interventions with personal contact were most effective.^298^ This approach was employed by an included U.S.-based trial that supplemented 18 phone-based coaching sessions with interactive voice recognition calls. It found relatively large benefits on lipids, fasting blood glucose, and weight.^141^ The same review found that team-based, interactive approaches with high-frequency contact with patients who were motivated found the largest effects.^298^

Most of the interventions had weight loss goals for all or some of the participants. Consistent with our review, another review found that explicitly targeting weight loss in behavioral counseling interventions was associated with greater weight loss.^299^ This review also found that providing dietary goals or meal plans and feedback on behavior change were associated with greater weight loss.^299^ A comparative effectiveness study compared the effects of a weight loss intervention against a weight-neutral approach for health promotion in 80 women with BMI ≥30 and age 30–45.^300^ At postintervention, the weight-neutral program had larger reductions in LDL cholesterol and greater improvements in intuitive eating, while the weight loss program had larger reductions in BMI, weight, and (in the short-term only) larger decreases in a dietary risk score. Both groups improved on waist-to-hip ratio, total cholesterol, physical activity, fruit and vegetable intake, self-esteem, and quality of life at the 24-month followup. These findings highlight that important health benefits can accrue for people with excess weight even in the absence of weight loss or encouragement to lose weight. This trial was not limited to people with CVD risk factors, however, so generalizability to this group is unclear.

Further arguing for the benefits of improved diet and physical activity even without weight loss are the results from a large epidemiologic study combining participants from the Nurses’ Health Study and the Health Professionals Follow-up Study.^301^ After 32 years, it found that all-cause mortality was lower in people with BMIs between 30 and 39.9 kg/m^2^ who had engaged in at least three of the following healthy behaviors: healthy diet, physical activity, moderate alcohol consumption, and not smoking (incidence rate [IR]=51.7/10,000 person-years for BMI 30.0 to 34.9; IR=81.1/10,000 person-years for BMI 35.0 to 39.9) than people of healthy weight who reported engaging in only one of these four healthy behaviors (IR=96.5/10,000 person-years for BMI 22.5 to 24.9). Thus, for people with excess weight, particularly for those with a history of unsuccessful weight loss, unhealthy weight loss approaches, or disordered eating, promoting diet and physical activity goals without targeting weight loss is likely to improve their health status.

We did not find that physical activity consistently increased with lifestyle counseling for patients with CVD risk factors, despite evidence that suggests physical activity can improve cardiometabolic profiles among people with CVD risk factors.^9,^ ^302,^ ^303^ In contrast, the USPSTF-commissioned systematic review of behavioral counseling for diet and physical activity in adults without CVD risk factors found a statistically significant 35-minute increase in physical activity per week and 32 percent higher odds of meeting physical activity recommendations.^293^ Like the current review, it also excluded trials with supervised physical activity. In both reviews, only a small subset of trials reported physical activity outcomes, although reporting was even more sparse in our review. It is possible that supervised activity is an important factor in helping adults with CVD risk factors increase and maintain physical activity regimens. Indeed, semi-structured interviews of participants who had declined participation in an intervention to increase walking identified existing medical conditions as one of the more common reasons for declining,^304^ so people with CVD risk factors may similarly prefer to undertake physical activity under the supervision of a health or exercise professional. However, it remains unclear why improvements in physical activity were consistent and statistically significant in one review and not another. While we theorize that differences may be due to differing needs of patients with cardiovascular risk factors, we were unable to provide a clear explanation and other hypotheses cannot be ruled out, including reporting issues in primary trials.

## Observational Evidence on the Association Between Differences in Intermediate and Behavioral Outcomes and Health Outcomes (Contextual Question)

Observational data from very large individual participant data (IPD) meta-analyses of prospective cohort studies show that small differences in blood pressure, non-HDL cholesterol, fasting glucose, and adiposity translate into small reductions in the risk of cardiovascular-related mortality (Table 17).^305–307^ In our review we found that behavioral counseling interventions in persons with CVD risk factors had a pooled effect size of 1.9 mm Hg greater reduction in SBP. Using observational data, an effect of 2 mm Hg was associated with reductions of 6 percent or more in the risk of cardiovascular-related mortality, and the effect appears to hold down to blood pressure levels of 115/75 mm Hg.^305^ A recent analysis extended these findings to show that important associations between blood pressure and CVD events exist regardless of threshold (e.g., 140/90 mm Hg vs 130/90 mm Hg) and when using real-world clinical databases that do not use research-quality blood pressure measurements.^308^ An average decrease in non-HDL cholesterol of 3 mg/dL (slightly smaller than the 3.7 mg/dL greater reduction in total cholesterol found in our review) was associated with a 4 percent reduction in IHD mortality in adults ages 40 to 49 years old (HR=0.96 [95% CI, 0.95 to 0.96].^305^ An incremental 2 mg/dL decrease in fasting blood glucose above 100 mg/dL was associated with an estimated 1 percent decreased risk of fatal plus nonfatal coronary heart disease (HR=0.99 [95% CI, 0.98 to 0.99]),^309^ vascular deaths (HR=0.99 [95% CI, 0.98 to 0.99]),^310^ and all-cause mortality (HR=0.99 [95% CI, 0.99 to 0.99]).^310^ The relationship between BMI and cardiovascular-related mortality is found only above a BMI of 25 kg/m^2^. A BMI decrease of 0.4 kg/m^2^ (the effect size found in our pooled analysis) was associated with an estimated 3 percent decreased risk of death caused by ischemic heart disease (HR=0.97 [95% CI, 0.96 to 0.97]) and fatal strokes (HR=0.97 [95% CI, 0.97 to 0.98]) among adults with a BMI above 25 kg/m^2^ and ranging from ages 35 to 59 years.^307^ Based on data pooled from multiple prospective cohort studies, we estimated that a 1.7 cm decline in waist circumference could be associated with a 5 percent lower risk of ischemic heart disease events (HR=0.95 [95% CI, 0.95 to 0.98])^311^ and a 1 to 3 percent lower risk of all-cause mortality (men: HR=0.97 [95% CI, 0.96 to 0.98] for a 2 cm decline; women: HR=0.99 [95% CI, 0.98 to 0.99] for a 1 cm decline).^312^

Table 17 Association Between Changes in Intermediate Outcomes and Mortality Outcomes, Based on Individual Patient Data Meta-Analysis of Epidemiological Studies

Intermediate Outcome | Original Increment Difference | HR (95% CI) for Health Outcome for Original Increment Change in Intermediate Outcome | Converted Increment Difference | Age, years | Mortality Outcome | HR (95% CI) for Health Outcome for Converted Increment Change in Intermediate Outcome
SBP^305,*^ | ↓20 mm Hg | 0.49 (0.45 to 0.53) | ↓2 mm Hg | 40-49 | IHD | 0.93 (0.92 to 0.94)
SBP^305,*^ | ↓20 mm Hg | 0.54 (0.53 to 0.55) | ↓2 mm Hg | 60-69 | IHD | 0.94 (0.94 to 0.94)
SBP^305,*^ | ↓20 mm Hg | 0.36 (0.32 to 0.40) | ↓2 mm Hg | 40-49 | Stroke | 0.90 (0.89 to 0.91)
SBP^305,*^ | ↓20 mm Hg | 0.43 (0.41 to 0.45) | ↓2 mm Hg | 60-69 | Stroke | 0.92 (0.91 to 0.92)
SBP^305,*^ | ↑14 mm Hg^337^ ABPM | 1.58 (1.55 to 1.60) | ↓2 mm Hg | 58.4^#^ | CVD | 0.94 (0.93 to 0.94)
SBP^305,*^ | ↑19 mm Hg^337^ clinic-based | 1.54 (1.52 to 1.56) | ↓2 mm Hg | 58.4^#^ | CVD | 0.96 (0.95 to 0.96)
Non-HDL-C^306^,^†^ | ↓1 mmol/L | 0.57 (0.52 to 0.62) | ↓3 mg/dL | 40-59 | IHD | 0.96 (0.95 to 0.96)
Non-HDL-C^306^,^†^ | ↓1 mmol/L | 0.66 (0.61 to 0.71) | ↓3 mg/dL | 60-69 | IHD | 0.97 (0.96 to 0.97)
TC^306^,^§^ | ↓1 mmol/L | 0.44 (0.42 to 0.48) | ↓3 mg/dL | 40-49 | IHD | 0.94 (0.93 to 0.94)
TC^306^,^§^ | ↓1 mmol/L | 0.72 (0.69 to 0.74) | ↓3 mg/dL | 60-69 | IHD | 0.97 (0.97 to 0.98)
TC^306ǁ^ | ↓1 mmol/L | 0.90 (0.84 to 0.97) | ↓3 mg/dL | 40-59 | Stroke | 0.99 (0.99 to 1.00)
TC^306ǁ^ | ↓1 mmol/L | 1.02 (0.97 to 1.08) | ↓3 mg/dL | 60-69 | Stroke | 1.00 (1.00 to 1.01)
FBG^309,^ ^310^,^¶^ | ↑1 mmol/L | 1.12 (1.08 to 1.15) | ↓2 mg/dL | 56^#^ | F+NF CHD | 0.99 (0.98 to 0.99)
FBG^309,^ ^310^,^¶^ | ↑18.02 mg/dL | 1.13 (1.11 to 1.15) | ↓2 mg/dL | 53^#^ | Vascular | 0.99 (0.98 to 0.99)
FBG^309,^ ^310^,^¶^ | ↑18.02 mg/dL | 1.10 (1.09 to 1.11) | ↓2 mg/dL | 53# | All-cause | 0.99 (0.99 to 0.99)
BMI^307,**^ | ↑5 kg/m^2^ | 1.50 (1.39 to 1.62) | ↓0.4 kg/m^2^ | 35-59 | IHD | 0.97 (0.96 to 0.97)
BMI^307,**^ | ↑5 kg/m^2^ | 1.40 (1.32 to 1.49) | ↓0.4 kg/m^2^ | 60-69 | IHD | 0.97 (0.97 to 0.98)
BMI^307,**^ | ↑5 kg/m^2^ | 1.76 (1.52 to 2.04) | ↓0.4 kg/m^2^ | 35-59 | Stroke | 0.94 (0.94 to 0.97)
BMI^307,**^ | ↑5 kg/m^2^ | 1.49 (1.34 to 1.67) | ↓0.4 kg/m^2^ | 60-69 | Stroke | 0.97 (0.96 to 0.98)

Abbreviations: BMI = body mass index; CHD = coronary heart disease; CI = confidence interval; dL = deciliter; F+NF = fatal plus nonfatal; FBG = fasting blood glucose; HDL-C = high-density lipoprotein cholesterol; Hg = mercury; HR = hazard ratio; IHD = ischemic heart disease; kg = kilogram(s); m = meter(s); mg = milligram(s); mm = millimeter(s); mmol = millimole(s); NS = not significant; SBP = systolic blood pressure; TC = total cholesterol.

* For SBPs above 115 mm Hg. Adjusted for age (within range being considered), sex, and study. Adjustments for lipids, diabetes, weight, alcohol, and smoking did not change results

† Adjusted for age (within range being considered), sex, and study. Formal test for heterogeneity NS for sex (significant for age)

‡ Directionality inverted from negative to positive

§ Adjusted for age (within range being considered), sex, and study. Result slightly attenuated by adjustment for SBP and unaltered by adjustment for smoking. Formal test for heterogeneity NS for sex for age <69 years; formal test for heterogeneity significant for age

ǁ Adjusted for age (within range being considered), sex, and study. Result attenuated with adjustment for SBP and minimal increase in HR with further adjustment for smoking for 40-59-year group only

¶ For FBG above 100 mg/dL and assuming log-linear association. Adjusted for age, smoking, BMI, SBP

# Mean age

** For BMI above 25 kg/m^2^. Adjusted for sex and smoking

Table 18 Summary of Evidence

Key Question | No. of Studies (No. of observations); Study Designs | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
KQ1 | CVD events: 12 RCTs (15,107); Mortality: 18 RCTs (18,146); Subjective well-being: 11 RCTs (5684) | CVD events were reported in 10 trials of medium or high-contact interventions and pooled analyses showed lower rates of total CVD events (pooled RR=0.80 [95% CI 0.73 to 0.87], k=9), and fairly large but statistically non-significant associations with myocardial infarction (pooled RR=0.85 [95% CI 0.70 to 1.02], k=6) and stroke (RR=0.52 [95% CI 0.25 to 1.10], k=4). Event rates were variable, but the largest trial reported 3.6% of intervention participants having CVD events, compared with 4.4% of control participants. Few studies were powered for mortality, neither those few studies nor the pooled estimate clearly demonstrated an impact on mortality (pooled RR=0.89 [95% CI 0.71 to 1.11]). Patient-reported measures of subjective well-being were sparely reported and showed no clear pattern of clinically important benefit. | Mortality: Reasonably consistent, Imprecise; CVD events: Reasonably consistent, Reasonably precise; Subjective well-being: Inconsistent, Imprecise | Sparsely reported, few trials had sufficient power and length of followup for mortality and CVD events; trial with the strongest evidence suffered from protocol violations in allocation, however extensive sensitivity analyses showed limited impact on results. | CVD events: Moderate for benefit; Mortality: Low for small to no benefit; Subjective well-being: Insufficient | CVD events: Most trials conducted in the US, however, the largest trial providing the strongest evidence was conducted in Spain. Most participants across all trials were middle aged and older adults who were predominantly white and not socioeconomically disadvantaged.
KQ2 | Continuous clinical measures: 89 RCTs (46,354); Hypertension incidence: 5 RCTs (2707); Diabetes incidence: 4 RCTs (6701); Metabolic syndrome: 5 RCTs (3103) | Behavioral counseling interventions were associated with small, statistically significant reductions in blood pressure, total and LDL cholesterol, fasting glucose, and adiposity-related outcomes at 12 to 24 months’ followup. Hypertension incidence was lower with interventions designed to prevention hypertension in those who did not have it already (pooled RR=0.74 [95% CI 0.58 to 0.94]; 5 RCTs, [n=2707]; I^2^=12%). No intervention factors were clearly associated with effect size, but among trials with the largest effects across multiple domains, most offered more than 6 hours of intervention contact and offered group as well as individual contact. Selected Pooled MDs were as follows:; - SBP= −1.8 (95% CI −2.5 to −1.1), k=44; - DBP= −1.2 (95% CI −1.6 to −0.8), k=40; - TC= −3.5 (95% CI −5.6 to −1.4), k=38; - LDL= −2.1 (95% CI −4.1 to −0.2), k=32; - FBG=-2.3 (95% CI −3.6 to −1.0), k=22; - BMI=-0.5 (95% CI −0.7 to −0.2), k=30; Evidence primarily in medium and high-contact interventions. | Reasonably consistent, Reasonably precise | Hypertension prevalence, diabetes and metabolic syndrome were reported in very few trials, raising concerns about reporting bias | High for benefit | Substantial number of trials conducted in the US and in conducted in or recruited from primary care. Most participants across all trials were middle aged and older adults who were predominantly white and not socioeconomically disadvantaged.
KQ3 | 70 RCTs (43,243) | Interventions were associated with small reductions in saturated fat and small increases in fruit, vegetable, and fiber consumption. For example, fruit and vegetables consumption increased by an average of 0.7 servings/day more in the intervention than the control groups (pooled MD=0.7 [95% CI 0.1 to 1.3]; 14 effects [11 RCTs] [n=4310]; I^2^=90%). The average increase in fiber consumption was 1.3 grams per day (95% CI 0.1 to 2.6, 5 trials [n=1350], I^2^=42%). In addition, trials of persons with hypertension or elevated blood pressure who were counseled to reduce sodium consumption showed greater reductions in urinary sodium (pooled MD=-18.0 [95% CI −34.8 to −1.2]; 9 RCTs [n=3583]; I^2^=89%). Findings were mixed for physical activity. Most trials included medium or high-contact interventions. | Diet: Reasonably consistent, imprecise; Physical activity: inconsistent, imprecise | Sparse reporting with substantial variability in measures used, particularly for physical activity. Clinical importance of effect sizes could not be clearly determined | Diet: Low for benefit; Physical activity: Low for no benefit | Substantial number of trials conducted in the US and in conducted in or recruited from primary care. Most participants across all trials were middle aged and older adults who were predominantly white and not socioeconomically disadvantaged.
KQ4 | 20 RCTs (18,263) | Adverse events related to diet and physical activity counseling were very rare, with generally no statistically significant differences in any study for: serious adverse events, any adverse events, hospitalizations, musculoskeletal injuries, withdrawals due to adverse events, gallbladder disease, and headaches. There was no consistent evidence of paradoxical effects for intermediate or behavioral outcomes. | Reasonably consistent, imprecise | Sparsely reported, ascertainment typically not described. | Low for no harms | Substantial number of trials conducted in the US and in conducted in or recruited from primary care. Most participants across all trials were middle aged and older adults who were predominantly white and not socioeconomically disadvantaged.

Abbreviations: BMI = body mass index; CI = confidence interval; CVD = cardiovascular disease; DBP = diastolic blood pressure; FBG = fasting blood glucose; k = number of studies analyzed; KQ = key question; LDL = low-density lipoprotein cholesterol; MD = mean difference; No. = number; RCT = randomized controlled trial; RR = risk ratio; SBP = systolic blood pressure; TC = total cholesterol

For dietary outcomes, the impact of individual diet components is difficult to evaluate, as the totality of the diet is most important.^288^ One meta-analysis of 16 cohort studies found a 5 percent lower risk of all-cause mortality for an increment of one serving of fruit and vegetables per day (pooled HR=0.95 [95% CI, 0.92 to 0.98]),^20^ although our analysis found a mean difference in change of less than one serving. The effect of a 17.9 mmol/L greater reduction in sodium is unclear. Meta-analyses of cohort studies indicate that a 40 mmol/L reduction was associated with reduced incidence of stroke and fatal coronary heart disease events, but some other cardiovascular-related outcomes did not show a clear association.^313^ The DASH feeding study found that a reduction in urinary sodium of approximately 50 mmol per day (a level of change consistent with someone who eats a typical American diet reducing their intake to meet current recommendations) was associated with approximately 2 mm Hg reduction in SBP,^313^ which is the effect we found in this review.

The findings on intake of different types of dietary fats are less clear, although evidence suggests that a fat-modified diet may not assist with weight loss or decrease CVD and cancer mortalities.^314–317^ Evidence suggests that replacing 5 percent of energy from saturated fats with other types of fats or whole-grain carbohydrates is associated with health benefits,^21^ but not all researchers agree with this conclusion.^318–320^ Further, a 5 percent change is larger than the 1.5 percent difference in change that we found in this review.

There is a strong body of evidence showing substantial health benefits associated with physical activity, and current evidence suggests that there is no threshold that must be exceeded before benefits can occur.^9^ Thus, despite the small, statistically nonsignificant findings for minutes and MET-minutes per week of exercise, any increase in physical activity is likely beneficial.

See Appendix E for a more detailed description of observational evidence supporting the link between changes in behavior and intermediate outcomes of the magnitude found in this review and long-term cardiovascular health outcomes. However, it is always worth emphasizing that observational evidence may overestimate the benefits of behavior change due to the inherent difficulty in controlling for confounding factors in non-randomized studies. Biases in observational results may be even more pronounced when long-term adherence to drug or behavioral change is assumed in order to maintain benefits. Some have noted that this concern is particularly important for applying effects of observational evidence to preventive interventions in primary care settings.^321^ Moreover, observational evidence does not reflect changes in intermediate or behavioral outcomes based on counseling interventions.

## Limitations of Our Approach

This review addressed a subset of a larger body of literature on behavioral counseling interventions to promote a healthy diet and increase physical activity to encourage health and wellness more broadly. We focused narrowly on CVD prevention, limited further to patients with problematic blood pressure or lipids, to complement related USPSTF-sponsored reviews surrounding CVD prevention.^45,^ ^46,^ ^322^ Interventions targeting other health conditions are not represented, such as those focused on reducing or managing chronic pain, stress, limiting disability/frailty in older adults, improving mental health, or myriad other conditions that may be affected by diet and physical activity. We also did not include studies limited to some important underrepresented populations, such as those with physical or intellectual disabilities, and some of the included trials specifically excluded these individuals from their studies, although these interventions are relevant to these populations.^323^

In addition, we limited our definition of high risk to hypertension, dyslipidemia, and any of multiple risk factors (including estimated 10-year risk). However, increasing age is a primary risk factor for CVD and studies restricted to older adults but without 10-year CVD risk inclusion requirements were excluded. In addition, we did not include studies focused on persons with mild chronic kidney disease, many of whom also have hypertension and dyslipidemia and who may also benefit from behavioral counseling for diet and physical activity.

Our search did not comprehensively address weight loss for trials published prior to 2016. Since the previous review did not include weight loss trials, the previous search did not include weight loss terms. We used the USPSTF review on weight management interventions to identify weight loss trials in people with CVD risk factors that were published prior to 2016.^322^ In addition, we searched the excluded studies lists from the previous on lifestyle counseling for people with CVD risk factors to identify studies that had been excluded because they were considered to be weight loss studies.^324^

Additionally, we excluded populations with prediabetes or identified with a diabetes risk score. A concurrent companion systematic review is addressing behavioral counseling interventions to prevent diabetes in those at increased risk of diabetes. While we are confident that this targeted approach will not miss any literature, we acknowledge that prediabetes commonly coexists in adults with obesity, hypertension, and dyslipidemia.

## Limitations of the Studies and Future Research Needs

Although the evidence base for the impact of diet and physical activity counseling on health outcomes has improved since the previous review, one limitation of the literature is that only a small proportion of trials had sufficient sample size and length of followup to explore the impact of their interventions on important health outcomes such as stroke, MI, and mortality. Continued long-term followup presents a valuable opportunity to assess the impact on these important outcomes. Data were also very limited on lifestyle counseling’s impact on subjective well-being, which reflect health outcomes of great importance to patients.

Another important limitation of this literature is the highly variable reporting of behavioral outcomes, particularly physical activity outcomes. The variability in specific measures used, as well as the general lack of reporting of behavioral outcomes in studies reporting intermediate outcomes, made it very difficult to understand the range of effects and to interpret the pooled effects. In addition, for dietary outcomes, it is difficult to understand the clinical importance of changes in a single aspect of diet, particularly in the area of fat consumption, because recommendations have changed over the past decades and controversy remains over the role of saturated fats in the development of heart disease.^318,^ ^325^ Given the importance of substitutions when modifying diet,^21^ validated measures of overall diet pattern would be a more valuable outcome; however, the field has not converged on a consistent measure of overall optimal diet pattern. The Healthy Eating Index (HEI), for example, is a validated measure of overall diet quality assessing alignment with the Dietary Guidelines for Americans, and is associated with all-cause, CVD, and cancer mortality.^326^ Yet, only two included studies reported this measure.^97,^ ^123^ This field would benefit from establishing a set of core outcome measures of optimal diet and physical activity.

Additionally, changes over time in eating patterns, treatment guidelines, and our understanding of the science of nutrition increase the clinical heterogeneity of participants as well as the interventions used in these trials. Treatment guidelines for hypertension and dyslipidemia have changed over time, generally becoming more aggressive. At the same time, rates of smoking have declined. Dietary messages as well as technology platforms available to deliver interventions have similarly undergone rapid change. While we restricted our included literature to trials published from 1990 to present, this review encompasses nearly 30 years of literature, during which the clinical context of behavioral counseling for individuals with CVD risk factors has changed. The sparse reporting of baseline estimated 10-year CVD risk—coupled with the rarity of trials powered for CVD events—makes it difficult to characterize the risk levels of participants in terms consistent with treatment guidelines that are informed by 10-year risk levels.

The wide-ranging clinical characteristics of the study populations also made it difficult to generalize from study-reported subgroup analyses, which were rarely available from more than one or two studies for any given outcome for a given patient subpopulation. Thus, we were not able to provide a robust analysis of differential effectiveness across patient characteristics. While we conducted meta-regression and subgroup analysis in our meta-analyses to address effect modification to the extent possible, these analyses were very limited due to the risk of ecological bias, and the best analysis of effect modification across patient subpopulations is with individual-level data. Another analysis issue that is best addressed in individual-level analyses is controlling for the confounding effects of medication use. Medication use may have systematically differed between groups if control participants had a greater need for medication use due to poorer lifestyle behaviors. Individual studies rarely controlled for this potentially important confounding variable.

In addition, there was little literature on the use of technology, online resources, or other low-contact approaches, which may be valuable in settings with very limited resources. Relatedly, there was very limited use of modern wearable activity trackers in the included interventions, but these may be useful tools to increase engagement in physical activity as well as to provide objective physical activity outcomes. Research suggests that these devices can even be acceptable to adults over the age of 50 with chronic illnesses.^327^ The included studies also provided very limited information on whether lifestyle change can reduce the risk of CVD in older adults, such as those age 75 and older. Many studies had upper age limited in the 60s or 70s and few included a substantial number of participants older than 70.

Despite the large number of included trials in this review, there were few replication studies, unlike DPP in the diabetes prevention literature. Large replication studies of interventions showing reduction in CVD events are urgently needed. Given the recency and magnitude of benefit from PREDIMED, it would be of great value to determine if these findings could be replicated in the United States. Our review includes only one U.S.-based trial explicitly stating that a Mediterranean diet message was evaluated.^136^ This 12-month trial of 184 participants showed statistically significant improvement in blood pressure, adiposity, and saturated fat outcomes; however, it was too small to assess impact on CVD events.

The PREDIMED-Plus (ISRCTN89898870 (http://www.isrctn.com/ISRCTN89898870)) trial currently underway in Spain intends to build upon the findings of PREDIMED. PREDIMED-Plus, for which 6,874 individuals were recruited, will compare a Mediterranean diet (with supplemental olive oil and nuts given at no cost) to a Mediterranean diet (with the same supplemental foods) together with promotion of physical activity, behavioral support, and weight loss goals. The primary outcome of this trial is a CVD event composite, and the anticipated trial completion date is 2020. Many behavioral counseling trials are currently in progress, with many being conducted in the United States (Appendix I). The trials are evaluating different intervention formats in both general and targeted populations with CVD risk factors. With the exception of PREDIMED-Plus, none of the trials appear to be powered for CVD events.

Finally, we agree with the Hypertension Canadian Priority Setting Partnership Group that more research is needed to determine the combinations of healthy lifestyle modifications that are necessary and sufficient to reduce the need for medications to manage CVD risk factors, and the optimal use of educational tools and technologies to improve patient motivation and health behavior change.^328^ While great strides have been made in developing and testing numerous interventions, it is still unclear exactly which intervention components and messages are most effective, how much contact time is required, and who should deliver these interventions to help most individuals substantially improve their diet or increase physical activity, and to maintain the changes for the long term. Comparative effectiveness studies are the best vehicle for addressing these types of questions; however, they fall outside the scope of the current review.

Thus, with the caveats surrounding the need to standardized measures, future research needs include:

- Replication of effective studies (e.g., PREDIMED, others showing reductions in CVD events or relatively large effects on intermediate outcomes) in the current US environment with respect to clinical care, dietary recommendations, and food intake patterns
- Long-term followup on previously completed studies examining CVD and mortality outcomes
- Large-scale implementation studies of effective interventions in health systems
- Studies examining the impact of lifestyle counseling interventions in older adults, including endpoints that are relevant to older individuals, such as subjective well-being.

## Conclusions

Medium- and high-contact multisession behavioral counseling interventions to improve diet and increase physical activity provided to people with hypertension or dyslipidemia, or who have elevated blood pressure and lipid levels, are effective in reducing CVD events, blood pressure, total cholesterol, and adiposity-related outcomes, with little to no risk of serious harm.