# Chapter 3 Results

## Description of Included Studies

Ninety-four randomized and cluster-randomized trials^56–149^ (N=52,174) of diet and physical activity counseling, reported in 227 publications^56–282^ (Appendix B), met our inclusion criteria. Twenty-nine trials reported a health (KQ1) outcome (n=23,854), 91 reported an intermediate (KQ2) outcome (n=47,951), 70 reported a behavioral (KQ3) outcome (n=43,243), and 20 reported on harms or potential harms (n=18,263). Forty-two trials were newly identified in this update.^108–137,^ ^139–144,^ ^261^

Of all included studies, 32 (34.0%) were limited to people with hypertension or elevated blood pressure, 16 (17.0%) were limited to those with dyslipidemia, and the remaining 46 (49.0%) included people with any of multiple risk factors, typically including excess weight, impaired glucose tolerance, metabolic syndrome, type 2 diabetes, smoking, and/or elevated 10-year cardiovascular risk in addition to hypertension and dyslipidemia (Table 5). Most trials recruited participants from healthcare settings: 38 (40.4%) in primary care settings and 20 (21.3%) in similar settings, such as community health clinics or health plan membership databases. Forty-three (45.7%) of the trials were conducted in the United States. The median (interquartile range [IQR]) sample size was 314 (154 to 601). One of the newly published trials was the PREDIMED trial, a large (n=7,447) multisite trial with long-term (5-year) followup conducted by Estruch and colleagues.^131^

Table 5 Summary of Study Characteristics of All Included Studies (94 Studies, n=52,174), Overall and by Risk Focus

Characteristics | All studies | | Hypertension | | Dyslipidemia | | Mixed Risk Factors
Characteristics | No. studies | % | No. studies | % | No. studies | % | No. studies | %
All studies | 94 | 100 | 32 | 100 | 16 | 100 | 46 | 100
Study design
RCT | 78 | 83.0 | 27 | 84.4 | 11 | 68.8 | 40 | 87.0
Cluster RCT | 16 | 17.0 | 5 | 15.6 | 5 | 31.2 | 6 | 13.0
Good quality rating^*^ | 19 | 20.2 | 9 | 28.1 | 1 | 6.2 | 10 | 21.7
Conducted in the US | 43 | 45.7 | 19 | 59.4 | 9 | 56.2 | 15 | 32.6
Recruitment setting
Primary care | 38 | 40.4 | 12 | 37.5 | 5 | 31.2 | 21 | 45.6
Other health care | 20 | 21.3 | 3 | 9.4 | 5 | 31.2 | 12 | 26.1
Other (e.g., media, community settings, research center, epidemiologic surveys, etc.) | 36 | 38.3 | 17 | 53.1 | 6 | 37.5 | 13 | 28.3
Risk group
Hypertension | 32 | 34.0
Dyslipidemia | 16 | 17.0
Multiple risk factors | 46 | 48.9
Medication use restrictions
Limited to those taking medications to manage risk factors | 11 | 11.7 | 9 | 28.1 | 0 | 0 | 2 | 4.4
Excluded those taking medications to manage risk factors | 21 | 22.3 | 9 | 28.1 | 10 | 62.5 | 2 | 4.4
No restrictions | 62 | 66.0 | 14 | 43.8 | 6 | 37.5 | 42 | 91.3
Control Group
No intervention/usual care | 73 | 77.7 | 22 | 68.8 | 14 | 87.5 | 37 | 80.4
Minimal intervention | 19 | 20.2 | 9 | 28.1 | 1 | 6.2 | 9 | 19.6
Attention control | 2 | 2.1 | 1 | 3.1 | 1 | 6.2 | 0 | 0
Control group instructed to maintain typical habits | 7 | 7.4 | 2 | 6.3 | 3 | 18.8 | 2 | 4.4
Median sample size (IQR), Range | 314 (154 – 601) | 24 – 7447 | 272 (197 – 762) | 24– 2382 | 222 (133 – 420) | 80 – 1197 | 342 (154 – 601) | 37 – 7447
Median % followup at 12 months or closest (IQR), Range | 86 (79 – 92) | 63 – 100 | 88 (80– 92) | 69– 100 | 88 (78– 96) | 73 – 99 | 84 (78 – 91) | 63 – 100

Abbreviations: IQR = Interquartile range; No. = Number; RCT = Randomized controlled trial; US = United States

* 12 additional studies were rated as poor quality and excluded from the review

### Included Populations

Across all trials, 49.5 percent of the participants were female and the mean (SD) age was 56.0 (8.3) years. Eleven trials had a minimum age of 50 or higher (Table 6), including PREDIMED, which had a mean age of 67 years. Among the trials reporting baseline CVD risk factor status, 62.0 percent of the participants had hypertension, 70.3 percent had dyslipidemia, 20.2 percent had diabetes, 2.8 percent had known cardiovascular disease, and 22.7 percent were current smokers. Twenty-one trials were limited to individuals with excess weight,^58,^ ^60,^ ^69,^ ^84,^ ^98,^ ^109,^ ^116,^ ^119–121,^ ^123–130,^ ^134,^ ^141,^ ^144^ and although this was not an inclusion requirement for the remaining trials, most participants in the included trials were overweight or had obesity; the mean (SD) baseline BMI was 29.8 (2.6) kg/m^2^. Of the 43 trials conducted in the United States, 16 trials (37.2%) appeared to include majority Hispanic or nonwhite samples. Overall, 19 (20.2%) focused on low-SES populations. Detailed population characteristics are available in Appendix F Table 1.

Table 6 Summary of Population Characteristics of All Included Studies (94 Studies), Overall and by Risk Factor Focus

| All studies (k=94) | | Hypertension (k=32) | | Dyslipidemia (k=16) | | Mixed Risk Factors (k=46)
Baseline Characteristic (No. studies reporting) | Weighted Mean or Percent^*^ | SD or k/K | Weighted Mean or Percent^*^ | SD or k/K | Weighted Mean or Percent^*^ | SD or k/K | Weighted Mean or Percent^*^ | SD or k/K
Age; Mean (k=92) | 56.0 | 8.3 | 52.9 (31) | 7.9 | 57.6 (16) | 8.5 | 57.3 (45) | 8.0
% of trials restricted to older adults (minimum age ≥50) | 11.7 | 11/94 | 15.6 | 5/32 | 6.2 | 1/16 | 10.9 | 5/46
Female; % (k=90) | 49.5 | 20.5 | 45.1 (31) | 18.0 | 57.2 (15) | 23.6 | 50.6 (44) | 20.7
Hypertension; % (k=61) | 62.0 | 35.5 | 62.7 (30) | 44.2 | 30.9 (8) | 21.3 | 67.0 (23) | 24.2
Systolic blood pressure; Mean (k=63) | 138.6 | 10.3 | 135.5 (28) | 10.3 | 115.0 (2) | 2.8 | 140.8 (33) | 9.5
Diastolic blood pressure; Mean (k=62) | 83.8 | 5.3 | 85.6 (30) | 5.5 | 76.0 (2) | 1.4 | 82.3 (30) | 4.4
Dyslipidemia; % (k=39) | 70.3 | 23.7 | 32.2 (5) | 10.8 | 100 (16) | 0 | 65.9 (18) | 17.3
Total cholesterol; Mean mg/dL (k=50) | 217.4 | 21.4 | 218.7 (9) | 16.7 | 254.5 (12) | 20.2 | 210.7 (29) | 14.5
Low-density lipoprotein; Mean mg/dL (k=39) | 135.9 | 18.6 | 132.0 (4) | 8.0 | 160.4 (10) | 22.4 | 131.3 (25) | 14.1
Diabetes; % (k=60) | 20.2 | 18.5 | 13.1 (17) | 16.1 | 7.5 (11) | 6.7 | 25.3 (32) | 18.8
Fasting blood glucose; Mean mg/dL (k=33) | 110.0 | 12.0 | 105.3 (5) | 9.4 | 115.7 (2) | 8.2 | 110.0 (26) | 12.3
Cardiovascular disease; % (k=51) | 2.8 | 6.1 | 3.2 (18) | 5.1 | 13.3 (10) | 8.8 | 0.6 (23) | 3.0
Current smokers; % (k=62) | 22.7 | 17.6 | 17.5 (25) | 17.0 | 17.7 (10) | 7.1 | 26.6 (27) | 18.0
BMI; Mean kg/m^2^ (k=77) | 29.8 | 2.6 | 29.8 (26) | 2.9 | 27.9 (11) | 1.9 | 30.0 (40) | 2.5
% of trials restricted to persons with excess weight | 22.3 | 21/94 | 25.0% | 8/32 | 0 | 0/16 | 28.3% | 13/46
% of trials majority Hispanic or non-white^†ǂ^ | 37.2 | 16/43 | 36.8 | 7/19 | 22.2 | 2/9 | 46.7 | 7/15
% of trials targeted low socioeconomic status population^§^ | 20.2 | 19/94 | 25.0 | 8/32 | 25.0 | 4/16 | 17.4 | 8/46

Abbreviations: IQR = Interquartile range; k = number of trials with the stated characteristics; K = total number of trials in the analysis; SD = Standard deviation; US = United States

* Mean or percent across all trials, weighted by number randomized in each trial; numbers in parentheses are the numbers of trials reporting on the pertinent characteristics

† Limited to trials conducted in the US (43 trials)

ǂ Assuming majority white, non-Hispanic if race and ethnicity were not reported

§ Described as targeting a low-resource community or any of the following (or equivalent): >20% unemployment, >30% combination of unemployed or disabled (among the working-age population), <70% high school graduates, >20% ≤100% of federal poverty level, >30% in Medicaid, recruited from a Federally Qualified Healthcare Clinic

Among the 32 trials that were limited to people with hypertension or elevated blood pressure, the mean (SD) baseline systolic and diastolic blood pressure values were 136 (10) and 86 (6) mm Hg, respectively, with 61.1 percent of participants meeting diagnostic criteria for hypertension according to study criteria. Nine of these studies (28.1%) were limited to patients taking antihypertensive medications, and nine other trials (28.1%) excluded patients taking antihypertensive medications. Four trials (n=4,659) excluded people with hypertension and limited participation to those with elevated blood pressure, with the goal of preventing progression to hypertension.^120,^ ^122,^ ^133,^ ^138^ Among the 16 trials limited to patients with dyslipidemia, baseline mean (SD) total cholesterol was 254 (20.2) mg/dL and LDL cholesterol was 160 (22) mg/dL. Ten (62.5%) of the trials in populations with dyslipidemia excluded patients who were taking lipid-lowering medications, and the remaining trials had no restrictions related to medication use. Among the 46 trials that recruited patients with any of multiple CVD risk factors, 42 (91.3%) had no restrictions related to medication use.

### Included Interventions

The 94 included trials had 120 active intervention arms (Table 7). Eighty-one (67.5%) of the interventions provided counseling that encompassed both diet and physical activity, 33 (27.5%) addressed only diet, and six (5.0%) addressed only physical activity. None of the physical activity trials focused exclusively on reducing sedentary behavior. The median (IQR) number of contacts was 12 (5–27), with an estimated 6 (2.2–15.8) hours of contact over 12 (6–18) months. Fifty-four (45.0%) of the interventions offered high-contact interventions, that is, over 6 hours of contact time with an interventionist (in person or over the phone), 59 (49.2%) offered medium-contact interventions, or an estimated 31 minutes to 6 hours of contact, and only 7 (5.8%) were low-contact interventions with 30 minutes or less of direct contact. The trials that only addressed physical activity had relatively low contact time, ranging up to an estimated 4.5 hours of contact at most.^61,^ ^87,^ ^90,^ ^94,^ ^132,^ ^140^ See Figure 2 for a graph showing the distribution of contact time by intervention target. Almost all of the interventions involved some one-on-one time with an interventionist; however, nine (7.5%) were limited to group sessions and four (3.3%) were entirely computer- and/or print-based,^97,^ ^103,^ ^123,^ ^142^ including one that tested an online training module for primary care physicians without any specific patient-facing components.^97^ The use of motivational interviewing was described in 43 (35.8%) interventions. Other common elements included typical behavior change techniques such as goal setting, problem solving, and self-monitoring. Primary care clinicians were involved in delivering 27 (22.5%) of the interventions, and primary clinicians or their staff delivered all or most of the interventions in eight (6.7%) trials.^77,^ ^80,^ ^83,^ ^97,^ ^102,^ ^119,^ ^128,^ ^129^ Other interventionists included nutritionists, registered dieticians, exercise specialists, nurses, master’s- and doctoral-level counselors trained in behavioral methods, and lifestyle coaches.

Table 7 Summary of Intervention Characteristics of All Included Studies (94 Studies, 120 Intervention Groups), Overall and by Risk Factor Focus

Characteristics | All studies; (120 groups) | | Hypertension; (50 groups) | | Dyslipidemia; (20 groups) | | Mixed Risk Factors; (50 groups)
Characteristics | No. | % | No. | % | No. | % | No. | %
Behavioral target
Diet and Physical Activity | 81 | 67.5 | 33 | 66.0 | 6 | 30.0 | 42 | 84.0
Diet only | 33 | 27.5 | 14 | 28.0 | 14 | 70.0 | 5 | 10.0
Physical Activity only | 6 | 5.0 | 3 | 6.0 | 0 | 0 | 3 | 6.0
Contact time
Low (0–30 minutes) | 7 | 5.8 | 6 | 12.0 | 0 | 0 | 1 | 2.0
Medium (31–360 minutes) | 59 | 49.2 | 18 | 36.0 | 17 | 85.0 | 24 | 48.0
High (>360 minutes) | 54 | 45.0 | 26 | 52.0 | 3 | 15.0 | 25 | 50.0
Intervention directed at
Patient (only) | 115 | 95.8 | 47 | 94.0 | 19 | 95.0 | 49 | 98.0
Provider (only) | 1 | 0.8 | 1 | 2.0 | 0 | 0 | 0 | 0
Both | 4 | 3.3 | 2 | 4.0 | 1 | 5.0 | 1 | 2.0
Primary care clinician involvement
Delivered all/most | 8 | 6.7 | 2 | 4.0 | 3 | 15.0 | 3 | 6.0
Delivered part | 19 | 15.8 | 7 | 14.0 | 2 | 10.0 | 10 | 20.0
No involvement | 84 | 70.0 | 34 | 68.0 | 15 | 75.0 | 35 | 70.0
Not described | 9 | 7.5 | 7 | 14.0 | 0 | 0 | 2 | 4.0
Type of sessions
Individual session (only) | 63 | 52.5 | 19 | 38.0 | 13 | 65.0 | 31 | 62.0
Group sessions (only) | 9 | 7.5 | 5 | 10.0 | 1 | 5.0 | 3 | 6.0
Both individual and group | 44 | 36.7 | 23 | 46.0 | 6 | 30.0 | 15 | 30.0
Tech or print-based (only) | 4 | 3.3 | 3 | 6.0 | 0 | 0 | 1 | 2.0
Included family members | 11 | 9.2 | 4 | 8.0 | 2 | 10.0 | 5 | 10.0
Motivational Interviewing | 43 | 35.8 | 14 | 28.0 | 2 | 10.0 | 27 | 54.0
Dietary recommendation *
General heart healthy, or not described | 59 | 49.2 | 19 | 38.0 | 8 | 40.0 | 32 | 64.0
Low sodium | 31 | 25.8 | 29 | 58.0 | 0 | 0 | 2 | 4.0
Fat modified | 23 | 19.2 | 5 | 10.0 | 12 | 60.0 | 6 | 12.0
DASH | 14 | 11.7 | 11 | 22.0 | 0 | 0 | 3 | 6.0
Mediterranean | 5 | 4.2 | 0 | 0 | 0 | 0 | 5 | 10.0
DPP-based approach | 5 | 4.2 | 0 | 0 | 0 | 0 | 5 | 10.0
Weight loss approach
Promoted for all | 29 | 24.2 | 13 | 26.0 | 0 | 0 | 16 | 32.0
Promoted if excess weight | 31 | 25.8 | 13 | 26.0 | 4 | 20.0 | 14 | 28.0
Not promoted | 11 | 9.2 | 5 | 10.0 | 2 | 10.0 | 4 | 8.0
Not described | 49 | 40.8 | 19 | 38.0 | 14 | 70.0 | 16 | 32.0
Equipment/Services
Pedometer | 22 | 18.3 | 7 | 14.0 | 0 | 0 | 15 | 30.0
Blood pressure monitor | 7 | 5.8 | 5 | 10.0 | 0 | 0 | 2 | 4.0
Medication management | 23 | 19.2 | 18 | 36.0 | 1 | 5.0 | 4 | 8.0
Intervention Contact | Median (IQR) | Range | Median (IQR) | Range | Median (IQR) | Range | Median (IQR) | Range
Intervention duration, months | 12 (6–18) | 1 day – 60 mo. | 14 (6-24) | 1 day-36 mo. | 8.5 (6-12) | 2-12 | 12 (6-24) | 1 day – 60 mo.
Est. contact hours | 6 (2.2-15.8) | 0-68 | 9.9 (3.2-28) | 0-59 | 2.8 (1.8-4.2) | 0.7-20 | 5.4 (2.1-12.8) | 0-68
Number of contacts^†^ | 12 (5-27) | 0-73 | 18 (8-32) | 0-60 | 6 (4-13) | 2-28 | 9 (5-20) | 0-73

Abbreviations: DASH = Dietary Approaches to Stop Hypertension; DPP = Diabetes Prevention Program; IQR = Interquartile range; SD = Standard deviation; US = United States

* Interventions may advocate multiple diet approaches (e.g., low sodium and low fat)

† Contacts involving a live interventionist; excludes print, text message, technology-only contacts

Figure 2 Distribution of Intervention Arms by Contact Time^*^ * Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min and Focus

Abbreviations: HD = healthy diet only; HD + PA = healthy diet and physical activity; min = minutes; PA = physical activity only

Figure 2 is a distribution of intervention arms by contact time (minutes) and intervention focus. The contact time is also depicted in three categories: 0 to 30 minutes (low), 31 to 360 minutes (medium), and >360 minutes (high).

Among the trials targeting people with hypertension or elevated blood pressure, the most commonly used dietary approaches were a low-sodium diet (29 of 50 groups [58.0%]) and the DASH diet (11 of 50 groups [22.0%]), which also recommends moderate or restricted sodium intake. Eighteen of these trials (36.0%) included management of antihypertensive medications, and five (10.0%) provided blood pressure monitors. Of the interventions limited to people with dyslipidemia or suboptimal lipid levels, 12 (60%) recommended a fat modified diet. Of all studies, the approach for weight loss was variable: 29 (24.2%) interventions were limited to people with excess weight and explicitly recommended weight loss for all participants, 31 (25.8%) interventions recommended weight loss for those in the sample with excess weight, and 11 interventions (9.2%) focused on improving diet and physical activity without explicitly promoting weight loss. The remaining 49 (40.8%) interventions did not report whether or for whom weight loss was promoted. Usual care was the most common type of control group (73 [77.7%] of the trials), but 7 trials instructed control group participants to maintain their usual habits.^57,^ ^58,^ ^72,^ ^87,^ ^95,^ ^121,^ ^148^ For detailed information about intervention characteristics for each trial, see Appendix F Tables 2 and 3. Table 8 lists recommended eating plans for two diets used in the included trials, the DASH diet and the Mediterranean diet.

Table 8 Daily and Weekly DASH and Mediterranean Eating Plan Goals for a 2,000-Calorie-a-Day Diet^*^

Food Group | DASH^336^; Servings | Mediterranean^131^; Servings
Grains | 6–8 per day | (not specified)
Vegetables | 4–5 per day | ≥2 (≥1 fresh vegetables)
Fruit | 4–5 per day | ≥2 to 3
Low-fat or fat-free dairy products | 2–3 per day | (not specified)
Fats and oils | 2–3 per day | Abundant use of olive oil for cooking and dressing dishes; minimize food products high in saturated fats
Sodium | ≤2,300 mg per day; (1,500 mg for even greater blood-pressure lowering benefits) | (not specified)
Alcohol | -- | ≤300 ml/day, primarily wine
Meats, poultry, and fish | 6 or less per week | ≥3 of fish or seafood per week, use chicken or rabbit rather than other red or processed meats
Nuts, seeds, dry beans, and peas | 4–5 per week | ≥3 of legumes per day; ≥1 of nuts or seeds per day
Sweets | 5 or less per week | Minimize consumption of sweets and simple carbohydrates
Other | -- | Cook at least twice per week with tomato, garlic, and onion with other aromatic herbs; dress vegetables, pasta, and rice with tomato, garlic, and onion.

Abbreviations: DASH = Dietary Approaches to Stop Hypertension; mg = milligrams; ml = milliliters

* Adapted from https://www.nhlbi.nih.gov/health-topics/dash-eating-plan. This is the reduced-sodium version of the DASH diet plan; the initial DASH diet included 3,000 mg/day of sodium (and demonstrated efficacy in reducing blood pressure in the original DASH feeding study).

The PREDIMED trial was a large trial conducted in Spain among adults age 55 to 80 years who had any of a number of CVD risk factors and did not score as “unlikely to change” according to the Stages of Change model. The trial is an important addition to this literature base, given its large sample size and length of followup. Participants in both active intervention groups first met with a dietitian to discuss individual recommendations to help them adopt the Mediterranean diet based on a dietary assessment. Next, they participated in a group educational session covering dietary goals, meal plans, shopping lists, and questions they had about the recommended diet. Participants then had quarterly visits with the dietitian, who assessed their progress, discussed dietary goals, and offered support for an estimated 20 sessions of individual diet counseling. Throughout the program, interventionists emphasized the holistic approach to lifestyle change in order to tailor the intervention to nutritional assessment and individual needs, instill a sense of empowerment, and support a sense of accomplishment for each upward step in the 14-point Mediterranean diet score. Interventionists used cognitive behavioral techniques such as goal setting, self-monitoring, feedback and reinforcement, self-efficacy enhancement, incentives, problem solving, relapse prevention, and motivational interviewing in individual and group sessions. In addition, participants received either 20 1.5-liter allotments of extra virgin olive oil (intervention group 1 [IG1]) or 20 allotments of 2,700–3,700 grams of mixed nuts (intervention group 2 [IG2]). The dietary recommendations are listed in Table 8. Also, dietitians insisted that two main meals per day should be eaten seated at a table and last more than 20 minutes. Control group participants received a brief counseling session promoting a low-fat diet and annual leaflets, and in the fourth year of the study and beyond, received quarterly invitations to individual and group-based sessions focused on low-fat diets.

### Study Quality

Among all trials, 19 (20.2%) were rated as “good” quality, and the remaining were rated as “fair.” The median (IQR) study retention was 86 percent (79%–92%) at 12 months’ followup or the closest to 12 months reported by the trial. Among those that did not receive the “good” rating, attrition was typically 15 percent or greater; important methodologic information was often missing, such as blinding of allocation and outcomes assessment, and, particularly for smaller trials, groups were not clearly comparable at baseline. The PREDIMED trial received a “fair” rating primarily due to noted protocol violations regarding enrollment of household members without randomization and inconsistent use of randomization tables. The study investigators issued a retraction of the original publication after violations were discovered with updated analyses,^193^ including extensive sensitivity analyses to explore the impact of the violations (e.g., dropping sites in which the violations had occurred) and found that effect sizes were only minimally affected. Results reported here are from the updated version of the results. Eleven trials were excluded due to quality concerns; most had either very high attrition (>40%) or very differential attrition between groups (>20%), or we had serious concerns about the baseline comparability of the groups and usually other concerns as well (e.g., failure to report randomization methods and blind, lack of information about outcomes assessment).

Adherence to the interventions was variable and reporting of adherence was very heterogeneous. In general, most trials providing data indicated that a very high proportion (typically >90%) engaged in the intervention at least minimally, and that roughly 60 to 80 percent of participants participated in more than half of the offered sessions. A few trials reported attendance rates that exceeded ~80 percent of all sessions, for all participants, for interventions involving two,^143^ three,^81^ five,^63,^ ^65,^ ^80^ six,^67^ and nine sessions.^104^

## KQ1 Do Behavioral Counseling Interventions to Improve Diet and Increase Physical Activity Improve CVD and Related Health Outcomes in Adults With Known CVD Risk Factors?

### Summary of Results

Only 29 of the 94 included studies reported health outcomes. Twelve trials^59,^ ^65,^ ^75,^ ^105,^ ^116,^ ^120,^ ^121,^ ^125,^ ^131,^ ^138,^ ^141,^ ^148^ reported CVD events with followup ranging from six months to sixteen years, and medium- or high-contact behavioral counseling was associated with lower risk of any CVD event (RR=0.80 [95% CI, 0.73 to 0.87]; 9 RCTs [n=12,551]; I^2^=0%), myocardial infarction (MI, RR=0.85 [95% CI, 0.70 to 1.02]; 6 RCTs [n=10,375]; I^2^=0%), and stroke (RR=0.52 [95% CI, 0.25 to 1.10]; 4 RCTs [n=9,800]; I^2^=0%), although the pooled effect was only statistically significant for the composite CVD events outcome (Figure 3, Table 9). Only three of these trials were included in the previous review.^59,^ ^75,^ ^105^ The PREDIMED study reported a number of cardiovascular outcomes at 5-year followup, with statistically significant reductions in stroke, incident peripheral artery disease (PAD), and all CVD events combined, but not MI (Table 10). Overall, 3.6 percent (179/4997) of PREDIMED intervention participants, compared with 4.4 percent (109/2450) of control participants, experienced a CVD event, for a 30 percent reduction in risk (HR=0.70 [95% CI, 0.55 to 0.89]).^131^ Few studies were powered for mortality, and neither individual large studies nor the pooled estimate showed a beneficial effect on mortality (pooled RR=0.89 [95% CI, 0.71 to 1.11]; 18 RCTs [n=17,939], I^2^=0%, Figure 4) at followup ranging from 6 months to 16 years. Among three large trials,^75,^ ^131,^ ^138^ all findings for both all-cause and cardiovascular-related mortality were in the direction of a greater benefit for intervention participants relative to control participants; however, results were statistically significant in only one trial.^75^ This trial was limited to men with treated hypertension and offered seven diet and physical activity counseling sessions for all participants as well as smoking cessation counseling to the 29 percent of participants who were smokers (estimated 11.5 hours of interventionist contact for non-smokers and 17.5 hours for smokers). Both all-cause mortality (RR=0.62 [95% CI, 0.42, 0.92]) and cardiovascular mortality (RR=0.56 [95% CI, 0.34, 0.92]) were reduced at 6.6-year followup.^75^ A variety of patient-reported subjective well-being measures were reported in eleven trials, but group differences were generally very small and statistically nonsignificant.

Figure 3 CVD Events (KQ1)

Abbreviations: CG = control group; CI = confidence interval; CVD = cardiovascular disease; IG = intervention group; KH = Knapp-Hartung adjustment; MI = myocardial infarction; REML = restricted maximum likelihood; RR = risk ratio; TOHP I CRG = The Trials of Hypertension Prevention – Phase I Collaborative Research Group; TOHP II CRG = The Trials of Hypertension Prevention – Phase II Collaborative Research Group

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Figure 3 is a forest plot of the pooled risk ratios of stroke, MI, and CVD events, comparing behavioral counseling interventions to the controls. This figure is discussed in the Results section.

Table 9 Summary of Pooled Analyses of CVD Events

CVD Outcome | Pooled RR (95% CI) | N | No. Studies | I^2^ | Tau^2^
Stroke | 0.52 (0.25, 1.10) | 9,800 | 4 | 0 | 0.1
Myocardial Infarction | 0.85 (0.70, 1.02) | 10,375 | 6 | 0 | 0.0
CVD Events | 0.80 (0.73, 0.87) | 12,551 | 9 | 0 | 0.0
CVD Events sensitivity analysis: Dropping PREDIMED | 0.79 (0.70, 0.90) | 5,104 | 8 | 0 | 0.0

Abbreviations: CI = confidence interval; CVD = cardiovascular disease; No. = number; PREDIMED = Primary Prevention of Cardiovascular Disease with a Mediterranean Diet; RR = risk ratio

Table 10 PREDIMED CVD Events: Hazard Ratios and Number of CVD Events for Each Group Reported by the PREDIMED131 Study (n=7,447)

Outcome | Group | Intervention; n/N (%) | Control; n/N (%) | HR (95% CI)
Stroke | Both | 81/4997 (1.6) | 58/2450 (2.4) | 0.58 (0.42 to 0.82)
Myocardial Infarction | Both | 68/4997 (1.4) | 38/2450 (1.6) | 0.80 (0.53 to 1.21)
Incident PAD | Olive oil | 18/2539 (0.7) | 45/2444 (1.8) | 0.36 (0.20 to 0.62)
Incident PAD | Nuts | 26/2452 (1.1) | 45/2444 (1.8) | 0.52 (0.32 to 0.86)
Total CVD Events | Both | 179/4997 (3.6) | 109/2450 (4.4) | 0.70 (0.55 to 0.89)

Abbreviations: CI = confidence interval; CVD = cardiovascular disease; HR = hazard ratio; PAD = peripheral artery disease

Figure 4 All-Cause Mortality (KQ1)

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; KH = Knapp-Hartung adjustment; REML = restricted maximum likelihood; RR = risk ratio; TOHP I CRG = The Trials of Hypertension Prevention – Phase I Collaborative Research Group; TOHP II CRG = The Trials of Hypertension Prevention – Phase II Collaborative Research Group

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Figure 4 is a forest plot of the pooled risk ratio of all-cause mortality events, comparing behavioral counseling interventions to the controls with no intervention. This figure is discussed in the Results section.

### Detailed Results by Outcome

#### CVD Events

CVD events were reported in 12 trials (Figure 3, Appendix G Figures 1 and 2, Appendix H Table 1).^59,^ ^75,^ ^105,^ ^116,^ ^120,^ ^121,^ ^125,^ ^131,^ ^138,^ ^141,^ ^148^ Only three of these trials were included in the previous review.^59,^ ^75,^ ^105^ Among the eight trials reporting a composite outcome of any CVD event, the pooled effect showed lower risk among those participating in a behavioral counseling intervention (pooled RR=0.80 [95% CI, 0.73 to 0.87]; 9 RCTs [n=12,551]; I^2^=0%, Figure 3, Table 9). A sensitivity analysis dropping outcomes assessed prior to 2 years of followup showed almost identical results (pooled RR=0.80 [95% CI, 0.72 to 0.88]; 7 RCTs [n=12,105]; I^2^=0%). Populations in these trials were recruited based on hypertension or the presence of multiple risk factors, and control group event rates suggest that these trials included populations with a broad range of underlying CVD risk. For example, in PREDIMED, 4.4 percent of the control group experienced an event over 5-year followup. Considering that 49 percent of participants had diabetes and 47 percent were obese, event rates may be lower than expected; however, 49 percent were on antihypertensive medication and 40 percent were on statin-lowering medication at baseline.^131^ On the other hand, in the trial by Fagerberg, 32.9 percent of the control group experienced a CVD event over 6.6 years of followup. Thirteen percent of participants in this study had a history of a prior CVD event, 29 percent were smokers, and mean BP was 155/91 mm Hg despite participants having taken multiple antihypertensive medications for a decade or more.^75^ The behavioral counseling interventions employed in these trials reporting CVD events were heterogeneous in terms of dietary messages and did not consistently include a PA component. For example, the PREDIMED trial^131^ was based on the Mediterranean diet, and the Fagerberg trial^75^ promoted a fat-modified diet consistent with older NCEP guidelines at the time; additionally, it offered a robust 6-session smoking cessation component. In contrast, two of three intervention groups in the TONE trial involved sodium reduction.^105^ Among trials reporting CVD events, three^105,^ ^116,^ ^141^ were weight loss trials, three^120,^ ^121,^ ^131^ made no mention of weight loss (although one of these had no observed CVD events^121^), and two recommended weight loss for participants with excess weight.^75,^ ^138^

Pooled analysis of MI (RR=0.85 [95% CI, 0.70 to 1.02]; 6 RCTs [n=10,375]; I^2^=0%) and stroke (RR=0.52 [95% CI, 0.25 to 1.10]; 4 RCTs [n=9,800]; I^2^=0%) showed a statistically non-significant lower risk of events in the intervention groups. The PREDIMED trial accounted for approximately two-thirds of the individuals included in these analyses, and reported hazard ratios for a number of cardiovascular outcomes at 5-year followup (Table 10). PREDIMED reported statistically significant reductions in stroke (1.6% in intervention group vs. 2.4% in control group, HR=0.58 [95% CI, 0.42 to 0.82]), incident PAD (0.7 to 1.1% in the intervention groups vs. 1.8% in the control group, HR=0.36 to 0.52, [95% CI, range 0.20 to 0.86 for both intervention groups), and all CVD events combined (3.6% in the intervention groups vs. 4.4% in the control group, HR=0.70 [95% CI, 0.55 to 0.89]), but not MI (1.4% in the intervention groups vs. 1.6% in the control group, HR=0.80 [95% CI, 0.53 to 1.21]).^131^ The overall beneficial effect on any CVD event was maintained in a sensitivity analysis dropping the PREDIMED trial from the meta-analysis (pooled RR=0.79 [95% CI, 0.70 to 0.90], 8 RCTs [n=5,104], Table 9). Of all trials reporting CVD outcomes, other outcomes reported included transient ischemic attacks, arrhythmias, angina, claudication, congestive heart failure, and “other CVD event.” Most of these outcomes were hampered by small numbers of events, however, and results were wide-ranging, typically very imprecise (i.e., very wide confidence intervals), and usually not statistically significant.

PREDIMED also reported on the consistency of effects on any CVD event (their primary endpoint) among a number of patient subgroups.^131^ They found that the effect was larger for people with a baseline BMI of 30 or more (HR=0.51 [95% CI, 0.37 to 0.71]) than those with a BMI of 25 to 30 (HR=1.04 [95% CI, 0.71 to 1.54]) or less than 25 (HR=0.69 [95% CI, 0.29 to 1.67], interaction p=0.05). In addition, intervention effects were larger for those with hypertension (HR=0.65 [95% CI, 0.50 to 0.84]) and dyslipidemia (HR=0.60 [95% CI, 0.44 to 0.80]) at baseline compared with their counterparts (no baseline hypertension HR=1.25 [95% CI, 0.64 to 2.45], no baseline dyslipidemia HR=0.95 [95% CI, 0.64 to 1.42], interaction p=0.06 for both). They found no differences in the impact of the intervention on effect size by sex, age (<70 vs. ≥70), presence of diabetes at baseline, smoking status (never vs. ever smokers), family history of premature CHD, waist circumference (<median vs. ≥median), or baseline Mediterranean diet adherence score (<10 vs. ≥10).

#### Mortality

Eighteen trials of medium and high-contact interventions reported all-cause mortality (Figure 4, Appendix H Table 2), and the pooled effect did not demonstrate a benefit (pooled RR=0.89 [95% CI, 0.71 to 1.11], 18 RCTs [n=17,939], I^2^=0%) at followup ranging from 6 months to 16 years. Among these 18 studies are three that reported that there were no deaths,^110,^ ^126,^ ^127^ and other studies had a limited number of deaths, likely due to trial duration and sample sizes. Only three had sufficient sample size and time to followup to have more than 10 deaths per study group.^75,^ ^131,^ ^138^ A sensitivity analysis dropping mortality outcomes assessed prior to 2 years of followup showed similar results (pooled RR=0.85 [95% CI, 0.67 to 1.07]; 10 RCTs [n=14,017]; I^2^=3%).

The most recent of the large trials was PREDIMED.^131^ PREDIMED found no difference between groups in all-cause mortality after 5 years, but did show slightly reduced cardiovascular-related mortality, with 1.1 percent of intervention participants dying (57/4,997), compared with 1.2 percent of control participants (30/2,450). However, this difference was not statistically significant (HR=0.83 [95% CI, 0.54 to 1.29]).^131^ The trial with the largest effect, offering a high-contact intervention limited to 508 men with treated hypertension, found statistically significant reductions in mortality after 6.6 years for both all causes (16.2% [41/253] of intervention participants vs. 25.1% [64/255] of control participants, RR=0.62 [95% CI, 0.42 to 0.92]) and cardiovascular-related mortality (9.5% [24/253] vs. 16.5% [42/255], RR=0.56 [95% CI, 0.34 to 0.92]), but smaller statistically nonsignificant findings at 3.3 years’ followup.^75^ This trial also offered smoking cessation counseling to the 29 percent of participants who were smokers. The third large trial to examine mortality was the Trial of Hypertension Prevention-II (TOHP-II) trial among adults younger than age 50 with elevated blood pressure who were 110 to 165 percent of their ideal weight, offering sodium reduction and/or weight loss interventions in a 2x2 factorial design.^138^ TOHP-II found no group differences for all-cause mortality at 16-year followup (RR=0.90 [95% CI, 0.52 to 1.52], 2.1% [25/1,191] deaths in the intervention group vs. 2.4% [28/1,191] in the control group) comparing sodium reduction vs. no sodium reduction.

#### Patient-Reported Outcomes of Subjective Well-Being

Eleven^59,^ ^62,^ ^68,^ ^75,^ ^103,^ ^109,^ ^114,^ ^126,^ ^148,^ ^149,^ ^224^ trials reported some type of patient-reported health outcome, including SF-36 or SF-12 scores;^59,^ ^68,^ ^126,^ ^148,^ ^224^ Minor Symptoms Evaluation Profile measures of vitality, contentment, and sleep;^75^ the General Health Questionnaire;^62^ the EQ-5D quality of life measure;^109,^ ^114,^ ^224^ the European Quality of Life instrument,^149^ and quality-adjusted life years (Appendix H Table 3).^103^ Although most results favored the intervention groups in absolute differences, very few differences were statistically significant and most group differences in change were less than one point. The single measure that showed a benefit among multiple intervention groups or timepoints was the SF-36 vitality score in a single study of a 33-session intervention promoting either the DASH diet or a low-sodium diet for patients with untreated elevated blood pressure or hypertension.^59^ This trial reported 1.8- to 3.6-point greater improvement in the intervention groups on a 100-point scale at 6- and 18-month followup.

## KQ2 Do Behavioral Counseling Interventions to Improve Diet and Increase Physical Activity Improve Intermediate Outcomes in Adults With Known CVD Risk Factors?

### Summary of Results

Behavioral counseling interventions were associated with small, statistically significant reductions in continuous measures of blood pressure, total cholesterol, fasting glucose, and adiposity-related outcomes at 12 to 24 months’ followup. There was a mean 1.8/1.2 mm Hg greater reduction in blood pressure in intervention than control groups after 12 to 24 months (pooled systolic blood pressure [SBP]=−1.8 [95% CI, −2.5 to −1.1]; 42 RCTs [44 effects, n=14,580]; I^2^=37%; pooled diastolic blood pressure [DBP]=−1.2 [95% CI, −1.6 to −0.8]; 38 RCTs [40 effects, n=13,098]; I^2^=33%; Figure 5, Table 11). In addition, in trials reporting incidence of hypertension, intervention groups had a 26 percent lower risk of onset (pooled RR=0.74 [95% CI, 0.58 to 0.94]; 5 RCTs [n=2,707]; I^2^=12%) (Table 12). For lipids, the pooled average mg/dL difference in change between groups was −3.5 for total cholesterol, −2.1 for LDL, and 0.6 for HDL (total cholesterol MD=−3.5 [95% CI, −5.6 to −1.4]; 36 RCTs [38 effect, n=11,414]; I^2^=66%; LDL=−2.1 [95% CI, −4.1 to −0.2]; 30 RCTs [32 effects, n=8,894]; I^2^=56%; HDL= 0.6 [95% CI, 0.2 to 1.0]; 32 RCTs [34 effects, n=8,974]; I^2^=34%; Figures 9 and 10, Table 11). The impact on diabetes was mixed in four trials and the pooled effect was not statistically significant (RR=0.82 [95% CI, 0.66 to 1.03]; 5 effects [4 RCTs, n=7,848]; I^2^=19%; Figure 13, Table 12). Among 20 trials reporting on fasting glucose, there was an average 2.3 mg/dL greater reduction in fasting blood glucose in the intervention than the control groups at 12 to 24 months’ followup (MD=−2.3 [95% CI, −3.6 to −1.0]; 20 RCTs [22 effects, n=5,950]; I^2^=82%, Figure 12, Table 11). At 12 to 24 months, the intervention groups showed slightly greater reductions in all three adiposity-related measures examined: pooled BMI MD=−0.5 kg/m^2^ (95% CI, −0.7 to −0.3); 30 RCTs (n=9,909); I^2^=83%; pooled weight=−1.6 kg (95% CI, −2.1 to −1.1); 37 RCTs (n=16,345); I^2^=88%; pooled waist circumference=−1.7 cm (95% CI, −2.4 to −1.1); 23 RCTs (n=11,708); I^2^=87%; Figure 15, Table 11). Very few trials offered low-contact interventions, and there was no clear difference in effect size between medium- and high-contact interventions.

Figure 5 Systolic and Diastolic Blood Pressure Summary (KQ2)

Abbreviations: CI = confidence interval; DBP = diastolic blood pressure; Diff. = difference; studies (including studies reported by subgroups); mm Hg = millimeter of mercury; SBP = systolic blood pressure

Figure 5 is a summary forest plot of the pooled change in systolic and diastolic blood pressure (mm Hg) by risk group and followup category. This figure is discussed in the Results section.

Table 11 Pooled Difference in Mean Change for Blood Pressure, Lipids, Glucose, and Adiposity-Related Outcomes at 12 to 24 Months’ Followup

Outcome | Study population risk focus | Effect size (95% CI)^*^ | K | N | I^2^ | Median (IQR) change, IG | Median (IQR) change, CG
SBP (mm Hg) | All available trials | −1.81 (−2.49, −1.13) | 44 | 14580 | 37.3% | −5.1 (−7.6, −1.7) | −2.9 (−6.0, −0.2)
SBP (mm Hg) | Hypertension | −1.97 (−2.59, −1.36) | 16 | 5769 | 7.8% | −5.8 (−8.6, −3.9) | −3.1 (−7.5, −1.8)
DBP (mm Hg) | All available trials | −1.16 (−1.57, −0.75) | 40 | 13098 | 32.5% | −3.4 (−4.6, −0.7) | −1.6 (−3.7, −0.2)
DBP (mm Hg) | Hypertension | −1.06 (−1.75, −0.38) | 15 | 5461 | 43.4% | −4.4 (−6.0, −2.2) | −3.2 (−5.0, −0.3)
TC (mg/dL) | All available trials | −3.48 (−5.57, −1.38) | 38 | 11414 | 65.9% | −7.1 (−12.4, −2.3) | −4.4 (−6.6, 0)
TC (mg/dL) | Dyslipidemia | −3.80 (−7.23, −0.37) | 9 | 2001 | 24.0% | −8.8 (−15.8, −7.6) | −8.6 (−12.8, −5.0)
LDL-C (mg/dL) | All available trials | −2.14 (−4.08, −0.21) | 32 | 8894 | 55.9% | −4.8 (−11.2, −1.5) | −3.9 (−7.7, 0.1)
LDL-C (mg/dL) | Dyslipidemia | −4.12 (−8.81, 0.57) | 7 | 1271 | 36.3% | −11.0 (−19.6, −7.3) | −10.4 (−15.4, −4.6)
HDL-C (mg/dL) | All available trials | 0.58 (0.19, 0.98) | 34 | 8974 | 33.7% | 0.8 (0.3, 2.6) | 0.5 (0, 1.7)
HDL-C (mg/dL) | Dyslipidemia | −0.44 (−1.26, 0.37) | 6 | 1033 | 0.0% | 0.4 (0, 3.1) | 1.0 (0.4, 2.7)
FBG (mg/dL) | All available trials | −2.33 (−3.64, −1.02) | 22 | 5950 | 82.5% | −2.9 (−5.7, −0.4) | 0.2 (−2.0, 3.6)
Weight (kg) | All available trials | −1.59 (−2.06, −1.12) | 37 | 16345 | 88.1% | −1.5 (−2.8, −0.8) | −0.3 (−1.0, 0)
Weight (kg) | Weight loss trials^†^ | −2.55 (−3.40, −1.70) | 12 | 3193 | 66.9% | −1.9 (−3.6, −1.2) | −0.6 (−1.1, 0)
BMI (kg/m^2^) | All available trials | −0.46 (−0.66, −0.26) | 30 | 9909 | 83.3% | −0.5 (−0.9, −0.2) | −0.1 (−0.4, 0)
BMI (kg/m^2^) | Weight loss trials^†^ | −0.91 (−1.43 to −0.40) | 7 | 1520 | 78.0% | −1.0 (−1.6, −0.6) | −0.3 (−0.4, −0.2)
Waist circumference (cm) | All available trials | −1.75 (−2.44, −1.06) | 23 | 11708 | 87.3% | −2.2 (−3.7, −0.8) | −0.9 (−1.8, −0.2)
Waist circumference (cm) | Weight loss trials^†^ | −2.50 (−3.97 to −1.03) | 8 | 1654 | 85.4% | −2.9 (−4.6, −1.4) | −1.2 (−2.3, −0.7)

Abbreviations: BMI = body mass index; CG = control group; CI = confidence interval; cm = centimeters; DBP = diastolic blood pressure; FBG = fasting blood glucose; IG = intervention group; IQR = interquartile range; HDL-C = high-density lipoprotein cholesterol; K = number of effects analyzed; N = number of participants analyzed; kg = kilograms; kg/m^2^ = kilograms per meter squared; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; mm Hg = millimeters of mercury; TC = total cholesterol

* Between-group mean difference in change unless otherwise specified

† Weight loss trials are those that required all participants to have a specified level of excess weight at baseline and had an explicit goal of weight loss for all participants.

Table 12 Pooled Results for Group Differences in the Proportion With Hypertension, Meeting Blood Pressure Goal, Diabetes, and Metabolic Syndrome, for All Trials Reporting Each Outcome

Outcome | RR (95% CI) | K | N | I^2^ | Median (IQR) percent, IG | Median (IQR) percent, CG | Median (IQR) Absolute risk difference
Hypertension incidence | 0.74 (0.58, 0.94) | 5 | 2707 | 12% | 21.7 (8.0, 31.9) | 21.1 (11.2, 39.2) | −5.3 (−6.4, −3.1)
Hypertension prevalence | 0.98 (0.89, 1.08) | 5 | 5633 | 56% | 24.1 (18.2, 84.9 | 31.9 (26.1, 89.2) | −4.5 (−8.9, −0.6)
Meeting blood pressure goal | 1.13 (1.04, 1.23) | 13 | 6485 | 70% | 64.9 (48.6, 79.4) | 60.9 (43.0, 75.0) | 5.0 (1.0, 8.1)
Diabetes incidence | 0.82 (0.66, 1.03) | 5 | 7848 | 0% | 7.4 (6.9, 8.3) | 8.8 (7.4, 16.3) | −1.6 (−5.5, −0.5)
Metabolic syndrome | 0.78 (0.53, 1.16) | 5 | 1847 | 85% | 54.5 (44.3, 64.8) | 63.0 (50.2, 68.6) | −2.8 (−22.6, −0.2)

Abbreviations: CG = control group; CI = confidence interval; cm = centimeters; IG = intervention group; IQR = interquartile range; K = number of effects analyzed; N = number of participants analyzed

### Detailed Results by Outcome

#### Blood Pressure

Some type of blood pressure outcome was reported by 67 trials (n=36,079), most commonly mean change in systolic and diastolic blood pressure (Appendix H Tables 5 and 6). Among all trials reporting these outcomes at 12 to 24 months, the pooled average difference between groups in blood pressure reductions was 1.8/1.2 mm Hg (pooled SBP mean difference between groups [MD]=−1.8] [95% CI, −2.5 to −1.1]; 42 RCTs [44 effects, n=14,580]; I^2^=37%; pooled DBP=−1.2 [95% CI, −1.6 to −0.8]; 38 RCTs [40 effects, n=13,098]; I^2^=33%; Figure 5, Table 11, Appendix G Figures 3 and 4). Among all intervention arms and timepoints in the 12- to 24-month range, the median reductions in blood pressure at 12 to 24 months were 5.1/3.4 mm Hg in the intervention groups and 2.9/1.6 mm Hg in control groups, with a baseline mean blood pressure of 139/84 mm Hg. Effects were similar when limited to studies that only recruited participants with hypertension or elevated blood pressure, which also had similar mean baseline blood pressure (136/86 mm Hg).

Meta-regressions and subgroup analyses on SBP (the most commonly reported blood pressure outcome) demonstrated generally consistent effects among studies with various characteristics, including study quality, setting, baseline weight selection and weight loss approach, some key intervention characteristics, and socioeconomic status (Figure 6). There was no indication that smaller studies were associated with larger effect sizes (Egger’s test of bias=0.01, p=0.99).

Figure 6 Systolic Blood Pressure Subgroup Analyses (KQ2)

Abbreviations: BP = blood pressure; CI = confidence interval; Diff. = difference; K = number of studies (including studies reported by subgroups); KH = Knapp-Hartung adjustment; mm Hg = millimeters of mercury; NOS = not otherwise specified; NR = not reported; REML = restricted maximum likelihood; SES = socioeconomic status

*Bivariate P-values derived from Q test of between-subgroups heterogeneity (based on random effects model)

^†^For this analysis, the most comprehensive or highest dose intervention group was selected if a study had multiple intervention groups, and the followup timepoint closest to 12 months was selected of there were multiple followup assessments

Figure 6 is a forest plot of the subgroup analyses on systolic blood pressure (mm Hg) demonstrating the effects with various characteristics, including study quality, setting, age group, baseline weight selection and weight loss approach, some key intervention characteristics, and socioeconomic status. For these analyses, the most comprehensive or highest dose intervention group was selected if a study had multiple intervention groups, and the followup timepoint closest to 12 months was selected if there were multiple followup assessments. The biavariate p-values are derived from the Q test of between-groups heterogeneity.

Some trials reported the number of participants who met the blood pressure goal established for the study (typically SBP<140 mm Hg, DBP<90 mm Hg, or both) or the percent meeting criteria for hypertension at followup (Table 12). For incidence of hypertension, the pooled RR reflected a 26 percent lower likelihood of hypertension onset at 6 to 36 months’ followup (RR=0.74 [95% CI, 0.58 to 0.94]; 5 RCTs [n=2,707]; I^2^=12%) (Figure 7). Three^120,^ ^122,^ ^138^ of the five^59,^ ^62,^ ^120,^ ^122,^ ^138^ trials reporting hypertension incidence were limited to people with elevated blood pressure (without hypertension) with the goal of preventing progression, and the other trials included both patients who did and did not meet criteria for hypertension.^59,^ ^62^ Of all available timepoints and intervention groups, the median (interquartile range [IQR]) percent with incident hypertension was 21.7 percent (8.0% to 31.9%) in the intervention groups and 21.1 percent (11.2% to 39.2%) in the control groups. The median (IQR) absolute risk difference was −5.3 (−6.4 to −3.1).

Figure 7 Hypertension Incidence and Prevalence (KQ2)

Abbreviations: CI = confidence interval; HD = healthy diet; HD + PA = healthy diet and physical activity; K = number of studies (including studies reported by subgroups); KH = Knapp-Hartung adjustment; REML = restricted maximum likelihood; RR = risk ratio; TOHP I CRG = The Trials of Hypertension Prevention – Phase I Collaborative Research Group; TOHP II CRG = The Trials of Hypertension Prevention – Phase II Collaborative Research Group

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Figure 7 is a forest plot of the pooled risk ratios of hypertension incidence and prevalence, comparing behavioral counseling interventions to the controls. This figure is discussed in the Results section.

Similarly, there was a 14 percent higher likelihood of meeting the study BP goal at followup among intervention participants (pooled RR=1.13 [95% CI, 1.04 to 1.23]; 13 RCTs [n=6,485]; I^2^=70%) (Figure 8). The median (IQR) percent meeting the study goal at followup was 64.9 percent (48.6% to 79.4%) in the intervention groups and 60.9 percent (43.0% to 75.0%) in the control groups with a median (IQR) absolute risk difference of 5.0 (1.0 to 8.1). Most of the trials reporting this outcome were limited to patients with existing hypertension and included medication management as an intervention component. Thus, the blood pressure goal was achieved through a combination of lifestyle modification and optimized medication use for most of these trials. The pooled effect for five trials reporting the prevalence of hypertension at 12 to 60 months’ followup (as opposed to the incidence of hypertension) did not show group differences (pooled RR=0.98 [95% CI, 0.89 to 1.08]; 5 RCTs [n=5,633]; I^2^=56%).

Figure 8 Blood Pressure at Goal (KQ2)

Abbreviations: CG = control group; CI = confidence interval; FUP = followup; hrs = hours; IG = intervention group; K = number of studies; KH = Knapp-Hartung adjustment; Med mgmt. = medication management; mo. = months; REML = restricted maximum likelihood; RR = risk ratio

Figure 8 is a forest plot depicting the pooled risk ratios of meeting blood pressure goals, comparing behavioral counseling interventions to the controls.

#### Lipids

Total cholesterol, LDL, or HDL were reported by 59 trials (n=30,245; Appendix H Tables 7 and 8). Among all trials reporting these outcomes at 12 to 24 months, the pooled average mg/dL difference in change between groups was −3.5 for total cholesterol, −2.1 for LDL, and 0.6 for HDL (total cholesterol MD=−3.5 [95% CI, −5.6 to −1.4]; 36 RCTs [38 effects, n=11,414]; I^2^=66%; LDL=−2.1 [95% CI, −4.1 to −0.2]; 30 RCTs [32 effects, n=8,894]; I^2^=56%; HDL= 0.6 [95% CI, 0.2 to 1.0]; 32 RCTs 34 effect, [n=8,974]; I^2^=34%; Figures 9 and 10, Table 11). Among all intervention arms and timepoints in the 12- to 24-month range, the median (IQR) reduction in total cholesterol at 12 to 24 months was 7.1 (12.4 to 2.3) mg/dL in the intervention groups and 4.4 (6.6 to 0) in control groups, from an average baseline of 217 mg/dL. Effects were similar when limited to studies that only recruited participants with dyslipidemia. Pooled effects for LDL change were slightly smaller than for total cholesterol and not statistically significant in the near-term (<12 months followup) nor when limited to studies that only recruited participants with dyslipidemia. Most pooled effects did not show group differences in HDL change from baseline to followup and were generally of a magnitude that is unlikely to be of clinical importance.

Figure 9 Total Cholesterol and Low-Density Lipoprotein Cholesterol Summary (KQ2)

Abbreviations: CI = confidence interval; Diff. = difference; K = number of studies (including studies reported by subgroups); LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; TC = total cholesterol

Figure 9 is a summary forest plot of the pooled change in total cholesterol (mg/dL) and low-density lipoprotein cholesterol (mg/dL) by risk group and followup category. This figure is discussed in the Results section.

Figure 10 High-Density Lipoprotein Cholesterol (KQ2)

Abbreviations: CI = confidence interval; Diff. = difference; HDL = high-density lipoprotein cholesterol; K = number of studies (including studies reported by subgroups); mg/dL = milligrams per deciliter

Figure 10 summary forest plot of the pooled change in high-density lipoprotein cholesterol (mg/dL) by risk group and followup category. This figure is discussed in the Results section.

Meta-regressions and subgroup analyses of total cholesterol (the most commonly reported lipid outcome [46 RCTs]) identified some statistically significant or nearly statistically significant bivariate relationships, with larger effects found in trials that were conducted in older adults (p<0.01), were conducted outside of the United States (p=0.04), and included medication management as an intervention component (p=0.06); smaller effects were found in weight loss trials (p=0.01) and those that targeted low-income populations (p=0.01) (Figure 11). However, only medication management (p=0.003) and older adult population (p=0.03) were statistically significant in models controlling for the other population or intervention characteristics showing bivariate relationships. Larger effects were seen when medication management was included and trials were limited to older adults. There was no indication that small studies were associated with larger effect sizes (Egger’s test of bias=−0.7, p=0.29).

Figure 11 Total Cholesterol Subgroup Analyses (KQ2)

Abbreviations: CI = confidence interval; CG = control group; Diff. = difference; IG = intervention group; K = number of studies (including studies reported by subgroups); KH = Knapp-Hartung adjustment; mg/dL = milligrams per deciliter; NR = not reported; REML = restricted maximum likelihood; SES = socioeconomic status; TC = total cholesterol

*Bivariate P-values derived from Q test of between-subgroups heterogeneity (based on random effects model)

^†^For this analysis, the most comprehensive or highest dose intervention group was selected if a study had multiple intervention groups, and the followup timepoint closest to 12 months was selected of there were multiple followup assessments

Figure 11 is a forest plot of the subgroup analyses on total cholesterol (mg/dL) demonstrating the effects with various characteristics, including study quality, setting, age group, baseline weight selection and weight loss approach, some key intervention characteristics, and socioeconomic status. For these analyses, the most comprehensive or highest dose intervention group was selected if a study had multiple intervention groups, and the followup timepoint closest to 12 months was selected if there were multiple followup assessments. The biavariate p-values are derived from the Q test of between-groups heterogeneity.

#### Glucose and Metabolic Outcomes

The proportion of participants with diabetes in the included trials ranged from 0 (in 27 trials) to 49 percent. Per our inclusion and exclusion criteria, we excluded trials if 50 percent or more of participants had impaired glucose tolerance or diabetes. Fasting glucose, diabetes incidence, or metabolic syndrome was reported by 31 of the included trials (n=21,521; Appendix H Tables 9 and 10). There was an average 2.3 mg/dL greater reduction in fasting blood glucose in the intervention than the control groups at 12 to 24 months’ followup (MD=−2.3 [95% CI, −3.6 to −1.0]; 20 RCTs [22 effects, n=5,950]; I^2^=82%, Figure 12, Table 11). Four trials reported diabetes incidence,^62,^ ^65,^ ^100,^ ^131^ and the pooled effect using calculated RRs did not show an association between behavioral counseling and reduced diabetes onset (pooled RR=0.82 [95% CI, 0.66 to 1.02]; 5 effects [4 RCTs, n=7,848]; I^2^=0%, Figure 13, Table 12). However, interventions in two trials reduced diabetes incidence, either as calculated based on unadjusted results as shown in the forest plot^65,^ ^131^ or in study-reported adjusted analyses.^131^ PREDIMED reported a 40 percent reduction in the risk of incident diabetes in the intervention group that was given olive oil (HR=0.60 [95% CI, 0.43 to 0.85]; 6.9% in the intervention group, 8.8% in the control group), but the effect was slightly smaller and not statistically significant for the group that was given nuts (HR=0.82 [95% CI, 0.61 to 1.10]; 7.4% in the intervention group, 8.8% in the control group) after 48 months of observation.^131^ Another small trial found a large effect after only 12 months (OR=0.23 [95% CI, 0.06 to 0.85]; 1.8% in the intervention group, 7.2% in the control group), but included a total of only 15 cases of incident diabetes.^65^ Calculated RRs in the other trials showed no impact: 0.98 (95% CI, 0.47 to 0.07)^62^ and 1.03 (95% CI, 0.67 to 1.59).^100^ Metabolic syndrome incidence or prevalence was reported in five trials; the effects were wide-ranging, PREDIMED showed no benefit, and the pooled effect did not demonstrate an association (pooled RR=0.78 [95% CI, 0.53 to 1.16]; 5 effects [5 RCTs, n=1,847]; I^2^=85%) (Figure 14, Table 12).

Figure 12 Fasting Blood Glucose (KQ2)

Abbreviations: CI = confidence interval; Diff. = difference; FBG = fasting blood glucose; K = number of studies (including studies reported by subgroups); mg/dL = milligrams per deciliter

Figure 12 is a forest plot of the pooled change in fasting blood glucose (mg/dL) by risk group and followup category. This figure is discussed in the Results section.

Figure 13 Incident Diabetes (KQ2)

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; Int arm = intervention arm; KH = Knapp-Hartung adjustment; REML = restricted maximum likelihood; RR = risk ratio

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Figure 13 is a forest plot depicting the pooled risk ratio of incidence of diabetes in persons with multiple risk factors, comparing behavioral counseling interventions to the controls. This figure is discussed in the Results section.

Figure 14 Metabolic Syndrome Incidence and Prevalence (KQ2)

Abbreviations: CG = control group; CI = confidence interval; Int arm = intervention arm; HD = healthy diet; HD + PA = healthy diet and physical activity; KH = Knapp-Hartung adjustment; METS = metabolic syndrome; REML = restricted maximum likelihood; RR = risk ratio

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Figure 14 is a forest plot depicting the pooled risk ratio of metabolic syndrome incidence or prevalence in persons with multiple risk factors, comparing behavioral counseling interventions to the controls. This figure is discussed in the Results section.

#### Weight/Adiposity

Weight, BMI, or waist circumference was reported by 72 trials (n=35,228; Appendix H Tables 11 and 12). At 12 to 24 months, the intervention groups were associated with slightly greater reductions in all three measures: pooled BMI MD=−0.5 kg/m^2^ (95% CI, −0.7 to −0.3); 30 RCTs (n=9,909); I^2^=83%; pooled weight=−1.6 kg (95% CI, −2.1 to −1.1); 35 RCTs (37 effects, n=16,345); I^2^=88%; pooled waist circumference=−1.8 cm (95% CI, −2.4 to −1.1); 22 RCTs (23 effects, n=11,708); I^2^=87%; Figure 15, Table 11). Among all intervention arms and timepoints in the 12- to 24-month range, the median (IQR) change in BMI at 12 to 24 months was −0.5 kg/m^2^ (−0.9 to −0.2) in the intervention groups and −0.1 (−0.4 to 0) in control groups. For weight, median (IQR) intervention group effect wase −1.5 kg (−2.8 to −0.8), compared with −0.3 (−1.0, 0.0) in the control groups. The median (IQR) change in waist circumference was −2.2 cm (−3.7 to −0.8) in the intervention groups and −0.9 (−1.8 to −0.2) in the control groups (Table 11). Effects were larger in weight loss trials (that is, trials in which participants were only included if they had excess weight and weight loss was an explicit goal of the trial), where the pooled mean between-group difference in weight change was −2.6 kg (95% CI, −3.4 to −1.7; 12 RCTs [n=3,193]; I^2^=67%), BMI was −0.9 kg/m^2^ (95% CI, −1.4 to −0.4; 7 RCTs [n=1,520]; I^2^=78%), and waist circumference was −2.5 cm (95% CI, −4.0 to −1.0; 8 RCTs [n=1,654]); I^2^=85%) (Table 11). Effects were intermediate among those that had a mix of people with and without excess weight and only recommended weight loss for those with excess weight (e.g., weight change: −1.4 kg (95% CI, −2.0 to −0.7); 15 RCTs [n=6,486]; I^2^=73%). Five^57,^ ^98,^ ^122,^ ^131,^ ^148^ trials appeared to focus only on behavior change without directly assigning a weight loss goal for participants, and did not result in greater weight loss than control groups (pooled MD=−1.1 [95% CI, −2.5to 0.4]; 6 RCTs [n=6124]; I^2^=90%).

Figure 15 Weight, BMI, WC Summary Plot (KQ2)

Abbreviations: BMI = body mass index; CI = confidence interval; cm = centimeters; Diff. = difference; IG = intervention group; K = number of studies (including studies reported by subgroups); kg = kilograms; kg/m^2^ = kilograms per meter squared; WC = waist circumference

Figure 15 is a summary forest plot of the pooled change in weight (kg), body mass index (kg/m2) and waist circumference (cm) by risk group and followup category. This figure is discussed in the Results section.

In addition, 11 trials reported the proportion of participants who lost at least 5 percent of their weight or had a 5 percent reduction in BMI.^82,^ ^107,^ ^110,^ ^116,^ ^123,^ ^125,^ ^126,^ ^129,^ ^132,^ ^134,^ ^141^ Behavioral counseling interventions were associated with a 86 percent increase in the likelihood of losing 5 percent of baseline weight or BMI (pooled RR=1.86 [95% CI, 1.33 to 2.60]; 11 RCTs [n=3,970]; I^2^=68%, Figure 16). Other than one small trial that focused only on increasing physical activity,^132^ all trials reporting this outcome were either weight loss trials^116,^ ^123,^ ^125,^ ^129,^ ^134,^ ^141^ or explicitly stated that weight loss was recommended for all participants with overweight or obesity.^82,^ ^107,^ ^110,^ ^126^ Three trials also reported the proportion who lost 10 percent or more of their baseline weight and all found an increased probability of this level of weight loss at one or more followup timepoints (percent with 10% weight loss ranged from 7.5% to 25.0% in the intervention groups and 2.3% to 8.6% in the control groups).^125,^ ^126,^ ^129^

Figure 16 ≥5% Reduction in Weight or BMI (KQ2)

Abbreviations: BMI = body mass index; CG = control group; CI = confidence interval; Int arm = intervention arm; HD = healthy diet; HD + PA = healthy diet and physical activity; KH = Knapp-Hartung adjustment; REML = restricted maximum likelihood; RR = risk ratio

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

^†^Reflects ≥5% BMI reduction; all other studies reflect ≥5% weight reduction

Figure 16 is a forest plot depicting the pooled risk ratio of 5% or more reduction in weight or body mass index, comparing behavioral counseling interventions to the controls. This figure is discussed in the Results section.

Meta-regressions and subgroup analyses on weight (the most commonly reported adiposity-related outcome) identified some statistically significant bivariate relationships, with larger effects being found in trials conducted in the United States (p=0.01), those that were limited to individuals with obesity or who were overweight (p=0.04), and in weight loss trials (p<0.03) (i.e., trials that recruited people with excess weight and had an explicit weight loss goal for all participants), but no effect modification based on intervention contact, age group, socioeconomic status, and whether a fat-modified diet was recommended (Figure 17). Most weight loss trials were conducted in the USA and all were limited to individuals with obesity or who were overweight, so we were unable to disentangle the relative impacts of these factors. The test of small study effects was statistically significant (Egger’s test of bias=−2.8, p<0.001), indicating that smaller trials tended to have larger effects. Weight loss trials tended to be smaller studies: the average sample size in weight loss trials was 461, compared with 585 in non-weight loss trials. Thus, small studies effects may be related to intervention content and target population rather than publication bias.

Figure 17 Weight Subgroup Analyses (KQ2)

Abbreviations: CI = confidence interval; Diff. = difference; K = number of studies (including studies reported by subgroups); kg = kilograms; KH = Knapp-Hartung adjustment; NR = not reported; REML = restricted maximum likelihood; SES = socioeconomic status

*P-values derived from Q test of between-subgroups heterogeneity (based on random effects model)

^†^For this analysis, the most comprehensive or highest dose intervention group was selected if a study had multiple intervention groups, and the followup timepoint closest to 12 months was selected of there were multiple followup assessments

Figure 17 is a forest plot of the subgroup analyses on weight (kg) demonstrating the effects with various characteristics, including study quality, setting, age group, baseline weight selection and weight loss approach, some key intervention characteristics, and socioeconomic status. For these analyses, the most comprehensive or highest dose intervention group was selected if a study had multiple intervention groups, and the followup timepoint closest to 12 months was selected if there were multiple followup assessments. The bivariate p-values are derived from the Q test of between-groups heterogeneity.

#### Cardiovascular Risk

Twelve trials used published models or calculators to calculate 5- or 10-year risk of CVD or CHD events^68,^ ^70,^ ^77,^ ^106,^ ^109,^ ^142,^ ^144,^ ^224^ or mortality^84,^ ^85,^ ^98,^ ^99^ (Appendix H Table 13). Two trials found statistically significant reductions in 10-year CVD risk after 1 year, reporting reductions of 1.8 (95% CI, −3.0 to −0.6)^106^ and 2.1 (95% CI, −4.1 to −0.1)^142^ percentage points, although the pooled effect was not statistically significant when combining all trials reporting 8- or 10-year CVD risk outcomes (pooled MD=−0.5 percentage points [95% CI, −1.3 to 0.3]; 7 RCTs [n=2,533]; I^2^=53%, Figure 18). None of the trials reporting the 10-year CVD mortality risk found group differences, nor was the pooled effect statistically significant (pooled MD=−0.1 percentage points (95% CI, −0.3 to 0.2); 5 effects [4 RCTs, n=1,764]; I^2^=0%).

Figure 18 10-Year CVD Risk and 10-Year CVD Mortality Risk (KQ2)

Abbreviations: CG = control group; CI = confidence interval; CVD = cardiovascular disease; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; KH = Knapp-Hartung adjustment; REML = restricted maximum likelihood; RR = risk ratio; SD = standard deviation

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

^†^8-year CVD risk

Figure 18 is a forest plot depicting the pooled risk ratios of 8- or 10-year CVD risk and 10-year CVD mortality risk outcomes, comparing behavioral counseling interventions to the controls. This figure is discussed in the Results section.

#### Impact of Population, Study, and Intervention Characteristics on Effect Size

Based on direct within-study comparisons using study-reported subgroup analyses, we found no indication that any demographic subgroups consistently benefited more or less than others. Sixteen trials examined variability in effects by sex,^59,^ ^69,^ ^85,^ ^91,^ ^98,^ ^114,^ ^116,^ ^120,^ ^123,^ ^127,^ ^129–131,^ ^138,^ ^142,^ ^144^ and while some showed larger effects for some outcomes in men than women (overall^69,^ ^98,^ ^127,^ ^142^ or among African-American participants only^59^), one showed larger effects in women for some outcomes^130^ and the remaining reported no differential effect by sex. Some trials found that effect sizes increased with age for weight loss^59,^ ^123,^ ^138^ and blood pressure,^59,^ ^93^ but other trials found no association between intermediate outcomes and age.^91,^ ^114,^ ^130,^ ^131^ Most trials examining interactions by race or ethnicity reported no differential effectiveness;^120,^ ^123,^ ^129,^ ^144^ however, TOHP II reported a larger effect for weight loss in white participants than African-American participants.^138^ Risk factor status was associated with effect size in several trials: people with hypertension experienced a greater reduction in blood pressure than those without hypertension,^59^ those with the highest 10-year CVD risk had the greatest reductions in future CVD risk,^68,^ ^71^ and people with dyslipidemia had the greatest reductions in lipids.^76^ However, other trials did not show an association between baseline risk and improvement in intermediate outcomes.^75,^ ^130,^ ^131^ Effects on lipids were not moderated by medication status in three trials.^78,^ ^80,^ ^83^

As described under the outcome-specific results, we found very few intervention or population characteristics that were clearly associated with effect size. In meta-regressions examining the association between study and intervention characteristics and effect size, we did not see a clear indication that high-contact (>360 min) trials showed larger effects than medium-contact trials, nor was there an association between continuous measures of contact (number of sessions, total estimated minutes of contact) and effect size. However, very few trials offered low-contact (<30 min) interventions (Figure 2). See the Methods section for the full list of characteristics explored.

While there were no differences in effect size between interventions that counseled people only to change their diet compared with those that addressed both diet and physical activity, evidence was limited on interventions that only addressed physical activity. Only five studies^61,^ ^87,^ ^94,^ ^132,^ ^140^ with interventions that addressed physical activity alone reported intermediate outcomes. Among these 5 trials, sample sizes were generally very small and outcome reporting was inconsistent.

We attempted to identify common intervention elements of effective trials by examining trials that showed the largest beneficial effects on intermediate outcomes. For this exercise, we limited to trials that randomized at least 150 participants to limit the risk of spurious findings. We focused on four intermediate outcome domains of blood pressure, lipids, fasting glucose, and weight. Then we identified studies with the 10 largest absolute effect sizes for outcomes in each domain. Sixteen trials had relatively large effects in at least two of the four intermediate outcome domains.^65,^ ^69,^ ^75,^ ^76,^ ^79,^ ^92,^ ^95,^ ^98,^ ^99,^ ^106,^ ^107,^ ^113,^ ^120,^ ^126,^ ^139,^ ^141^ Five of these trials had relatively large effects in the three^92,^ ^106,^ ^107,^ ^141^ or four^65^ domains and are listed in Table 13. Each of these five trials selected participants based on having any of multiple CVD risk factors or metabolic syndrome and included counseling for both diet and physical activity. Interventions in these 5 trials are described below.

Table 13 Results in Trials With Relatively Large Effects^*^ Across Multiple Domains of Blood Pressure, Lipids, Fasting Glucose, or Weight

Outcome | Measure | Bennett, 2018^141^ | Bo, 2007^65^ | Rodriguez-Cristobal, 2012^92^ | Wister, 2007^106^ | Wood, 2008^107^
Outcome | Measure | 18 phone, 3 PCP weight loss counseling sessions, 52 IVR calls (est 324 min) | 1 individual, 4 group 60 min sessions, 3 mailings (est 300 min) | 24 individual in-person and phone sessions (est 540 min) | 2 phone sessions, 4 additional calls for smokers (est 60 min for non-smokers) | Individual assessment, 8 group sessions (est 480 min)
SBP (mm Hg) | Mean difference in change (95% CI) | −0.9 (−4.9 to 3.1) | −6.8 (−10.6 to −3.0) | −6.8 (−10.7 to −2.8) | −3.9 (−7.4 to −0.4) | −4.8 (−10.2 to 0.6)
SBP (mm Hg) | IG mean change (SD) | −8.4 (20.3) | −2.0 (18.8) | −4.2 (17.2) | −7.5 (15.9) | −7.6 (NR)
SBP (mm Hg) | CG mean change (SD) | −7.5 (19.5) | 4.8 (17.0) | 2.2 (17.4) | −3.6 (16.0) | −2.8 (NR)
DBP (mm Hg) | Mean difference in change (95% CI) | −1.0 (−3.5 to 1.5) | −2.3 (−4.4 to −0.2) | −4.4 (−6.8 to −2.0) | NR | −2.7 (−5.9 to 0.6)
DBP (mm Hg) | IG mean change (SD) | −5.2 (12.6) | −2.6 (9.3) | −5.2 (10.2) | NR | −4.1 (NR)
DBP (mm Hg) | CG mean change (SD) | −4.2 (12.2) | −0.3 (10.0) | −1.3 (9.5) | NR | −1.6 (NR)
TC (mg/dL) | Mean difference in change (95% CI) | 3.1 (−4.7 to 10.9) | −2.3 (−9.6 to 4.9) | −19.2 (−25.6 to −12.7) | −10.4 (−20.2 to −0.6) | −13.1 (−20.9 to −5.8)
TC (mg/dL) | IG mean change (SD) | −3.5 (41.7) | 0.0 (33.2) | −6.7 (24.2) | −15.8 (44.4) | −14.7 (NR)
TC (mg/dL) | CG mean change (SD) | −6.6 (41.4) | 2.3 (34.4) | 14.2 (24.8) | −5.4 (44.4) | 0.0 (NR)
LDL (mg/dL) | Mean difference in change (95% CI) | −3.2 (−10.5 to 4.1) | NR | 1.9 (−6.0 to 9.9) | NR | −13.1 (−20.1 to −6.2)
LDL (mg/dL) | IG mean change (SD) | −5.0 (37.6) | NR | −3.5 (23.0) | NR | −15.8 (NR)
LDL (mg/dL) | CG mean change (SD) | −1.8 (38.0) | NR | −4.7 (25.2) | NR | −1.2 (NR)
HDL (mg/dL) | Mean difference in change (95% CI) | 3.5 (1.1 to 5.9) | 3.5 (2.2 to 4.7) | 2.1 (−0.9 to 5.1) | 0.4 (−1.2 to 2.0) | NR
HDL (mg/dL) | IG mean change (SD) | 3.2 (12.6) | 0.8 (5.4) | 7.5 (8.0) | 1.5 (7.3) | NR
HDL (mg/dL) | CG mean change (SD) | −0.3 (12.4) | −2.7 (6.2) | 5.1 (7.7) | 1.2 (7.3) | NR
FBG (mg/dL) | Mean difference in change (95% CI) | −8.1 (−17.1 to 0.9) | −5.9 (−8.4 to −3.5) | NR | −6.8 (−18.3 to 4.6) | −2.0 (−13.5 to 9.6)
FBG (mg/dL) | IG mean change (SD) | −4.9 (48.2) | −4.7 (11.9) | NR | −6.7 (55.3) | −8.3 (NR)
FBG (mg/dL) | CG mean change (SD) | 3.2 (48.0) | 1.3 (10.6) | NR | 0.2 (48.5) | −5.1 (NR)
BMI (kg/m^2^) | Mean difference in change (95% CI) | −1.4 (−1.8 to −0.9) | −0.9 (−1.3 to −0.5) | −1.7 (−2.2 to −1.1) | −0.1 (−0.6 to 0.3) | −0.6 (−0.9 to −0.2)
BMI (kg/m^2^) | IG mean change (SD) | −1.4 (2.3) | −0.3 (1.8) | −0.7 (2.0) | −0.5 (2.0) | −0.5 (NR)
BMI (kg/m^2^) | CG mean change (SD) | 0.0 (2.0) | 0.6 (2.0) | 1.3 (1.6) | −0.3 (1.8) | 0.1 (NR)
Weight (kg) | Mean difference in change (95% CI) | −3.8 (−5.1 to −2.5) | −2.4 (−3.5 to −1.3) | NR | NR | −1.5 (−2.5 to −0.5)
Weight (kg) | IG mean change (SD) | −4.0 (6.3) | −0.7 (4.9) | NR | NR | NR
Weight (kg) | CG mean change (SD) | −0.1 (5.9) | 1.6 (5.2) | NR | NR | NR
WC (cm) | Mean difference in change (95% CI) | −3.6 (−5.0 to −2.1) | −4.5 (−5.8 to −3.2) | NR | −0.5 (−2.1 to 1.1) | −1.6 (−2.6 to −0.6)
WC (cm) | IG mean change (SD) | −2.9 (7.0) | −2.5 (5.2) | NR | −2.8 (7.0) | −1.7 (NR)
WC (cm) | CG mean change (SD) | 0.6 (6.6) | 2.0 (6.7) | NR | −2.3 (7.1) | −0.2 (NR)

Abbreviations: BMI = body mass index; CG = control group; CI = confidence interval; cm = centimeters; DBP = diastolic blood pressure; est = estimated; FBG = fasting blood glucose; HDL = high-density lipoprotein cholesterol; IG = intervention group; IVR = interactive voice recognition; kg = kilograms; kg/m^2^ = kilograms per meter squared; LDL = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; min = minutes; mm Hg = millimeters of mercury; NR = not reported; PCP = primary care provider; SD = standard deviation; SBP = systolic blood pressure; TC = total cholesterol; WC = waist circumference

* One of the 10 largest absolute effect sizes for the specified outcome, at 12 to 24 months’ followup

One of these successful trials was a good-quality, U.S.-based weight-loss trial that was part of the NHLBI-funded Practice-Based Opportunity for Promotion of Weight Reduction Trials (POWER) project.^141^ This intervention included 18 10–15 minute coaching sessions by phone, a median of three brief counseling visits with the primary care provider, and 52 brief interactive voice recognition calls.^141^ Intervention participation in this study was generally good: participants completed a median of 89 percent of the coaching calls and a median of 93 percent of their weekly self-monitoring forms. Another successful trial was a good-quality Canadian trial that recruited participants with a 10-year CVD risk of 10 percent or more based on the Framingham model.^106^ The intervention involved two 30-minute phone sessions 6 months apart, a CVD risk “report card” sent to each participant and their provider, and two additional mailings after each call summarizing the counseling sessions and including education materials addressing smoking, diet, physical activity, weight management, and stress management as appropriate to the participant’s profile. Smokers were eligible for four additional smoking-cessation phone counseling sessions.

The other three trials—which were given fair-quality ratings—were conducted in Europe among Italians with metabolic syndrome,^65^ Spaniards with moderate or high Framingham CHD risk (specific thresholds not reported) and elevated fibrinogen levels,^92^ and Europeans from six countries with a 10-year CVD mortality risk score of 5 percent or higher.^107^ While none of these was a weight loss trial, specifically, all promoted weight loss for participants who were overweight or with obesity. The Italian trial involved one individual and four group sessions lasting 1 hour each, covering diet and physical activity, with participants attending an average of 4.1 to 4.5 of the five sessions.^65^ The Spanish trial included 12 individual sessions with the primary care provider and 12 follow-up phone sessions with a psychologist covering diet, physical activity, medication management, and smoking cessation (if applicable).^92^ The multi-country European trial included family members in the intervention and involved an individual nurse assessment with a personal “report card,” a family support pack, and eight group workshops on diet, physical activity, and risk factor management.^107^ Intervention adherence was not reported in either of these trials.^92,^ ^107^

The range of average between-group difference in change for blood pressure in these five trials was −0.9 (−4.9 to 3.1)^141^ to −6.8 (−10.7 to −2.8)^92^ SBP and −1.0 (−3.5 to 1.5)^141^ to −4.4 (−6.8 to −2.0)^92^ DBP (Table 13). Differences in total cholesterol change ranged from +3.1 mg/dL (−4.7 to 10.9)^141^ to −19.2 mg/dL (−25.6 to −12.7),^92^ and BMI change differences ranged from −0.1 kg/m^2^ (−0.6 to 0.3)^106^ to −1.7 kg/m^2^ (−2.2 to −1.1).^92^

#### Role of Weight Management

We were unable to provide a robust analysis of the importance of weight loss on the impact of intermediate outcomes, since this question is better approached with individual patient data. Weight loss interventions did have a larger pooled effect on weight change than interventions that did not promote weight loss (Figure 17). There was no bivariate or multivariate association between weight loss promotion and SBP, and an inverse association with total cholesterol such that smaller reductions in total cholesterol were seen in weight loss trials, however this effect disappeared when controlling for medication management and older adult populations.

We examined trials with multiple intervention arms with direct comparison of weight-loss versus other messages to evaluate the role of weight loss on intermediate outcomes. Four trials had this design.^120,^ ^122,^ ^138,^ ^144^ All of these trials targeted people with hypertension and the diet-only intervention arms (with no explicit mention of weight loss) encouraged either sodium reduction or sodium reduction and an increase in potassium intake. Effect sizes were generally slightly larger in intervention arms that promoted weight loss, however the intervention conditions encouraging sodium reduction without apparent encouragement to lose weight also had statistically larger reductions in blood pressure than control groups for three of these trials.^120,^ ^122,^ ^138^ One small (n=95) trial of people with untreated elevated blood pressure who were either overweight or had obesity explicitly instructed participants to focus on adopting the DASH diet without changing their weight or physical activity level.^121^ The intervention involved four in-person individual instructional sessions and 14 30- to 45-minute group sessions, and was effective in reducing systolic but not diastolic blood pressure. At 12-month followup, there was a 5.6 (95% CI, −9.8 to −1.4) mm Hg greater reduction in systolic blood pressure in the intervention group: a 9.5 (SD 9.1) mm Hg reduction in the intervention group compared with a 3.9 (SD 11.8) mm Hg reduction in the control group.^121^

## KQ3 Do Behavioral Counseling Interventions to Improve Diet and Increase Physical Activity Improve Behavioral Outcomes in Adults With Known CVD Risk Factors?

### Summary of Results

Altogether, 70 of the included trials reported some type of behavioral outcome (n=43,243); however, most specific outcomes were reported by fewer than 15 trials, and there was substantial variability in measurement for most of these outcomes. Behavioral counseling interventions were associated with dietary improvements, including reductions in saturated fat consumption and increases in the consumption of fruits, vegetables, and fiber (Table 14). The average difference in reduction in the percent of calories from saturated fat was 1.5 percentage points after 12 to 24 months (pooled MD=−1.5 [95% CI, −1.9 to −1.1]; 15 RCTs [17 effects, n=6,229]; I^2^=72%). The median (IQR) reduction in the intervention groups was −1.9 (−3.0 to −1.4), compared with −0.6 (−1.0 to −0.1) in the control groups. For fruits and vegetables, the intervention groups increased consumption by an average of 0.7 servings per day more than the control groups (pooled MD=0.7 [95% CI, 0.1 to 1.3]; 11 RCTs [n=4,310]; I^2^=90%). The average increase in fiber consumption was 1.3 grams per day (95% CI, 0.1 to 2.6, 5 RCTs [n=1,350], I^2^=42%) more than control groups. In addition, trials among people with hypertension or elevated blood pressure who were counseled to reduce sodium consumption did show reduced urinary sodium (pooled MD=−18.0 [95% CI, −34.8 to −1.2]; 9 RCTs [n=3,583]; I^2^=89%). Dietary pattern scores, arguably the better measures of dietary improvement than those that capture only a single aspect of diet, generally showed greater improvement in intervention groups, but measurement was heterogeneous and interpretation of effect sizes was unclear. Physical activity outcomes were highly variable in terms of both measurement and results, with minimal evidence to suggest that interventions were associated with increased physical activity. Trials that had relatively large benefits for intermediate outcomes also tended to report mean differences in change in behavioral outcomes that were at or above the means for the full body of evidence.

Table 14 Pooled Difference in Mean Change for Dietary Fats, Fruit Vegetable, Urinary Sodium, and Physical Activity Outcomes at 12 to 24 Months’ Followup

Outcome | Unit | Effect size (95% CI)^*^ | K | N | I^2^ | Median (IQR) change, IG | Median (IQR) change, CG
Saturated fat | % of energy | −1.5 (−1.9, −1.1) | 15 | 6229 | 72% | −1.9 (−3.0, −1.4) | −0.6 (−1.0, −0.1)
Saturated fat (Fat modified diet interventions only) | % of energy | −1.5 (−2.3, −0.8) | 8 | 3951 | 72% | −2.2 (−3.0, −1.6) | −0.5 (−1.0, −0.01)
Polyunsaturated fat | % of energy | −0.4 (−1.0, 0.3) | 7 | 2032 | 90% | −0.9 (−1.2, −0.1) | 0 (−0.3, 0)
Monounsaturated fat | % of energy | −1.7 (−2.5, −0.9) | 7 | 1827 | 83% | −2.0 (−2.1, −1.9) | −0.2 (−0.4, 0)
Fruits and vegetables | Servings/day | 0.7 (0.1, 1.3) | 11 | 4310 | 90% | 0.5 (−0.01, 1.2) | 0.1 (0, 0.3)
Fruits | Servings or pieces/day | 0.2 (0.04, 0.3) | 9 | 3698 | 71% | 0.2 (0.1, 0.5) | 0 (0, 0.1)
Vegetables | Standardized mean difference | 0.1 (0.02, 0.2) | 9 | 3555 | 50% | s/d: 0.5 (0, 0.8); g/d: 11 (9, 16) | s/d: 0.3 (0.2, 0.3); g/d: 2 (−3, 12)
Fiber | Grams/day | 1.3 (0.1, 2.6) | 5 | 1350 | 42% | 1.7 (0, 3.0) | 0.1 (−0.7, 0.2)
Urinary Sodium | mmol/L | −18.0 (−34.8 to −1.2) | 9 | 3583 | 89% | −18.4 (−45.4, −5.3) | −6 (−10.0, −3.4)
Physical activity | Standardized mean difference | 0.1 (−0.03 to 0.1) | 30 | 19834 | 64% | -- | --
Physical activity | Minutes/week | 9.1 (−4.6 to 22.8) | 13 | 10758 | 48% | 44.4 (−2.5, 97.0) | 31.2 (−13.0, 74.7)
Physical activity | MET-min/week | 83 (−101 to 267) | 7 | 5580 | 62% | 130 (33, 289) | 70 (−16, 112)
Physical activity | % Meeting PA goal | RR=1.22 (1.00, 1.50) | 11 | 5887 | 91% | 36.0 (28.1, 52.8)^†^ | 23.8 (22.9, 50.8)^†^

Abbreviations: CG = control group; CI = confidence interval; g/d = grams/day; IG = intervention group; IQR = interquartile range; K = number of studies; MET = metabolic equivalent; mmol/L = millimoles per liter; N = number of participants analyzed; PA = physical activity; RR = risk ratio; s/d = servings per day

* Between-group mean difference in change unless otherwise specified

† Median (IQR) percent meeting physical activity goal

### Detailed Results by Outcome

#### Dietary Fat Intake

Behavioral counseling interventions were associated with small reductions in saturated fat: the average difference in reduction in the percent of calories from saturated fat was 1.5 percentage points after 12 to 24 months (pooled MD=−1.5 [95% CI, −1.9 to −1.1]; 17 effects [15 RCTs] [n=6,229]; I^2^=72%; Table 14, Appendix G Figure 12). The median (IQR) reduction in the intervention groups was −1.9 (−3.0 to −1.4), compared with −0.6 (−1.0 to −0.1) in the control groups. Effects were similar in trials that specifically encouraged people to adopt a fat-modified diet (pooled MD=−1.5 [95% CI, −2.3 to −0.8]; 10 effects [8 RCTs] [n=3,951]; I^2^=72%). Polyunsaturated fat intake did not change (Table 14, Appendix G Figure 13), and monounsaturated fat (MUFA) intake was reduced on average (pooled MD=−1.7 [95% CI, −2.5 to −0.9]; 8 effects [7 RCTs] [n=1,827]; I^2^=83%; Table 14, Appendix G Figure 14). However, in PREDIMED, which encouraged a Mediterranean diet and supplied participants with either olive oil or nuts, MUFA increased by 1.9 (95% CI, 1.4 to 2.3) percentage points more in the group receiving nuts and 3.0 (95% CI, 2.6 to 3.5) percentage points in the olive oil group, compared with the control group.^131^ All other trials reporting MUFA and most reporting polyunsaturated fat intake found reductions in intake. Trials reporting other fat-related outcomes (grams per day, score on a dietary fat scale) generally found group differences in the direction of greater reductions in the intervention groups, with most reporting only saturated fat (Appendix H Tables 15 and 16).

Table 15 Comparison With Previous and Related Reviews

Outcome | Current Review | Previous Review^44^ | 2017 Adult Obesity review^*^,^47^, 2011 Adult Obesity review^292^, behavioral counseling interventions^†^
Mortality | 17 trials, no clear benefit (Pooled RR NSD, mixed findings in 3 adequately powered trials) | 3 trials, no benefit | 4 trials, small number of deaths, no benefit
CVD events | 12 trials, reduced MI, total events; pooled RRs (95% CI):; Total: 0.80 (0.73 to 0.87), k=9; MI: 0.85 (0.70 to 1.02), k=6; Stroke: 0.52 (0.25 to 1.10), k=4 | 5 trials, no benefit, low event rates | 2 trials in persons with prediabetes, no differences in CVD events.
Blood Pressure | Pooled MD (95% CI):; SBP: −1.8 (−2.5 to −1.1), k=44; DBP: −1.2 (−1.6 to −0.8), k=40; HTN Incidence: 0.74 (0.58, 0.94), k=5 | Pooled MD (95% CI):; SBP: −2.0 (−2.9 to −1.2), k=48; DBP: −1.4 (−1.9 to −0.8), k=24; HTN Incidence: Not examined | Pooled MD (95% CI):; SBP: −2.0 (−2.9 to −1.2), k=48
Lipids | Pooled MD (95% CI):; TC: −3.5 (−5.6 to −1.4), k=38; LDL: −2.1 (−4.1 to −0.2), k=32; HDL: 0.6 (0.2, 1.0), k=34 | Pooled MD (95% CI):; TC: −4.5 (−6.4 to −2.6), k=34; LDL: −3.4 (−5.4 to −1.5), k=25; HDL: 0.7 (0.1, 1.3), k=19 | Pooled MD (95% CI):; LDL: −4.9 (−7.3 to −2.6), k=8
Glucose | Pooled MD (95% CI):; FBG: −2.3 (−3.6 to −1.0), k=22; DM Incidence: 0.82 (0.66, 1.03), k=5 (4 trials) | Pooled MD (95% CI):; FBG: −2.1 (−3.3 to −0.9), k=22; DM Incidence: 0.58 (0.37, 0.89), k=8 | 2 trials in persons with prediabetes, 30% to 50% reductions in diabetes incidence
Weight | Pooled MD (95% CI):; BMI: −0.5 (−0.7 to −0.3), k=30; Weight: −1.6 (−2.1, −1.1), k=37; WC: −1.8 (−2.4, −1.1), k=23 | Pooled MD (95% CI):; Hedge’s g (BMI or weight):; -0.26 (−0.35 to −0.16), k=34 | Pooled MD (95% CI), 12–18 months:; BMI: −1.0 (−1.2 to −0.7), k=40; Weight: −2.4 (−2.9, −1.9), k=67; WC: −2.5 (−3.2, −1.9), k=41

Abbreviations: BMI = body mass index; CI = confidence interval; CVD = cardiovascular disease; DBP = diastolic blood pressure; DM = diabetes mellitus; FBG = fasting blood glucose; HTN = hypertension; HDL = high-density lipoprotein cholesterol; LDL = low-density lipoprotein cholesterol; MD = mean difference; MI = myocardial infarction; NSD = no statistically significant difference; RR = risk ratio; SBP = systolic blood pressure; TC = total cholesterol; WC = waist circumference

* For mortality, CVD events, and weight outcomes

† For blood pressure, lipids, and glucose outcomes

Table 16 Behavioral Intervention Implementation Table: Summary and Examples of Included Interventions

Primary Population | Adults with hypertension, prehypertension, dyslipidemia, or any of multiple cardiovascular disease risk factors; most participants were overweight or with obesity (mean BMI=29.8)
Primary Outcomes Measured | Cardiovascular events (stroke, myocardial infarction, any CVD event); blood pressure; lipids; weight
Study Findings | Intervention groups had fewer cardiovascular events at 1 to 16 years’ followup (pooled RR=0.81 (0.74 to 0.88), with 10 trials reporting. At 12 to 24 months, the intervention groups showed greater reductions in blood pressure (SBP=-1.8 [−2.5 to −1.2] / DBP=-1.2 [−1.6 to −0.7] mm Hg), total cholesterol (−3.7 mg/dL [−5.9 to −1.5]), low-density lipoproteins (−2.3 mg/dL [−4.3 to −0.2]), BMI (−0.4 kg/m^2^ [−0.7 to −0.2]), weight (−1.5 kg [−2.1 to −1.1]), and waist circumference (−1.6 [−2.3 to −0.9]).
Behavior change goals and techniques | Designed to help participants improve dietary intake (e.g., reduce saturated fat; reduce sodium intake to below 1500–2300 mg/day; increase consumption of fruits, vegetable, whole grains, healthy fats, fish; reduce sweets and added sugar) and increase physical activity. Many interventions also had weight loss goals for all or some of the participants, some also offered smoking cessation support. Behavior change techniques included goal setting, active use of self-monitoring, and addressing barriers related to diet, physical activity, or weight change. Motivational interviewing commonly employed. A small number of trials in each category below included family members as well as the individual with CVD risk factors themselves.
Duration of interventions | Typically 6 to 18 months
Settings of Studies | Most took place in primary care settings, 46% took place in the United States.
To Whom is Intervention Targeted? | Adults with hypertension, prehypertension, dyslipidemia, or any of multiple cardiovascular disease risk factors; most participants were overweight or with obesity (mean BMI=29.8)
INTERVENTION TYPE | Group-based counseling with individual support, broadly targeted intervention | Individual-based support only, broadly targeted intervention | Hypertension prevention or management | Dyslipidemia management
Mode and intensity of delivery | Psychoeducational group sessions lasting 1 to 2 hours for each session, typically with an additional single individual meeting for each person. Number of sessions typically ranged from 20–30 over 24 months (~16-36 contact hours) for weight loss interventions and 5-12 sessions over 4–12 months (~6-13 contact hours) for general behavior change interventions. | Typically face-to-face sessions, with or without additional telephone support. Some also used web-based programs or other technology-enhanced components. Number of sessions typically ranged from 2-32 over 9–24 months (~1-7 contact hours) for weight loss interventions and 4-17 sessions over 6–16 months (~1.5-7 contact hours) for general behavior change interventions. | Prevention interventions were most commonly delivered in group settings, but hypertension management interventions were evenly split between offering group sessions and only seeing participants individually. Number of sessions typically ranged from 28-53 over 18–36 months (~28-42 contact hours) for hypertension prevention interventions and 5-24 sessions over 6–18 months (~3-14 contact hours) for hypertension management interventions. Typically recommended a low-sodium diet, often specifically promoting the DASH diet. Hypertension management interventions frequently included active monitoring and management of blood pressure medications. | Number of sessions typically ranged from 4-12 over 6–12 months (~2-4 contact hours), most commonly delivered during individual face-to-face sessions. Typically recommended limiting overall fat intake or limiting saturated fat intake.
Example interventions * | General: Bo 2007; RIS (Fagerberg 1998); EUROACTION (Wood 2008); Weight loss: POWER Hopkins (Appel 2011)^†^; Track (Bennett 2018)^†^ | General: Hardcastle 2008; PREDIMED (Estruch 2018); Rodriguez-Cristobol 2012; SPRING (Tiessen 2012); Wister 2008; Weight loss: GOAL (Ter Bogt 2009) | Prevention: TOHP I & II (TOHP I CRG, 1992 & TOHP II CRG, 1997)^†^; Management: ADAPT (Burke 2006); Hyman 2007^†^ | DEER (Stefanick 1998)^†^
Materials Provided for Practice (Materials for specific cited programs) | Track:; https://www.ncbi.nlm.nih.gov/pmc/articles/PMC4885789/ (study protocol) | PREDIMED:; https://www.nejm.org/doi/suppl/10.1056/NEJMoa1800389/suppl_file/nejmoa1800389_appendix.pdf (pages 20–24, study protocol) | TOHP II:; https://www.ncbi.nlm.nih.gov/pubmed/7795834 (study protocol) | ^‡^
Evidence of effect modification | Larger weight loss effects were evident in weight loss trials. No pattern of effects was based on intensity of the intervention, duration of the intervention, whether there as in-person support, whether individual in-person or telephone sessions were offered, whether medication management was offered, or whether blood pressure monitors or pedometers were provided.
Comparison group | Typically usual care consisting of brief messages from the primary care provider.
Interventionist and Training Required | Many trials used Registered Dieticians as interventionists, but other common providers were health educators, nurses, lifestyle coaches, psychologists or psychology graduate students, and exercise physiologists. Brief (60–90 minute) training was typically provided to primary care providers and their staff when they were involved in the delivery of the intervention (22% of trials included the primary care provider or staff), and 2- to 5-day intensive training sessions were typically required for other front-line interventionists, as well as regular check-ins or supervised sessions to ensure fidelity to intervention protocol.
Reported adherence to Intervention | Relatively high adherence with most studies reporting more than two-thirds of the intervention participants at least half of the intervention sessions. Participation rates declined over time, especially as intervention intensity lessened.

Abbreviations: ADAPT = Activity, Diet, and Blood Pressure Trial; DEER = Diet and Exercise for Elevated Risk; GOAL = Groningen Overweight and Lifestyle; PREDIMED = Primary Prevention of Cardiovascular Disease with a Mediterranean Diet; RIS = Risk Factor Intervention Study; TOHP I = Trials of Hypertension Phase 1; TOHP II = Trials of Hypertension Phase 2

* Primarily focused on trials that had one of the top 10 largest absolute effect sizes across 2 more of the four intermediate outcome domains of blood pressure, lipids, fasting glucose, and weight.

† Study conducted in US

‡ DEER intervention materials not provided, based on out-of-date guidance

#### Fruits and Vegetables

Behavioral counseling interventions were also associated with an average 0.7 greater increase in servings per day of fruits and vegetables compared with control groups after 12 to 24 months (pooled MD=0.7 [95% CI, 0.1 to 1.3]; 11 RCTs [n=4,310]; I^2^=90%, Table 14, Appendix G Figure 15). The median (IQR) increase in fruit and vegetable servings per day was 0.5 (0 to 1.2) in the intervention groups, compared with 0.1 (0 to 0.3) in the control groups. Fruit consumption was typically reported as servings or pieces per day, and there was in average 0.2 greater increase in servings per day for intervention than the control groups (pooled MD=0.2 [95% CI, 0.0 to 0.3]; 9 RCTs [n=3,698]; I^2^=72%, Table 14, Appendix G Figure 16). The two most common vegetable-specific outcomes were servings per day and grams per day, which were combined into a single meta-analysis of standardized mean differences (SMD). The results indicated a very small effect in the direction of benefit (SMD=0.12 [95% CI, 0.02 to 0.21]; 9 RCTs [n=3,555]; I^2^=50%, Table 14, Appendix G Figure 17). Intervention groups increased consumption by a median (IQR) of 0.5 (0 to 0.8) servings or 11 (9 to 16) grams per day, while the control groups increased consumption by 0.3 (0.2 to 0.3) servings or 2 (−3 to 12) grams per day. Interestingly, the effect measured in grams/day appears to be smaller; one serving (0.5 cup of cooked vegetables) is approximately 75g, so 11 grams is equivalent to approximately 1 tablespoon, while 0.5 of a serving is 4 tablespoons. Data were insufficient to determine whether this was due to random chance or related to the measurement approach. At 12 to 24 months’ followup, the median (IQR) consumption of fruits and vegetables was 5.1 (4.3 to 6.4) servings per day in the intervention groups and 4.6 (3.4 to 6.2) servings per day in the control groups.

#### Fiber

Seven trials reported change in grams per day of fiber (Appendix H Table 15).^57,^ ^65,^ ^69,^ ^72,^ ^82,^ ^104,^ ^131^ Most trials reported group differences in change that ranged up to 5 grams per day, and most differences were not statistically significant. At 12–24 months’ followup, the pooled mean difference in change was 1.3 grams per day (95% CI, 0.1 to 2.6, 5 trials [n=1,350], I^2^=42.4%, Table 14, Appendix G Figure 18). The USDA recommends eating 28 grams per day for a heart-healthy diet, for a 2,000-calorie-per-day diet.^2^

#### Sodium

Twelve trials in populations with hypertension or elevated blood pressure reported urinary sodium to determine whether participants had reduced sodium intake as encouraged by their interventions.^59,^ ^61,^ ^63,^ ^69,^ ^79,^ ^82,^ ^97,^ ^111,^ ^120,^ ^122,^ ^138,^ ^144^ Most trials reported greater reductions in 24-hour urinary sodium excretion in intervention groups that were coached to reduce their sodium intake than control groups (pooled MD=−18.0 [95% CI, −34.8 to −1.2]; 9 RCTs [n=3,583]; I^2^=89%; Appendix G Figure 19); at 12 to 24 months’ followup, the median (IQR) change in the interventions groups was −18.4 mmol/L (−45.4 to −5.3) and was −6 mmol/L (−10 to −3.4) in the control groups. The largest reduction seen in any control group was 16.8 mmol/L, while reductions in the intervention group ranged up to 72 mmol/L (Appendix H Table 15). In addition, trials that had separate intervention arms that did and did not promote a low-sodium diet saw reductions in the low-sodium diet intervention arms but not the other intervention arms.^122,^ ^138^ The typical American diet includes approximately 150 mmol per day of sodium, while the recommended intake is below 100 mmol per day.^283^

#### Dietary Pattern

Ten trials reported some type of dietary pattern or quality measure (Appendix H Table 15).^58,^ ^70,^ ^86,^ ^97,^ ^106,^ ^109,^ ^114,^ ^131,^ ^137,^ ^143^ For most of these outcomes, dietary patterns improved in intervention participants and showed very little change in control group participants, and quite a few group differences were statistically significant, although the clinical importance of the effects are difficult to interpret. For example, two trials^131,^ ^137^ (one of them PREDIMED) reported MEDAS-14 scores, which measures adherence to the Mediterranean diet. Considering all available followup assessments and intervention groups in both studies, intervention groups generally improved their adherence scores by 1.4 to 2.0 points on a 14-point scale. Intervention groups showed greater improvements than the control group that were statistically significant at all timepoints in PREDIMED. No other instrument was used in more than one trial.

#### Physical Activity

Altogether, 50 trials reported some type of physical activity outcome (n=34,028), and no consistent evidence of benefit emerged using a variety of self-report measures (Appendix H Tables 17 and 18). Outcome reporting was highly variable both in the measure reported (e.g., any, moderate, moderate-to-vigorous, leisure physical activity, meeting goal) and unit of measurement (e.g., minute/week, MET-hours/week, sessions/week, kJ/kg/day, steps/day). When standardized mean differences of the continuous outcomes were examined, effect sizes were very heterogeneous and inconsistent, with a number of effects favoring control groups, although those were typically not statistically significant. The pooled effect was not statistically significant, represented an effect size well below what would typically be considered a “small” effect, and had high statistical heterogeneity (pooled SMD=0.06 [95% CI, −0.03 to 0.14]; 32 effects [30 RCTs, n=19,834]; I^2^=64%) (Appendix G Figure 20). When similar outcomes were isolated, there was an average 9.1 additional minutes’ increase in physical activity per week in the intervention groups compared with the control groups (pooled MD=9.1 minutes/week [95% CI, −4.6 to 22.8]; 11 effects [10 RCTs, n=9,746]; I^2^=48%), and 83 MET-minutes per week (pooled MD=83 [95% CI, −83 to 249]; 7 effects [6 RCTs, n=4,958]; I^2^=62%), however neither of these findings were statistically significant. For comparison, an hour of walking briskly expends approximately 200 MET-minutes, so the pooled effect is roughly equivalent to an additional 25 minutes of walking per week. Again, the discrepancy in effect sizes using different measures is puzzling.

Of the six^61,^ ^87,^ ^90,^ ^94,^ ^132,^ ^140^ trials with intervention arms that addressed only physical activity (and not diet), four^61,^ ^90,^ ^132,^ ^140^ found greater improvements in physical activity in the intervention groups and one reported only intermediate outcomes.^87^ Of those reporting physical activity outcomes, no two studies used the same measure and the clinical significance of the effects was difficult to understand. Results included:

- 17 kJ/kg/d greater total energy expenditure (95% CI, 5.6 to 28.4)^61^
- 6-fold increase in the risk of increasing physical activity over baseline levels (RR=6.13 [95% CI, 3.07 to 12.23], 52.7% in the intervention group vs. 8.6% in the control group)^140^
- 29 percent increase in the odds of increasing by one of five levels on a measure of total physical activity (95% CI, 1.04 to 1.60)^90^
- 1,400 additional kcal/week (95% CI, −1299 to 4100) of moderate to vigorous physical activity (p=0.03 in an adjusted analysis)^132^
- No difference in the likelihood of meeting physical activity guideline recommendations (OR=0.99 [95% CI, 0.62 to 1.57])^94^

Intervention groups had a higher likelihood of meeting the study-defined physical activity goal, which typically was 90–180 minutes per week of moderate to vigorous physical activity (pooled RR=1.22 [95% CI, 1.00 to 1.50]; 11 RCTs [n=5,887]; I^2^=91%, Appendix G Figure 21). The median (IQR) percent meeting the study goal was 36 percent (28.1% to 52.8%) in the intervention groups and 23.8 percent (22.9% to 50.8%) in the control groups, with median (IQR) absolute risk differences of 3.7 percent (0.4% to 10.1%).

Two trials reported change in resting heartbeat, with greater reductions representing improved cardiorespiratory fitness (Appendix H Table 17).^59,^ ^69^ Both found greater reductions in the intervention groups. For example, one of these reported 8 and 9 beat-per-minute reductions in intervention groups at stage 2 of a submaximal exercise test, compared with 5.3 beats per minute reduction in the control group at 6 months’ followup.^59^ This study reported a slightly smaller difference after 18 months, when the control group average had dropped 2 more beats per minute, but the intervention groups maintained the previous changes.^59^ In the other trial, the intervention group saw a 1-beat-per-minute increase in 24-hour heart rate after 16 months, while the control group had increased by 7 beats per minute, but there was no difference between groups after 40 months (2 years after the intervention had ended).^69^ Three trials explored sedentary time using a variety of measures but found no group differences on any measure.^85,^ ^109,^ ^135^

#### Consistency With Intermediate and Health Outcomes

We addressed the issue of consistency between the intermediate and behavioral outcomes in two ways. First, we examined subgroup analyses reported by the included trials and noted whether participant subgroups with large behavioral effects also had large effects on intermediate outcome within the same study. Some trials reported that subgroups with the largest changes in behavioral outcomes also showed the largest improvements in intermediate outcomes.^59,^ ^64,^ ^69,^ ^73^

Next, we examined behavior change in the trials with relatively large intermediate and health outcome effects, and found that behavior change in these trials tended to be higher than the pooled average effects. Of the five trials that had relatively large effects in three or four domains of intermediate outcomes; two also reported behavioral outcomes.^65,^ ^107^ After 12 months, the Italian trial reported greater reductions in saturated fat percent of energy in the intervention group (MD in change=−1.8 percentage points [95% CI, −2.6 to −1.0]) and increases in polyunsaturated fatty acids (PUFA) (MD in change=1.0 percentage point [95% CI, 0.6 to 1.4]), fiber intake (MD in change=1.5 g/day [95% CI, 0.8 to 2.3]), and physical activity (MD in change=5.0 MET-hours/week [95% CI, 3.0 to 6.9], roughly equivalent to 1.5 additional hours of brisk walking per week) (Appendix H Tables 15 and 17).^65^ The multi-country European study reported that after 12 months, intervention participants were more likely to have consumed 400 or more grams of fruits and vegetables per day (78.4% in the intervention group vs. 38.8% in the control group, difference in probability= 39.7 [95% CI, 18.1 to 61.3]) and to have reported 30 or more minutes of physical activity on 4 or more days per week (50.3% in the intervention group vs. 22.1% in the control group, difference in probability=29.4 [95% CI, 10.7 to 48.0]).^107^

In addition, the PREDIMED trial had relatively large beneficial effects on health outcomes. It also showed improvements in both intervention groups at all follow-up assessments on the MEDAS-14, a measure of adherence to the Mediterranean diet, on the order of 1.3 to 1.6-point greater increases on a 14-point scale.^131^ Regarding specific dietary components, PREDIMED intervention participants reported greater increases in MUFA, PUFA, saturated fat (for the olive oil supplementation group only), and fiber (for the nuts supplementation group only), but did not differ from the control group on fruit and vegetable consumption.^131^

Several additional trials with relatively large effects in two domains of intermediate outcomes also reported behavioral outcomes, with findings that were generally in the direction of benefit for the intervention group, often at or above the pooled mean difference, but with mixed findings in terms of statistical significance.^69,^ ^76,^ ^79,^ ^95,^ ^98,^ ^106,^ ^131^ For example, relative to change in control groups, fruit and vegetable consumption increased in intervention groups by 0.8 servings per day (95% CI, 0.3 to 1.3)^69^ after 16 months, 0.70 servings per day (95% CI, −0.18 to 1.58)^76^ after 18 months, 23.5 g/day (95% CI, −15.0 to 62.0) after 12 months,^98^ and 0.07 (95% CI, −0.11 to 0.25, study-reported p<0.05) and 0.18 servings per day (95% CI, 0.00 to 0.36 study-reported p<0.05) after 5 years (Appendix H Table 15).^131^ Of the four trials^69,^ ^76,^ ^79,^ ^98^ reporting the percent meeting physical activity goals, most did not find that the groups differed, with absolute risk differences generally on the order of 0.2 to 10 percent (Appendix H Table 18). These same four trials also reported a continuous measure of change in physical activity, with mixed findings. Differences in change in these trials included: 53 minutes per week vigorous activity (95% CI, 15 to 91, study-reported p=0.007) at 40 months’ followup, but a smaller, statistically nonsignificant difference at 16 months;^69^ 3.1 MET-hours per week walking (95% CI, −2.2 to 8.3, study-reported p<0.01) at 18 months, but no statistically significant findings for either moderate- or vigorous-intensity physical activity;^76^ 723 steps per day (95% CI, −519 to 1966, p not reported) at 18 months;^79^ and 38.0 minutes per day walking (95% CI, 0.2 to 75.8, p=0.05) at 12 months, but no differences in minutes per week of moderate to vigorous or total physical activity, or in any physical activity outcomes at 36-month followup (Appendix H Table 17).^98^ The PREDIMED intervention did not discuss physical activity and found no group differences in leisure physical activity.^131^

## KQ4 What Are the Harms of Behavioral Counseling Interventions to Improve Diet and Increase Physical Activity in Adults With Known CVD Risk Factors?

### Summary of Results

We narrowly focused this question on harms of counseling interventions, rather than broadly on harms of dietary or physical activity changes themselves. We examined the 94 trials included for KQs 1 through 3 for harms, as defined by the study authors, or any paradoxical change in outcomes (e.g., worsening of blood pressure, lipids, glucose, measures of weight, dietary intake, physical activity). We searched for additional studies examining harms of healthy lifestyle counseling interventions but did not find any such studies.

The reporting of adverse events was sparse and variable. A subset of 20 of the 94 included trials reported one or more adverse events. Adverse events related to diet and physical activity counseling appear to be exceedingly rare, with generally no statistically significant differences in any study for: serious adverse events, any adverse events, hospitalizations, musculoskeletal injuries, or withdrawals due to adverse events. There was no consistent evidence of paradoxical effects for intermediate or behavioral outcomes. There were occasional instances of control groups showing more improvement than intervention groups, but this was usually not statistically significant and was often accompanied by greater improvement for the intervention group for other outcomes.

### Detailed Results for Harms

Twenty trials reported harms (N=18,263),^59,^ ^65,^ ^69,^ ^73,^ ^93,^ ^105,^ ^107,^ ^112,^ ^114,^ ^116,^ ^125–127,^ ^131,^ ^134,^ ^139,^ ^141,^ ^148,^ ^149,^ ^224^ (Appendix H Table 19). Seven of these 20 trials reported that there were no adverse events or no serious adverse events,^65,^ ^73,^ ^107,^ ^131,^ ^134,^ ^139,^ ^224^ and other trials reported one or more of the following: serious adverse events, any adverse events, hospitalizations, musculoskeletal injuries, withdrawals due to adverse events, gallbladder disease, and headaches.

#### Serious Adverse Events

Three trials reported serious adverse events, all of which included medium- to high-intensity diet and physical activity counseling interventions.^112,^ ^114,^ ^125^ While serious adverse events were not rare—occurring in 6.8 to 15.3 percent of intervention group participants and 7.6 to 12.3 percent of control group participants—serious adverse events attributed to interventions were exceedingly rare. In a U.K. primary-care based telephone and web-based intervention study of adults with multiple risk factors, one serious adverse event was potentially associated with the intervention: hospitalization due to low blood pressure. This could have been related to antihypertensive drug dose not being reduced after weight loss, according to the trial authors.^114^ In the Practice-based Opportunities for Weight Reduction at the University of Pennsylvania (POWER-UP) trial of weight loss in participants with CVD risk factors, three serious adverse events—two cholecystectomies and one case of syncope—were determined to be related to the intervention.^125^ In the Counseling African Americans to Control Hypertension (CAATCH) trial, which recruited African Americans with hypertension, one serious adverse event in the intervention group was considered possibly related to the intervention and two serious adverse events, one in the intervention group and one in the control group, were considered definitely related; however, the nature of these events was not reported.^112^ Differences in serious adverse events were not statistically significant between groups in any study.

#### Any Adverse Events

Seven trials reported that no adverse events occurred,^65,^ ^73,^ ^107,^ ^131,^ ^134,^ ^139,^ ^224^ and three trials reported a general measure of “any adverse events.”^93,^ ^112,^ ^114^ In these three trials, the rates of any adverse events among intervention group participants ranged from 0 to 11.7 percent and from 0 to 12.0 among control group participants. Differences in any adverse events were not statistically significant in any study, and details were not described in any reporting study.

#### Withdrawal Due to Adverse Events

Only two trials explicitly mentioned withdrawals due to adverse events. The study by Rodriguez^93^ noted that nine participants were withdrawn by study staff due to an adverse event that would affect study participation, but events by group are not reported. The CAATCH trial reported that no individuals terminated study participation due to adverse events.^112^

#### Hospitalizations

Five trials reported hospitalizations.^112,^ ^116,^ ^126,^ ^127,^ ^141^ In four of these trials, there were no statistically significant differences between groups, and the nature of the hospitalizations was not further specified.^112,^ ^116,^ ^126,^ ^127^ A study of the Track intervention—a medium-intensity diet and physical activity intervention with weight loss focus that was conducted in obese adults with at least one risk factor—reported 11 hospitalizations in the intervention group and one in the control group (6.3% vs. 0.6%).^141^ Hospitalizations were for causes other than CVD, cancer, or musculoskeletal injury, and authors reported that no events were deemed to be related to the trial. The study by Rosas et al additionally reported emergency department visits, which occurred in 35.4 percent and 27.4 percent of the two intervention arms and 41.5 percent in the control arm.^127^

#### Musculoskeletal Injuries

Six trials reported musculoskeletal injuries or serious musculoskeletal injuries, all of which were trials of medium- to high-intensity diet and physical activity counseling interventions.^59,^ ^116,^ ^126,^ ^141,^ ^148,^ ^149^ Rates of injuries ranged from 0.0 to 6.3 percent in intervention groups and 0.0 to 7.3 percent in control groups, with no statistically significant differences in any study. Two trials reported one case each of musculoskeletal injury related to the intervention, one as the result of an assault while exercising,^126^ and the other a twisted ankle sustained while running.^148^

#### Other Outcomes

Other adverse events were variably reported among trials, with no between-group differences noted (Appendix H Table 19).^105,^ ^116,^ ^131^

#### Paradoxical Changes

There was little evidence to suggest any paradoxical changes in intermediate outcomes. For each continuous intermediate outcome, there were a few studies in which the control group performed better than the intervention group, but in only one case was this statistically significant and it was offset by benefit for other outcomes. This occurred for the outcome of total cholesterol in the POWER study at 12–24 months (between-group difference of 7.80 mg/dL favoring the control group [95% CI, 0.39 to 15.21]), but LDL was not statistically significantly worsened (5.70 mg/dL favoring the control group [95% CI, −1.00 to 12.40]).^126^ However, weight loss was the primary outcome of this study, which had an impressive between-group difference favoring the intervention group of −4.30 kg (95% CI, −6.30 to −2.30)—one of the largest weight-loss effects in this body of literature. The study by Liira showed nonstatistically significant poorer outcomes in the intervention group (IG) for several intermediate outcome categories (blood pressure, lipids, adiposity), yet had a statistically significant improvement in fasting blood glucose favoring the IG at 12–24 months (−5.41 mg/dl [95% CI, −9.76 to −1.06]). This was a small Finnish study of adults with multiple risk factors who received a one-time 90-minute risk assessment and counseling intervention from a public health nurse.^117^

With respect to behavioral outcomes, a small number of studies showed greater control group improvements for some dietary intake outcomes compared with intervention groups, but none was statistically significant in adjusted analyses. Authors of the Activity, Diet, and Blood Pressure Trial (ADAPT) study noted that there was a reported decrease in the consumption of high-fat dairy that wasn’t necessarily replaced with low-fat dairy and considered a potential reduction in calcium intake a possible harm.^69^ For physical activity, effects favored control groups in a few studies, although those were typically not statistically significant in analyses reported by authors.