# Chapter 2 Methods

## Scope and Purpose

This review is an update of the systematic review^44^ that supported the 2014 USPSTF recommendation on this topic.^1^ In contrast to the previous review, the current review excluded studies limited to or predominantly in populations with diabetes or prediabetes. This change was made because the USPSTF has commissioned a companion, concurrent systematic review to support the update of the recommendation on screening for abnormal blood glucose in adults that will include the evidence on behavioral counseling in populations with diabetes or prediabetes.^45^ Thus, that population will be addressed in the separate diabetes screening review. In addition, weight loss trials that specifically targeted people with relevant cardiovascular risk factors were included in this review but were not included in the previous review.

## Analytic Framework and Key Questions

With input from the USPSTF, we developed an Analytic Framework (Figure 1) and four Key Questions (KQs) to guide the literature search and selection of studies, data abstraction, and data synthesis.

Figure 1 Analytic Framework

Figure 1 is the proposed analytic framework that depicts the four Key Questions (KQs) to be addressed in the systematic review. The figure illustrates how behavioral counseling interventions for healthy diet and/or physical activity may improve cardiovascular disease (CVD) health outcomes (KQ1) in adults (aged ?18 years) with known CVD risk factors. The figure also depicts how these interventions may influence intermediate health outcomes associated with CVD (KQ2) or associated health behaviors (KQ3). In addition, the figure depicts whether these interventions have any potential harms (KQ4).

### Key Questions

1. Do primary care-relevant behavioral counseling interventions to improve diet, increase physical activity, and reduce sedentary behavior improve [underlined: cardiovascular disease (CVD) and related health outcomes] (e.g., morbidity, mortality) in adults with known CVD risk factors (hypertension or elevated blood pressure, dyslipidemia, or mixed or multiple risk factors [e.g., 10-year CVD risk >7.5%, metabolic syndrome])?
2. Do primary care-relevant behavioral counseling interventions to improve diet, increase physical activity, and reduce sedentary behavior improve [underlined: intermediate outcomes] associated with CVD (e.g., blood pressure, lipid levels, blood glucose, body mass index) in adults with known CVD risk factors (hypertension or elevated blood pressure, dyslipidemia, or mixed or multiple risk factors [e.g., 10-year CVD risk >7.5%, metabolic syndrome])?
3. Do primary care-relevant behavioral counseling interventions to improve diet, increase physical activity, and reduce sedentary behavior improve [underlined: behavioral outcomes] (e.g., diet, physical activity, sedentary behavior) in adults with known CVD risk factors (hypertension or elevated blood pressure, dyslipidemia, or mixed or multiple risk factors [e.g., 10-year CVD risk >7.5%, metabolic syndrome])?
4. What are the [underlined: harms] of primary care-relevant behavioral counseling interventions to improve diet, increase physical activity, and reduce sedentary behavior in adults with known CVD risk factors (e.g., hypertension or elevated blood pressure, dyslipidemia, or mixed or multiple risk factors [e.g., 10-year CVD risk >7.5%, metabolic syndrome])?

## Data Sources and Searches

In addition to evaluating all studies that were included in the previous review of lifestyle counseling in populations with CVD risk factors,^44^ we conducted a search to find studies published since the previous review, covering literature published from January 2013 through September 5, 2019. Additionally, to identify studies published during the search window of the previous review that might meet our updated inclusion criteria, we also evaluated selected studies excluded from the previous review and studies that were included in related reviews.^46,^ ^47^ The search strategy was developed by a research librarian and was peer-reviewed by a second research librarian (Appendix A). It included searches of MEDLINE, PubMed (publisher-supplied records only), PsycINFO, and the Cochrane Central Register of Controlled Trials. All searches were limited to articles published in the English language.

In addition to these database searches, we examined the reference lists of other previously published reviews, meta-analyses, and primary studies to identify additional potential studies for inclusion. We supplemented our searches with suggestions from experts and articles identified through news and table-of-content alerts such as those produced by the USPSTF Scientific Resource Center LitWatch activity. We also searched ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform (www.who.int/ictrp) for ongoing trials through August 2019. Active surveillance was conducted through July 24, 2020 via article alerts and targeted journal searches to identify major studies that might affect the conclusions or understanding of the evidence. None were identified. We managed the literature search results using version X9 of EndNote® (Thomson Reuters, New York, NY), a bibliographic management software database.

## Study Selection

Two reviewers independently reviewed 14,409 unique citations and 466 full-text articles against a priori inclusion and exclusion criteria (Appendix A Table 1, Appendix B). We included studies that targeted populations at increased risk of cardiovascular disease due to hypertension or elevated blood pressure, dyslipidemia, or through examination of multiple risk factors. Examination of multiple risk factors may include estimated 10-year CVD risk of >7.5 percent or higher (e.g., using the Pooled Cohort Equations^17^ or Framingham risk calculators^15^), presence of the metabolic syndrome, or having any of multiple risk CVD factors (as long as hypertension/elevated blood pressure and dyslipidemia are among the eligible risk factors). For all key questions, we included randomized controlled trials (RCTs), including cluster-randomized trials, as well as nonrandomized controlled trials of behavioral counseling interventions to improve diet and increase physical activity in people with CVD risk factors. In addition, we allowed inclusion of systematic reviews, comparative cohort studies, and population-based case-control studies for assessments of harms of lifestyle counseling (KQ4).

We excluded studies that targeted populations with known CVD, diabetes, or chronic kidney disease; and studies that targeted populations with prediabetes. We also excluded studies of behavioral counseling interventions that targeted prevention or management of other medical conditions, such as cognitive impairment, serious mental health conditions, arthritis, falls, chronic pain, and cancer. We included trials whose primary aim was weight loss if the study targeted people with CVD risk factors and involved a behavioral counseling intervention. We limited inclusion to studies in adult populations in countries rated as “Very High” on the human development index according to the UN, based on 2015 indicators.^48^

We included studies of behavioral counseling interventions on diet and nutrition, physical activity (including sedentary behavior), or a combination thereof. Interventions could be delivered alone or as part of a larger multicomponent intervention that also addressed other health behaviors (e.g., smoking cessation, medication adherence). There were no restrictions on the contact time or duration of the interventions for inclusion, however, 6 months after randomization or the baseline assessment was the required minimum followup time for outcome assessment. Interventions had to have been conducted in a healthcare setting or be feasible for a healthcare setting to implement, meaning that the intervention could be “referable” from primary care were it to be implemented in a healthcare system. Thus, we excluded interventions with components that were not feasible for implementation in healthcare settings (e.g., interventions conducted within existing social networks, media campaigns, environmental interventions, public policy interventions). We also excluded studies conducted in settings that were not generalizable to primary care, such as inpatient facilities, emergency departments, nursing homes or other institutional settings, classrooms, and occupational settings. Comparative effectiveness studies were excluded, and allowable control groups included no intervention (e.g., usual care, wait list), a minimal intervention (e.g., pamphlets, links to preexisting internet resources, brief counseling of no more than an estimated 60 minutes annually), and attention controls with similar format and intensity but a different content area.

For the main search results, pairs of independent reviewers assessed a sample of 1,500 abstracts for inclusion, and discrepancies were resolved by discussion and consultation with the larger review team as needed. An artificial intelligence (AI) program embedded in the DistillerSR platform (Evidence Partners, Ottawa, Canada) then “trained” on these 1,500 abstracts and the abstracts of other known included studies from the previous review and related reviews. For the remaining abstracts, we conducted dual human review (if the AI score was equivocal for inclusion; 2,241 abstracts) or used the AI program in place of one of two human reviewers (if the AI score indicated a low probability of inclusion; 4,217 abstracts). Every abstract was assessed by at least one human reviewer. All abstracts identified in subsequent updating bridge searches (6,451 abstracts) were reviewed only by human reviewers. Discrepancies between any two reviewers (either two human reviewers or the AI and a human reviewer) were resolved by a different human reviewer or consultation with the larger team. Two independent (human) reviewers assessed full-text articles against our inclusion criteria and discrepancies were resolved by discussion or consultation with the larger review team as necessary.

## Quality Assessment and Data Abstraction

Two reviewers independently rated the studies’ methodological quality using USPSTF design-specific criteria (Appendix A Table 2).^49^ Studies were rated as “good,” “fair,” or “poor,” and discrepancies between raters were resolved by discussion or consultation with the larger review team. Good-quality studies were those that met nearly all of the specified quality criteria (e.g., comparable groups were assembled initially and maintained throughout the study and followup was approximately 90% or higher), whereas fair-quality studies did not meet these criteria but did not have serious threats to their internal validity related to their design, execution, or reporting. Poor-quality studies typically had several important limitations, including at least one of the following risks of bias: very high attrition (generally >40%), differential attrition between intervention arms (generally >20%); substantial lack of baseline comparability between groups without adjustment; or issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting, inappropriate exclusion of participants from analyses, questionable validity of randomization and allocation concealment procedures). Studies rated as “poor” quality were excluded from the review. For studies that had been included in the previous review on this topic or the recent USPSTF review of weight management interventions, we did not repeat critical appraisal of the original studies since we were updating our own work.

For all of the included studies, one reviewer extracted key elements into standardized abstraction forms in DistillerSR (Evidence Partners, Ottawa, Canada). A second reviewer checked the data for accuracy. For each study, we abstracted general characteristics (e.g., author, year, study design), clinical and demographic characteristics of the sample and setting (e.g., age, race/ethnicity, baseline clinical characteristics, setting, country), intervention details, and results. Outcomes of interest included health outcomes (cardiovascular events and related morbidity, including myocardial infarction [MI], stroke, coronary event, transient ischemic attack, arrhythmia, incident peripheral artery disease, angina, claudication, congestive heart failure, any CVD event); mortality; quality-of-life and related measures), intermediate outcomes (blood pressure, lipids, glucose, adiposity-related measures, 10-year CVD risk, cardiorespiratory fitness), and behavioral outcomes (dietary intake, physical activity, sedentary behavior). We abstracted objectively measured weight loss outcomes (weight, BMI, waist circumference) instead of self-reported weight or energy intake. We required that all outcomes were measured 6 months or more after baseline assessment.

For population risk factors, we categorized studies based on the risk factors required by the studies’ inclusion criteria. We labeled trials limited to people with hypertension or elevated blood pressure as “Hypertension,” even if the trial was limited to people with elevated blood pressure and excluded those meeting criteria for hypertension. Similarly, the label “Dyslipidemia” was used for trials that required all participants to have lipid levels outside of the optimal range, including both borderline and high LDL (or low for HDL) levels. Trials that included participants with any of multiple risk factors are labeled as “Multiple.” Trials are described as “weight loss” trials if the study required all participants to have a specified level of excess weight at study entry and had an explicit goal of weight loss for all participants. Trials were categorized as targeting low socioeconomic status (SES) populations if the community in which recruitment took place was described as low-income by the authors, or if any of the following were true: there was 20 percent or higher unemployment among participants, or 30 percent or more of participants were either unemployed or disabled, among working-age populations; fewer than 70 percent or participants were high school graduates (U.S. studies only); more than 20 percent of participants were at or below the 100 percent of federal poverty limit; more than 30 percent of participants were on Medicaid; or all participants were recruited from Federally Qualified Health Centers (designed to serve low-income individuals).

For intervention characteristics, we abstracted a detailed description of the interventions and information on the setting, format, mode of delivery (i.e., in-person, telephone, electronic, or print), dietary approach (Dietary Approaches to Stop Hypertension [DASH], fat-modified [low in saturated fat, low in all fats, or moderate levels of fats], low sodium, Mediterranean), duration, number and length of sessions, providers and provider training, and adherence. We estimated the total hours of interventionist contact based on the planned number and length of contacts. If a study did not report the length of sessions, we estimated session length as follows: a session described as “brief” was assumed to last 15 minutes if there was face-to-face, individual contact and 5 minutes if it was a phone session and for sessions that were not described as “brief,” individual face-to-face or interactive web-based sessions were assumed to last 30 minutes and group sessions was assumed to last for 60 minutes. Consistent with the previous review, we grouped the studies into three levels of contact dose (referred to as “intensity” in the previous review): low (estimated ≤30 minutes of phone or in-person contact), medium (31–360 minutes), and high (>360 minutes). Interventions that consisted of only print materials were categorized as low contact. Mailings and print materials were not included in the estimated of number of sessions or session length.

During data abstraction, we catalogued the availability and characteristics of subgroup analyses by age, sex, race/ethnicity, and other characteristics of interest (e.g., BMI or weight status). We noted whether subgroup analyses were prespecified or post-hoc and whether interaction testing was reported.

## Data Synthesis and Analysis

We created summary tables for all KQs showing study, population, intervention characteristics, and outcomes for qualitative evidence synthesis. For both continuous and dichotomous outcomes, adjusted effect estimates reported by primary studies were used over unadjusted values. Crude effect estimates were calculated if between-group results were not reported. For pooling, we used the Restricted Maximum Likelihood model with the Knapp-Hartung correction for small numbers of studies.^50,^ ^51^ We chose this method because there was either a small number of trials to be pooled or high statistical heterogeneity (commonly I^2^>50%, often >80%) for most analyses.^52^ We generated analyses that included all available intervention groups for each study and that were limited to the single most intensive or comprehensive intervention group per study (termed primary intervention group). Effect sizes were generally slightly larger when limited to the primary intervention group, with slightly larger confidence intervals, but statistical significance was almost always consistent between the two approaches. Meta-analyses limited to the primary intervention group are presented for all intermediate (KQ2) and behavioral (KQ3) outcomes except diabetes incidence and metabolic syndrome, where we included results for both groups from the Prevención con Dieta Mediterránea (PREDIMED) study, since a substantial proportion of the evidence would have been lost if one PREDIMED arm was excluded. However, for mortality and cardiovascular event outcomes, for which the absolute number of events was generally small, results for multiple intervention groups were combined. For pooled analyses of intermediate (KQ2) and behavioral (KQ3) outcomes, the followup time point closest to 12 months was selected if there were multiple followup assessments. For systolic blood pressure, total cholesterol, and weight outcomes, we generated funnel plots and ran Egger’s test to explore small-study effects, which can be related to publication bias.^53^

Additionally, we conducted meta-regression and subgroup analyses to explore whether there were study, population, or intervention characteristics that were associated with effect size for systolic blood pressure, total cholesterol, and weight. These outcomes were selected for prespecified subgroup and meta-regression analyses because they were the most commonly reported outcome in each of the three main intermediate outcome domains. Characteristics explored were: intervention contact (number of sessions, estimated contact hours, high- vs. medium- vs. low-contact category, duration [in weeks]); diet recommendation (fat-modified, low-sodium); delivery (group, in-person contact); weight loss approach (recommended for all participants, recommended for the subset of participants with overweight or obesity); use of motivational interviewing; incorporation of the Transtheoretical (Stages of Change) Model; active medication management; provision of pedometers; provision of blood pressure monitors; primary care staff involvement; population targets (older adults, CVD risk factor selection, low SES), U.S. setting; and indicators of study quality (quality rating, time to followup, sample size, year of publication). Initially we also planned to explore whether trials with majority nonwhite samples differed from those that did not; however, almost all trials with high race/ethnic minority representation were in economically disadvantaged populations, so we were unable to disentangle these effects and instead focused on socioeconomic status.

The availability of subgroup analyses within individual studies was audited to determine the proportion of studies reporting outcomes according to various subgroups. Subgroup analyses were sparsely and inconsistently conducted in included studies and thus were not quantitatively pooled. Analyses were qualitative and aimed to determine whether interventions were broadly effective among various subpopulations.

We used Stata 15.1 (StataCorp LLC, College Station, TX) and R 3.5.2 (R Foundation for Statistical Computing, Vienna, Austria). All significance testing was 2-sided, and results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each key question. We adapted the Evidence-based Practice Center approach,^54^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^55^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the key questions (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

The domain of consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). The domain of precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body-of-evidence limitations field highlights important restrictions in answering the overall key question (e.g., evidence of reporting bias, lack of replication of interventions, nonreporting of outcomes important to patients).

At least two independent reviewers rated the overall strength of evidence for each intervention type. We resolved discrepancies through consensus discussion with the full review team, consulting with outside reviewers as needed. We graded the overall strength of evidence as high, moderate, low, or insufficient. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit an estimate of an effect.

## Expert Review and Public Comment

The draft Research Plan was posted from June 14 to July 17, 2018. Comments addressed the types of eligible interventions, selection of outcomes, eligible settings, clarity about included populations, and integration of findings with the diabetes review. Clarifying text was added to the intervention inclusion and exclusion criteria. Waist circumference was added as an outcome, and cardiorespiratory fitness was explicitly listed as an included intermediate outcome. The setting description was broadened to include the term primary care-referable in addition to primary care-generalizable. With respect to included populations, language in the KQs was clarified, and the condition definition in the inclusion and exclusion criteria table was modified to explicitly define the included populations; newly included in this update are populations with elevated blood pressure in addition to populations with hypertension. The draft version of this report was reviewed by three invited experts and 9 individuals at 5 USPSTF Federal Partner agencies. Experts were selected based on their expertise with fundamental methodologic and content aspects of the review (i.e., nutrition, physical activity, hypertension, and dyslipidemia, CVD epidemiology, and population health) and were selected to obtain diverse informed perspectives. All expert comments were considered, and selected comments from experts were used to clarify and extend the synthesis of evidence to ensure accuracy and address scientifically relevant concerns. All comments were shared with members of the USPSTF and the Agency for Healthcare Research and Quality (AHRQ). Finally, a draft report was posted for public comment on the AHRQ website from May 12 to June 9, 2020. Additional minor modifications were made in response to comments received, including some added detail, minor clarifications, and mention of additional evidence limitations.

## USPSTF Involvement

This systematic review was funded by AHRQ under contract to support the USPSTF. We consulted with USPSTF liaisons at key points in the review regarding the development of the research plan (i.e., KQs, analytic framework, and inclusion and exclusion criteria) and the finalization of the systematic review. An AHRQ Medical Officer provided project oversight, reviewed the draft and final versions of the review, and assisted with public comment on the research plan and draft review. The USPSTF and AHRQ had no role in the study selection, quality assessment, or writing of the systematic review.