# Chapter 1 Introduction

## Purpose

This report will be used by the United States Preventive Services Task Force (USPSTF) to update its 2014 recommendation on behavioral counseling to promote a healthy diet and physical activity for cardiovascular disease (CVD) prevention in adults with cardiovascular risk factors.^1^

## Condition Background

### Condition Definition

#### CVD Risk Factors

For the purposes of this review, adults with CVD risk factors are defined as individuals with hypertension, dyslipidemia, impaired fasting glucose/impaired glucose tolerance, metabolic syndrome, or calculated 10-year CVD risk of 7.5 percent or greater. Because of the broad and multicomponent nature of cardiovascular risk, not all features of elevated risk are captured by this definition.

#### Diet

Healthy eating includes a balance and variety of foods and beverages that assist people in achieving and maintaining a healthy weight, supporting health, and preventing disease. For the purposes of this review, we consider any dietary counseling that focuses on increasing consumption of fruits, vegetables, whole grains, fat-free or low-fat dairy, lean proteins, and oils, and decreasing consumption of foods with high sodium levels, saturated- or trans fats, and added sugars, as recommended by the United States Department of Agriculture (USDA).^2^ This guidance is generally consistent with dietary recommendations of a number of professional medical organizations as well as the USDA (Table 1).^3–8^

Table 1 U.S. Dietary Intake and Physical Activity Recommendations

Recommendations category | Category | Amount
Dietary^2^ | Fiber | 28 g/day
Dietary^2^ | Vegetables | 2.5 c-eq
Dietary^2^ | Fruits | 2 c-eq
Dietary^2^ | Saturated fat | <20 g/day
Dietary^2^ | Sodium | <2,300 mg/day
Dietary^2^ | Potassium | 4,700 mg/day
Physical activity^9^ | Sedentary behavior | All adults should avoid inactivity. Some physical activity is better than none, and adults who participate in any amount of physical activity gain some health benefits.
Physical activity^9^ | Moderate-to-vigorous physical activity | ≥150 minutes per week of moderate-intensity, or ≥75 minutes per week of vigorous-intensity aerobic physical activity, or an equivalent combination of moderate- and vigorous-intensity aerobic activity.
Physical activity^9^ | Moderate-to-vigorous physical activity | ≥2 days per week muscle-strengthening activities that involve all major muscle groups.

Abbreviations: c-eq = cup equivalents; g/day = grams per day; mg/day = milligrams per day

#### Physical Activity

Physical activity is broadly defined as any bodily activity that enhances or maintains overall health and physical fitness. Prominent organizations have most recently recommended that adults 18 years and older engage in at least 150 minutes of moderate-intensity or 75 minutes of vigorous-intensity aerobic physical activity per week in addition to engaging in strengthening activities at least twice per week.^3,^ ^9^ These guidelines emphasize that some physical activity is better than none.

### Burden of Preventable Illness

CVD is the leading cause of death in the United States for both men and women, and most ethnicities, including Hispanics, African Americans, and whites.^10,^ ^11^ In 2016, CVD was the underlying cause of 840,678—or 1 in 3—deaths.^12^ CVD prevalence is higher in males (9.6%) than females (8.47%), and is higher for African Americans (10.7% for males, 10.5% for females) than whites (9.76% for males, 8.1% for females among non-Hispanic whites; prevalence is comparable or lower for Hispanics and Asians).^12^ CVD prevalence increases with age; among males, CVD prevalence is 7.5 percent among those age 40 to 59 years, 25.1 percent among those age 60 to 79 years, and 43.3 percent among those age 80 and older.^12^ Between 2008 and 2010, CVD death rates in the United States were highest in the South and lowest in the West.^10^ The American Heart Association (AHA) estimates that by 2035, over 130 million adults in the US will have some form of CVD.^13^

### Risk Factors

Risk factors for CVD are well-established, multicomponent, and common in adults. Modifiable risk factors include dyslipidemia or hyperlipidemia (referred to as dyslipidemia in this report), hypertension, diabetes, overweight and obesity, smoking, lack of physical activity, and unhealthy diet.^14–16^ Nonmodifiable risk factors include age, sex, and family history.^14,^ ^16^ The CDC estimates that nearly half of all U.S. adults age 20 years or older have at least one of the following CVD risk factors: uncontrolled hypertension; uncontrolled, elevated low-density lipoprotein (LDL) cholesterol level; or use of tobacco. Prevalence of risk factors defined by the AHA’s “Life’s Simple 7” similarly show the pervasiveness of modifiable risk factors (Table 2).^12^

Table 2 Prevalence of Risk Factors Defined by the AHA’s Life’s Simple 7^*^,^12^

Risk factor | Definition of Intermediate or Poor | Age 20-39 (%) | Age 40-59 (%) | Age ≥60 (%)
Smoking | Smoker or quit <12 months ago | 25.0 | 23.0 | 13.5
Body mass index | BMI ≥25 kg/m^2^ | 63.7 | 74.6 | 74.4
Physical activity | <150 mins/week moderate or <75 mins/week vigorous or equivalent combination of moderate and vigorous | 55.0 | 65.8 | 73.3
Healthy diet score | <4–5 Diet goals met^†^ | 100 | 99.8 | 99.6
Total cholesterol | ≥200 mg/dL or not reaching treatment goal | 27.1 | 61.0 | 74.8
Blood pressure | SBP ≥120 mm Hg or DBP ≥80 mm Hg or not reaching treatment goal | 38.3 | 65.9 | 74.8
Fasting plasma glucose | ≥100 mg/dL or not reaching treatment goal | 21.5 | 42.3 | 64.6

Abbreviations: BMI = body mass index; DBP = diastolic blood pressure; kg/m^2^ = kilograms per meter squared; mg/dL = milligrams per deciliter; mins = minutes; mm Hg = millimeters of mercury; SBP = systolic blood pressure

* Percentages represent those with intermediate or poor cardiovascular health

† In the context of a healthy dietary pattern that is consistent with a Dietary Approaches to Stop Hypertension (DASH)–type eating pattern, with goals to: (1) consume ≥4.5 cups/day of fruits and vegetables, (2) ≥2 servings/wk of fish, and (3) ≥3 servings/day of whole grains, (4) and no more than 36 ounces/week of sugar-sweetened beverages and (5) 1500 mg/day of sodium.

Cardiovascular risk can be characterized as the elevation of a single risk factor or can be quantitatively estimated from multivariate risk tools that are readily available in primary care. The most recent of these are the Pooled Cohort Equations, which estimate the 10-year risk of a cardiovascular event through application of the variables of age, sex, race, total and high-density lipoprotein cholesterol, blood pressure (including treatment status), current smoking, and diabetes.^17^ Thresholds for pharmacologic treatment with statins are recommended as 10 percent by the USPSTF and 7.5 percent by the American College of Cardiology/American Heart Association (ACC/AHA) (and considered when risk is 5 to 7.5% in the presence of risk-enhancing factors).^3,^ ^18^ Recent guidance for adults from the AHA/ACC recommends lifestyle modification when BP is 130–139/80–89 mm Hg and estimated risk is less than 10 percent, and blood pressure-lowering medication when blood pressure is greater than 130/80 mm Hg and 10-year risk is greater than 10 percent.^19^ Treatment thresholds recommended by guidelines and definitions around elevated values have generally decreased over time.

### Dietary and Physical Activity Behaviors: Association With Health Outcomes and Prevalence in the United States

Large observational studies show that healthy diet and physical activity are associated with lower cardiovascular and all-cause mortality.^20–24^ The U.S. Burden of Disease Collaborators found that poor diet was the leading risk factor contributing to death in the United States in 2016—even greater than tobacco smoking; physical inactivity and low physical activity were also among the leading risk factors for death.^25^ A risk assessment study utilizing National Health and Nutrition Examination Survey (NHANES) data estimated that dietary factors were associated with 45.4 percent of deaths due to heart disease, stroke, or diabetes; high sodium, high intake of processed meats, and low fruit and vegetable intake were the dietary components conferring the highest risk.^26^

Despite observational evidence for associations between these behaviors and outcomes, current diet and physical activity behaviors in the United States are suboptimal. Data from the 2015 Behavioral Risk Factor Surveillance System (BRFSS) found only 12.2 percent of adults meet the daily recommendation of 1.5 to 2.0 cups of fruit each day and 9.3 percent of adults met the vegetable consumption target of 2.0 to 3.0 cups per day.^27^. Based on 2013 BRFSS data, an estimated 36.8 percent of U.S. adults met the criteria for the 2014 USPSTF recommendation for intensive behavioral counseling for CVD prevention in adults with risk factors, based on self-reported BMI of 25 or greater and the presence of hypertension, dyslipidemia, or impaired fasting glucose.^28^ Adults ≥65 years (56.4%), non-Hispanic blacks (43.3%), and men (40%) were most likely to meet criteria for behavioral counseling according to the existing USPSTF recommendation.^28^ Of the AHA’s seven components of ideal cardiovascular health—smoking, BMI, physical activity, healthy diet, total cholesterol, blood pressure, and fasting plasma glucose—the proportion of Americans meeting targets for a healthy diet is consistently the lowest among all age groups (Table 2).^11^ There are some indications of progress, however, as NHANES data show that overall dietary pattern score improved between 1999 and 2016, with slight increases in carbohydrates from high quality sources, including whole grains (+2.95 g/day, p<.001), whole fruits (1.21 g/day, p<.001), non-starchy vegetables (0.44 g/day, p<.001); protein from nuts (+0.44 g/day, p<.001) and legumes (+0.13 g/day, p<.001); and decreased consumption of added sugar (−7.0 g/day, p<.001).^29,27^ Progress was uneven, however^27^. The largest improvements in Healthy Eating Index scores were among younger adults and those with high income and education; no differences in eating trends were found by sex or race/ethnicity^27^.

More U.S. adults are meeting physical activity guidelines than dietary recommendations; however, the proportion is still low. As of 2018, 54.2 percent of U.S. adults ≥18 years are meeting leisure-time aerobic physical activity goals.^30^ However, only 24.0 percent are meeting both the aerobic and muscle-strengthening guidelines.^30^ Older people, women of any age, and Hispanics are less likely to meet either of these guidelines.^30^ Fortunately, recent trends suggest physical activity among adults in the United States is improving.^31,^ ^32^

### Behavioral Counseling Approaches

Most behavioral counseling interventions to reduce cardiovascular risk among those with elevated blood pressure or lipids address both diet and physical activity, although some focus on only one of these. The interventions can include goal setting, self-monitoring, feedback and reinforcement, self-efficacy enhancement, incentives, modeling, problem-solving, and motivational interviewing.^4^ These interventions are typically delivered by specially trained health professionals (e.g., health educator, dietitian)^1^ and can take different formats, including brief counseling by a primary care provider, with or without accompanying materials or followup counseling; mailed, print-based interventions with tailored feedback; individual or group counseling; telephone counseling with no face-to-face contact; and computer-based interventions, including web-based sessions, email, or mobile technology.^4^ Additionally, support that addresses barriers to change, social support, and general education and advice regarding the benefits of healthy eating or physical activity can be provided.^4^ Some interventions included addition of cardiovascular-related components such as smoking cessation support and stress management. Most interventions also encourage weight loss among patients with excess weight.

### Current Clinical Practice in the United States and Recent Recommendations

Numerous organizations, including the AHA, Academy of Nutrition and Dietetics, and Department of Veterans Affairs, recommend that all adults adhere to a healthy lifestyle, which includes a balanced diet low in sodium and saturated fats, and regular exercise. Lifestyle counseling for weight loss is additionally recommended for people with overweight or obesity. Details of these and other recommendations appear in Table 3.

Table 3 Other Relevant Guidelines on Diet and Physical Activity for CVD Risk Reduction

Organization; Title (year) | Recommendation(s)
American Academy of Family Physicians; Management of Blood Cholesterol (2019)^329^ | The AAFP refer to and affirm the ACC/AHA 2018 guideline on management of blood cholesterol^8^ which recommends that a heart-healthy lifestyle should be emphasized for all individuals. Lifestyle therapy should be the primary intervention for metabolic syndrome.
American College of Cardiology/American Heart Association; Guideline on the Primary Prevention of Cardiovascular Disease, 2019^3^ | All adults should consume a diet emphasizing intake of vegetables, fruits, legumes, nuts, whole grains and fish; replacement of saturated fat with dietary monounsaturated and polyunsaturated fats; reduced amounts of cholesterol and sodium; minimized intake of processed meats, refined carbohydrates, and sweetened beverages; and intake of trans fats avoided.; For adults with overweight and obesity, counseling and comprehensive lifestyle interventions, including caloric restriction are recommended for achieving and maintaining weight loss.; Adults should be routinely counseled in healthcare visits to optimize a physically active lifestyle and should engage in at least 150 minutes per week of accumulated moderate-intensity or 75 minutes per week of vigorous-intensity aerobic physical activity (or an equivalent combination of moderate and vigorous activity). For adults unable to meet the minimum physical activity recommendations, engaging in some moderate- or vigorous-intensity physical activity, even if less than this recommended amount, can be beneficial. Decreasing sedentary behavior in adults may be reasonable to reduce ASCVD risk.; In adults with elevated blood pressure (BP) or hypertension, including those requiring antihypertensive medications, nonpharmacological interventions are recommended to reduce BP. These include:; - weight loss; - a heart-healthy dietary pattern; - sodium reduction; - dietary potassium supplementation; - increased physical activity with a structured exercise program; and; - limited alcohol
US Department of Health and Human Services; Physical Activity Guidelines for Americans, 2^nd^ edition, 2018 ^9^ | For the general adult population:; - Adults should move more and sit less throughout the day. Some physical activity is better than none. Adults who sit less and do any amount of moderate-to-vigorous physical activity gain some health benefits.; - For substantial health benefits, adults should do at least 150 minutes (2 hours and 30 minutes) to 300 minutes (5 hours) a week of moderate-intensity, or 75 minutes (1 hour and 15 minutes) to 150 minutes (2 hours and 30 minutes) a week of vigorous-intensity aerobic physical activity, or an equivalent combination of moderate- and vigorous-intensity aerobic activity. Preferably, aerobic activity should be spread throughout the week.; - Additional health benefits are gained by engaging in physical activity beyond the equivalent of 300 minutes (5 hours) of moderate-intensity physical activity a week.; - Adults should also do muscle-strengthening activities of moderate or greater intensity and that involve all major muscle groups on 2 or more days a week, as these activities provide additional health benefits; PA in adults with chronic health conditions:; - When adults with chronic conditions or disabilities are not able to meet the above key guidelines, they should engage in regular physical activity according to their abilities and should avoid inactivity.
American Association of Clinical Endocrinologists and American College of Endocrinology; Guidelines for Management of Dyslipidemia and Prevention of Cardiovascular Disease, 2017 ^5^ | A comprehensive strategy to control lipid levels and address associated metabolic abnormalities and modifiable risk factors is recommended primarily using lifestyle changes and patient education with pharmacotherapy as needed to achieve evidence-based targets. A reasonable and feasible approach to fitness therapy (i.e., exercise programs that include at least 30 minutes of moderate-intensity physical activity [consuming 4–7 kcal/min] 4 to 6 times weekly, with an expenditure of at least 200 kcal/day) is recommended; suggested activities include brisk walking, riding a stationary bike, water aerobics, cleaning/scrubbing, mowing the lawn, and sporting activities. Daily physical activity goals can be met in a single session or in multiple sessions throughout the course of a day (10 minutes minimum per session); for some individuals, breaking activity up throughout the day may help improve adherence with physical activity programs. In addition to aerobic activity, muscle-strengthening activity is recommended at least 2 days a week. For adults, a reduced-calorie diet consisting of fruits and vegetables (combined ≥5 servings/day), grains (primarily whole grains), fish, and lean meats is recommended. For adults, the intake of saturated fats, transfats, and cholesterol should be limited, while LDLC-lowering macronutrient intake should include plant stanols/sterols (~2 g/day) and soluble fiber (10–25 g/day).
American Association of Clinical Endocrinologists and American College of Endocrinology; Comprehensive Clinical Practice Guidelines for Medical Care of Patients with Obesity, 2017 ^6^ | Patients with overweight or obesity and dyslipidemia (elevated triglycerides and reduced HDL-c) should be treated with lifestyle therapy to achieve 5 to 10% weight loss or more as needed to achieve therapeutic targets. The lifestyle intervention should include a physical activity program and a reduced-calorie healthy meal plan that minimizes sugars and refined carbohydrates, avoids trans fats, limits alcohol use, and emphasizes fiber.; Patients with overweight or obesity and elevated blood pressure or hypertension should be treated with lifestyle therapy to achieve 5 to 15% weight loss or more as necessary to achieve blood pressure reduction goals in a program that includes caloric restriction and regular physical activity.
Academy of Nutrition and Dietetics; Hypertension evidence-based nutrition practice guideline, 2015 ^330^ | Medical Nutrition Therapy (MNT) provided by a registered dietitian nutritionist (RDN) is recommended to reduce blood pressure (BP) in adults with hypertension (HTN). To reduce BP in adults with HTN, the RDN should provide MTN encounters at least monthly for the first year. After the first year, the RDN should schedule follow-up sessions at least two to three times per year to maintain reductions in BP. The RDN should counsel on a DASH dietary pattern plus reduced sodium intake for BP reduction in adults with HTN. The RDN should encourage adults with HTN to engage in regular aerobic activity to lower BP. Physical activity should be of moderate intensity to vigorous intensity three to four times per week for an average of 40 minutes per session.
Department of Veterans Affairs / Department of Defense; VA/DoD Clinical Practice Guideline for the diagnosis and management of hypertension in the primary care setting, 2014 ^331^; Update in Progress | Offer lifestyle modification interventions for patients with prehypertension or hypertension based on patient indications and preferences as well as assessment of available local resources. Discuss healthy weight range and advising overweight or obese hypertensive patients to reduce their body mass index to below 25; if a normal body mass index (<25) cannot be achieved, advise patients that a weight reduction of at least 10 pounds can achieve a decrease in blood pressure. Target aerobic exercise at 30 to 45 minutes per session, at least four times per week and the use of a self-monitoring device (e.g., pedometer, mobile apps, etc.) to increase adherence to physical activity. Recommend a dietitian-led Dietary Approaches to Stop Hypertension (DASH) Diet for the treatment and/or prevention of hypertension for patients with hypertension and/or interested patients with prehypertension and other cardiovascular risk factors. In patients with additional cardiovascular risk factors, such as dyslipidemia, we suggest considering a dietitian-led Mediterranean Diet as an alternative to the DASH Diet. Recommend against the use of soy protein supplements for the treatment of hypertension. In patients with hypertension or prehypertension, sodium intake should be limited to no more than 2300 mg/day (100 mmol/day), with referral to a dietitian or other support as appropriate.; Advise hypertensive and prehypertensive patients to limit alcohol intake to no more than 1 oz per day for men or 0.5 oz of alcohol per day for women.
Department of Veterans Affairs / Department of Defense; VA/DoD Clinical Practice Guideline for the management of dyslipidemia for cardiovascular risk reduction, 2014 ^332^; Update in Progress | Recommend all adults adopt healthy lifestyles to reduce CVD risk, including Therapeutic Lifestyle Changes (TLC) diet to optimize nutrition and optimal physical activity per the 2008 physical activity guidelines.; Suggest offering high-risk patients a dietitian-monitored Mediterranean diet supplemented with either extra-virgin olive oil or mixed nuts for the reduction of CVD events.; Suggest that each patient’s diet be individualized based on a nutrition assessment other CVD risk factors, other disease conditions, and lifestyle.
American Academy of Family Physicians; Lifestyle Management to Reduce Cardiovascular Risk (2014)^7^ | The AAFP refer to and endorse the AHA/ACC 2014 guideline on lifestyle management to reduce cardiovascular risk^333^ which recommends the following:; Adults who would benefit from lowering of LDL-C and/or lowering of blood pressure should consume a dietary pattern that emphasizes intake of vegetables, fruits, and whole grains; includes low-fat dairy products, poultry, fish, legumes, non-tropical vegetable oils and nuts; and limits intake of sweets, sugar-sweetened beverages and red meats. Adults who would benefit from lowering of LDL-C should reduce the percent of calories in their diet that come from saturated- and trans-fat, and should aim for a dietary pattern that achieves 5–6% of calories from saturated fat.; Adults who would benefit from lowering of their blood pressure should lower their sodium intake, consuming no more than 2,400 mg of sodium per day. Further reduction of sodium to 1,500 mg/day is associated with an even greater reduction in blood pressure. Reducing intake of sodium by at least 1,000 mg/day will decrease blood pressure, even if the desired daily sodium intake is not achieved.; Adults should engage in aerobic physical activity to reduce LDL-C and non-HDL-C and to lower blood pressure. This should include 3–4 sessions per week lasting an average of 40 minutes per session and involving moderate-to-vigorous intensity physical activity.

The 2018 U.S. physical activity guidelines recommend that all adults engage in at least 150–300 minutes of moderate-intensity or 75–150 minutes a week of vigorous-intensity aerobic physical activity, or an equivalent combination of moderate- and vigorous-intensity aerobic activity in addition to engaging in strengthening activities at least twice per week. For adults with chronic conditions, including hypertension, who are not able to meet the key guidelines for general adult populations, the guideline recommends they engage in regular physical activity according to their abilities and should avoid inactivity.^9^

Despite these recommendations, counseling referral rates in primary care remain low and there are a number of barriers to referral from the clinician’s perspective. A 2015 survey of U.S. primary care providers found that 58.6 percent discussed physical activity with most of their patients with CVD risk factors.^33^ Nearly all providers that reported discussing physical activity with their patients reported encouraging increased physical activity (98.5%), but only 8.1 percent actually referred at-risk patients to intensive behavioral counseling. A major barrier to low rates of referral included attitudes and beliefs of providers that “patients won’t do it” (53.4% of providers) and that “counseling is ineffective” (10%).^33^ With respect to system-level barriers, “not enough time during visit” (60.9%), “insurance doesn’t cover it” (12.1%) and “referral services aren’t available” (11.4%) were among the barriers cited.

These findings are supported by other studies assessing treatment of at-risk patients in primary care. A 2014 review of physicians’ use of the 5 A’s model for weight loss counseling (Assess, Advise, Agree, Assist and Arrange) found that physicians frequently asked about or assessed patients’ behavioral habits and readiness for change and provided behavior change advice, but rarely assisted patients in achieving goals or arranging support or referral to more intensive treatment.^34^ Another review found that general practitioners tended to provide very little combined diet and physical activity advice to patients who were overweight or had obesity.^35^ A survey of practitioners found that while 70 percent encountered conditions related to nutrition on a daily or weekly basis, only 25 percent felt “very confident” in providing nutrition advice.^36^ It was also found that physicians infrequently referred patients to specialists such as dietitians for tailored interventions and advice.^35^

## Previous USPSTF Recommendation

In 2014, the Task Force recommended offering or referring adults who were overweight or had obesity and had additional CVD risk factors to intensive behavioral counseling interventions to promote a healthy diet and physical activity for CVD prevention (Grade: B recommendation).^1^ Specific guidance was not provided on what constituted an “intensive” intervention, but the recommendation statement noted that effective interventions involved multiple contacts over an extended period of time, typically 5 to 16 contacts over 9 to 12 months. This recommendation applied to adults age 18 years or older in primary care settings who were overweight or had obesity and known CVD risk factors, defined as hypertension, dyslipidemia, impaired fasting glucose, or the metabolic syndrome. The USPSTF maintains reviews and recommendations for a number of other conditions associated with increased cardiovascular risk, including obesity, smoking, diabetes, lipids, peripheral artery disease, carotid artery stenosis, and nontraditional risk factors.^37–43^ Because these risk factors and conditions frequently coexist with those encompassed in this review, there exists some overlap of included populations and interventions. The recommendations related to behavioral counseling in adults without risk factors, those with abnormal blood glucose levels or diabetes, and those with obesity are particularly inter-related and are shown in Table 4. The recommendation on screening and treatment of adults for abnormal blood glucose is being updated concurrently with this recommendation.

Table 4 Related USPSTF Behavioral Counseling Recommendations

Risk Factors | Normal Weight (BMI 18.5 to <25)^*^ | Overweight (BMI 25 to <30)^*^,^‡^ | Obese (BMI ≥30)^*^,^‡^
No hypertension, dyslipidemia, or abnormal blood glucose levels | Individualize the decision to provide or refer to behavioral counseling^334^ | Individualize the decision to provide or refer to behavioral counseling^334^ | Provide or refer to intensive behavioral counseling^335^
Hypertension, dyslipidemia, or both | Individualize the decision to provide or refer to behavioral counseling^334^,^†^ | Provide or refer to intensive behavioral counseling^1^ | Provide or refer to intensive behavioral counseling^1,^ ^335^
Abnormal blood glucose levels or diabetes | Provide or refer to intensive behavioral counseling^43^ | Provide or refer to intensive behavioral counseling^1,^ ^43^ | Provide or refer to intensive behavioral counseling^1,^ ^43,^ ^335^

Abbreviations: BMI = body mass index; USPSTF = US Preventive Services Task Force

* BMI calculated as weight in kilograms divided by the square of height in meters.

† From the “Other Considerations” section of the referenced recommendation statement

‡ The 2015 USPSTF recommendation also recommends screening for abnormal blood glucose levels as part of cardiovascular risk assessment in adults aged 40 to 70 years who are overweight or have obesity. Patients with certain risk factors (family history of diabetes, personal history of gestational diabetes or polycystic ovarian syndrome, or being a member of certain racial/ethnic groups [African Americans, American Indians or Alaskan Natives, Asian Americans, Hispanics or Latinos, or Native Hawaiians or Pacific Islanders]) may also be at increased risk of diabetes at a younger age or at a lower BMI and should be considered for earlier screening.^43^