# Appendix I Ongoing Studies

Trial Identifier | Principal Investigator | Study Name | Country | Estimated N | Purpose (as reported) | Estimated Completion Date
NCT02342808 (https://clinicaltrials.gov/ct2/show/record/NCT02342808) | James A. Blumenthal, PhD | Lifestyle Interventions in Treatment-Resistant Hypertension (TRIUMPH) | US | 150 | To examine the effects of a lifestyle intervention on fitness, dietary habits, and body weight in patients with resistant hypertension | December 2019
NCT01180673 (https://clinicaltrials.gov/ct2/show/NCT01180673) | Olugbenga Ogedegbe, MD | Counseling Older Adults to Control Hypertension (COACH) | US | 251 | To evaluate the effect of a senior center-based comprehensive therapeutic lifestyle intervention delivered through group-based counseling and motivational interviewing among hypertensive African American or Latino seniors aged ≥60 years | Completed as of March 2019. Awaiting publication of results.
ISRCTN18008011 (http://www.isrctn.com/ISRCTN18008011) | Oliver Peacock, PhD | Multidimensional Individualized Physical Activity profiles for behavior Change using Technology (MiPACT) | UK | 216 | To examine whether personalized multidimensional physical activity feedback and self-monitoring using a web-based platform alongside in-person advice supports an increase in physical activity and weight loss in men and women at risk for future chronic disease | Completed as of November 2018. Awaiting publication of results.
ACTRN12613000715774 (https://www.anzctr.org.au/Trial/Registration/TrialReview.aspx?id=364471) | Julie Redfern, PhD | Consumer Navigation of electronic cardiovascular Tools (CONNECT) | AUS | 934 | To test whether a consumer-focused e-health strategy provided to Aboriginal and Torres Strait Islander and non-indigenous adults, recruited through primary care, at moderate-to-high risk of a cardiovascular disease event will improve risk factor control when compared with usual care | NR – Ongoing as of August, 2018
NCT02283697 (https://clinicaltrials.gov/ct2/show/NCT02283697) | Marcel Ruzicka, MD, PhD | Dietary Counseling to Reduce Salt Intake in Patients With High Blood Pressure | CAN | 120 | To test the efficacy of a structured counseling session by a registered dietitian in addition to usual care on sodium intake and blood pressure compared with usual care alone | December 2019
NCT02551640 (https://clinicaltrials.gov/ct2/show/NCT02551640) | Kamal Jethwani, MD | Improving Physical Activity Through a mHealth Intervention in Cardio-metabolic Risk Patients | US | 300 | To examine the effects of a smartphone-based physical activity-focused application in patients with cardiometabolic risk factors compared with usual care | December 2018. Awaiting publication of results.
NCT01838226 (https://clinicaltrials.gov/ct2/show/record/NCT01838226) | David Edelman, MD | Randomized Controlled Trial of Group Prevention Coaching | US | 401 | To test the effectiveness of a group prevention coaching (GPC) intervention in improving cardiovascular risk | Completed June, 2019. Awaiting publication of results
NCT03052959 (https://clinicaltrials.gov/ct2/show/study/NCT03052959) | Lawrence Paszat, MD | BETTER HEALTH: Durham | US | 120 | To examine the effectiveness of supportive meetings between a specially trained prevention practitioner nurse and individuals aged 40–64 years to review recommended chronic disease prevention and screening activities (CDPS) | July 2019
NCT03164499 (https://clinicaltrials.gov/ct2/show/NCT03164499) | Sara Mora Simón, PhD | Intensive Intervention to Improve Lifestyles in Subjects With Intermediate Cardiovascular Risk | ESP | 203 | To evaluate the effectiveness of an intensive intervention to modify lifestyles of subjects with intermediate cardiovascular risk | Completed March 2019. Awaiting publication of results.
NCT03092960 (https://clinicaltrials.gov/ct2/show/NCT03092960) | Lisa Goldman Rosas, PhD | Comparing Two Innovative Approaches to Reduce Chronic Disease Risk Among Latino Men (HOMBRE) | US | 424 | To test a flexible lifestyle program designed to help Latino men make healthy lifestyle changes to lower their risk of developing diabetes and heart disease | July 2020
ISRCTN76069254 (http://www.isrctn.com/ISRCTN76069254) | Aina Riera, PhD | Effectiveness of a brief multifactorial intervention in adherence to physical exercise prescription of moderate to high cardiovascular risk patients | ESP | 616 | To evaluate the effectiveness of a brief multifactorial intervention designed to improve the adherence to physical exercise prescription of moderate to high cardiovascular risk patients | Completed December 2017. Awaiting publication of results.
NCT02725203 (https://clinicaltrials.gov/ct2/show/record/NCT02725203) | Marieke J. Schuurmans, PhD | Unravelling Effectiveness of a Nurse-led Behavior Change Intervention to Enhance Physical Activity in Patients | NLD | 195 | To evaluate the effectiveness of the Active intervention, consisting of four nurse-led consultations over 3-months in patients at risk for cardiovascular disease | Completed October 2018. Awaiting publication of results.
ISRCTN54638034 (https://doi.org/10.1186/ISRCTN54638034) | Varun Anand, MBChB, BMedSc | Communicating cardiovascular disease risk in UK primary care | UK | 60 | To investigate the effects of GPs using heart age to communicate the risk of CVD to patients | Completed 2018. Awaiting publication of results.
ISRCTN89898870 (http://www.isrctn.com/ISRCTN89898870) | Jordi Salas-Salvadó, MD, PhD | PREDIMED-Plus | ESP | 6874 | To evaluate whether intensive interventions involving an energy-restricted Mediterranean diet, promotion of physical activity, and behavioral support are likely to result in long-term weight loss, reduced CVD risk, and greater quality of life for older people with metabolic syndrome. | May 2020
NCT03577990 (https://clinicaltrials.gov/ct2/show/NCT03577990) | Willie M Abel, PhD | Interactive Technology-Enhanced Coaching (ITEC) | US | 90 | To evaluate the effectiveness of a technology coaching Intervention for black women with hypertension. | May 2022
NCT02499731 (https://clinicaltrials.gov/ct2/show/NCT02499731) | Rebecca A. Seguin-Fowler, PhD | Strong Hearts: Rural CVD Prevention | US | 194 | To evaluate the efficacy of the Strong Hearts Healthy Communities (SHHC) curriculum in a 24-week community based randomized controlled intervention trial in an underserved rural population. | February 2022

## Appendix References

1 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force: 2015.
2 Wells G, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed: April 10, 2019.
3 Patnode CD, Evans CV, Senger CA, . Behavioral Counseling to Promote a Healthful Diet and Physical Activity for Cardiovascular Disease Prevention in Adults Without Known Cardiovascular Disease Risk Factors: Updated Systematic Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2017 Jul. Report No.: 15-05222-EF-1. Agency for Healthcare Research and Quality. 2017:07. PMID: 2936462029364620.
4 Shrank WH, Patrick AR, Brookhart MA. Healthy user and related biases in observational studies of preventive interventions: a primer for physicians. J Gen Intern Med. 2011;26(5):546–50. PMID: 21203857. 10.1007/s11606-010-1609-1 21203857
5 Banegas JR, Ruilope LM, de la Sierra A, . Relationship between clinic and ambulatory blood-pressure measurements and mortality. N Engl J Med. 2018;378(16):1509–20. PMID: 29669232. 10.1056/NEJMoa1712231 29669232
6 Lewington S, Clarke R, Qizilbash N, . Age-specific relevance of usual blood pressure to vascular mortality: a meta-analysis of individual data for one million adults in 61 prospective studies. Lancet. 2002;360(9349):1903–13. PMID: 12493255. 10.1016/s0140-6736(02)11911-8 12493255
7 Blood Pressure Lowering Treatment Trialists Collaboration. Blood pressure-lowering treatment based on cardiovascular risk: a meta-analysis of individual patient data. Lancet. 2014;384(9943):591–8. PMID: 25131978. 10.1016/S0140-6736(14)61212-5 25131978
8 Ettehad D, Emdin CA, Kiran A, . Blood pressure lowering for prevention of cardiovascular disease and death: a systematic review and meta-analysis. Lancet. 2016;387(10022):957–67. PMID: 26724178. 10.1016/S0140-6736(15)01225-8 26724178
9 Cook NR, Cutler JA, Obarzanek E, . Long term effects of dietary sodium reduction on cardiovascular disease outcomes: observational follow-up of the trials of hypertension prevention (TOHP). BMJ. 2007;334(7599):885–8. PMID: 17449506. 10.1136/bmj.39147.604896.55 17449506
10 Navarese EP, Robinson JG, Kowalewski M, . Association between baseline LDL-C level and total and cardiovascular mortality after LDL-C lowering: a systematic review and meta-analysis. JAMA. 2018;319(15):1566–79. PMID: 29677301. 10.1001/jama.2018.2525 29677301
11 Prospective Studies Collaboration, Lewington S, Whitlock G, . Blood cholesterol and vascular mortality by age, sex, and blood pressure: a meta-analysis of individual data from 61 prospective studies with 55,000 vascular deaths. Lancet. 2007;370(9602):1829–39. PMID: 18061058. 10.1016/S0140-6736(07)61778-4 18061058
12 Rao Kondapally Seshasai S, Kaptoge S, Thompson A, . Diabetes mellitus, fasting glucose, and risk of cause-specific death. N Engl J Med. 2011;364(9):829–41. PMID: 21366474. 10.1056/NEJMoa1008862 21366474
13 Lin JS, O’Connor EA, Evans CV, . Behavioral Counseling to Promote a Healthy Lifestyle for Cardiovascular Disease Prevention in Persons With Cardiovascular Risk Factors: An Updated Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2014. Available from: https://www.ncbi.nlm.nih.gov/pubmed/25232633.
14 Prospective Studies Collaboration, Whitlock G, Lewington S, . Body-mass index and cause-specific mortality in 900 000 adults: collaborative analyses of 57 prospective studies. Lancet. 2009;373(9669):1083–96. PMID: 19299006. 10.1016/S0140-6736(09)60318-4 19299006
15 Afzal S, Tybjaerg-Hansen A, Jensen GB, . Change in body mass index associated with lowest mortality in Denmark, 1976-2013. JAMA. 2016;315(18):1989–96. PMID: 27163987. 10.1001/jama.2016.4666 27163987
16 Cerhan JR, Moore SC, Jacobs EJ, . A pooled analysis of waist circumference and mortality in 650,000 adults. Mayo Clin Proc. 2014;89(3):335–45. PMID: 24582192. 10.1016/j.mayocp.2013.11.011 24582192
17 Asia Pacific Cohort Studies Collaboration. Central obesity and risk of cardiovascular disease in the Asia Pacific Region. Asia Pac J Clin Nutr. 2006;15(3):287–92. PMID: 16837418.16837418
18 Aune D, Giovannucci E, Boffetta P, . Fruit and vegetable intake and the risk of cardiovascular disease, total cancer and all-cause mortality-a systematic review and dose-response meta-analysis of prospective studies. Int J Epidemiol. 2017;46(3):1029–56. PMID: 28338764. 10.1093/ije/dyw319 28338764
19 Wang X, Ouyang Y, Liu J, . Fruit and vegetable consumption and mortality from all causes, cardiovascular disease, and cancer: systematic review and dose-response meta-analysis of prospective cohort studies. BMJ. 2014;349:g4490. PMID: 25073782. 10.1136/bmj.g4490 25073782
20 Kim Y, Je Y. Dietary fiber intake and total mortality: a meta-analysis of prospective cohort studies. Am J Epidemiol. 2014;180(6):565–73. PMID: 25143474. 10.1093/aje/kwu174 25143474
21 Beresford SA, Johnson KC, Ritenbaugh C, . Low-fat dietary pattern and risk of colorectal cancer: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):643–54. PMID: 16467233. 10.1001/jama.295.6.643 16467233
22 Howard BV, Manson JE, Stefanick ML, . Low-fat dietary pattern and weight change over 7 years: the Women’s Health Initiative Dietary Modification Trial. JAMA. 2006;295(1):39–49. PMID: 16391215. 10.1001/jama.295.1.39 16391215
23 Howard BV, Van Horn L, Hsia J, . Low-fat dietary pattern and risk of cardiovascular disease: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):655–66. PMID: 16467234. 10.1001/jama.295.6.655 16467234
24 Prentice RL, Caan B, Chlebowski RT, . Low-fat dietary pattern and risk of invasive breast cancer: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. JAMA. 2006;295(6):629–42. PMID: 16467232. 10.1001/jama.295.6.629 16467232
25 Li Y, Hruby A, Bernstein AM, . Saturated fats compared with unsaturated fats and sources of carbohydrates in relation to risk of coronary heart disease: a prospective cohort study. J Am Coll Cardiol. 2015;66(14):1538–48. PMID: 26429077. 10.1016/j.jacc.2015.07.055 26429077
26 Sacks FM, Lichtenstein AH, Wu JHY, . Dietary fats and cardiovascular disease: a Presidential advisory from the American Heart Association. Circulation. 2017;136(3):e1–e23. PMID: 28620111. 10.1161/CIR.0000000000000510 28620111
27 Harcombe Z. Dietary fat guidelines have no evidence base: where next for public health nutritional advice? Br J Sports Med. 2017;51(10):769–74. PMID: 27797736. 10.1136/bjsports-2016-096734 27797736
28 US Department of Health and Human Services, US Department of Agriculture. 2015-2020 Dietary Guidelines for Americans. 8th edition. http://health.gov/dietaryguidelines/2015/guidelines/. Accessed: August 7, 2019.
29 US Department of Health and Human Services. Physical Activity Guidelines for Americans. 2nd ed. Wasington, DC: US Dept of Health and Human Services; 2018. https://health.gov/paguidelines/second-edition/pdf/Physical_Activity_Guidelines_2nd_edition.pdf. Accessed: May 25, 2019.
30 Arem H, Moore SC, Patel A, . Leisure time physical activity and mortality: a detailed pooled analysis of the dose-response relationship. JAMA Intern Med. 2015;175(6):959–67. PMID: 25844730. 10.1001/jamainternmed.2015.0533 25844730
31 Lear SA, Hu W, Rangarajan S, . The effect of physical activity on mortality and cardiovascular disease in 130 000 people from 17 high-income, middle-income, and low-income countries: the PURE study.[Erratum appears in Lancet. 2017 Dec 16;390(10113):2626; PMID: 28988792]. Lancet. 2017;390(10113):2643–54. PMID: 28943267. 10.1016/S0140-6736(17)31634-3 28943267
32 Wen CP, Wai JP, Tsai MK, . Minimum amount of physical activity for reduced mortality and extended life expectancy: a prospective cohort study. Lancet. 2011;378(9798):1244–53. PMID: 21846575. 10.1016/S0140-6736(11)60749-6 21846575
33 Brown DW, Balluz LS, Heath GW, . Associations between recommended levels of physical activity and health-related quality of life. Findings from the 2001 Behavioral Risk Factor Surveillance System (BRFSS) survey. Prev Med. 2003;37(5):520–8. PMID: 14572437.14572437
34 Kruger J, Bowles HR, Jones DA, . Health-related quality of life, BMI and physical activity among US adults (>/=18 years): National Physical Activity and Weight Loss Survey, 2002. Int J Obes (Lond). 2007;31(2):321–7. PMID: 16703001. 10.1038/sj.ijo.0803386 16703001
35 Wolin KY, Glynn RJ, Colditz GA, . Long-term physical activity patterns and health-related quality of life in U.S. women. Am J Prev Med. 2007;32(6):490–9. PMID: 17533064. 10.1016/j.amepre.2007.02.014 17533064
36 Tessier S, Vuillemin A, Bertrais S, . Association between leisure-time physical activity and health-related quality of life changes over time. Prev Med. 2007;44(3):202–8. PMID: 17208289. 10.1016/j.ypmed.2006.11.012 17208289
37 Wendel-Vos GC, Schuit AJ, Tijhuis MA, . Leisure time physical activity and health-related quality of life: cross-sectional and longitudinal associations. Qual Life Res. 2004;13(3):667–77. PMID: 15130029. 10.1023/B:QURE.0000021313.51397.33 15130029
38 Ammerman AS, Keyserling TC, Atwood JR, . A randomized controlled trial of a public health nurse directed treatment program for rural patients with high blood cholesterol. Prev Med. 2003;36(3):340–51. PMID: 12634025.12634025
39 Anderson JW, Garrity TF, Wood CL, . Prospective, randomized, controlled comparison of the effects of low-fat and low-fat plus high-fiber diets on serum lipid concentrations. Am J Clin Nutr. 1992;56(5):887–94. PMID: 1329482.1329482
40 Anderssen SAH, A.; Hjerman, I.; Urdal, P.; Gjesdal, K.; Holme, I. Oslo diet and exercise study: a one year randomized intervention trial. Efect on Haemostatic variables and other coronary risk factors. Nutr Metab Cardiovasc Dis. 1995;5:189–200. PMID: 8339552. 10.1016/0197-2456(93)90005-X 8339552
41 Appel LJ, Champagne CM, Harsha DW, . Effects of comprehensive lifestyle modification on blood pressure control: main results of the PREMIER clinical trial. JAMA. 2003;289(16):2083–93. PMID: 12709466. 10.1001/jama.289.16.2083 12709466
42 Appel L, Clark J, Yeh H, . Comparative effectiveness of weight-loss interventions in clinical practice. N Engl J Med. 2011;365(21):1959–68. PMID: 22085317 10.1056/NEJMoa1108660 22085317
43 Applegate WB, Miller ST, Elam JT, . Nonpharmacologic intervention to reduce blood pressure in older patients with mild hypertension. Arch Intern Med. 1992;152(6):1162–6. PMID: 1599343. 10.1001/archinte.1992.00400180034005 1599343
44 Arroll B, Beaglehole R. Salt restriction and physical activity in treated hypertensives. N Z Med J. 1995;108(1003):266–8. PMID: 7637923.7637923
45 Babazono A, Kame C, Ishihara R, . Patient-motivated prevention of lifestyle-related disease in Japan: A randomized, controlled clinical trial. Dis Manage Health Outcomes. 2007;15(2):119–26. PMID: None. 10.2165/00115677-200715020-00007
46 Beckmann SL, Os I, Kjeldsen SE, . Effect of dietary counselling on blood pressure and arterial plasma catecholamines in primary hypertension. Am J Hypertens. 1995;8(7):704–11. PMID: 7546496.7546496
47 Bennett GG, Warner ET, Glasgow RE, . Obesity treatment for socioeconomically disadvantaged patients in primary care practice. Arch Intern Med. 2012;172(7):565–74. PMID: 22412073 10.1001/archinternmed.2012.1 22412073
48 Bennett GG, Steinberg D, Askew S, . Effectiveness of an App and Provider Counseling for Obesity Treatment in Primary Care. Am J Prev Med. 2018. PMID: 30361140. 10.1016/j.amepre.2018.07.005 30361140
49 Beune EJ, Moll van Charante EP, Beem L, . Culturally adapted hypertension education (CAHE) to improve blood pressure control and treatment adherence in patients of African origin with uncontrolled hypertension: cluster-randomized trial. PLoS One. 2014;9(3):e90103. PMID: 24598584. 10.1371/journal.pone.0090103 24598584
50 Blackford K, Jancey J, Lee AH, . Home-based lifestyle intervention for rural adults improves metabolic syndrome parameters and cardiovascular risk factors: A randomised controlled trial. Prev Med. 2016;89:15–22. PMID: 27196148. 10.1016/j.ypmed.2016.05.012 27196148
51 Bloemberg BP, Kromhout D, Goddijn HE, . The impact of the Guidelines for a Healthy Diet of The Netherlands Nutrition Council on total and high density lipoprotein cholesterol in hypercholesterolemic free-living men. Am J Epidemiol. 1991;134(1):39–48. PMID: 1853859.1853859
52 Bo S, Ciccone G, Baldi C, . Effectiveness of a lifestyle intervention on metabolic syndrome. A randomized controlled trial. J Gen Intern Med. 2007;22(12):1695–703. PMID: 17922167. 10.1007/s11606-007-0399-6 17922167
53 Bosworth HB, Olsen MK, Grubber JM, . Two self-management interventions to improve hypertension control: a randomized trial. Ann Intern Med. 2009;151(10):687–95. PMID: 19920269. 10.7326/0003-4819-151-10-200911170-00148 19920269
54 Broekhuizen K, van Poppel MN, Koppes LL, . Can multiple lifestyle behaviours be improved in people with familial hypercholesterolemia? Results of a parallel randomised controlled trial. PLoS One. 2012;7(12):e50032. PMID: 23251355. 10.1371/journal.pone.0050032 23251355
55 Bruckert E, Giral P, Paillard F, . Effect of an educational program (PEGASE) on cardiovascular risk in hypercholesterolaemic patients. Cardiovasc Drugs Ther. 2008;22(6):495–505. PMID: 18830810. 10.1007/s10557-008-6137-4 18830810
56 Burke V, Beilin L, Cutt H, . A lifestyle program for treated hypertensives improved health-related behaviors and cardiovascular risk factors: a randomized controlled trial. J Clin Epidemiol. 2007;60(2):133–41. PMID: 17208119. 10.1016/j.jclinepi.2006.05.012 17208119
57 Chirinos DA, Goldberg RB, Llabre MM, . Lifestyle modification and weight reduction among low-income patients with the metabolic syndrome: the CHARMS randomized controlled trial. J Behav Med. 2016;39(3):483–92. PMID: 26846133. 10.1007/s10865-016-9721-2 26846133
58 Christian JG, Byers TE, Christian KK, . A computer support program that helps clinicians provide patients with metabolic syndrome tailored counseling to promote weight loss. J Am Diet Assoc. 2011;111(1):75–83. PMID: 21185968. 10.1016/j.jada.2010.10.006 21185968
59 Cicolini G, Simonetti V, Comparcini D, . Efficacy of a nurse-led email reminder program for cardiovascular prevention risk reduction in hypertensive patients: a randomized controlled trial. Int J Nurs Stud. 2014;51(6):833–43. PMID: 24225325. 10.1016/j.ijnurstu.2013.10.010 24225325
60 Cochrane T, Davey R, Iqbal Z, . NHS health checks through general practice: randomised trial of population cardiovascular risk reduction. BMC Public Health. 2012;12:944. PMID: 23116213. 10.1186/1471-2458-12-944 23116213
61 Cohen MD, D’Amico FJ, Merenstein JH. Weight reduction in obese hypertensive patients. Fam Med. 1991;23(1):25–8. PMID: 2001777.2001777
62 Coleman KJ, Farrell MA, Rocha DA, . Readiness to be physically active and self-reported physical activity in low-income Latinas, California WISEWOMAN, 2006-2007. Prev Chronic Dis. 2012;9:E87. PMID: 22515969. 10.5888/pcd9.110190 22515969
63 Delahanty LM, Sonnenberg LM, Hayden D, . Clinical and cost outcomes of medical nutrition therapy for hypercholesterolemia: a controlled trial. J Am Diet Assoc. 2001;101(9):1012–23. PMID: 11573752. 10.1016/S0002-8223(01)00250-4 11573752
64 Eakin E, Reeves M, Lawler S, . Telephone counseling for physical activity and diet in primary care patients. Am J Prev Med. 2009;36(2):142–9. PMID: 19062240. 10.1016/j.amepre.2008.09.042 19062240
65 Edelman D, Oddone EZ, Liebowitz RS, . A multidimensional integrative medicine intervention to improve cardiovascular risk. J Gen Intern Med. 2006;21(7):728–34. PMID: 16808774. 10.1111/j.1525-1497.2006.00495.x 16808774
66 Ellsworth DL, Costantino NS, Blackburn HL, . Lifestyle modification interventions differing in intensity and dietary stringency improve insulin resistance through changes in lipoprotein profiles. Obes Sci Pract. 2016;2(3):282–92. PMID: 27708845. 10.1002/osp4.54 27708845
67 Estruch R, Ros E, Salas-Salvado J, . Primary prevention of cardiovascular disease with a Mediterranean diet supplemented with extra-virgin olive oil or nuts. N Engl J Med. 2018;378(25):e34. PMID: 29897866. 10.1056/NEJMoa1800389 29897866
68 Fagerberg B, Wikstrand J, Berglund G, . Mortality rates in treated hypertensive men with additional risk factors are high but can be reduced: a randomized intervention study. Am J Hypertens. 1998;11(1 Pt 1):14–22. PMID: None. 10.1016/S0895-7061(97)00363-4 9504445
69 Gill R, Superko HR, McCarthy MM, . Cardiovascular risk factor reduction in first responders resulting from an individualized lifestyle and blood test program: a randomized controlled trial. J Occup Environ Med. 2019;61(3):183–9. PMID: 30475306. 10.1097/JOM.0000000000001490 30475306
70 Gill DP, Blunt W, Boa Sorte Silva NC, . The HealtheStepsTM lifestyle prescription program to improve physical activity and modifiable risk factors for chronic disease: a pragmatic randomized controlled trial. BMC Public Health. 2019;19(1):841. PMID: 31253112. 10.1186/s12889-019-7141-2 31253112
71 Greaves C, Gillison F, Stathi A, . Waste the waist: a pilot randomised controlled trial of a primary care based intervention to support lifestyle change in people with high cardiovascular risk. Int J Behav Nutr Phys Act. 2015;12:1. PMID: 25592201. 10.1186/s12966-014-0159-z 25592201
72 Groeneveld IF, Proper KI, van der Beek AJ, . Sustained body weight reduction by an individual-based lifestyle intervention for workers in the construction industry at risk for cardiovascular disease: results of a randomized controlled trial. Prev Med. 2010;51(3–4):240–6. PMID: 20692282. 10.1016/j.ypmed.2010.07.021 20692282
73 Hardcastle S, Taylor A, Bailey M, . A randomised controlled trial on the effectiveness of a primary health care based counselling intervention on physical activity, diet and CHD risk factors. Patient Educ Counsel. 2008;70(1):31–9. PMID: 17997263. 10.1016/j.pec.2007.09.014 17997263
74 Harris MF, Fanaian M, Jayasinghe UW, . A cluster randomised controlled trial of vascular risk factor management in general practice. Med J Aust. 2012;197(7):387–93. PMID: 23025735. 10.5694/mja12.10313 23025735
75 Haufe S, Kerling A, Protte G, . Telemonitoring-supported exercise training, metabolic syndrome severity, and work ability in company employees: a randomised controlled trial. Lancet Public Health. 2019;4(7):e343–e52. PMID: 31204284. 10.1016/S2468-2667(19)30075-1 31204284
76 Hinderliter AL, Sherwood A, Craighead LW, . The long-term effects of lifestyle change on blood pressure: One-year follow-up of the ENCORE study. Am J Hypertens. 2014;27(5):734–41. PMID: 24084586. 10.1093/ajh/hpt183 24084586
77 Hypertension Prevention Trial Research Group. The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Hypertension Prevention Trial Research Group. Arch Intern Med. 1990;150(1):153–62. PMID: 2404477. 10.1001/archinte.1990.00390130131021 2404477
78 Hyman DJ, Ho KS, Dunn JK, . Dietary intervention for cholesterol reduction in public clinic patients. Am J Prev Med. 1998;15(2):139–45. PMID: 9713670. 10.1016/S0749-3797(98)00038-5 9713670
79 Hyman DJ, Pavlik VN, Taylor WC, . Simultaneous vs sequential counseling for multiple behavior change. Arch Intern Med. 2007;167(11):1152–8. PMID: 17563023. 10.1001/archinte.167.11.1152 17563023
80 Ives DG, Kuller LH, Traven ND. Use and outcomes of a cholesterol-lowering intervention for rural elderly subjects. Am J Prev Med. 1993;9(5):274–81. PMID: 8257616.8257616
81 Johnston HJ, Jones M, Ridler-Dutton G, . Diet modification in lowering plasma cholesterol levels. A randomised trial of three types of intervention. Med J Aust. 1995;162(10):524–6. PMID: 7776913. 10.5694/j.1326-5377.1995.tb138510.x 7776913
82 Jones DW, Miller ME, Wofford MR, . The effect of weight loss intervention on antihypertensive medication requirements in the hypertension Optimal Treatment (HOT) study. Am J Hypertens. 1999;12(12 Pt 1-2):1175–80. PMID: 10619579. 10.1016/S0895-7061(99)00123-5 10619579
83 Kandula NR, Dave S, De Chavez PJ, . Translating a heart disease lifestyle intervention into the community: the South Asian Heart Lifestyle Intervention (SAHELI) study; a randomized control trial. BMC Public Health. 2015;15:1064. PMID: 26475629. 10.1186/s12889-015-2401-2 26475629
84 Kanke S, Kawai T, Takasawa N, . Interventions for body weight reduction in obese patients during short consultations: an open-label randomized controlled trial in the Japanese primary care setting. Asia Pacific Fam Med. 2015;14(1):5. PMID: 26015773. 10.1186/s12930-015-0022-7 26015773
85 Kastarinen MJ, Puska PM, Korhonen MH, . Non-pharmacological treatment of hypertension in primary health care: a 2-year open randomized controlled trial of lifestyle intervention against hypertension in eastern Finland. J Hypertens. 2002;20(12):2505–12. PMID: 12473876. 10.1097/01.hjh.0000042893.24999.db 12473876
86 Keyserling TC, Ammerman AS, Davis CE, . A randomized controlled trial of a physician-directed treatment program for low-income patients with high blood cholesterol: the Southeast Cholesterol Project. Arch Fam Med. 1997;6(2):135–45. PMID: 9075448.9075448
87 Khanji MY, Balawon A, Boubertakh R, . Personalized E-Coaching in Cardiovascular Risk Reduction: A Randomized Controlled Trial. Ann Glob Health. 2019;85(1). PMID: 31298823. 10.5334/aogh.2496 31298823
88 Koelewijn-van Loon MS, van der Weijden T, van Steenkiste B, . Involving patients in cardiovascular risk management with nurse-led clinics: a cluster randomized controlled trial. CMAJ. 2009;181(12):E267–E74. PMID: 19948811. 10.1503/cmaj.081591 19948811
89 Kramer MK, Vanderwood KK, Arena VC, . Evaluation of a Diabetes Prevention Program Lifestyle Intervention in Older Adults: A Randomized Controlled Study in Three Senior/Community Centers of Varying Socioeconomic Status. Diabet Educ. 2018;44(2):118–29. PMID: 29514568. 10.1177/0145721718759982 29514568
90 Lakerveld J, Bot SD, Chinapaw MJ, . Motivational interviewing and problem solving treatment to reduce type 2 diabetes and cardiovascular disease risk in real life: a randomized controlled trial. Int J Behav Nutr Phys Act. 2013;10:47. PMID: 23597082. 10.1186/1479-5868-10-47 23597082
91 Langford HG, Davis BR, Blaufox D, . Effect of drug and diet treatment of mild hypertension on diastolic blood pressure. The TAIM Research Group. Hypertension. 1991;17(2):210–7. PMID: 1671380. 10.1161/01.HYP.17.2.210 1671380
92 Lee LL, Arthur A, Avis M. Evaluating a community-based walking intervention for hypertensive older people in Taiwan: a randomized controlled trial. Prev Med. 2007;44(2):160–6. PMID: 17055561. 10.1016/j.ypmed.2006.09.001 17055561
93 Liira H, Engberg E, Leppavuori J, . Exercise intervention and health checks for middle-aged men with elevated cardiovascular risk: a randomized controlled trial. Scand J Prim Health Care. 2014;32(4):156–62. PMID: 25434409. 10.3109/02813432.2014.984967 25434409
94 Migneault JP, Dedier JJ, Wright JA, . A culturally adapted telecommunication system to improve physical activity, diet quality, and medication adherence among hypertensive African-Americans: a randomized controlled trial. Ann Behav Med. 2012;43(1):62–73. PMID: 22246660. 10.1007/s12160-011-9319-4 22246660
95 Moreau KL, Degarmo R, Langley J, . Increasing daily walking lowers blood pressure in postmenopausal women. Med Sci Sports Exercise. 2001;33(11):1825–31. PMID: 11689731.11689731
96 Moy TF, Yanek LR, Raqueño JV, . Dietary counseling for high blood cholesterol in families at risk of coronary disease. Prev Cardiol. 2001;4(4):158–64. PMID: 11832672. 10.1111/j.1520-037X.2001.00543.x 11832672
97 Muhlhauser I, Sawicki PT, Didjurgeit U, . Evaluation of a structured treatment and teaching programme on hypertension in general practice. Clin Exp Hypertens. 1993;15(1):125–42. PMID: 8467308.8467308
98 Murphy SM, Edwards RT, Williams N, . An evaluation of the effectiveness and cost effectiveness of the National Exercise Referral Scheme in Wales, UK: a randomised controlled trial of a public health policy initiative. J Epidemiol Commun Health. 2012;66(8):745–53. PMID: 22577180. 10.1136/jech-2011-200689 22577180
99 Neil HA, Roe L, Godlee RJ, . Randomised trial of lipid lowering dietary advice in general practice: the effects on serum lipids, lipoproteins, and antioxidants. BMJ. 1995;310(6979):569–73. PMID: 7888933. 10.1136/bmj.310.6979.569 7888933
100 Niiranen TJ, Leino K, Puukka P, . Lack of impact of a comprehensive intervention on hypertension in the primary care setting. Am J Hypertens. 2014;27(3):489–96. PMID: 24186848. 10.1093/ajh/hpt204 24186848
101 Nolan RP, Feldman R, Dawes M, . Randomized Controlled Trial of E-Counseling for Hypertension: REACH. Circ Cardiovasc Qual Outcomes. 2018;11(7):e004420. PMID: 30006474. 10.1161/CIRCOUTCOMES.117.004420 30006474
102 Ogedegbe G, Tobin JN, Fernandez S, . Counseling African Americans to Control Hypertension: cluster-randomized clinical trial main effects. Circulation. 2014;129(20):2044–51. PMID: 24657991. 10.1161/circulationaha.113.006650 24657991
103 Reid RD, McDonnell LA, Riley DL, . Effect of an intervention to improve the cardiovascular health of family members of patients with coronary artery disease: a randomized trial. CMAJ. 2014;186(1):23–30. PMID: 24246588. 10.1503/cmaj.130550 24246588
104 Rodriguez MA. Is behavior change sustainable for diet, exercise, and medication adherence? Dissertation. 2012;73(3-B):1860. PMID: None.
105 Rodriguez Cristobal JJ, Alonso-Villaverde Grote C, Trave Mercade P, . Randomised clinical trial of an intensive intervention in the primary care setting of patients with high plasma fibrinogen in the primary prevention of cardiovascular disease. BMC Res Notes. 2012;5:126. PMID: 22381072. 10.1186/1756-0500-5-126 22381072
106 Rosas LG, Thiyagarajan S, Goldstein BA, . The effectiveness of two community-based weight loss strategies among obese, low-income US Latinos. J Acad Nutr Diet. 2015;115(4):537–50.e2. PMID: 25578925. 10.1016/j.jand.2014.10.020 25578925
107 Rubinstein A, Miranda JJ, Beratarrechea A, . Effectiveness of an mHealth intervention to improve the cardiometabolic profile of people with prehypertension in low-resource urban settings in Latin America: a randomised controlled trial. Lancet Diabet Endocrinol. 2016;4(1):52–63. PMID: 26653067. 10.1016/S2213-8587(15)00381-2 26653067
108 Salisbury C, O’Cathain A, Thomas C, . Telehealth for patients at high risk of cardiovascular disease: pragmatic randomised controlled trial. BMJ. 2016;353:i2647. PMID: 27252245. 10.1136/bmj.i2647 27252245
109 Schoenthaler A, Luerassi L, Silver S, . Comparative Effectiveness of a Practice-Based Comprehensive Lifestyle Intervention vs. Single Session Counseling in Hypertensive Blacks. Am J Hypertens. 2016;29(2):280–7. PMID: 26135553. 10.1093/ajh/hpv100 26135553
110 Scott SE, Breckon JD, Copeland RJ. An integrated motivational interviewing and cognitive-behavioural intervention promoting physical activity maintenance for adults with chronic health conditions: A feasibility study. Chronic Illness. 2018:1742395318769370. PMID: 29642707. 10.1177/1742395318769370 29642707
111 Soto RA, García SJ, Toro SM, . Benefits of an educational intervention on diet and anthropometric profile of women with one cardiovascular risk factor. Med Clin. 2016;146(10):436–9. PMID: 26897504. 10.1016/j.medcli.2015.12.013 26897504
112 Stefanick ML, Mackey S, Sheehan M, . Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med. 1998;339(1):12–20. PMID: 9647874. 10.1056/NEJM199807023390103 9647874
113 Stevens VJ, Glasgow RE, Toobert DJ, . One-year results from a brief, computer-assisted intervention to decrease consumption of fat and increase consumption of fruits and vegetables. Prev Med. 2003;36(5):594–600. PMID: 12689805. 10.1016/S0091-7435(03)00019-7 12689805
114 Svetkey LP, Stevens VJ, Brantley PJ, . Comparison of strategies for sustaining weight loss: the weight loss maintenance randomized controlled trial. JAMA. 2008;299(10):1139–48. PMID: 18334689. 10.1001/jama.299.10.1139 18334689
115 Svetkey LP, Pollak KI, Yancy WS, Jr., . Hypertension improvement project: randomized trial of quality improvement for physicians and lifestyle modification for patients. Hypertension. 2009;54(6):1226–33. PMID: 19920081. 10.1161/HYPERTENSIONAHA.109.134874 19920081
116 Ter Bogt NC, Bemelmans WJ, Beltman FW, . Preventing weight gain: one-year results of a randomized lifestyle intervention. Am J Prev Med. 2009;37(4):270–7. PMID: 19765497. 10.1016/j.amepre.2009.06.011 19765497
117 Tiessen AH, Smit AJ, Broer J, . Randomized controlled trial on cardiovascular risk management by practice nurses supported by self-monitoring in primary care. BMC Fam Pract. 2012;13:90. PMID: 22947269. 10.1186/1471-2296-13-90 22947269
118 Toft U, Kristoffersen L, Ladelund S, . The effect of adding group-based counselling to individual lifestyle counselling on changes in dietary intake. The Inter99 study - a randomized controlled trial. Int J Behav Nutr Phys Act. 2008;5:59. PMID: 19025583. 10.1186/1479-5868-5-59 19025583
119 The Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels. Results of the Trials of Hypertension Prevention, Phase I. JAMA. 1992;267(9):1213–20. PMID: 1586398. 10.1001/jama.1992.03480090061028 1586398
120 The Trials of Hypertension Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. The Trials of Hypertension Prevention, phase II. The Trials of Hypertension Prevention Collaborative Research Group. Arch Intern Med. 1997;157(6):657–67. PMID: 9080920.9080920
121 Tomson Y, Johannesson M, Aberg H. The costs and effects of two different lipid intervention programmes in primary health care. J Intern Med. 1995;237(1):13–7. PMID: 7830025. 10.1111/j.1365-2796.1995.tb01134.x 7830025
122 van der Veen J, Bakx C, van den Hoogen H, . Stage-matched nutrition guidance for patients at elevated risk for cardiovascular disease: a randomized intervention study in family practice. J Fam Pract. 2002;51(9):751–8. PMID: 12366892.12366892
123 van Keulen HM, Mesters I, Ausems M, . Tailored print communication and telephone motivational interviewing are equally successful in improving multiple lifestyle behaviors in a randomized controlled trial. Ann Behav Med. 2011;41(1):104–18. PMID: 20878293. 10.1007/s12160-010-9231-3 20878293
124 van Sluijs EM, van Poppel MN, Twisk JW, . Effect of a tailored physical activity intervention delivered in general practice settings: results of a randomized controlled trial. Am J Public Health. 2005;95(10):1825–31. PMID: 16186461. 10.2105/AJPH.2004.044537 16186461
125 Viglione C, Bouwman D, Rahman N, . A technology-assisted health coaching intervention vs. enhanced usual care for Primary Care-Based Obesity Treatment: a randomized controlled trial. BMC Obes. 2019;6:4. PMID: 30766686. 10.1186/s40608-018-0226-0 30766686
126 Voils CI, Coffman CJ, Yancy WS, Jr., . A randomized controlled trial to evaluate the effectiveness of CouPLES: a spouse-assisted lifestyle change intervention to improve low-density lipoprotein cholesterol. Prev Med. 2013;56(1):46–52. PMID: 23146744. 10.1016/j.ypmed.2012.11.001 23146744
127 Wadden T, Volger S, Sarwer D, . A two-year randomized trial of obesity treatment in primary care practice. N Engl J Med. 2011;365(21):1969–79. PMID: 22082239 10.1056/NEJMoa1109220 22082239
128 Whelton PK, Appel LJ, Espeland MA, . Sodium reduction and weight loss in the treatment of hypertension in older persons: a randomized controlled trial of nonpharmacologic interventions in the elderly (TONE). TONE Collaborative Research Group. JAMA. 1998;279(11):839–46. PMID: 9515998. 10.1001/jama.279.11.839 9515998
129 Wister A, Loewen N, Kennedy-Symonds H, . One-year follow-up of a therapeutic lifestyle intervention targeting cardiovascular disease risk.[see comment]. CMAJ. 2007;177(8):859–65. PMID: 17923653. 10.1503/cmaj.061059 17923653
130 Wong MC, Wang HH, Kwan MW, . Dietary counselling has no effect on cardiovascular risk factors among Chinese Grade 1 hypertensive patients: a randomized controlled trial. Eur Heart J. 2015;36(38):2598–607. PMID: 26264550. 10.1093/eurheartj/ehv329 26264550
131 Wood DA, Kotseva K, Connolly S, . Nurse-coordinated multidisciplinary, family-based cardiovascular disease prevention programme (EUROACTION) for patients with coronary heart disease and asymptomatic individuals at high risk of cardiovascular disease: a paired, cluster-randomised controlled trial. Lancet. 2008;371:1999–2012. PMID: 18555911. 10.1016/S0140-6736(08)60868-5 18555911