# Appendix H Evidence Tables

Appendix H Table 1 CVD Events + CVD Mortality (KQ1)

Appendix H Table 2 All-Cause Mortality (KQ1)

Appendix H Table 3 Patient-Reported Measures of Subjective Well-Being (KQ1)

Appendix H Table 4 Meta-Analysis Summary of Pooled Intermediate Outcomes

Appendix H Table 5 Blood Pressure, Continuous (KQ2)

Appendix H Table 6 Blood Pressure, Dichotomous (KQ2)

Appendix H Table 7 Lipids, Continuous (KQ2)

Appendix H Table 8 Lipids, Dichotomous (KQ2)

Appendix H Table 9 Glucose, Continuous (KQ2)

Appendix H Table 10 Glucose and Metabolic Syndrome, Dichotomous (KQ2)

Appendix H Table 11 Adiposity, Continuous (KQ2)

Appendix H Table 12 Adiposity, Dichotomous (KQ2)

Appendix H Table 13 CVD Risk Score Outcomes (KQ2)

Appendix H Table 14 Other Intermediate Outcomes (KQ2)

Appendix H Table 15 Dietary, Continuous Outcomes (KQ3)

Appendix H Table 16 Dietary, Dichotomous Outcomes (KQ3)

Appendix H Table 17 Physical Activity, Continuous Outcomes (KQ3)

Appendix H Table 18 Physical Activity, Dichotomous Outcomes (KQ3)

Appendix H Table 19 Harms Outcomes (KQ4)