# Appendix G Detailed Figures

Appendix G Figure 1 All CVD Events by Study

Abbreviations: CG = control group; CI = confidence interval; CVD = cardiovascular disease; IG = intervention group; Int arm = intervention arm; MI = myocardial infarction; RR = risk ratio; TOHP I CRG = The Trials of Hypertension Prevention – Phase I Collaborative Research Group; TOHP II CRG = The Trials of Hypertension Prevention – Phase II Collaborative Research Group

Appendix G Figure 1 is a forest plot of the risk ratios of all the CVD events by study and their intervention arms. This figure is discussed in the Results section.

Appendix G Figure 2 Other CVD Events by Study

Abbreviations: CG = control group; CI = confidence interval; CVD = cardiovascular disease; IG = intervention group; Int arm = intervention arm; PAD = peripheral artery disease; RR = risk ratio

Appendix G Figure 2 is a forest plot of the risk ratios of other CVD events (e.g., angina, arrhythmia, transient ischemic attack, incident PAD, claudication, congestive heart failure) by study and their intervention arms. This figure is discussed in the Results section.

Appendix G Figure 3 Systolic Blood Pressure by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; HPT = Hypertension Prevention Trial; KH = Knapp-Hartung adjustment; mm Hg = millimeters of mercury; REML = restricted maximum likelihood; SBP = systolic blood pressure; SD = standard deviation; TOHP I CRG = The Trials of Hypertension Prevention – Phase I Collaborative Research Group; TOHP II CRG = The Trials of Hypertension Prevention – Phase II Collaborative Research Group

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 3 is a forest plot depicting the change in systolic blood pressure (mm Hg) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 4 Diastolic Blood Pressure by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; DBP = diastolic blood pressure; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; HPT = Hypertension Prevention Trial; KH = Knapp-Hartung adjustment; mm Hg = millimeters of mercury; REML = restricted maximum likelihood; SD = standard deviation; TOHP I CRG = The Trials of Hypertension Prevention – Phase I Collaborative Research Group; TOHP II CRG = The Trials of Hypertension Prevention – Phase II Collaborative Research Group

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 4 is a forest plot depicting the change in diastolic blood pressure (mm Hg) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 5 Total Cholesterol by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; KH = Knapp-Hartung adjustment; mg/dL = milligrams per deciliter; NR = not reported; REML = restricted maximum likelihood; SD = standard deviation; TC = total cholesterol

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 5 is a forest plot depicting the change in total cholesterol (mg/dL) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 6 LDL Cholesterol by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; KH = Knapp-Hartung adjustment; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; NR = not reported; REML = restricted maximum likelihood; SD = standard deviation

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 6 is a forest plot depicting the change in low-density lipoprotein cholesterol (mg/dL) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 7 HDL Cholesterol by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; HDL-C = low-density lipoprotein cholesterol; KH = Knapp-Hartung adjustment; mg/dL = milligrams per deciliter; REML = restricted maximum likelihood; SD = standard deviation

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 7 is a forest plot depicting the change in high-density lipoprotein cholesterol (mg/dL) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 8 Fasting Blood Glucose by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; FBG = fasting blood glucose; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; KH = Knapp-Hartung adjustment; mg/dL = milligrams per deciliter; NR = not reported; REML = restricted maximum likelihood; SD = standard deviation

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 8 is a forest plot depicting the change in fasting blood glucose (mg/dL) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 9 Body Mass Index by Study and Followup Category

Abbreviations: BMI = body mass index; CG = control group; CI = confidence interval; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; kg/m^2^ = kilograms per meter squared; KH = Knapp-Hartung adjustment; NR = not reported; REML = restricted maximum likelihood; SD = standard deviation

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 9 is a forest plot depicting the change in body mass index (kg/m2) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 10 Weight by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; kg = kilograms; KH = Knapp-Hartung adjustment; REML = restricted maximum likelihood; SD = standard deviation

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 10 is a forest plot depicting the change in weight (kg) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 11 Waist Circumference by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; cm = centimeters; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; KH = Knapp-Hartung adjustment; NR = not reported; REML = restricted maximum likelihood; SD = standard deviation

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 11 is a forest plot depicting the change in waist circumference (cm) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 12 Saturated Fat by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; KH = Knapp-Hartung adjustment; REML = restricted maximum likelihood; SD = standard deviation

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 12 is a forest plot depicting the change in saturated fat (% energy) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 13 Polyunsaturated Fat by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; KH = Knapp-Hartung adjustment; PUFA = polyunsaturated fatty acids; REML = restricted maximum likelihood; SD = standard deviation

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 13 is a forest plot depicting the change in polyunsaturated fat (% energy) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 14 Monounsaturated Fat by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; HD = healthy diet; HD + PA = healthy diet and physical activity; KH = Knapp-Hartung adjustment; MUFA = monounsaturated fatty acids; REML = restricted maximum likelihood; SD = standard deviation

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 14 is a forest plot depicting the change in monounsaturated fat (% energy) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 15 Fruit and Vegetable Intake by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; FUP = followup timepoint; HD = healthy diet; HD + PA = healthy diet and physical activity; IG = intervention group; KH = Knapp-Hartung adjustment; NR = not reported; REML = restricted maximum likelihood; SD = standard deviation; servings/d = servings per day

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 15 is a forest plot depicting the change in fruit and vegetable intake (servings per day) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 16 Fruit Intake by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; FUP = followup timepoint; g/day = grams per day; HD = healthy diet; HD + PA = healthy diet and physical activity; IG = intervention group; KH = Knapp-Hartung adjustment; NR = not reported; REML = restricted maximum likelihood; SD = standard deviation; servings/d = servings per day

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 16 is a forest plot depicting the change in fruit intake (servings per day) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 17 Vegetable Intake by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; FUP = followup timepoint; g/day = grams per day; HD = healthy diet; HD + PA = healthy diet and physical activity; IG = intervention group; KH = Knapp-Hartung adjustment; NR = not reported; REML = restricted maximum likelihood; SD = standard deviation; servings/d = servings per day; Tbsp/day = tablespoons per day

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 17 is a forest plot depicting the standardize mean difference (Hedges adjusted g method) in vegetable intake by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 18 Fiber Intake by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; FUP = followup timepoint; g/day = grams per day; HD = healthy diet; HD + PA = healthy diet and physical activity; IG = intervention group; KH = Knapp-Hartung adjustment; REML = restricted maximum likelihood; SD = standard deviation

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 18 is a forest plot depicting the change in fiber intake (grams per day) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 19 Urinary Sodium by Study and Followup Category

Abbreviations: CG = control group; CI = confidence interval; FUP = followup timepoint; HD = healthy diet; HD + PA = healthy diet and physical activity; IG = intervention group; KH = Knapp-Hartung adjustment; mmol/24-hr = millimoles per 24 hours; REML = restricted maximum likelihood; SD = standard deviation

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 19 is a forest plot depicting the change in urinary sodium (mmol/24-hr) by study and followup category in all risk groups. This figure is discussed in the Results section.

Appendix G Figure 20 Physical Activity at 12 to 24 Months’ Followup

Abbreviations: BG = between-group; CG = control group; CI = confidence interval; FUP = followup timepoint; HD = healthy diet; HD + PA = healthy diet and physical activity; IG = intervention group; KH = Knapp-Hartung adjustment; kcal/kg = kilocalories per kilogram; kcal/wk = kilocalories per week; kJ/kg/d = kilojoules per kilogram per day; MET-min/wk = metabolic equivalent of task minutes per week; METS = metabolic syndrome; min/wk = minutes per week; NR = not reported; NSD = no statistically significant difference; PA = physical activity; REML = restricted maximum likelihood; steps/d = steps per day

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 20 is a forest plot depicting the pooled standardized mean difference (Hedges adjusted g method) in physical activity by study at 12 to 24 months’ followup. This figure is discussed in the Results section.

Appendix G Figure 21 Physical Activity, Meeting Recommendations

Abbreviations: CG = control group; CI = confidence interval; FUP = followup timepoint; HD = healthy diet; HD + PA = healthy diet and physical activity; IG = intervention group; KH = Knapp-Hartung adjustment; PA = physical activity; REML = restricted maximum likelihood; RR = risk ratio

*Intervention contact time defined as: Low = 0–30 min, Medium = 31–360 min, High = >360 min

Appendix G Figure 21 is a forest plot depicting the pooled risk ratio in meeting the study-defined physical activity goal. This figure is discussed in the Results section.