# Appendix F Detailed Study Characteristics

Appendix F Table 1 Population Characteristics

Author, year (Study name) Quality | Country Recruitment setting | Population risk focus | Population description | N rand | All F/U timepoints (months) (% available at main F/U timepoint) | Mean age (range) | % Female | Mean BMI % overweight or obese | CVD risk factors | Socioeconomic status
Ammerman, 2003^38^; Fair | US; Mixed | Dyslipidemia | Residents of rural areas, age 20 to 70, with untreated hypercholesterolemia | 468 | 3, 6, 12 (75) | 55 (20-70) | 71 | 29; NR | HTN: 41; Dys: 100; PreDM: NR; DM: 3; CVD: 10; Smoking: 21 | % unemployed: 44; % education <high school: 30
Anderson, 1992^39^; Fair | US; Community | Dyslipidemia | Age 30 to 50 with moderate untreated hypercholesterolemia and without obesity or hypertension | 177 | 4, 8, 12 (82) | 41 (30-50) | 40 | NR; 0 | HTN: 0; Dys: 100; PreDM: NR; DM: 0; CVD: 0; Smoking: 12 | Mean education, years: 16
Anderssen, 1995^40^ (Oslo Diet and Exercise Study (ODES)); Fair | Norway; Community | Multiple risk factors | Age ≥40 with untreated elevated BP/hypertension and lipids, physically inactive and BMI >24 | 98 | 12 (97) | 45 (41-50) | NR | 29; 100 | HTN: NR; Dys: NR; PreDM: NR; DM: 0; CVD: 0; Smoking: NR | NR
Appel, 2003^41^ (PREMIER); Good | US; Mixed | Hypertension | Age ≥25 with untreated elevated BP/hypertension | 810 | 6, 18 (94) | 50 (≥25) | 62 | 33; 94 | HTN: 38; Dys: 24; PreDM: NR; DM: 0; CVD: 0; Smoking: 5 | No. (%) ≤ High school: 74 (9); No. (%) some college: 476 (59); No. (%) some graduate school: 260 (32); No. (%); No. (%) $30-60k annual income: 256 (32); No. (%) >$60k annual income: 441 (54)
Appel, 2011^42^ (POWER Hopkins (Practice Based Opportunities for Weight Reduction)); Good | US; Primary Health Care | Multiple risk factors | Age ≥21 with obesity and any of multiple risk factors | 415 | 6, 12, 24 (95) | 54 (≥21) | 64 | 37; 100 | HTN: 76; Dys: 68; PreDM: NR; DM: 23; CVD: NR; Smoking: NR | Education, %:; -HS grad or less, 10.6%; -Some college, 30.1%; -College grad, 59.3%; Household income, %:; -$50,000-$99,000, 37.3%; - ≥$100,000, 40.7%; Employment status, %:; -Employed, 75.2%; -Retired, 15.7%; -Other, 9.2%; Insurance status:; -Private, HMO, Medicare: 98.5%; -Medicaid, uninsured: 1.5%
Applegate, 1992^43^; Fair | US; Community | Hypertension | Age 60 to 85 at ≥115% of ideal body weight, with hypertension | 56 | 1, 2, 3, 4, 5, 6 (84) | 64 (60-85) | 55 | NR; 100 | HTN: 100; Dys: NR; PreDM: NR; DM: 0; CVD: 0; Smoking: 13 | Education (yrs): 12; Employment (Full time or part time): 30%
Arroll, 1995^44^; Fair | New Zealand; Mixed | Hypertension | Age 20 to 69 with treated hypertension and sedentary | 208 | 3, 6 (87) | 55 (20-69) | 48 | NR; NR | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: 0; Smoking: NR | NR
Babazono, 2007^45^ (PHPP); Fair | Japan; Health Care | Multiple risk factors | Japanese adults with elevated BP, hypertension or prediabetes | 99 | 4, 6, 12 (88) | 64 (NR) | 58 | 24; NR | HTN: 30; Dys: NR; PreDM: NR; DM: 17; CVD: NR; Smoking: NR | NR
Beckmann, 1995^46^; Fair | Norway; NR | Hypertension | Men, age 40 to 56, with untreated mild-to-moderate hypertension | 64 | 3, 6, 12 (100) | NR (40-56) | 0 | 27; NR | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: 22 | NR
Bennett, 2012^47^ (Be Fit, Be Well [POWER]); Good | US; Health Care | Hypertension | Age ≥21 with obesity and treated hypertension | 365 | 6, 12, 18, 24 (69) | 55 (≥21) | 68 | 37; 100 | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | Educational level, n (%); High school/GED, 109 (30); Some college/AD, 86 (24); ≥Bachelor’s degree, 50 (14); Income, n (%); $10,000 to; $25,000 to; ≥$50 000, 56 (15); Employment, n (%); Employed, 192 (53); Unemployed, 50 (14); Retired, 43 (12); Disabled, 80 (22); Health insurance, n (%); Medicaid, 123 (34); Medicare, 75 (21); Private insurance, 137 (38); Other, 30 (8)
Bennett, 2018^48^ (Track); Good | US; Health Care | Multiple risk factors | Age 21 to 65 with obesity and any of multiple CVD risk factors | 351 | 6, 12 (90) | 51 (21-65) | 68 | 36; 100 | HTN: 82; Dys: 55; PreDM: NR; DM: 42; CVD: 0; Smoking: NR | Education:; HS grad: 36%; Some college or vocational: 40%; 4-year college degree or higher: 10%; Annual household income:; 0-$11,999: 20%; $12,000-$24,999: 31%; $25,000-$34,999: 16%; $35,000-$49,999: 13%; ≥$50,000: 7%; Living under US poverty threshold:; Below: 30%; Borderline: 16%; Above: 41%; Current employment:; Full- or part-time: 67%; Unemployed: 31%
Beune, 2014^49^ (Culturally Adapted Hypertension Education (CAHE)); Fair | The Netherlands; Primary Health Care | Hypertension | Surinamese and Ghanaian immigrants, age ≥20, with hypertension | 146 | 6 (95) | 54 (≥20) | 53 | 31; 94 | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | Education:; Low: 50%; Middle: 30%; High: 19%; Employment:; Paid work: 64%; Unpaid work: 1%; Unemployed/disabled: 24%; Retired: 11%
Blackford, 2016^50^ (Albany Physical Activity and Nutrition (APAN)); Fair | Australia; Health Care | Multiple risk factors | Age 50 to 69 with or at risk of metabolic syndrome | 401 | 6 (78) | 61 (50-69) | 66 | 31; NR | HTN: NR; Dys: NR; PreDM: NR; DM: 0; CVD: NR; Smoking: 12 | Employment:; Full time: 46%; Part time: 17%; Unemployed: 4%; Retired: 33%; Education:; Primary: 2%; Secondary: 41%; Technical/diploma: 32%; University: 26%
Bloemberg, 1991^51^; Fair | The Netherlands; Other | Dyslipidemia | Men, age 30 to 60, with untreated dyslipidemia | 80 | 6 (99) | 47 (30-60) | 0 | 26; NR | HTN: 0; Dys: 100; PreDM: NR; DM: 0; CVD: 0; Smoking: NR | NR
Bo, 2007^52^; Fair | Italy; Primary Health Care | Multiple risk factors | Age 45 to 64 with metabolic syndrome | 375 | 12 (89) | 56 (45-64) | 58 | 30; NR | HTN: 94; Dys: NR; PreDM: 38; DM: 0; CVD: 0; Smoking: 22 | Education level, %:; - Primary, 79; - Secondary, 16; - University, 5
Bosworth, 2009^53^ (Take Control of Your Blood pressure (TCYB)); Fair | US; Primary Health Care | Hypertension | Adults with treated hypertension | 478 | 12, 24 (76) | 61 (NR) | 64 | 32; NR | HTN: 100; Dys: NR; PreDM: NR; DM: 36; CVD: NR; Smoking: 17 | % completed ≤12 years education: 35; % employed: 40; % inadequate income: 19
Broekhuizen, 2012^54^ (PRO-FIT); Fair | The Netherlands; Other | Dyslipidemia | Age 18 to 70 with familial hypercholesterolemia | 340 | 12 (94) | 45 (18-70) | 57 | 26; NR | HTN: NR; Dys: 100; PreDM: NR; DM: NR; CVD: NR; Smoking: 17 | Education, %:; - Low, 3; - Medium, 60; - High, 36
Bruckert, 2008^55^ (PEGASE (Effect of an Education Program)); Fair | France; Health Care | Dyslipidemia | Age ≥18 with elevated LDL and additional CVD risk factor (unless LDL very high) | 640 | 6 (74) | 57 (≥18) | 40 | NR; NR | HTN: 34; Dys: 100; PreDM: NR; DM: 9; CVD: 23; Smoking: 21 | Education, %:; - No education, 10; - HS grad, 14; - Tech school, 49; - Higher education, 24; Employed, %: 42; Retired,%: 47; Unemployed, %: 2
Burke, 2006^56^ (ADAPT); Fair | Australia; NR | Hypertension | Age 40 to 70 with treated hypertension and overweight or obese | 241 | 16, 40 (80) | 56 (40-70) | NR | 30; 100 | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | NR
Chirinos, 2016^57^ (Community Health and Risk-reduction for Metabolic Syndrome (CHARMS)); Fair | US; Health Care | Multiple risk factors | Low-income adults, age 30 to 70, with metabolic syndrome and BMI ≥25 | 120 | 6, 12 (78) | 52 (30-70) | 56 | NR; 100 | HTN: NR; Dys: NR; PreDM: NR; DM: 0; CVD: 0; Smoking: NR | Education, mean: 13 years; Income, %:; - $20,000-$40,000: 22; - >$40,000: 4
Christian, 2011^58^; Fair | US; Primary Health Care | Multiple risk factors | Age 18 to 75 with BMI >25 and ≥2 components of the metabolic syndrome | 279 | 12 (94) | 50 (18-75) | 68 | 34; 100 | HTN: NR; Dys: NR; PreDM: NR; DM: 0; CVD: NR; Smoking: NR | 100% uninsured, Medicaid-eligible, or Medicare 60% at or below 100% of federal poverty level among entire patient population
Cicolini, 2014^59^; Fair | Italy; Primary Health Care | Hypertension | Adults with treated hypertension | 203 | 3, 6 (98) | 59 (NR) | NR | 29; NR | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: 62 | NR
Cochrane, 2012^60^; Fair | UK; Primary Health Care | Multiple risk factors | Age 35 to 74 with Framingham 10-year CVD risk ≥20% | 601 | 12 (81) | 64 (35-74) | 11 | 28; NR | HTN: NR; Dys: NR; PreDM: NR; DM: 0; CVD: 0; Smoking: 53 | SES based on IMD deciles:; - Deprived, n (%): 282 (48); - Intermediate, n (%): 189 (32); - More affluent, n (%): 112 (19)
Cohen, 1991^61^; Fair | US; Primary Health Care | Hypertension | Age 20 to 75 with BMI ≥27.8 and hypertension | 30 | 6, 12 (100) | 60 (20-75) | 73 | 34; 100 | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | NR
Coleman, 2012^62^ (Wisewoman California); Fair | US; Health Care | Multiple risk factors | Low-income Hispanic females, age 40 to 64, with hypertension or hypercholesteremia | 1093 | 12 (80) | 52 (40-64) | 100 | 32; 90 | HTN: 45; Dys: 56; PreDM: NR; DM: 22; CVD: NR; Smoking: 5 | Education, %:; Some HS, 10; ≥HS, 20
Delahanty, 2001^63^; Good | US; Primary Health Care | Dyslipidemia | Age 21 to 65 with untreated dyslipidemia | 90 | 3, 6, 12 (97) | 49 (21-65) | 33 | 27; NR | HTN: NR; Dys: 100; PreDM: NR; DM: 0; CVD: NR; Smoking: 8 | % education < college grad: 33
Eakin, 2009^64^ (Logan Healthy Living); Fair | Australia; Primary Health Care | Multiple risk factors | Age ≥30 with diabetes or hypertension | 434 | 4, 12, 18 (79) | 58 (≥30) | 61 | 31; NR | HTN: 86; Dys: NR; PreDM: NR; DM: 45; CVD: NR; Smoking: 14 | % ≥ high school graduate: 45; % retired: 36; % employed: 46
Edelman, 2006^65^; Fair | US; Primary Health Care | Multiple risk factors | Age ≥45 with one or more CVD risk factors | 154 | 5, 10 (79) | 53 (≥45) | 80 | 34; NR | HTN: 38; Dys: NR; PreDM: NR; DM: 16; CVD: 0; Smoking: 10 | Education, n (%):; - completed college, 104 (68); Family income, n (%):; - $40,000 to $59,999, 16 (10); - >$60,000, 85 (55)
Ellsworth, 2016^66^; Fair | US; NR | Multiple risk factors | Age ≥18 with any of multiple risk factors | 184 | 12 (80) | 61 (34-86) | 58 | 31; 85 | HTN: 43; Dys: 33; PreDM: NR; DM: 24; CVD: 22; Smoking: NR | NR
Estruch, 2018^67^ (Primary Prevention of Cardiovascular Disease with a Mediterranean Diet (PREDIMED)); Fair | Spain; Primary Health Care | Multiple risk factors | Men, age 55 to 80, and women, age 60 to 80, with any of multiple CVD risk factors, who did not score as unlikely to change according to the Stages of Change model | 7447 | 12, 24, 36, 48, 60, 72 (93) | 67 (55-80) | 43 | 30; 93 | HTN: 83; Dys: 72; PreDM: NR; DM: 49; CVD: 0; Smoking: 14 | Employment status:; Working: 13%; Housewife: 32%; Unemployed: 1%; Retired: 52%; Education:; University graduate: 4%; Some college: 4%; Secondary education: 16%; Primary education: 74%; Illiterate: 2%
Fagerberg, 1998^68^ (Risk Factor Intervention Study (RIS)); Good (KQ1); Fair (KQ2) | Sweden; Mixed | Multiple risk factors | Men, age 50 to 72, with treated hypertension and any of high total cholesterol, diabetes, or current smoking | 508 | 12, 40, 79 (94) | 66 (50-72) | 0 | 27; NR | HTN: 100; Dys: 74; PreDM: NR; DM: 22; CVD: 13; Smoking: 29 | NR
Gill, 2019^69^ (Heartmatters Challenge - First Responders); Fair | US; Other | Multiple risk factors | Adults, aged 18 to 65, with low HDL or high waist circumference | 175 | 3, 6, 12 (78) | 42 (18-65) | NR | 32; NR | HTN: NR; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | NR
Gill, 2019^70^ (HealtheSteps); Fair | Canada; Mixed | Multiple risk factors | Adults, aged 18 to 85 years, with BMI >25 kg/m2 and any of multiple risk factors | 118 | 6 (75) | 58 (18-85) | 79 | 31; 100 | HTN: 28; Dys: 28; PreDM: 16; DM: 15; CVD: NR; Smoking: 8 | Education, n (%):; ≤High school, 35 (30); >High school, 83 (70)
Greaves, 2015^71^ (Waste the Waist); Fair | UK; Primary Health Care | Multiple risk factors | Age 40 to 74 with BMI ≥28 and ≥1 additional CV risk factor | 108 | 4, 12 (89) | 65 (40-74) | 31 | 33; 100 | HTN: NR; Dys: NR; PreDM: 8; DM: 0; CVD: NR; Smoking: NR | Education, n (%):; - Up to age 16, 50 (46.3); - Up to age 18, 8 (7.4); - Some additional, 23 (21.3); - ≥Undergraduate, 27 (25.0); Area deprivation (Index of Multiple Deprivation [IMD] score): 11.9
Groeneveld, 2010^72^ (Health Under Construction); Fair | The Netherlands; Health Care | Multiple risk factors | Males in the construction industry, age 18 to 65, with higher than moderate (thresholds not defined) Framingham 10-yr CVD risk and any of multiple risk factors | 816 | 6, 12 (72) | 47 (18-65) | 0 | 28; NR | HTN: NR; Dys: NR; PreDM: NR; DM: NR; CVD: 0; Smoking: 52 | % blue-collar workers (performing the construction vs. white-collar workers involved in admin and supervision): 74
Hardcastle, 2008^73^; Fair | UK; Primary Health Care | Multiple risk factors | Age 18 to 65 with BMI ≥28, hypertension, or hypercholesterolemia | 334 | 6, 18 (63) | 50 (18-65) | 67 | 34; 99 | HTN: 35; Dys: 57; PreDM: NR; DM: NR; CVD: NR; Smoking: 16 | NR
Harris, 2012^74^ (Health Improvement and Prevention Study (HIPS)); Fair | Australia; Health Care | Multiple risk factors | Age 40 to 55 with hypertension or dyslipidemia; age 56 to 64 with or without recorded risk factors | 814 | 6, 12 (80) | NR (40-64) | 57 | 29; 56 | HTN: 9; Dys: 88; PreDM: NR; DM: 0; CVD: 0; Smoking: 13 | % employed: 68; % tertiary educated (college of technical and further education or university): 47; % Socioeconomic Indexes for Areas score in lowest quintile: 2
Haufe, 2019^75^; Fair | Germany; Other | Multiple risk factors | Age >18 years with ≥3 of 5 components of metabolic syndrome | 314 | 6 (87.3) | 48 (>18) | 14 | 33; NR | HTN: NR; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | Type of work:; Manual: 36%; Office: 52%; Unclassified: 12%
Hinderliter, 2014^76^ (Exercise and Nutrition interventions for CardiOvasculaR hEalth (ENCORE)); Good | US; Mixed | Hypertension | Age ≥35 with untreated above-normal blood pressure and BMI between 25 and 39.9 | 95 | 4,12 (86) | 52 (≥35) | 66 | 33; 100 | HTN: NR; Dys: 27; PreDM: NR; DM: 0; CVD: 0; Smoking: 8 | Education: n (%); High school, 34 (36%); Completed college, 23 (24%); Income: n (%)
HPT, 1990^77^ (Hypertension Prevention Trial (HPT)); Good | US; Community | Hypertension | Age 25 to 49 with untreated high normal DBP | 841 | 6, 12, 18, 24, 30, 36 (90) | 39 (25-49) | 35 | 27; 75 | HTN: 0; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: 17 | College graduate, %: 54
Hyman, 1998^78^; Fair | US; Health Care | Dyslipidemia | Low-income patients, age 18 to 65, with untreated hypercholesterolemia | 123 | 6 (80) | 56 (18-65) | 75 | 31; NR | HTN: NR; Dys: 100; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | ≤ High school education, %: 89; Income level ≤$1000/month, %: 78
Hyman, 2007^79^; Fair | US; Primary Health Care | Hypertension | Sedentary African Americans adults, age 45 to 60, with hypertension and current smoking | 281 | 6, 18 (82) | 53 (45-65) | 67 | 32; NR | HTN: 100; Dys: NR; PreDM: NR; DM: 18; CVD: 0; Smoking: 100 | Recruited from facility that serves medically indigent, “most” patients ≤100% FPL
Ives, 1993^80^ (Rural Health Promotion Project (RHPP) Trial); Fair | US; Community | Dyslipidemia | Residents of rural areas, age 65 to 79, with TC ≥240 mg/dL | 1197 | 30 (77) | 71 (65-79) | 57 | NR; NR | HTN: 18; Dys: 100; PreDM: NR; DM: 16; CVD: 20; Smoking: 12 | Mean education, years: 11; Completed school; 60.1% completed HS or above; Mean annual household income: $15,500
Johnston, 1995^81^; Fair | Australia; Health Care | Dyslipidemia | Adults with elevated total cholesterol | 179 | 2, 6 (73) | 57 (24-81) | NR | 25; NR | HTN: NR; Dys: 100; PreDM: NR; DM: 0; CVD: 0; Smoking: NR | NR
Jones, 1999^82^ (Hypertension Optimal Treatment (HOT)); Fair | US; NR | Hypertension | Age 50 to 80 with BMI ≥27 and hypertension | 112 | 6, 12,18, 24, 30 (91) | 58 (50-80) | NR | 34; 100 | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | NR
Kandula, 2015^83^ (South Asian Heart Lifestyle Intervention (SAHELI)); Fair | US; Community | Multiple risk factors | Asian Indian or Pakistani immigrants, age 30 to 59, with at least one ASCVD risk factor | 63 | 3, 6 (100) | 50 (30-59) | 64 | 30; NR | HTN: NR; Dys: NR; PreDM: NR; DM: NR; CVD: 0; Smoking: NR | Born outside of the US: 100%; Limited English proficiency: 36%
Kanke, 2015^84^; Fair | Japan; Primary Health Care | Multiple risk factors | Age 30 to 69 with obesity (per Japanese cutpoints) and hypertension, dyslipidemia, and/or type 2 diabetes | 50 | 6, 12 (80) | 55 (30-69) | 36 | 28; 100 | HTN: 84; Dys: 38; PreDM: NR; DM: 16; CVD: NR; Smoking: 18 | Education n (%):; >HS: 14 (28.0%); ≥HS: 36 (72.0%)
Kastarinen, 2002^85^ (Lifestyle Intervention against Hypertension in Eastern Finland (LIHEF)); Fair | Finland; Primary Health Care | Hypertension | Age 25 to 74 with hypertension | 715 | 12, 24 (83) | 54 (25-74) | 53 | 29; 80 | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: 4; Smoking: 8 | NR
Keyserling, 1997^86^ (Southeast Cholesterol Project); Fair | US; Health Care | Dyslipidemia | Low-income adults, age 20 to 75, with elevated cholesterol | 372 | 4, 7, 12, 24 (92) | 56 (20-75) | 67 | NR; NR | HTN: 60; Dys: 100; PreDM: NR; DM: 0; CVD: 10; Smoking: 18 | Education, mean grade: 11; Employed full-time, %: 36
Khanji, 2019^87^ (HAPPY London); Good | UK; Primary Health Care | Multiple risk factors | Age 40 to 74 with QRISK2 10-year CVD risk score ≥10% | 402 | 6 (93.8) | 65 (40-74) | 37 | 28; NR | HTN: NR; Dys: NR; PreDM: NR; DM: 14; CVD: 0; Smoking: 8 | NR
Koelewijn-van Loon, 2009^88^ (Improving Patient Adherence to Lifestyle Advice (IMPALA)); Fair | The Netherlands; Primary Health Care | Multiple risk factors | Adults with one or more CVD risk factors | 615 | 3, 12 (79) | 57 (NR) | 55 | 29; NR | HTN: 65; Dys: 43; PreDM: NR; DM: 14; CVD: 0; Smoking: 26 | SES level, n (%):; -High, 134 (23); -Intermediate, 228 (39); -Low, 204 (35)
Kramer, 2018^89^ (Healthy Lifestyle Project); Fair | US; Community | Multiple risk factors | Age ≥18 with any of multiple risk factors | 134 | 6 (92) | 62 (28-88) | 67 | 34; 100 | HTN: NR; Dys: NR; PreDM: NR; DM: 0; CVD: NR; Smoking: NR | Median income for the three communities:; $62,058; $45,099; $38,811
Lakerveld, 2013^90^ (HOORN); Fair | The Netherlands; Primary Health Care | Multiple risk factors | Age 30 to 50 with any of multiple CVD risk factors | 622 | 6, 12, 24 (81) | 44 (30-50) | 58 | 29; NR | HTN: NR; Dys: NR; PreDM: NR; DM: 0; CVD: 0; Smoking: 21 | % employed: 85; % below average income: 37; % average income: 18; % above average income: 30; % ≤ primary education: 23; % secondary education: 46; % college/university: 21
Langford, 1991^91^ (Trial of Antihypertensive Interventions and Management (TAIM)); Fair | US; Mixed | Hypertension | Age 21 to 65 at 110-160% of ideal body weight and untreated hypertension | 878 | 6 (90) | 49 (21-65) | 44 | NR; 100 | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: 0; Smoking: 16 | % employed (FT or PT): 79; % education ≥college: 61
Lee, 2007^92^; Fair | Taiwan; Other | Hypertension | Older adults, age ≥60, with hypertension | 202 | 6 (91) | 71 (≥60) | 42 | 25; NR | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: 22 | Education level:; 4-7 yrs: 39%; >7 yrs: 18%
Liira, 2014^93^; Fair | Finland; Mixed | Multiple risk factors | Sedentary men, age 35 to 45, with at least 2 CVD risk factors | 114 | 3, 12 (77) | 40 (35-45) | 0 | NR; NR | HTN: NR; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | NR
Migneault, 2012^94^; Fair | US; Health Care | Hypertension | African-American adults, age ≥35, with treated hypertension | 337 | 4, 8, 12 (77) | 56 (≥35) | 70 | 34; NR | HTN: 100; Dys: NR; PreDM: NR; DM: 38; CVD: 8; Smoking: NR | Median household income: 10-20k/year; % Employed full or part-time: 39.7; Education, mean years: 12.2
Moreau, 2001^95^; Fair | US; NR | Hypertension | Postmenopausal women, age 52 to 56, with borderline to stage 1 hypertension | 24 | 3, 6 (100) | 54 (53-55) | 100 | NR; NR | HTN: NR; Dys: NR; PreDM: NR; DM: NR; CVD: 0; Smoking: 0 | NR
Moy, 2001^96^; Fair | US; Health Care | Multiple risk factors | Siblings of persons with CHD onset prior to age 60, age 30 to 59, with elevated LDL, hypertension, or current smoking | 235 | 24 (76) | 46 (30-59) | 48 | 29; NR | HTN: 57; Dys: 79; PreDM: NR; DM: NR; CVD: NR; Smoking: 46 | Education, mean years: 12
Muhlhauser, 1993^97^ (Hypertension Treatment and Teaching Program (HTTP)); Fair | Germany; Primary Health Care | Hypertension | Age 30 to 60 with hypertension | 200 | 18 (80) | 51 (30-60) | NR | NR; NR | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | NR
Murphy, 2012^98^ (National Exercise Referral Scheme (NERS)); Fair | UK; Health Care | Multiple risk factors | Age >16 with ≥1 CHD risk factors or a mental health condition and sedentary | 2160 | 12 (68) | 52 (16-88) | 66 | NR; NR | HTN: NR; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | Welsh deprivation index:; % low: 35; % mild: 34; % high: 31; Education beyond min school leaving age, %: 52.7; Employment:; % Employed: 31; % Retired: 34; % Housework: 19; % Other: 16; % Missing: 0
Neil, 1995^99^; Fair | UK; Primary Health Care | Dyslipidemia | European adults, age 35 to 64, with untreated hypercholesterolemia | 309 | 6 (97) | 55 (35-64) | 47 | 26; 59 | HTN: NR; Dys: 100; PreDM: NR; DM: NR; CVD: NR; Smoking: 22 | NR
Niiranen, 2014^100^; Fair | Finland; Primary Health Care | Hypertension | Age 35 to 74 with hypertension | 229 | 12 (96) | 62 (35-74) | 50 | 28; NR | HTN: 100; Dys: 43; PreDM: NR; DM: 11; CVD: NR; Smoking: 11 | >8 yrs education: 38%
Nolan, 2018^101^ (Reducing Risk with E-based Support for Adherence to Lifestyle Change in Hypertension (REACH)); Fair | Canada; Other | Hypertension | Age 35 to 74 with hypertension | 264 | 4, 12 (74) | 58 (35-74) | 58 | 31; NR | HTN: 100; Dys: NR; PreDM: NR; DM: 7; CVD: 5; Smoking: 9 | Mean years education: 16
Ogedegbe, 2014^102^ (Counseling African Americans to Control Hypertension (CAATCH)); Fair | US; Health Care | Hypertension | Black adults, age ≥18, with treated, uncontrolled hypertension | 1039 | 3, 6, 9, 12 (71) | 56 (≥18) | 72 | 33; 86 | HTN: 100; Dys: NR; PreDM: NR; DM: 36; CVD: 9; Smoking: 51 | Education:; ≤HS: 72%; Some college: 26%; Some graduate school: 2%; Annual household income < $20k: 72%; Employment status:; Unemployed: 11%; Retired or homemaker: 55%; Employed part time: 14%; Employed full time: 20%
Reid, 2014^103^; Fair | Canada; Health Care | Multiple risk factors | Family members of patients with CAD with ≥1 modifiable risk factor | 426 | 3, 12 (74) | 52 (NR) | 61 | 29; NR | HTN: NR; Dys: NR; PreDM: NR; DM: 0; CVD: 0; Smoking: 9 | Education, mean years: 14.7
Rodriguez, 2012^104^; Fair | US; Primary Health Care | Hypertension | Veterans, age ≥21, with treated uncontrolled hypertension | 533 | 6, 12 (90) | 66 (≥21) | 1 | 30; NR | HTN: 100; Dys: 24; PreDM: NR; DM: 44; CVD: 13; Smoking: 19 | Employed full-time, %: 14; Employed (unspecified), %: 21; College graduate, %: 22; ≤High school graduate, %: 46
Rodriguez-Cristobal, 2012^105^; Fair | Spain; Primary Health Care | Multiple risk factors | Age 30 to 75, with elevated fibrinogen levels and estimated moderate or high Framingham CHD risk (thresholds not defined) | 436 | 24 (69) | 58 (30-75) | 63 | 30; NR | HTN: 42; Dys: NR; PreDM: NR; DM: 14; CVD: 0; Smoking: 29 | NR
Rosas, 2015^106^ (Vivamos Activos Fair Oaks (VAFO)); Good | US; Health Care | Multiple risk factors | Latino adults, age ≥18, with BMI 30-60 and 1 or more additional CHD risk factors | 207 | 6, 12, 24 (84) | 47 (≥18) | 77 | 36; 100 | HTN: NR; Dys: NR; PreDM: NR; DM: 43; CVD: NR; Smoking: NR | Food insecure, %: 51; Education n (%):; ≤8th grade: 140 (67.6%); Some HS: 24 (11.3%); ≥HS: 43 (20.8%); Employment status n (%); Employed: 97 (46.9%); Unemployed: 21 (10.1%); Not working: 89 (43.0%); Annual income n (%):; < $10,000: 58 (28.0%); $10,000 - $20,000: 92 (44.4%); > $20,000: 56 (27.1%)
Rubinstein, 2016^107^; Good | Argentina; Mixed | Hypertension | Latino adults, age 30 to 60, with untreated prehypertension | 212 | 12 (90) | 43 (30-60) | 54 | 29; NR | HTN: 0; Dys: NR; PreDM: NR; DM: 0; CVD: 0; Smoking: 19 | Years education, mean: 11; Employment status:; Employee: 42%; Independent worker: 29%; Housewife: 25%; Other: 4%; Income:; First quintile: 9%; Fifth quintile: 23%
Salisbury, 2016^108^; Good | UK; Primary Health Care | Multiple risk factors | Age 40 to 74 with 10 year CVD risk ≥20% and any of: SBP ≥140 mm Hg, BMI ≥30, or current smoking | 641 | 6, 12 (91) | 67 (40-74) | 20 | 31; NR | HTN: NR; Dys: NR; PreDM: NR; DM: 22; CVD: NR; Smoking: 18 | Employment status:; Full time: 15%; Part time: 11%; Unemployed: 1%; Unable to work: 2%; Retired: 65%; Homemaker: 1%; Other: 4%; College degree or higher: 22%
Schoenthaler, 2016^109^ (Individual Motivational Interviewing - Therapeutic Lifestyle Changes (MINT-TLC)); Fair | US; Primary Health Care | Hypertension | Black adults, age ≥18, with hypertension | 194 | 1, 3, 6 (80) | 57 (≥18) | 50 | 33; NR | HTN: 100; Dys: NR; PreDM: NR; DM: 44; CVD: 14; Smoking: 18 | Highest degree or level of education:; < HS: 19%; HS diploma/GED: 47%; ≥ Some college: 34%; Current employment status:; Employed/self-employed: 27%; Retiree: 20%; On disability: 14%; Unemployed/not working: 39%; Annual income < $20k: 69%
Scott, 2018^110^; Fair | UK; Other | Multiple risk factors | Age ≥18 with any of multiple risk factors and completed previous exercise referral program | 37 | 3, 6 (94) | 59 (≥18) | 43 | NR; 94 | HTN: NR; Dys: NR; PreDM: NR; DM: NR; CVD: 6; Smoking: NR | Employment:; Full-time: 6%; Part-time: 17%; Full-time caregiver: 6%; Unemployed: 11%; Incapacity benefit: 14%; Retired: 46%
Soto Rodriguez, 2016^111^; Fair | Spain; Health Care | Multiple risk factors | Women, age 45 to 60, with any of diabetes, dyslipidemia, or hypertension | 320 | 12 (72) | 53 (45-60) | 100 | 27; NR | HTN: NR; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | NR
Stefanick, 1998^112^ (Diet and Exercise for Elevated Risk (DEER)); Fair | US; Mixed | Dyslipidemia | Postmenopausal women, age 45 to 64, and men, aged 30 to 64, with untreated dyslipidemia or mildly elevated lipids | 189 | 12 (98) | 52 (30-64) | 49 | 27; NR | HTN: NR; Dys: 100; PreDM: NR; DM: 0; CVD: 0; Smoking: NR | NR
Stevens, 2003^113^; Fair | US; Health Care | Dyslipidemia | Women, aged 40 to 70, with dyslipidemia | 616 | 12 (87) | 54 (40-70) | 100 | 30; NR | HTN: NR; Dys: 100; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | % college grad or more: 40
Svetkey, 2008^114^ (Weight Loss Maintenance (WLM)); Good | US; Mixed | Multiple risk factors | Age ≥25 with previous weight loss and pharmacologically treated for hypertension and/or dyslipidemia | 1032 | 12, 18, 24, 30, 60 (95) | 56 (28-83) | 63 | 34; 100 | HTN: NR; Dys: NR; PreDM: NR; DM: NR; CVD: 0; Smoking: NR | Household income/y:; ≥$60,000: 57.4%; Education:; ≤Some college: 38.4%; College degree: 61.6%
Svetkey, 2009^115^ (Hypertension Improvement Project (HIP)); Fair | US; Primary Health Care | Hypertension | Age ≥25 with hypertension | 574 | 6, 18 (88) | 60 (28-94) | 61 | 32; NR | HTN: 97; Dys: 48; PreDM: NR; DM: 30; CVD: 16; Smoking: 9 | % % inadequate income: 15
Ter Bogt, 2009^116^ (Groningen Overweight and Lifestyle (GOAL)); Good | The Netherlands; Primary Health Care | Multiple risk factors | Age 40 to 70 with BMI 25-40 and hypertension or dyslipidemia | 457 | 12, 36 (91) | 56 (40-70) | 52 | 30; 100 | HTN: 62; Dys: 39; PreDM: NR; DM: 0; CVD: NR; Smoking: 19 | % low education: 32
Tiessen, 2012^117^ (SPRING (Self-monitoring and Prevention of RIsk Factors by Nurse practitioners in the region of Groningen)); Fair | The Netherlands; Primary Health Care | Multiple risk factors | Age 50 to 75 with any of multiple CVD risk factors | 201 | 12 (89) | 65 (50-75) | 31 | 28; NR | HTN: 76; Dys: 79; PreDM: NR; DM: 0; CVD: 0; Smoking: 32 | % no education or primary education: 10; % lower secondary education: 42; % higher secondary education: 27; % college or university: 22
Toft, 2008^118^ (Inter99); Fair | Denmark; Research Center | Multiple risk factors | Age 30 to 60 with any of multiple CVD risk factors | 4053 | 12, 36, 60 (64) | 47 (30-60) | 51 | 27; NR | HTN: NR; Dys: NR; PreDM: NR; DM: 11; CVD: NR; Smoking: 59 | % employed: 83; % no vocational education: 19
TOHP I CRG, 1992^119^ (Trials of Hypertension Prevention Phase I (TOHP I)); Good | US; Research Center | Hypertension | Overweight or obese adults age 30 to 54 with prehypertension | 1224 | 3, 6, 12, 18, 192 (93) | 43 (30-54) | 28 | 28; 100 | HTN: 0; Dys: NR; PreDM: NR; DM: 0; CVD: 0; Smoking: 12 | College graduates: 54%; FT employment: 92%
TOHP II CRG, 1997^120^ (Trial of Hypertension Prevention II (TOHP II)); Good | US; Mixed | Hypertension | Age 30 to 54 with untreated prehypertension and 110 to 165% of ideal body weight | 2382 | 6, 18, 36, 48 (88) | 44 (30-54) | 34 | NR | HTN: 0; Dys: NR; PreDM: NR; DM: 0; CVD: 0; Smoking: 9 | Education:; Some college: 35%; College graduate: 21%; Postgraduate: 30%; Employed full time: 88%
Tomson, 1995^121^; Fair | Sweden; Primary Health Care | Dyslipidemia | Age 25 to 54 with dyslipidemia | 92 | 12 (83) | 42 (25-54) | NR | 25; NR | HTN: 0; Dys: 100; PreDM: NR; DM: 0; CVD: 0; Smoking: 54 | NR
van der Veen, 2002^122^ (Nijmegen Family Practices Monitoring Project (NFPMP)); Fair | The Netherlands; Primary Health Care | Dyslipidemia | Age 40 to 70 with dyslipidemia, high dietary fat intake, and hypertension or diabetes | 143 | 6, 12 (91) | 58 (40-70) | 73 | 29; NR | HTN: 92; Dys: 100; PreDM: NR; DM: 6; CVD: 0; Smoking: 22 | Education, %:; - Low, 68; - Intermediate, 19; - High, 14
van Keulen, 2011^123^ (Vitalum); Fair | The Netherlands; Primary Health Care | Hypertension | Age 45 to 70 with or without hypertension, not meeting Dutch diet and PA guidelines | 1629 | 6, 11, 17 (74) | 57 (45-70) | 45 | 27; 67 | HTN: 52; Dys: NR; PreDM: NR; DM: 10; CVD: NR; Smoking: 22 | % low education: 54; % with paying job: 48
van Sluijs, 2005^124^ (Physician-based Assessment and Counseling for Exercise (PACE)); Fair | The Netherlands; Primary Health Care | Multiple risk factors | Age 18 to 70 with hypertension, hypercholesterolemia, or non-insulin dependent diabetes | 358 | 2, 6, 12 (86) | 56 (18-70) | 49 | 29; NR | HTN: NR; Dys: NR; PreDM: NR; DM: NR; CVD: NR; Smoking: 25 | % low level of education: 36; % medium level of education: 43; % high level of education: 20; % employed full time: 30; % employed part time: 24; % unemployed: 46 (but average age is 55, unclear how many of these retired)
Viglione, 2019^125^ (Goals for Eating and Moving (GEM)); Fair | US; Primary Health Care | Multiple risk factors | Veterans, age 18 to 69, with obesity or overweight and multiple risk factors | 45 | 3, 6, 12 (84.4) | 54 (18-69) | 33 | NR; NR | HTN: 40; Dys: 28; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | Annual household income:; <$24,999: 27%; $25,000-49,999: 29%; $50,000-99,000: 31%; $≥100,000: 9%; Household food security:; Food secure: 72%; Food insecure: 21%; Hunger: 7%
Voils, 2013^126^ (CouPLES); Fair | US; Primary Health Care | Dyslipidemia | Veterans with dyslipidemia and their spouses | 255 | 6, 11 (89) | 61 (NR) | NR | NR | HTN: NR; Dys: 100; PreDM: NR; DM: NR; CVD: NR; Smoking: NR | ≤High School 24%; FT employment 41%
Wadden, 2011^127^ (Practice-based Opportunities for Weight Reduction at the University of Pennsylvania (POWER-UP)); Good | US; Primary Health Care | Multiple risk factors | Age ≥21 with obesity and two or more CVD risk factors | 261 | 6, 12, 18, 24 (85) | 52 (≥21) | 80 | 39; 100 | HTN: 71; Dys: 66; PreDM: NR; DM: 21; CVD: 0; Smoking: 10 | Education n (%):; Less than HS: 5.7%; HS: 19.9%; Some college/associate’s: 35.6%; BA: 21.0%; Graduate/professional degree: 17.6%
Whelton, 1998^128^ (Trial of Nonpharmacologic Interventions in the Elderly (TONE)); Good | US; Mixed | Hypertension | Age 60 to 80 with treated hypertension | 975 | 36 (92) | 66 (60-80) | 48 | 29; NR | HTN: 100; Dys: NR; PreDM: NR; DM: NR; CVD: 0; Smoking: 5 | No. (%) ≥11th grade: 107 (11); No. (%) College grad: 322 (33); No. (%) Unemployed: 29 (3); No. (%) Retired: 575 (59)
Wister, 2007^129^; Good | Canada; Mixed | Multiple risk factors | Age 45 to 64 with 10-yr CVD risk ≥10% based on Framingham risk score | 315 | 12 (88) | 55 (45-64) | 58 | 32; NR | HTN: NR; Dys: NR; PreDM: NR; DM: NR; CVD: 0; Smoking: 13 | NR
Wong, 2015^130^; Good | Hong Kong; Mixed | Hypertension | Age 40 to 70 with untreated newly-diagnosed Grade I hypertension | 556 | 6, 12 (87) | 55 (40-70) | 51 | 24; NR | HTN: 100; Dys: NR; PreDM: NR; DM: 0; CVD: NR; Smoking: 9 | Employment:; % unemployed: 43; % employed: 57; Monthly household income:; % on comprehensive social security assistance: 2; % % $1290-2579: 24; % $2580-3869: 19; % $3870-5159: 18; % ≥$5160: 25; Education:; % illiterate/kindergarten/primary: 19; % secondary: 64; % ≥undergraduate: 15; % other:
Wood, 2008^131^ (EUROACTION); Fair | Europe (6 countries); Primary Health Care | Multiple risk factors | Age 50 to 80 with 10-yr SCORE CVD risk score ≥5% | 2385 | 12 (85) | 62 (50-80) | NR | NR | HTN: 63; Dys: 75; PreDM: NR; DM: 30; CVD: 0; Smoking: 31 | NR

Abbreviations: ASCVD = atherosclerotic cardiovascular disease; BMI = body mass index; CAD = coronary artery disease; CHD = coronary heart disease; CVD = cardiovascular disease; DBP = diastolic blood pressure; DM = diabetes mellitus; Dys = dyslipidemia; F/U = followup; FPL = federal poverty line; GED = general education diploma; HMO = health management organization; HS = high school; HTN = hypertension; LDL = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; mm Hg; millimeters of mercury; N rand = number of participants randomized; No. = number; NR = not reported; PA = physical activity; PHPP = Patient-motivated Health Promotion Program; PREDIMED = Primary Prevention of Cardiovascular Disease with a Mediterranean Diet; PreDM = prediabetes mellitus; SBP = systolic blood pressure; TC = total cholesterol; yrs = years

Appendix F Table 2 Intervention Characteristics

Author, year (Study name) Quality | Int arm | Focus | Brief intervention description | Contacts | Diet Weight loss approach | Format | Delivery | Motiv Int | Role of PCP (Staff involved?) | Provider(s); Setting | Control Group
Ammerman, 2003^38^; Fair | IG1 | HD | 7 sessions of dietary counseling (3 nurse sessions, 1 phone call, 3 nutritionist visits [if referred]) and 2 newsletters; Total duration: 12 months | Total: 9; Interactive: 7; Other: 2; Est Tot Hr: 3.2; Category: Medium | Low-fat; NR | Indiv | In-person Phone Print | | None (No) | Nurse, nutritionist; Health department | UC
Anderson, 1992^39^; Fair | IG1 | HD | 10 60-min group dietary counseling sessions (high fiber diet) with 30-min individual dietitian consultation; 4 home visits (min NR); 12 monthly phone calls (min NR); Total duration: 12 months | Total: 26; Interactive: 26; Other: 0; Est Tot Hr: 20; Category: High | Low-fat; Not promoted | Indiv Group | In-person Phone | | None (No) | Dietitian, project staff; NR, home | UC
Anderson, 1992^39^; Fair | IG2 | HD | 10 60-min group dietary counseling sessions (AHA Diet) with 30-min individual dietitian consultation; 4 home visits (min NR); 12 monthly phone calls (min NR); Total duration: 12 months | Total: 26; Interactive: 26; Other: 0; Est Tot Hr: 20; Category: High | Low-fat; Not promoted | Indiv Group | In-person Phone | | None (No) | Dietitian, project staff; NR, home | UC
Anderssen, 1995^40^ (Oslo Diet and Exercise Study (ODES)); Fair | IG1 | HD | 3 individual sessions diet counseling; Total duration: 9 months | Total: 3; Interactive: 3; Other: 0; Est Tot Hr: 1.5; Category: Medium | Low-fat; Low sodium; Promoted for all participants | Indiv Family | In-person | | NR (NR) | NR | WL
Appel, 2003^41^ (PREMIER); Good | IG1 | HD + PA | 33 DASH diet and physical activity counseling, including 26 90–120 min group counseling sessionsand 7 30–60 min individual sessions using motivational interviewing; Total duration: 18 months | Total: 33; Interactive: 33; Other: 0; Est Tot Hr: 59; Category: High | DASH; Low sodium; Promoted for subset of participants | Indiv Group | In-person Print | X | None (No) | Master’s degree-level counselors (dietitians and health educators trained in behavioral methods); Clinical centers | UC
Appel, 2003^41^ (PREMIER); Good | IG2 | HD + PA | 33 sessions of low sodium diet and physical activity counseling, including 26 90–120 min group counseling sessions and 7 30–60 min individual sessions using motivational interviewing; Total duration: 18 months | Total: 33; Interactive: 33; Other: 0; Est Tot Hr: 59; Category: High | Low sodium; Promoted for subset of participants | Indiv Group | In-person Print | X | None (No) | Master’s degree-level counselors (dietitians and health educators trained in behavioral methods); Clinical centers | UC
Appel, 2011^42^ (POWER Hopkins (Practice Based Opportunities for Weight Reduction)); Good | IG1 | HD + PA | 30 group counseling sessions (90 min), 12 individual counseling sessions (20 min), 15 phone sessions (20 min) + PCP counseling at routine visits, weekly web-based modules, and monthly e-mail messages; Total duration: 24 months | Total: 58; Interactive: 58; Other: 0; Est Tot Hr: 54; Category: High | DASH; Promoted for all participants | Indiv Group | In-person Tech-based Phone | X | Deliver part (NR) | Lifestyle coach; Research clinic and home (web-based) | UC
Appel, 2011^42^ (POWER Hopkins (Practice Based Opportunities for Weight Reduction)); Good | IG2 | HD + PA | 33 lifestyle behavioral coaching calls (20 min), weekly web-based modules, PCP counseling at routine visits; Total duration: 24 months | Total: 34; Interactive: 34; Other: 0; Est Tot Hr: 11; Category: High | DASH; Promoted for all participants | Indiv | Tech-based Phone | X | Deliver part (NR) | PCP, lifestyle coach; Home (web-based) | UC
Applegate, 1992^43^; Fair | IG1 | HD + PA | 12 group and 2 individual sessions of weight management, sodium restriction, and PA counseling; Total duration: 6 months | Total: 14; Interactive: 14; Other: 0; Est Tot Hr: 13; Category: High | Low sodium; Promoted for all participants | Indiv Group | In-person | | None (No) | Registered dietitians; Clinic | None
Arroll, 1995^44^; Fair | IG1 | HD + PA | Advised to exercise, reduce salt intake.; Number/duration of sessions NR.; Total duration: 6 months | Total:; Interactive:; Other: 0; Est Tot Hr:; Category: Low | Low sodium; NR | Indiv | In-person Print | | NR (NR) | Research staff and GP; “community setting” | Min
Arroll, 1995^44^; Fair | IG2 | PA | Advised to walk briskly 40mins, 3 days per week.; Number/duration of sessions NR; Total duration: 6 months | Total:; Interactive:; Other: 0; Est Tot Hr:; Category: Low | NR | Indiv | In-person Print | | NR (NR) | Research staff and GP; “community setting” | Min
Arroll, 1995^44^; Fair | IG3 | HD | Advised to decrease salt intake.; Number/duration sessions NR.; Total duration: 6 months | Total:; Interactive:; Other: 0; Est Tot Hr:; Category: Low | Low sodium; NR | Indiv | In-person Print | | NR (NR) | Research staff and GP; “community setting” | Min
Babazono, 2007^45^ (PHPP); Fair | IG1 | HD + PA | 3 sessions of diet and physical activity counseling (length of sessions: NR), 1 at health center and 2 at home; Total duration: 12 months | Total: 3; Interactive: 3; Other: 0; Est Tot Hr: 3; Category: Medium | NR | Indiv | In-person | | None (No) | Dietitians, health exercise instructors, public health nurses; Medical center, home visits | UC
Beckmann, 1995^46^; Fair | IG1 | HD | 5 in-person individual dietary counseling sessions; Total duration: 12 months | Total: 5; Interactive: 5; Other: 0; Est Tot Hr: 2.5; Category: Medium | Low-fat; Low sodium; Promoted for subset of participants | Indiv | In-person | | None (No) | Nutritionist; Outpatient clinic | WL
Bennett, 2012^47^ (Be Fit, Be Well [POWER]); Good | IG1 | HD + PA | 18 tailored diet, physical activity and lifestyle counseling calls (20 min each); 12 optional group sessions; PCP endorsement message; and self-monitoring using study website or interactive voice response system; Total duration: 24 months | Total: 31; Interactive: 30; Other: 0; Est Tot Hr: 18; Category: High | Promoted for all participants | Indiv Group | In-person Tech-based Phone Print | X | Deliver part (Yes) | Community health educator and PCP endorsement; Home (web-based or print and phone) and community health center | UC
Bennett, 2018^48^ (Track); Good | IG1 | HD + PA | 18 10–15 min telephone coaching sessions of diet and physical activity counseling, 3 PCP 2 min weight counseling visits, 52 2–3 min IVR calls; Total duration: 12 months | Total: 73; Interactive: 21; Other: 0; Est Tot Hr: 5.4; Category: Medium | Promoted for all participants | Indiv | In-person Tech-based Phone Print | X | Deliver part (Yes) | PCP, dietitian, psychology graduate students; Primary care and home (coaching calls) | UC
Beune, 2014^49^ (Culturally Adapted Hypertension Education (CAHE)); Fair | IG1 | HD + PA | 3 30-min sessions of medication and lifestyle counseling and culturally-specific written materials; Total duration: 4.5 months | Total: 3; Interactive: 3; Other: 0; Est Tot Hr: 1.5; Category: Medium | NR | Indiv | In-person Print | | None (Yes) | Practice Nurse; Primary care | UC
Blackford, 2016^50^ (Albany Physical Activity and Nutrition (APAN)); Fair | IG1 | HD + PA | 6 motivational interviewing telephone calls, 3 newsletters, and website access; Total duration: 6 months | Total: 9; Interactive: 6; Other: 0; Est Tot Hr: 1.5; Category: Medium | NR | Indiv | Tech-based Phone Print | X | None (No) | Research assistants; Home | WL
Bloemberg, 1991^51^; Fair | IG1 | HD | 1 session of dietary counseling, 2 phone calls, and 5 mailers; Total duration: 6 months | Total: 8; Interactive: 3; Other: 5; Est Tot Hr: 1; Category: Medium | Low-fat; NR | Indiv | In-person Phone Print | | None (No) | Dietitian; NR | None
Bo, 2007^52^; Fair | IG1 | HD + PA | 5 sessions of diet and physical activity counseling (1 60-min individual session and 4 60-min interactive group sessions) and printed materials; Total duration: 12 months | Total: 5; Interactive: 5; Other: 0; Est Tot Hr: 5; Category: Medium | NR; Promoted for subset of participants | Indiv Group | In-person Print | | None (Yes) | Nutritionists, specialists in endocrinology, and internal medicine; Assumed health clinic | UC
Bosworth, 2009^53^ (Take Control of Your Blood pressure (TCYB)); Fair | IG1 | HD + PA | 12 16-min phone sessions of diet and physical activity counseling and self-administered blood pressure monitoring three times per week; Total duration: 24 months | Total: 12; Interactive: 12; Other: 0; Est Tot Hr: 3.2; Category: Medium | DASH; Low sodium; Promoted for subset of participants | Indiv | Phone | | None (No) | Nurse; Home | UC
Bosworth, 2009^53^ (Take Control of Your Blood pressure (TCYB)); Fair | IG2 | HD + PA | 12 16-min phone sessions of diet and physical activity counseling; Total duration: 24 months | Total: 12; Interactive: 12; Other: 0; Est Tot Hr: 3.2; Category: Medium | DASH; Low sodium; Promoted for subset of participants | Indiv | Phone | | None (No) | Nurse; Home | UC
Broekhuizen, 2012^54^ (PRO-FIT); Fair | IG1 | HD + PA | 1 in-person individual lifestyle counseling session (time, NR), 5 (time, NR) counsellor-initiated booster phone calls, and access to computer-tailored PRO-FIT*advice; Total duration: 11 months | Total: 6; Interactive: 6; Other: 0; Est Tot Hr: 2.2; Category: Medium | NR | Indiv | In-person Tech-based Phone | X | None (No) | Trained lifestyle coach; Participants’ home | UC
Bruckert, 2008^55^ (PEGASE (Effect of an Education Program)); Fair | IG1 | HD + PA | 6 sessions of diet and physical activity counseling (4 45-min group sessions, 2 in-person individual sessions) and educational pamphlets; Total duration: 6 months | Total: 6; Interactive: 6; Other: 0; Est Tot Hr: 4; Category: Medium | NR | Indiv Group | In-person Print | | None (No) | Physician, nurse, nutritionist; Medical centers specializing in CVD prevention | UC
Burke, 2006^56^ (ADAPT); Fair | IG1 | HD + PA | 6 group sessions of diet and physical activity counseling accompanied by 5 printed modules and 4 newsletters; Total duration: 16 months | Total: 10; Interactive: 6; Other: 4; Est Tot Hr: 6; Category: Medium | DASH; Promoted for all participants | Indiv Group Family | In-person Phone Print | | None (No) | Dietitian, program coordinators; Medical center | AC
Chirinos, 2016^57^ (Community Health and Risk-reduction for Metabolic Syndrome (CHARMS)); Fair | IG1 | HD + PA | 17 (90-min) diet and physical activity group counseling sessions; Total duration: 12 months | Total: 17; Interactive: 17; Other: 0; Est Tot Hr: 25.5; Category: High | DPP; Promoted for all participants | Group | In-person | | None (No) | Master and doctoral level clinicians; Research clinic | UC
Christian, 2011^58^; Fair | IG1 | HD + PA | 2 computer assessments (10 min) and 2 physician motivational feedback sessions (15 min); Total duration: 6 months | Total: 4; Interactive: 2; Other: 0; Est Tot Hr: 0.8; Category: Medium | NR; Promoted for all participants | Indiv | In-person Tech-based Print | X | Deliver all/most (Yes) | Computer expert system and PCP; Community health center | UC
Cicolini, 2014^59^; Fair | IG1 | HD + PA | 1 60-min (NR type of session) educational session on healthy lifestyle and hypertension management; 26 weekly email messages; two booklets; Total duration: 6 months | Total: 27; Interactive: 1; Other: 0; Est Tot Hr: 1; Category: Medium | Low sodium; NR | Indiv | Tech-based Phone Print | | None (NR) | Nurse care manager; Home | UC
Cochrane, 2012^60^; Fair | IG1 | HD + PA | Health check plus 1 individual 45–60 min lifestyle counseling/motivational interviewing session with lifestyle coach, with additional maximum of 6 hours of support offered over 6 months.; Total duration: 12 months | Total: 6; Interactive: 6; Other: 0; Est Tot Hr: 3.5; Category: Medium | NR; Promoted for subset of participants | Indiv | In-person Phone | X | None (No) | Lifestyle coach; Medical center | Min
Cohen, 1991^61^; Fair | IG1 | HD | 12 monthly diet counseling visits with family practice resident; Total duration: 12 months | Total: 12; Interactive: 12; Other: 0; Est Tot Hr: 6; Category: Medium | NR; Promoted for all participants | Indiv | In-person | | Deliver all/most (Yes) | Family practice resident; Primary care | UC
Coleman, 2012^62^ (Wisewoman California); Fair | IG1 | HD + PA | 3 in-person individual sessions of diet and physical activity counseling (averaged 50 min each), 3 phone calls and printed handouts; Total duration: 6 months | Total: 6; Interactive: 6; Other: 0; Est Tot Hr: 3.2; Category: Medium | NR | Indiv | In-person Phone Print | | None (No) | Bilingual (English/Spanish) community health workers (from same community as participants); medical center (4 sites) | UC
Delahanty, 2001^63^; Good | IG1 | HD + PA | 6 individual sessions of diet and physical activity counseling; Total duration: 6 months | Total: 4; Interactive: 4; Other: 0; Est Tot Hr: 4; Category: Medium | Low-fat; Promoted for subset of participants | Indiv | In-person | | Deliver part (Yes) | Registered dietitian; Medical center | UC
Eakin, 2009^64^ (Logan Healthy Living); Fair | IG1 | HD + PA | 18 (average 18-min) sessions of diet and physical activity telephone counseling and 1 workbook; Total duration: 12 months | Total: 19; Interactive: 18; Other: 1; Est Tot Hr: 5.4; Category: Medium | Low-fat; NR | Indiv | Phone Print | X | None (No) | Graduate-level counselors; Home | Min
Edelman, 2006^65^; Fair | IG1 | HD + PA | 52 total sessions of diet, physical activity, and mind-body approaches to reduce CVD risk (28 120-min group sessions, 24 20–30 min individual sessions); Total duration: 10 months | Total: 52; Interactive: 52; Other: 0; Est Tot Hr: 68; Category: High | NR | Indiv Group | In-person Phone | | None (No) | Master’s level trained health coaches, nutritionists, physician, physician assistant; Academic “integrative” medical center | UC
Ellsworth, 2016^66^; Fair | IG1 | HD + PA | 22 diet and physical activity counseling sessions (1 240-min orientation session, 3 individual counseling sessions with each of registered dietitian, exercise physiologist, stress management instructor, and psychologist (time NR); 9 individual counseling sessions with integrative health coach (time NR)); Total duration: 12 months | Total: 22; Interactive: 22; Other: 0; Est Tot Hr: 20.5; Category: High | Mediter; NR | Indiv | In-person | | None (No) | Registered dietitian, exercise physiologist, stress management instructor, psychologist, and integrative health coach; NR | UC
Estruch, 2018^67^ (Primary Prevention of Cardiovascular Disease with a Mediterranean Diet (PREDIMED)); Fair | IG1 | HD | 21 sessions of diet counseling (1 individual session with dietitian, 20 sessions with individual motivational interview and group session), print materials (shopping list, weekly meal plans, recipes), and 20 15-liter allotments of extra-virgin olive oil; Total duration: 60 months | Total: 21; Interactive: 21; Other: 0; Est Tot Hr: 30.5; Category: High | Mediter; Not promoted | Indiv Group | In-person Print | X | None (No) | Registered dietitians; Primary care centers, university health care centers, hospitals | Min
Estruch, 2018^67^ (Primary Prevention of Cardiovascular Disease with a Mediterranean Diet (PREDIMED)); Fair | IG2 | HD | 21 sessions of diet counseling (1 individual session with dietitian, 20 sessions with individual motivational interview and group session), print materials (shopping list, weekly meal plans, recipes), and 20 quarterly allotments of mixed nuts (2700-3700g); Total duration: 60 months | Total: 21; Interactive: 21; Other: 0; Est Tot Hr: 30.5; Category: High | Mediter; Not promoted | Indiv Group | In-person Print | X | None (No) | Registered dietitians; Primary care centers, university health care centers, hospitals | Min
Fagerberg, 1998^68^ (Risk Factor Intervention Study (RIS)); Good (KQ1); Fair (KQ2) | IG1 | HD + PA | 7 sessions of diet and physical activity counseling (1 group informational session, five weekly 2-hr group sessions, and 1 session individual followup).; For smokers, an additional 6 smoking cessation sessions offered; Total duration: 4 months | Total: 7; Interactive: 7; Other: 0; Est Tot Hr: 11.5; Category: High | Low-fat; Promoted for subset of participants | Indiv Group Family | In-person | | None (No) | Physician, nurses, and dietitian; Hypertension outpatient clinic | UC
Gill, 2019^69^ (Heartmatters Challenge - First Responders); Fair | IG1 | HD + PA | 30 20-min telephone lifestyle coaching; Total duration: 12 months | Total: 30; Interactive: 30; Other: 0; Est Tot Hr: 10; Category: High | DASH; Mediter; Promoted for subset of participants | Indiv | Tech-based Phone | | None (No) | Registered dietitian; Home | Min
Gill, 2019^70^ (HealtheSteps); Fair | IG1 | HD + PA | 4 in-person individual sessions of diet and physical activity counseling (4 35-min sessions), print materials, and health technology tools and resources (e.g., phone coaching, online HealtheSteps social network, smartphone app, HealtheSteps website); Total | Total: 4; Interactive: 4; Other: 0; Est Tot Hr: 2.3; Category: Medium | NR | Indiv | In-person Tech-based Phone Print | | None (No) | Health coach; Primary care community clinic sites | WL
Greaves, 2015^71^ (Waste the Waist); Fair | IG1 | HD + PA | 4 2-hr group sessions of diet and physical activity counseling, 5 90-min group maintenance support sessions, and intervention handbook; Total duration: 9 months | Total: 9; Interactive: 9; Other: 0; Est Tot Hr: 15.5; Category: High | Low-fat; Promoted for all participants | Group | In-person Print | X | None (No) | Lifestyle coach; Community | UC
Groeneveld, 2010^72^ (Health Under Construction); Fair | IG1 | HD + PA | 7 sessions of diet and PA for weight loss or smoking counseling (4 45–60 min in-person counseling sessions and 3 15–30 min telephone counseling sessions); Total duration: 6 months | Total: 7; Interactive: 7; Other: 0; Est Tot Hr: 5.5; Category: Medium | Promoted for subset of participants | Indiv Family | In-person Phone Print | X | None (No) | Occupational physicians and occupational nurses in the role of lifestyle counselors; Ocupational health clinic | UC
Hardcastle, 2008^73^; Fair | IG1 | HD + PA | 1 20–30 min motivational interviewing session of diet and/or physical activity change and up to 4 optional 20–30 min MI sessions (average 2.0 sessions); Total duration: 6 months | Total: 2; Interactive: 2; Other: 0; Est Tot Hr: 1; Category: Medium | NR | Indiv | In-person Print | X | None (No) | Physical activity specialist and a registered dietician; Primary care | UC
Harris, 2012^74^ (Health Improvement and Prevention Study (HIPS)); Fair | IG1 | HD + PA | 1 brief session with PCP, then 2 individual sessions of diet and physical activity counseling and 6 90-min group counseling and physical activity sessions; Total duration: 12 months | Total: 6; Interactive: 6; Other: 0; Est Tot Hr: 10.2; Category: High | Promoted for subset of participants | Indiv Group | In-person | X | Deliver all/most (Yes) | GP and practice nurse, dietitian or exercise physiologist, intervention officer; Primary care | WL
Haufe, 2019^75^; Fair | IG1 | HD + PA | 6 sessions of physical activity counseling and 1 session of diet counseling; Total duration: 6 months | Total: 7; Interactive: 7; Other: 0; Est Tot Hr: 3.5; Category: Medium | Not promoted | Indiv | Tech-based Phone | | None (No) | Exercise scientist; Community/home | WL
Hinderliter, 2014^76^ (Exercise and Nutrition interventions for CardiOvasculaR hEalth (ENCORE)); Good | IG1 | HD | 4 in-person individual instructional sessions on diet and 14 (30–45 min) in-person group sessions of diet counseling; Total duration: 4 months | Total: 18; Interactive: 18; Other: 0; Est Tot Hr: 11.5; Category: High | DASH; Not promoted | Indiv Group | In-person | | None (No) | Nutritionist; Medical research center | UC
HPT, 1990^77^ (Hypertension Prevention Trial (HPT)); Good | IG1 | HD | 28 60-min group dietary counseling sessions and 16 bimonthly newsletters; Total duration: 36 months | Total: 28; Interactive: 28; Other: 0; Est Tot Hr: 28; Category: High | Low sodium; Not promoted | Group | In-person Print | | None (No) | Nutritionists and behavioral specialists; Research clinic | None
HPT, 1990^77^ (Hypertension Prevention Trial (HPT)); Good | IG2 | HD | 28 60-min group diet counseling sessions and 16 bimonthly newsletters; Total duration: 36 months | Total: 28; Interactive: 28; Other: 0; Est Tot Hr: 28; Category: High | Low sodium; Promoted for subset of participants | Group | In-person Print | | None (No) | Nutritionists and behavioral specialists; Research clinic | None
HPT, 1990^77^ (Hypertension Prevention Trial (HPT)); Good | IG3 | HD | 28 60-min group weight loss counseling sessions and 16 bimonthly newsletters; Total duration: 36 months | Total: 28; Interactive: 28; Other: 0; Est Tot Hr: 28; Category: High | NR; Promoted for all participants | Group | In-person Print | | None (No) | Nutritionists and behavioral specialists; Research clinic | None
HPT, 1990^77^ (Hypertension Prevention Trial (HPT)); Good | IG4 | HD | 28 60-min group weight loss and sodium reduction counseling sessions and 16 bimonthly newsletters; Total duration: 36 months | Total: 28; Interactive: 28; Other: 0; Est Tot Hr: 28; Category: High | Low sodium; Promoted for all participants | Group | In-person Print | | None (No) | Nutritionists and behavioral specialists; Research clinic | None
Hyman, 1998^78^; Fair | IG1 | HD | 4 60-min in-person classes of dietary education and behavioral changes, 12 mailed individualized diet questionnaires with feedback, 12 2–3 min interactive computer call; Total duration: 6 months | Total: 28; Interactive: 16; Other: 12; Est Tot Hr: 4.6; Category: Medium | Low-fat; NR | Indiv Group | In-person Phone Print | | None (No) | Registered dietitian; CHC | UC
Hyman, 2007^79^; Fair | IG1 | HD + PA | 3 brief individual counseling sessions on smoking cessation, sodium reduction, and physical activity and 21 15-min motivational interviewing phone calls; Total duration: 18 months | Total: 27; Interactive: 24; Other: 3; Est Tot Hr: 6; Category: Medium | Low sodium; NR | Indiv | In-person Phone Print | X | None (No) | Health educator; Primary care clinic, home (phone sessions) | Min
Hyman, 2007^79^; Fair | IG2 | HD + PA | 3 brief individual counseling sessions on smoking cessation, sodium reduction, and physical activity and 21 15-min motivational interviewing phone calls; Total duration: 18 months | Total: 27; Interactive: 24; Other: 3; Est Tot Hr: 6; Category: Medium | Low sodium; NR | Indiv | In-person Phone Print | X | None (No) | Health educator; Primary care clinic, home (phone sessions) | Min
Ives, 1993^80^ (Rural Health Promotion Project (RHPP) Trial); Fair | IG1 | HD + PA | 5 visits of diet and physical activity counseling for cholesterol reduction; Total duration: 12 months | Total: 5; Interactive: 5; Other: 0; Est Tot Hr: 2.5; Category: Medium | NR | Indiv | In-person | | None (No) | Hospital staff; Hospital | UC
Ives, 1993^80^ (Rural Health Promotion Project (RHPP) Trial); Fair | IG2 | HD + PA | 5 visits of diet and physical activity counseling for cholesterol reduction; Total duration: 12 months | Total: 5; Interactive: 5; Other: 0; Est Tot Hr: 2.5; Category: Medium | NR | Indiv | In-person | | Deliver all/most (Yes) | PCP; Primary care clinic | UC
Johnston, 1995^81^; Fair | IG1 | HD | 3 90-min group sessions of diet counseling; Total duration: 6 months | Total: 3; Interactive: 3; Other: 0; Est Tot Hr: 4.5; Category: Medium | NR | Group | In-person Print | | None (No) | Dietitian/nutritionist; NR | UC
Johnston, 1995^81^; Fair | IG2 | HD | 3 in-person individual sessions of diet counseling; Total duration: 6 months | Total: 3; Interactive: 3; Other: 0; Est Tot Hr: 1.5; Category: Medium | NR | Indiv | In-person Print | | None (No) | Dietitian/nutritionist; NR | UC
Jones, 1999^82^ (Hypertension Optimal Treatment (HOT)); Fair | IG1 | HD | 2 in-person individual counseling sessions on diet and 11 in-person group support sessions; Total duration: 30 months | Total: 13; Interactive: 13; Other: 0; Est Tot Hr: 12; Category: High | NR; Promoted for all participants | Indiv Group | In-person | | NR (No) | Registered dietitian; NR | UC
Kandula, 2015^83^ (South Asian Heart Lifestyle Intervention (SAHELI)); Fair | IG1 | HD + PA | 6 60–90 min informational group classes about diet, physical activity, and stress reduction; 6 15-min individual telephone support calls, and 2 group gatherings involving culturally-relevant PA- and diet-related activities; Total duration: 4 months | Total: 14; Interactive: 14; Other: 0; Est Tot Hr: 12.5; Category: High | NR; Promoted for subset of participants | Indiv Group | In-person Phone | X | None (No) | Health educators; Community (classes and melas), home (phone calls) | UC
Kanke, 2015^84^; Fair | IG1 | HD + PA | 12 7-min sessions of weight loss, diet, and physical activity counseling (1 introductory session followed by 11 monthly or bimonthly routine consultations); Total duration: 12 months | Total: 12; Interactive: 12; Other: 0; Est Tot Hr: 1.4; Category: Medium | NR; Promoted for all participants | Indiv | In-person Print | | Deliver all/most (Yes) | PCP; Primary care | Min
Kastarinen, 2002^85^ (Lifestyle Intervention against Hypertension in Eastern Finland (LIHEF)); Fair | IG1 | HD + PA | 7 individual sessions of individualized diet and physical activity counseling and 2 120-min group counseling sessions; Total duration: 21 months | Total: 9; Interactive: 9; Other: 0; Est Tot Hr: 7.5; Category: High | Low sodium; Promoted for subset of participants | Indiv Group | In-person | | (Yes) | Public health nurses; Primary health care center | UC
Keyserling, 1997^86^ (Southeast Cholesterol Project); Fair | IG1 | HD | 3 5–10 min in-person individual diet counseling visits with PCP, referral to 3 30-min in-person individual diet counseling with dietician, 1 mailing; Total duration: 12 months | Total: 7; Interactive: 6; Other: 4; Est Tot Hr: 2; Category: Medium | NR | Indiv | In-person Print | | Deliver all/most (Yes) | PCPs; dieticians; health educators; Community and rural health centers, local health department, hospital outpatient services | UC
Khanji, 2019^87^ (HAPPY London); Good | IG1 | HD + PA | Diet and physical activity counseling (1 25-min physician-delivered counseling and instructional session and auto-generated personalized web-based counseling); Total duration: 6 months | Total: 1; Interactive: 1; Other: 0; Est Tot Hr: 0.4; Category: Low | Promoted for all participants | Indiv | In-person Tech-based | | Deliver part (Yes) | Study physician; Primary care, home | UC
Koelewijn-van Loon, 2009^88^ (Improving Patient Adherence to Lifestyle Advice (IMPALA)); Fair | IG1 | HD + PA | 2 (15–20 min) in-person individual diet and physical activity counseling sessions with practice nurse, 1 (10-min) follow-up telephone call, and printed materials; Total duration: 1 months | Total: 3; Interactive: 3; Other: 0; Est Tot Hr: 0.8; Category: Medium | NR | Indiv | In-person Phone Print | X | None (Yes) | Nurses; General practice | UC
Kramer, 2018^89^ (Healthy Lifestyle Project); Fair | IG1 | HD + PA | Participant could choose between 16 (1-hr) group lifestyle counseling sessions or 12 (1-hr) individually-viewed lifestyle DVD sessions followed by brief telephone sessions (5-min); both handouts, self-monitoring logs, a pedometer and exercise bands.; Total duration: 6 months | Total: 16; Interactive: 16; Other: 0; Est Tot Hr: 16; Category: High | DPP; Promoted for all participants | Indiv Group | In-person Tech-based Phone Print | | None (No) | Registered dietitians and exercise specialist; Senior community centers | WL
Lakerveld, 2013^90^ (HOORN); Fair | IG1 | HD + PA | Nine sessions of diet and physical activity counseling (6 30-min individual counseling sessions and 3 30-min booster phone calls); Total duration: 16 months | Total: 9; Interactive: 9; Other: 0; Est Tot Hr: 4.5; Category: Medium | NR | Indiv | In-person Phone | X | None (Yes) | Practice nurses; Diabetes research center | UC
Langford, 1991^91^ (Trial of Antihypertensive Interventions and Management (TAIM)); Fair | IG1 | HD + PA | 10 group sessions and 2 individual sessions of lifestyle counseling for weight loss and 6 individual BP medication management visits; Total duration: 6 months | Total: 18; Interactive: 18; Other: 0; Est Tot Hr: 14; Category: High | NR; Promoted for all participants | Indiv Group | In-person | | NR (NR) | Nutritionists and therapists (nutritional intervention); NR (medical intervention); NR | Min
Langford, 1991^91^ (Trial of Antihypertensive Interventions and Management (TAIM)); Fair | IG2 | HD | 10 group sessions and 2 individual sessions of nutrition counseling for reducing sodium intake and increasing potassium intake and 6 individual BP medication management visits; Total duration: 6 months | Total: 18; Interactive: 18; Other: 0; Est Tot Hr: 14; Category: High | Low sodium; Not promoted | Indiv Group | In-person | | NR (NR) | Nutritionists and therapists (nutritional intervention); NR (medical intervention); NR | Min
Lee, 2007^92^; Fair | IG1 | PA | Median of 6 sessions of individual in-person and telephone physical activity counseling; Total duration: 6 months | Total: 6; Interactive: 6; Other: 0; Est Tot Hr: 3; Category: Medium | NR | Indiv | In-person Phone | | None (No) | Public health nurse; Community centers, home | UC
Liira, 2014^93^; Fair | IG1 | HD + PA | 1 90-min in-person diet and physical activity counseling session; Total duration: 0.03 months | Total: 1; Interactive: 1; Other: 0; Est Tot Hr: 1.5; Category: Medium | NR | Indiv | In-person | | None (No) | Public health nurses; Primary care | UC
Migneault, 2012^94^; Fair | IG1 | HD + PA | 32 weekly 15-min automated phone sessions and one 20-min in-home health education session; Total duration: 8 months | Total: 33; Interactive: 33; Other: 0; Est Tot Hr: 8.3; Category: High | Low-fat; DASH; Low sodium; NR | Indiv | In-person Phone Print | X | Deliver part (Yes) | NA (automated phone system), PCP; Home | Min
Moreau, 2001^95^; Fair | IG1 | PA | Instructions and pedometer provided for self-directed walking program; Total duration: 6 months | Total: 0; Interactive: 0; Other: 0; Est Tot Hr: 0; Category: Low | NR | Indiv | In-person | | NR (No) | NR; Home | None
Moy, 2001^96^; Fair | IG1 | HD | 13 sessions of individual and family dietary counseling (1 120-min sessions and 12 60-min sessions); Total duration: 24 months | Total: 13; Interactive: 13; Other: 0; Est Tot Hr: 14; Category: High | Low-fat; NR | Indiv Family | In-person Phone | | None (No) | Nurse; NR | UC
Muhlhauser, 1993^97^ (Hypertension Treatment and Teaching Program (HTTP)); Fair | IG1 | HD + PA | 4 60–90 min group counseling sessions on diet, exercise, and self-monitoring of blood pressure; Total duration: 1 months | Total: 4; Interactive: 4; Other: 0; Est Tot Hr: 6; Category: Medium | NR | Group | In-person Print | | Deliver part (Yes) | Physicians and practice staff; Primary health care | Min
Murphy, 2012^98^ (National Exercise Referral Scheme (NERS)); Fair | IG1 | PA | 3 individual in-person sessions of physical activity counseling with 2 telephone calls focused on relapse prevention and discounted access to 1-on-1 exercise instruction or group classes; Total duration: 12 months | Total: 5; Interactive: 5; Other: 0; Est Tot Hr: 2; Category: Medium | NR | Indiv Group | In-person Phone | X | None (No) | Exercise professional; Leisure centre, home (phone) | WL
Neil, 1995^99^; Fair | IG1 | HD | 1 30-min in-person session of dietary counseling and 1 10-min in-person followup session; Total duration: 2 months | Total: 2; Interactive: 2; Other: 0; Est Tot Hr: 0.7; Category: Medium | Low-fat; Promoted for subset of participants | Indiv | In-person | | None (No) | Dietitian; General practice clinic | UC
Neil, 1995^99^; Fair | IG2 | HD | 1 30-min in-person session of dietary counseling and 1 10-min in-person followup session; Total duration: 2 months | Total: 2; Interactive: 2; Other: 0; Est Tot Hr: 0.7; Category: Medium | Low-fat; NR | Indiv | In-person | | None (No) | Nurse; General practice clinic | UC
Niiranen, 2014^100^; Fair | IG1 | HD + PA | 3 sessions of diet and physical activity counseling (2 30-min individual counseling sessions and 1 60-min group session) and 5 PCP BP medication management calls that included individualized lifestyle advice.; Total duration: 12 months | Total: 8; Interactive: 8; Other: 0; Est Tot Hr: 3.2; Category: Medium | Low sodium; Promoted for subset of participants | Indiv Group | In-person Print | | Deliver part (Yes) | PCPs and nurses; Primary care, home | UC
Nolan, 2018^101^ (Reducing Risk with E-based Support for Adherence to Lifestyle Change in Hypertension (REACH)); Fair | IG1 | HD + PA | 28 automated e-counseling sessions including videos on diet, exercise, and BP management; online handouts; and online monitoring forms; Total duration: 12 months | Total: 28; Interactive: 0; Other: 0; Est Tot Hr: NA; Category: High | NR | Indiv | Tech-based | X | None (No) | NA (counseling fully automated); Home | Min
Ogedegbe, 2014^102^ (Counseling African Americans to Control Hypertension (CAATCH)); Fair | IG1 | HD + PA | 6 group sessions of diet and physical activity counseling, four interactive computerized educational modules, and home BP monitoring; Total duration: 6 months | Total: 10; Interactive: 6; Other: 0; Est Tot Hr: 6; Category: Medium | DASH; Low sodium; Promoted for subset of participants | Indiv Group | In-person Tech-based | X | Deliver part (Yes) | Nutritionists, nurses, and health educators (from study and community health center), physicians; Community health center | Min
Reid, 2014^103^; Fair | IG1 | HD + PA | 17 sessions of diet and physical activity counseling (1 45-min in-person counseling session, 1 45-min phone counseling session, and 15 15–20 min phone counseling sessions) and print materials on smoking cessation, healthy eating, weight mgmt, and physical activity; Total duration: 12 months | Total: 17; Interactive: 17; Other: 0; Est Tot Hr: 6.5; Category: High | NR; Promoted for subset of participants | Indiv | In-person Phone Print | | None (No) | Health educators; Tertiary care cardiac center | UC
Rodriguez, 2012^104^; Fair | IG1 | HD + PA | 6 monthly telephone sessions of diet, medication, and physical activity counseling individualized based on stage of change; Total duration: 6 months | Total: 6; Interactive: 6; Other: 0; Est Tot Hr: 1.5; Category: Medium | Low-fat; Low sodium; NR | Indiv | Phone | | None (No) | Counselors (Master’s degree or higher in psychology or social work); Home | UC
Rodriguez-Cristobal, 2012^105^; Fair | IG1 | HD + PA | 24 sessions of individual lifestyle counseling on diet, PA, and smoking cessation (12 physician-delivered in-person sessions and 12 psychologist follow-up calls); Total duration: 24 months | Total: 24; Interactive: 24; Other: 0; Est Tot Hr: 9; Category: High | NR; Promoted for subset of participants | Indiv | In-person Phone | | Deliver part (Yes) | Physician, psychologist; Primary care | UC
Rosas, 2015^106^ (Vivamos Activos Fair Oaks (VAFO)); Good | IG1 | HD + PA | 20 weight loss counseling sessions (15 120-min group sessions and 5 30-min individual counseling sessions), 7 home visits with community health workers, and take home items (pedometers, exercise CDs, and free weights); Total duration: 24 months | Total: 27; Interactive: 27; Other: 0; Est Tot Hr: 36; Category: High | DPP; Promoted for all participants | Indiv Group | In-person | X | None (No) | Research staff & community health workers; Community health center, home | UC
Rosas, 2015^106^ (Vivamos Activos Fair Oaks (VAFO)); Good | IG2 | HD + PA | 20 weight loss counseling sessions (15 120-min group sessions and 5 30-min individual counseling sessions) and take home items (pedometers, exercise CDs, and free weights); Total duration: 24 months | Total: 20; Interactive: 20; Other: 0; Est Tot Hr: 32.5; Category: High | DPP; Promoted for all participants | Indiv Group | In-person | X | None (No) | Research staff; Community health center | UC
Rubinstein, 2016^107^; Good | IG1 | HD + PA | 12 20–30 min telephone sessions of diet and physical activity counseling, 48 followup text messages, and an informational leaflet about healthy lifestyles; Total duration: 12 months | Total: 60; Interactive: 12; Other: 0; Est Tot Hr: 6; Category: Medium | NR | Indiv | Tech-based Phone Print | X | None (No) | Nutritionists; Home | None
Salisbury, 2016^108^; Good | IG1 | HD + PA | 12 18-min telephone sessions of diet, physical activity, and blood pressure management counseling and access to a web-based behavior management program; Total duration: 12 months | Total: 12; Interactive: 12; Other: 0; Est Tot Hr: 3.6; Category: Medium | NR; Promoted for subset of participants | Indiv | Tech-based Phone | X | None (No) | Health advisors; Home | UC
Schoenthaler, 2016^109^ (Individual Motivational Interviewing - Therapeutic Lifestyle Changes (MINT-TLC)); Fair | IG1 | HD + PA | 13 sessions of diet and physical activity counseling (10 60–90 min group sessions and 3 30-min individual phone sessions); Total duration: 6 months | Total: 13; Interactive: 13; Other: 0; Est Tot Hr: 16.5; Category: High | Low-fat; DASH; Low sodium; Promoted for subset of participants | Indiv Group | In-person Phone | X | None (No) | Health educators; Hospital, home | Min
Scott, 2018^110^; Fair | IG1 | PA | 7 sessions of physical activity counseling (2 1-hr in-person sessions and 5 15–30 min phone sessions); Total duration: 3 months | Total: 7; Interactive: 7; Other: 0; Est Tot Hr: 4.5; Category: Medium | NR | Indiv | In-person Phone | X | None (No) | PhD-level psychologist; NR (in-person sessions), home (phone sessions) | UC
Soto Rodriguez, 2016^111^; Fair | IG1 | HD | Three 90-min group sessions of CVD prevention counseling; Total duration: 0.25 months | Total: 3; Interactive: 3; Other: 0; Est Tot Hr: 4.5; Category: Medium | Mediter; NR | Group | In-person | | NR (NR) | NR; Health care | None
Stefanick, 1998^112^ (Diet and Exercise for Elevated Risk (DEER)); Fair | IG1 | HD | 17 sessions of dietary counseling (1 individual session, eight 60-min group sessions, and 6–8 maintenance sessions); Total duration: 11 months | Total: 17; Interactive: 17; Other: 0; Est Tot Hr: 12.5; Category: High | Low-fat; NR | Indiv Group | In-person Phone Print | | None (No) | Registered dietitians; Research clinic, home | None
Stevens, 2003^113^; Fair | IG1 | HD | 2 45-min sessions of individual diet counseling (including 20-min computer assessment) and 2 10-min followup phone calls; Total duration: 2 months | Total: 4; Interactive: 4; Other: 0; Est Tot Hr: 1.8; Category: Medium | Low-fat; NR | Indiv | In-person Tech-based Phone Print | X | None (No) | Health counselors; Research clinic | AC
Svetkey, 2008^114^ (Weight Loss Maintenance (WLM)); Good | IG1 | HD + PA | 30 sessions of weight loss maintenance counseling (23 5–15 min phone sessions and 45–60 min individual in-person sessions); participants in extended followup received 4 in-person group sessions and an additional 29 5–15 min phone calls); Total duration: 60 months | Total: 30; Interactive: 30; Other: 0; Est Tot Hr: 12.8; Category: High | NR; Promoted for all participants | Indiv Group | In-person Phone | X | None (No) | Research interventionist; NR | Min
Svetkey, 2008^114^ (Weight Loss Maintenance (WLM)); Good | IG2 | HD + PA | Access to weight-loss maintenance support website, email reminders for weekly use for 30 months (median 107 log-ins); Total duration: 30 months | Total: 0; Interactive: 0; Other: 0; Est Tot Hr: 0; Category: High | NR; Promoted for all participants | Indiv | Tech-based | | None (No) | NA; Home | Min
Svetkey, 2009^115^ (Hypertension Improvement Project (HIP)); Fair | IG1 | HD + PA | Physicians received 2 45-min online training modules, a pocket reference card, and quarterly feedback reports.; Patients received 20 weekly group sessions of diet and physical activity counseling followed by 12 monthly individual phone sessions; Total duration: 18 months | Total: 39; Interactive: 32; Other: 4; Est Tot Hr: 24.5; Category: High | DASH; Low sodium; Promoted for subset of participants | Indiv Group | In-person Phone Print | X | Deliver part (Yes) | Behavioral interventionists and community health advisors, PCP; Physician: Clinic, Patients: At or near participant’s clinic site | UC
Svetkey, 2009^115^ (Hypertension Improvement Project (HIP)); Fair | IG2 | HD + PA | 20 weekly group sessions of diet and physical activity counseling followed by 12 monthly individual phone sessions; Total duration: 18 months | Total: 32; Interactive: 32; Other: 0; Est Tot Hr: 23; Category: High | DASH; Low sodium; Promoted for subset of participants | Indiv Group | In-person Phone Print | X | None (No) | Behavioral interventionists and community health advisors; At or near participant’s clinic site | UC
Svetkey, 2009^115^ (Hypertension Improvement Project (HIP)); Fair | IG3 | HD + PA | 2 45-min online training modules, pocket reference care, and quarterly feedback reports (est. 5 x); Total duration: 18 months | Total: 7; Interactive: 0; Other: 0; Est Tot Hr: 1.5; Category: Medium | NR | | Tech-based Print | | Deliver all/most (Yes) | NA (Physicians trained); Clinic | UC
Ter Bogt, 2009^116^ (Groningen Overweight and Lifestyle (GOAL)); Good | IG1 | HD + PA | 7 sessions of individual diet and physical activity counseling (1 GP session and 4 NP sessions) and 5 followup calls over 3 years (estimated 245 mins of contact in year 1); Total duration: 36 months | Total: 12; Interactive: 12; Other: 0; Est Tot Hr: 7.2; Category: High | NR; Not promoted | Indiv | In-person Tech-based Phone | | Deliver part (Yes) | General practitioner, nurse practitioner; Primary care, home | UC
Tiessen, 2012^117^ (SPRING (Self-monitoring and Prevention of RIsk Factors by Nurse practitioners in the region of Groningen)); Fair | IG1 | HD + PA | 1 20-min individual session with nurse using motivational interviewing and 6-12 follow-up visits based on self-monitoring feedback with the number of follow-up visits determined by the presence of risk factors; Total duration: 12 months | Total: 5; Interactive: 5; Other: 0; Est Tot Hr: 2.1; Category: Medium | Promoted for subset of participants | Indiv | In-person | X | None (Yes) | Trained nurses; Primary care | Min
Toft, 2008^118^ (Inter99); Fair | IG1 | HD + PA | 4 15–45 min individual sessions of smoking cessation/reduction and diet and physical activity counseling and 6 120-min group sessions of diet and physical activity counseling; Total duration: 60 months | Total: 10; Interactive: 10; Other: 0; Est Tot Hr: 14; Category: High | Low-fat; Low sodium; Promoted for subset of participants | Indiv Group | In-person | X | None (No) | Doctors, nurses, and dietitians; Research center | Min
TOHP I CRG, 1992^119^ (Trials of Hypertension Prevention Phase I (TOHP I)); Good | IG1 | HD | 10 weekly 90-min sessions of sodium reduction counseling (8 group counseling sessions and 2 individual counseling sessions) and 16 monthly 90-min group or individual counseling sessions; Total duration: 18 months | Total: 26; Interactive: 26; Other: 0; Est Tot Hr: 39; Category: High | Low sodium; Not promoted | Indiv Group | In-person | | None (No) | Registered dietitian and psychologist or exercise psychologist; Research center | UC
TOHP I CRG, 1992^119^ (Trials of Hypertension Prevention Phase I (TOHP I)); Good | IG2 | HD + PA | 30 sessions of diet and physical activity weight loss counseling (1 individual session and 29 group sessions) and optional individual check-in sessions; Total duration: 18 months | Total: 30; Interactive: 30; Other: 0; Est Tot Hr: 36.5; Category: High | NR; Promoted for all participants | Indiv Group | In-person | | None (No) | Registered dietitian and psychologist or exercise psychologist; Clinical center | UC
TOHP II CRG, 1997^120^ (Trial of Hypertension Prevention II (TOHP II)); Good | IG1 | HD + PA | 57 weight loss and sodium reduction counseling sessions (1 individual introductory session, 14 90-min weekly group sessions, 6 90-min biweekly group sessions and 3-6 “minimodules” consisting of up to 6 sessions each [36 available sessions], and optional participant-initiated individual counseling sessions); Total duration: 36 months | Total: 57; Interactive: 57; Other: 0; Est Tot Hr: 48.5; Category: High | Low sodium; Promoted for all participants | Indiv Group Family | In-person Phone Print | | None (No) | Centrally trained staff (dietitians, psychologists, or health counselors); Research clinic | None
TOHP II CRG, 1997^120^ (Trial of Hypertension Prevention II (TOHP II)); Good | IG2 | HD + PA | 57 weight loss counseling sessions (1 individual introductory session, 14 90-min weekly group sessions, 6 90-min biweekly group sessions and 3-6 “minimodules” consisting of up to 6 sessions each [36 available sessions], and optional participant-initiated individual counseling sessions); Total duration: 36 months | Total: 57; Interactive: 57; Other: 0; Est Tot Hr: 48.5; Category: High | NR; Promoted for all participants | Indiv Group Family | In-person Phone Print | | None (No) | Centrally trained staff (dietitians, psychologists, or health counselors); Research clinic | None
TOHP II CRG, 1997^120^ (Trial of Hypertension Prevention II (TOHP II)); Good | IG3 | HD | 53 sodium reduction counseling sessions (1 individual introductory session, 10 90-min weekly group sessions, 6 90-min biweekly group sessions and 3-6 “minimodules” consisting of up to 6 sessions each [36 available sessions], and optional participant-initiated individual counseling sessions); Total duration: 36 months | Total: 53; Interactive: 53; Other: 0; Est Tot Hr: 42.5; Category: High | Low sodium; Not promoted | Indiv Group Family | In-person Phone Print | | None (No) | Centrally trained staff (dietitians, psychologists, or health counselors); Research clinic | None
Tomson, 1995^121^; Fair | IG1 | HD | 6 sessions diet counseling, including 3 sessions with primary care physician and 3 sessions with dietician (1 individual, 1 with spouse, and 1 group session with trip to grocery store); Total duration: 12 months | Total: 6; Interactive: 6; Other: 0; Est Tot Hr: 3; Category: Medium | Low-fat; Promoted for subset of participants | Indiv Group Family | In-person | | Deliver part (Yes) | PCP, dietician; Medical center | UC
van der Veen, 2002^122^ (Nijmegen Family Practices Monitoring Project (NFPMP)); Fair | IG1 | HD | Maximum of 3 10-min family physician nutrition counseling sessions with referral to dietician for 3 sessions (initial consultation of 30–40 mins and 10–15 mins for second and third consultation); Total duration: 2.5 months | Total: 6; Interactive: 6; Other: 0; Est Tot Hr: 1.7; Category: Medium | Low-fat; Promoted for subset of participants | Indiv | In-person | | Deliver all/most (Yes) | Family physician; dietician; Family practice | UC
van Keulen, 2011^123^ (Vitalum); Fair | IG1 | HD + PA | 4 20-min telephone-based sessions of diet and physical activity counseling; Total duration: 10 months | Total: 4; Interactive: 4; Other: 0; Est Tot Hr: 1.3; Category: Medium | NR | Indiv | Phone | X | None (No) | Counselors (students of Health Education and Health Promotion, Mental Health Sciences, or Psychology); Home | UC
van Keulen, 2011^123^ (Vitalum); Fair | IG2 | HD + PA | 2 20-min telephone-based sessions of diet and physical activity counseling and 2 tailored letters; Total duration: 10 months | Total: 4; Interactive: 2; Other: 2; Est Tot Hr: 0.7; Category: Medium | NR | Indiv | Phone Print | X | None (No) | Counselors (students of Health Education and Health Promotion, Mental Health Sciences, or Psychology); Home | UC
van Keulen, 2011^123^ (Vitalum); Fair | IG3 | HD + PA | Four tailored letters addressing physical activity and consumption of fruits and vegetables; Total duration: 10 months | Total: 4; Interactive: 0; Other: 4; Est Tot Hr: 0; Category: Low | NR | Indiv | Print | | None (No) | NA; Home | UC
van Sluijs, 2005^124^ (Physician-based Assessment and Counseling for Exercise (PACE)); Fair | IG1 | PA | Two GP/NP sessions of physical activity counseling (10-min consultation followed by a counseling appointment) and two phone sessions with physical activity counselors; Total duration: 2 months | Total: 4; Interactive: 4; Other: 0; Est Tot Hr: 0.8; Category: Medium | NR | Indiv | In-person Phone | | Deliver part (Yes) | GP/NP and PA counselor; Clinic, home (phone) | UC
Viglione, 2019^125^ (Goals for Eating and Moving (GEM)); Fair | IG1 | HD + PA | 13 sessions of diet and physical activity counseling delivered by health coaches (1 60-min in-person counseling session and 12 25-min coaching calls) and an average of 2.3 counseling sessions with PCP; Total duration: 12 months | Total: 15; Interactive: 15; Other: 0; Est Tot Hr: 6.6; Category: High | Promoted for all participants | Indiv | In-person Tech-based Phone Print | X | Deliver part (Yes) | Health coaches (trained students), PC team; Primary care (baseline and PCP visits), home (calls) | UC
Voils, 2013^126^ (CouPLES); Fair | IG1 | HD + PA | 9 phone counseling sessions for the patient and 9 phone counseling sessions for their spouse; Total duration: 11 months | Total: 18; Interactive: 18; Other: 0; Est Tot Hr: 3.4; Category: Medium | NR | Indiv Family | Phone Print | | None (No) | Research nurse; Home | Min
Wadden, 2011^127^ (Practice-based Opportunities for Weight Reduction at the University of Pennsylvania (POWER-UP)); Good | IG1 | HD + PA | 32 sessions of diet and lifestyle counseling (8 5–7 min individual sessions with PCP and 24 10–15 min individual in-person and phone sessions with lifestyle coach) and printed handouts; Total duration: 24 months | Total: 32; Interactive: 32; Other: 0; Est Tot Hr: 6.9; Category: High | DPP; Promoted for all participants | Indiv | In-person Phone Print | | Deliver part (Yes) | Medical assistant (lifestyle coach) and PCP; Primary care | Min
Whelton, 1998^128^ (Trial of Nonpharmacologic Interventions in the Elderly (TONE)); Good | IG1 | HD + PA | 53 sessions of sodium reduction and weight loss counseling, including 7 individual and 46 group sessions. (Limited to pts with obesity); Total duration: 36 months | Total: 53; Interactive: 53; Other: 0; Est Tot Hr: 49.5; Category: High | Low sodium; Promoted for all participants | Indiv Group | In-person | | None (No) | Nutritionists and exercise counselors; Academic health center | Min
Whelton, 1998^128^ (Trial of Nonpharmacologic Interventions in the Elderly (TONE)); Good | IG2 | HD + PA | 53 sessions of weight loss counseling, including 7 individual and 46 group sessions. (Limited to pts with obesity); Total duration: 36 months | Total: 53; Interactive: 53; Other: 0; Est Tot Hr: 49.5; Category: High | NR; Promoted for all participants | Indiv Group | In-person | | None (No) | Nutritionists and exercise counselors; Academic health center | Min
Whelton, 1998^128^ (Trial of Nonpharmacologic Interventions in the Elderly (TONE)); Good | IG3 | HD | 53 sessions of sodium reduction counseling, including 7 individual and 46 group sessions; Total duration: 36 months | Total: 53; Interactive: 53; Other: 0; Est Tot Hr: 49.5; Category: High | Low sodium; Promoted for subset of participants | Indiv Group | In-person | | None (No) | Nutritionists and exercise counselors; Academic health center | Min
Wister, 2007^129^; Good | IG1 | HD + PA | 2 30-min phone sessions (4 additional 20–30 min sessions for smokers) and 3 mailings, targeting smoking, diet, physical activity, weight management and/or stress management; Total duration: 12 months | Total: 5; Interactive: 2; Other: 1; Est Tot Hr: 1; Category: Medium | NR; Promoted for subset of participants | Indiv | Phone Print | X | None (No) | Clinical lifestyle counselors (were also kinesiologists); Home | UC
Wong, 2015^130^; Good | IG1 | HD | 1 3–5 min physician-delivered UC session and 1 25-min dietitian-delivered DASH diet counseling session; Total duration: 0.03 months | Total: 2; Interactive: 2; Other: 0; Est Tot Hr: 0.5; Category: Low | Low-fat; DASH; Low sodium; NR | Indiv | In-person; Print | | Deliver part (Yes) | Physician and dietitian; Primary care | UC
Wood, 2008^131^ (EUROACTION); Fair | IG1 | HD + PA | Individual nurse assessment with personal report card and family support pack plus 8 group workshops of diet, PA, and risk factor counseling; Total duration: 4 months | Total: 8; Interactive: 8; Other: 0; Est Tot Hr: 8; Category: High | NR; Promoted for subset of participants | Indiv Group Family | In-person | X | Deliver part (Yes) | Nurses; family doctors; General practice center | UC

Abbreviations: AC = attention control; AHA = American Heart Association; DASH = Dietary Approaches to Stop Hypertension; DPP = Diabetes Prevention Program diet; Est Tot Hr = estimated total intervention contact hours; GP = general practitioner; HD = healthy diet only; HD = healthy diet and physical activity; IG = intervention group; Indiv = intervention delivered individually; Int arm = intervention arm; IVR = Interactive Voice Response; Mediter = Mediterranean diet; mgmt = management; Min = minimal intervention; min = minutes; Motiv Int = motivational interviewing; NR = not reported; PA = physical activity only; PCP = primary care provider; UC = usual care; WL = waitlist

Appendix F Table 3 Detailed Intervention Descriptions

Author, year (Study name) Quality | Int arm | Intervention description | Intervention focus; Total contact (hrs); Total duration | Provider(s); Setting | Control group description
Ammerman, 2003^38^; Fair | IG1 | Participants received an intervention with 3 components: (1) Public health nurse-directed Food For Heart Program (FFHP) during three tailored counseling sessions, (2) referral to local nutritionist if lipids remained elevated at 3 month followup, and (3) a reinforcement program during the second half of the intervention (phone call, two newsletters focusing on seasonal tips for food preparation and strategies to enhance dietary change). The FFHP is a theory-based dietary assessment and tailored counseling program for lower income patients with high blood cholesterol who reside in the southeastern United States. The FFHP is initiated and guided by the Dietary Risk Assessment (DRA) instrument, a validated food frequency instrument. The primary nutritional goals of the FFHP are aimed to reduce consumption of foods high in saturated fat and increase fruit and vegetable intake and complex carbohydrates. The nurse provided structured, individually tailored dietary counseling with illustrated goal sheets, educational pamphlets and southern-style cookbooks. Behavior change recommendations were broken into small, achievable steps, and specific strategies were recommended that addressed barriers to dietary change. The DRA was used to monitor progress and facilitate reinforcement during a followup counseling session. Participants were also referred to a nutritionist for three counseling visits if their 3-month lipid levels remained above the NCEP cutpoints for nutritional counseling. Nutritionist reviewed progress, helped address problems related to dietary change, and worked with participants to set new goals. | HD only; Total contact hrs: 3.25; Total duration: 12 months | Nurse, nutritionist; Health department | Usual care: Nurses were instructed to provide counseling for high cholesterol as usual. Participants were instructed to see their physician if total cholesterol remained high.
Anderson, 1992^39^; Fair | IG1 | Participants attended 10-weekly 1- hour group sessions; and after each session 30-min individual session with dietitian to discuss dietary progress and set achievable goals. Each session followed recommended nutritional targets derived from the American Heart Association Phase II guidelines: 55% carbohydrate energy, 20% protein energy, 25% fat energy, ≤200 mg dietary cholesterol per day, and dietary fiber was 50 g. Individually tailored preplanned meal patterns with daily goal of 3 servings each of fruits and vegetables, 4 starches/breads (which always included 1 serving each of beans and a cereal), 2 low-fat dairy, ≤198.5 g lean meat, poultry or seafood, no egg yolks, fat servings based on energy content. Optional sweets and alcohol servings available. No additional recommendations regarding modification of other risk-relevant behaviors (e.g., smoking, exercise). Encouraged to attend sessions with spouse/close friend; included demonstrations, problem solving, individual counseling (problems, questions about diet; goals). Home visits (4/year) by dietitian who provided further instruction and problem solving; also dietitian made monthly phone calls to check progress and problem solve. | HD only; Total contact hrs: 20; Total duration: 12 months | Dietitian, project staff; NR, home | Usual care: Participants were directed to maintain current dietary behaviors.
Anderson, 1992^39^; Fair | IG2 | Participants attended 10-weekly 1- hour group sessions; and after each session 30-min individual session with dietitian. Each session followed recommended nutritional targets derived from the American Heart Association Phase II guidelines: 55% carbohydrate energy, 20% protein energy, 25% fat energy, ≤ 200 mg dietary cholesterol per day, 15 g fiber. Individually tailored preplanned meal patterns for daily pattern with 3 servings each of fruits and vegetables, 4 starches/breads, 2 low-fat dairy, ≤ 198.5 g lean meat, poultry or seafood, no egg yolks, fat servings based on energy content. Optional sweets and alcohol servings available. No additional recommendations regarding modification of other risk-relevant behaviors (e.g., smoking, exercise). Encouraged to attend sessions with spouse/close friend; included demonstrations, problem solving, individual counseling (problems, questions about diet; goals). Home visits (4/year) by dietitian who provided further instruction and problem solving; also dietitian made monthly phone calls to check progress and problem solve. | HD only; Total contact hrs: 20; Total duration: 12 months | Dietitian, project staff; NR, home | Usual care: Participants were directed to maintain current dietary behaviors.
Anderssen, 1995^40^ (Oslo Diet and Exercise Study (ODES)); Fair | IG1 | 3 individual sessions diet counseling. Diet counseling was individualized and included spouse at the initial session, with additional sessions at 3 and 9 months followup without spouse. Diet messages were to decrease total calories, increase fish, reduce total and saturated fat, increase vegetables, and reduce sugar. Participants with elevated BP were advised to reduce salt. A target body weight reduction goal was set during counseling (typically 0.5 to 1 kg per month). | HD only; Total contact hrs: 1.5; Total duration: 9 months | NR; NR | Waitlist: Participants were offered dietary advice and physical training after 1 year. CG were told not to change their lifestyle during the trial but were advised against smoking.
Appel, 2003^41^ (PREMIER); Good | IG1 | Same goals as IG2 plus instruction and counseling on the Dietary Approaches to Stop Hypertension (DASH) diet. Goals related to DASH diet were: increased consumption of fruits and vegetables (9-12 servings/day) and low-fat dairy products (2-3 servings/d), and reduced intake of saturated fat (≤7% of energy) and total fat (≤25% of energy). To achieve weight loss, increased physical activity and reduced total energy intake was emphasized (as in IG2) but DASH intervention also emphasized substitution of fruits and vegetables for high-fat, high-calorie foods. In addition to food diaries, recording physical activity, and monitoring calorie and sodium intake (as with IG2), DASH intervention participants also monitored intake of fruits, vegetables, and dairy products and monitored their intake of fat.; The individual 30–60 minute sessions focused on the participant’s specific concerns, behavior change goals, and ways to maintain motivation during challenging situations. Interventionists used motivational enhancement techniques to assess the participant’s current stage of change relative to dietary and physical activity behavior. Participants received individualized graphs of attendance, weight change, physical activity, and dietary goals to use as resources for goal setting and problem solving. The 90–120 minute group sessions were interactive, with group activities to foster problem solving, support, and program ownership. Behavior-change techniques (checking progress, problem solving, action planning, goal setting, and self-monitoring) occurred at each session. PA was incorporated into group sessions where participants exercised along with videos, took group walks, and watched demonstrations of stretching, weight training, and aerobics. Print materials contained information on physical activity, sodium, alcohol, weight loss, and DASH dietary recommendations; The intervention was composed of 3 phases. The Intensive Phase I consisted of 3 months of weekly contacts (8 group and 3 individual). The Intermediate Phase II consisted of 3 months of biweekly contacts (6 group and 1 individual) and the Maintenance Phase III consisted of 12 months of monthly group sessions supplemented with 3 individual visits.; The link provided for publicly available curriculum no longer works: http://www.kpchr.org/public/premier/intervention/ | HD + PA; Total contact hrs: 59; Total duration: 18 months | Master’s degree-level counselors (dietitians and health educators trained in behavioral methods); Clinical centers | Usual care: Interventionist discussed nonpharmacological factors that affect blood pressure (weight, sodium intake, physical activity, and the DASH diet) and provided printed educational materials. Counseling on behavior change not provided. Advice provided in two 30-minute individual sessions, 1 immediately after random assignment and 1 after 6-month data collection visit.
Appel, 2003^41^ (PREMIER); Good | IG2 | Participant goals were: (1) weight loss ≥15 lbs at 6 months for those with BMI ≥25, (2) ≥180 minutes/week moderate-intensity physical activity, (3) daily intake ≤2400 mg dietary sodium, and (4) daily intake ≤1 oz alcohol (2 drinks) for men and ½ oz of alcohol (1 drink) for women. No goals for fruit, vegetable, or dairy intake; saturated fat goal ≤10%, total fat goal ≤30% of energy. To achieve weight loss, increased physical activity and reduced total energy intake was emphasized. Participants kept food diaries, recorded physical activity, and monitored calorie and sodium intake.; The individual 30–60 minute sessions focused on the participant’s specific concerns, behavior change goals, and ways to maintain motivation during challenging situations. Interventionists used motivational enhancement techniques to assess the participant’s current stage of change relative to dietary and physical activity behavior. Participants received individualized graphs of attendance, weight change, physical activity, and dietary goals to use as resources for goal setting and problem solving. The 90–120 minute group sessions were interactive, with group activities to foster problem solving, support, and program ownership. Behavior-change techniques (checking progress, problem solving, action planning, goal setting, and self-monitoring) occurred at each session. Physical activity was incorporated into group sessions where participants exercised along with videos, took group walks, and watched demonstrations of stretching, weight training, and aerobics. Print materials contained information on physical activity, sodium, alcohol, and weight loss.; The intervention was composed of 3 phases. The Intensive Phase I consisted of 3 months of weekly contacts (8 group and 3 individual). The Intermediate Phase II consisted of 3 months of biweekly contacts (6 group and 1 individual) and the Maintenance Phase III consisted of 12 months of monthly group sessions supplemented with 3 individual visits.; The link provided for publicly available curriculum no longer works: http://www.kpchr.org/public/premier/intervention/ | HD + PA; Total contact hrs: 59; Total duration: 18 months | Master’s degree-level counselors (dietitians and health educators trained in behavioral methods); Clinical centers | Usual care: Interventionist discussed nonpharmacological factors that affect blood pressure (weight, sodium intake, physical activity, and the DASH diet) and provided printed educational materials. Counseling on behavior change not provided. Advice provided in two 30-minute individual sessions, 1 immediately after random assignment and 1 after 6-month data collection visit.
Appel, 2011^42^ (POWER Hopkins (Practice Based Opportunities for Weight Reduction)); Good | IG1 | 30 group counseling sessions, 12 individual counseling sessions, 15 phone sessions, and PCP counseling at routine visits, including weekly web-based modules and monthly e-mail messages. Intervention focused on behavioral self-management approaches designed to help participants set weight-related goals, self-monitor weight and weight-related behaviors, increase self-efficacy and support, and solve problems. Motivational interviewing was the primary approach to interactions with participants. Participants were encouraged to lose 5% of their weight within 6 months and maintain reduced weight through end of study at 2 years. Participants were encouraged to log on to the study-specific Web site weekly that contained learning modules and opportunities for self-monitoring of weight, calorie intake, and exercise. Monthly e-mail messages were sent to provide tailored feedback. In addition, participants received in-person contact with lifestyle coaches to encourage completing web-based module and reinforce key behaviors. In-person support included weekly contact in months 1–3 (9 group sessions plus 3 individual sessions), monthly contact in months 4–6 (1 group session plus 2 individual sessions), and two monthly contacts in months 7–24 (1 group and 1 individual session [in-person or via phone per month). Group sessions were 90 minutes and individual and telephone calls were approximately 20 minutes. At routine medical visits, PCP encouraged participant to actively engage in the intervention and reviewed one-page report on patients’ weight-loss progress at routine office visits. | HD + PA; Total contact hrs: 54; Total duration: 24 months | Lifestyle coach; Research clinic and home (web-based) | Usual care: At randomization, participant met with a weight-loss coach for brief orientation to the static website and, if desired, after participant’s 24-month follow up visit, can meet again to discuss weight management guidelines. Received NHLBI “Aim for a Healthy Weight” brochure and a list of recommended Web sites promoting weight loss.
Appel, 2011^42^ (POWER Hopkins (Practice Based Opportunities for Weight Reduction)); Good | IG2 | 33 lifestyle behavioral coaching calls, weekly web-based modules, and PCP counseling at routine visits. Intervention focused on behavioral self-management approaches designed to help participants set weight-related goals, self-monitor weight and weight-related behaviors, increase self-efficacy and support, and solve problems. Motivational interviewing was the primary approach to interactions with participants. Participants were encouraged to lose 5% of their weight within 6 months and maintain reduced weight through end of study at 2 years. Participants were encouraged to log on to the study-specific Web site weekly that contained learning modules and opportunities for self-monitoring of weight, calorie intake, and exercise. Monthly e-mail messages were sent to provide tailored feedback. In the first 3 months, participants received 12 weekly coaching calls with lifestyle coaches to encourage completing web-based module and reinforce key behaviors. In months 7–24, monthly coaching calls were received. Telephone calls were approximately 20 minutes. At routine medical visits, PCP encouraged participant to actively engage in the intervention. | HD + PA; Total contact hrs: 11; Total duration: 24 months | PCP, lifestyle coach; Home (web-based) | Usual care: At randomization, participant met with a weight-loss coach for brief orientation to the static website and, if desired, after participant’s 24-month follow up visit, can meet again to discuss weight management guidelines. Received NHLBI “Aim for a Healthy Weight” brochure and a list of recommended Web sites promoting weight loss.
Applegate, 1992^43^; Fair | IG1 | 12 group and 2 individual sessions of weight management, sodium restriction, and PA counseling. Weight loss goal of 4.5 kg and individualized calorie restrictions (for women, no less than 1200 calories per day and no less than 1500 calories per day for men). Sodium consumption goal was 1400 mg daily and PA goal was 120 minutes/week (4 30-minute sessions of slow walking per week). Participants self-monitored sodium, calories, and minutes of PA; food records were reviewed each week and returned to participants with suggestions for improvement. Anti-HTN meds withdrawn at start of intervention. | HD + PA; Total contact hrs: 13; Total duration: 6 months | Registered dietitians; Clinic | No advice: Received no treatment; if DBP exceeded 105 mm Hg, participants were placed on meds and removed from trial. At the end of the trial, any participant with DBP >90 mm Hg placed on open-label medication
Arroll, 1995^44^; Fair | IG1 | Exercise and salt interventions: Advised to walk 40mins 3 times per week, 1 page pamphlet, general article on BP/salt reduction, book containing salt content of common foods. Number and duration of sessions NR, but state that “The interventions were very simple and based on written and verbal information that could be easily used in a primary care setting. There was no intensive dietary advice…”; All participants kept a weekly diary tracking injuries or health problems and medication compliance. | HD + PA; Total contact hrs: NR; Total duration: 6 months | Research staff and GP; “community setting” | Minimal intervention: Usual care; weekly diary of health problems and medication changes.
Arroll, 1995^44^; Fair | IG2 | Participants advised to walk briskly for 40 minutes 3 days a week. A plan to build up to this amount of exercise was determined by the patient’s doctor. Number and duration of sessions NR, but state that “The interventions were very simple and based on written and verbal information that could be easily used in a primary care setting. There was no intensive dietary advice…”; All participants kept a weekly diary tracking injuries or health problems and medication compliance. | PA only; Total contact hrs: NR; Total duration: 6 months | Research staff and GP; “community setting” | Minimal intervention: Usual care; weekly diary of health problems and medication changes.
Arroll, 1995^44^; Fair | IG3 | Participants advised to decrease their use of high salt foods and added salt when cooking and eating. Each person received a simple pamphlet, a general article about salt and BP, and an in depth book with information about salt content of common foods. Number and duration of sessions NR, but state that “The interventions were very simple and based on written and verbal information that could be easily used in a primary care setting. There was no intensive dietary advice…”; All participants kept a weekly diary tracking injuries or health problems and medication compliance. | HD only; Total contact hrs: NR; Total duration: 6 months | Research staff and GP; “community setting” | Minimal intervention: Usual care; weekly diary of health problems and medication changes.
Babazono, 2007^45^ (PHPP); Fair | IG1 | Team encouraged patients to set their own goals & to select lifestyle improvements that they were interested in making; choose and prioritize physical activity to achieve goals; provided advice about how to achieve the goals set using “Stages of change” challenge cards. Problem solving for ways to achieve goals, or discussion about changing goals when appropriate, was a part of sessions. The primary goals of the intervention were to physical activity and vegetable intake, but other dietary goals were also listed on the “challenge cards, such as decreasing salty foods, oily foods, sugar, and alcohol, and increasing tofu intake, increasing time for meals, and eating more slowly. | HD + PA; Total contact hrs: 3; Total duration: 12 months | Dietitians, health exercise instructors, public health nurses; Medical center, home visits | Usual care: Asked to return to the medical center 1 month after baseline assessments, where they received results and were given instructions on how to enhance physical activity via leaflets only.
Beckmann, 1995^46^; Fair | IG1 | Participants were instructed to lower their sodium intake (e.g., not adding salt at table or while cooking, avoiding sodium-rich foods, processed food; bake own bread, use oil, salt-free margarine and increase use of fruits and vegetables) and provided with a free 2-week supply of unsalted foods with aim to reduce average daily sodium intake to 30 mmol/d. Following the two weeks of food provision, participants aimed to achieve an average daily sodium intake of 100 mmol/d. After 3 months, participants with elevated BMI (≥27 kg/m^2^) or total cholesterol (>50th percentile) received advice to reduce body weight and reduce saturated and increase intake of polyunsaturated dietary fat. | HD only; Total contact hrs: 2.5; Total duration: 12 months | Nutritionist; Outpatient clinic | Waitlist: At 12 months, participants were given dietary advice similar to that given to the intervention group.
Bennett, 2012^47^ (Be Fit, Be Well [POWER]); Good | IG1 | 18 tailored diet, physical activity and lifestyle counseling calls (20 min each); 12 optional group sessions; PCP endorsement message; and self-monitoring using study website or interactive voice response system. Participants were prescribed 3 tailored goals for modifying obesogenic lifestyle behaviors with new goals selected at subsequent 13-week intervals. For the duration of the study, participants maintained a hypertension medication adherence goal. Participants self-monitored behavioral goals via the study website or printed logs which were then entered into an interactive voice response system. Trained community health educators delivered monthly 15–20-min telephone counseling calls in the first year and bimonthly during the second year (18 telephone calls total) that covered data from self-monitoring, problem solving and behavioral skills training. Twelve optional bimonthly group sessions were also offered including interactive skills training and a physical activity component (e.g., group walk), and promoting social support for behavioral change. PCP delivered at least 1 brief, standardized message about the importance of intervention participation. Participants were provided behavior change “prescription” that included PCP’s electronic signature, as well as tailored information on community resources (e.g., public parks, walking groups, and farmers’ market) and received a walking kit with a pedometer. | HD + PA; Total contact hrs: 18; Total duration: 24 months | Community health educator and PCP endorsement; Home (web-based or print and phone) and community health center | Usual care: Received NHLBI self-help booklet, “Aim for a Healthy Weight.”
Bennett, 2018^48^ (Track); Good | IG1 | Weight-loss intervention informed by social cognitive theory, and had a weight loss goal of 7% weight reduction. The Track intervention contained five components: (1) tailored physical activity- and diet-related behavioral goals; (2) self-monitoring of behavioral goals via interactive voice response (IVR) phone calls and SMS text messages with automated, tailored feedback; (3) daily self-weighing via a cellular connected scale; (4) skills training materials in print and video; (5) 18 weight loss counseling 10–15 min coaching calls (weekly for calls 1–4; biweekly for calls 5–10; and monthly for calls 11–18), during which registered dietitians and psychology graduate students (i) reviewed self-monitoring data (behavioral goals and daily weights) and reinforced its importance, (ii) discussed barrier reduction strategies, (iii) delivered skills training content, and (iv) discussed community resources; and (6) brief PCP-delivered weight-loss counseling at medical visits. To facilitate PCP counseling, regular participant progress reports were delivered to PCPs through the EHR that include the participant’s status on behavioral change goals, weight change data, and feedback regarding the participant’s adherence to self-monitoring. Clinicians are alerted to their updates through pop-ups that display upon opening an intervention participant’s EHR. PCPs also received quarterly reports with feedback on their individual counseling rates. PCPs also received annual in-service trainings and period presentations at staff meetings showing clinic-level data.; Four individualized behavior change goals were selected among 24 dietary and PA goals, rotating every 8 weeks, based on a self-administered survey. Each person was assigned their top 3 goals based on a computer algorithm, and plus a rotating 4th goal which was the same for all participants. The 4th goal also changed every 8 weeks and were: (1) “no red zone foods” [red zone foods are commonly eaten high-calorie foods and beverages (sodas, sweet teas, desserts, potato chips, pizza, hamburgers) that the participant typically eats 3 times per week or more], (2) practice portion control, (3) walk 7000–10000 steps per day. | HD + PA; Total contact hrs: 5.4; Total duration: 12 months | PCP, dietitian, psychology graduate students; Primary care and home (coaching calls) | Usual care: Participants received current standard of care offered by their primary care providers, as well as self-help materials (NHLBI “Aim for a Healthy Weight”) and a collated list of community resources for healthful eating, physical activity, and weight management. Participants also received quarterly newsletters that included seasonal-related health tips, and financial and safety information.
Beune, 2014^49^ (Culturally Adapted Hypertension Education (CAHE)); Fair | IG1 | Participants received three 30-minute culturally-appropriate hypertension education (CAHE) sessions adapting the “5As” model (ask, assess, advise, assist, arrange) over a period of 4.5 months, conducted by a trained practice nurse. During the first session, the PN educated the participant about hypertension and discussed hypertension treatment goals for the next 3 months, as well as potential barriers/facilitators in achieving treatment goals. During the second and third sessions, the PN discussed with the participant their experiences of culturally-specific barriers/enables in achieving their hypertension treatment goals, such as medication use and lifestyle changes. PNs also discussed the participant’s current BP measurement; self-reported medication and lifestyle adherence; goals for the next 3 months; potential barriers/facilitators in achieving treatment goals; and feasible steps needed to maintain/achieve treatment goals. In addition to the CAHE sessions, participants received culturally-specific, educational written material, and if necessary, referrals to neighborhood facilities (e.g., walking clubs or health food stores) that could help Surinamese and Ghanaian patients adopt healthier lifestyles. | HD + PA; Total contact hrs: 1.5; Total duration: 4.5 months | Practice Nurse; Primary care | Usual care: Participants received standard hypertension care and education following the recommendations in the Dutch clinical guidelines.
Blackford, 2016^50^ (Albany Physical Activity and Nutrition (APAN)); Fair | IG1 | As part of a 6-month home-based intervention, participants received a package designed to educate, motivate, and support improvement in nutrition and physical activity through goal setting. The program empowers individuals to self-manage and monitor their health behaviors and weight, emphasizing the importance of regular self-weighing. The package contained a booklet, exercise chart, calendar, resistance bands, and nutrition panel wallet cards. The educational materials provide illustrations and tips on how to perform exercises safely. The PA component will use accelerometers to measure PA at baseline and posttest for the IG group only, with graphical feedback provided to participants at baseline. A resistance band was provided for strength training exercises. The nutrition component consists of suggested meal plans, recipes, and tips on healthy eating, encouraging a higher consumption of fruits and vegetables and fiber while reducing intake of fat and sugar. The package materials were adapted from PANS study materials for a rural context. The booklet had materials based on the Australian Dietary Guidelines and Australia’s Physical Activity and Sedentary Behavior Guidelines, which participants used to set their diet and PA goals for the duration of the intervention. The calendar was used to support goal setting by providing a resource for their planning and recording their PA and eating habits and supplemented the program booklet as a quick and convenient reference. In addition to the package materials, participants received 6 motivational telephone calls (weeks 3, 6, 12, 18, and 24) utilizing strategies such as empathy, shared decision-making, and reflective listening and followup emails from research assistants, which were used to support goal setting and use of the program resources. Participants chose their own goals. Participants had the option to contact the research assistant they had been allocated to throughout the course of the intervention. Participants also received a bimonthly newsletter and had access to a website that included diet and PA information and links, a blog for program news and updates, and a daily and weekly progress tracker to PA, diet behaviors, and weight. | HD + PA; Total contact hrs: 1.5; Total duration: 6 months | Research assistants; Home | Waitlist: Participants received the intervention after completing post-test data collection.
Bloemberg, 1991^51^; Fair | IG1 | Participants received individualized dietary advice based on their habitual food intake and the “Guidelines for a Healthy Diet” of Netherlands Nutrition Council. The aim of the advice was to lower plasma total cholesterol level without lowering the HDL cholesterol level. With the aid of a study-created computer program, the study dietitian examined data on participant baseline habitual food intake and checked the effect of changes on the energy and nutrient content. The computer program was also able to estimate the expected decrease of plasma total cholesterol level due to changes in fatty acid and cholesterol content of their diet. The aim of the dietary advice was to reduce total cholesterol by 1 mmol/L. One week after examination, dietitian counseled participants on their diet and tried to convince them to adhere to their advice. In addition, participants received an average of two telephone calls in which the dietitian inquired about possible problems related to their dietary advice. Five mailers with information on healthy diets were sent to participants. | HD only; Total contact hrs: 1; Total duration: 6 months | Dietitian; NR | No advice: Did not receive any advice to improve diet during the study period.
Bo, 2007^52^; Fair | IG1 | Trained interventionists delivered the following: 1 individual session prescribing diet tailored to participants’ current weight and dietary intake (normo- or hypocaloric); general dietary recommendations about cooking, reducing fat, sugar, and salt intake, and tips for dining out; discussion about behavior modifications; written recommendations for physical activity; a brief written guide on behavioral change; a copy of the food pyramid; explanations about the benefits of using diet and exercise to control metabolic abnormalities; and individualized diet and physical activity goals; and 4 group sessions for each different topics: food composition; portion control, strategies for dining out; and physical activity benefits. In addition, PCP delivered a brief general healthy lifestyle advice according to their usual practice to participants in both groups. | HD + PA; Total contact hrs: 5; Total duration: 12 months | Nutritionists, specialists in endocrinology, and internal medicine; Assumed health clinic | Usual care: General information on the importance of a healthy lifestyle was given from participants’ physicians according to their usual practice.
Bosworth, 2009^53^ (Take Control of Your Blood pressure (TCYB)); Fair | IG1 | Participants received a tailored behavioral self-management intervention, delivered by one nurse via bi-monthly telephone calls. Information was presented in an easily understood format with a readability score of 9th grade or less. Factors targeted in calls were: perceived risk for HTN, memory, literacy, social support, patients’ relationships with their healthcare provider, and side effects of medication. The intervention also focused on improving adherence to the DASH diet, weight loss, reduced sodium intake, regular moderate intensity PA, smoking cessation, and moderation of alcohol intake. Each encounter included a core group of modules potentially implemented during each call and additional modules activated at specific intervals. In addition to the dietary and PA counseling calls, participants received a blood pressure monitor, which they were trained to self-administer 3 times weekly on separate days at the same time of day. The trial nurse was not aware of home monitored BP values, but participants asked to maintain and turn in BP logs. | HD + PA; Total contact hrs: 3.2; Total duration: 24 months | Nurse; Home | Usual care: Participants received usual hypertension care from their primary care provider.
Bosworth, 2009^53^ (Take Control of Your Blood pressure (TCYB)); Fair | IG2 | Participants received a tailored behavioral self-management intervention, delivered by one nurse via bi-monthly telephone calls. Information was presented in an easily understood format with a readability score of 9th grade or less. Factors targeted in calls were: perceived risk for HTN, memory, literacy, social support, patients’ relationships with their healthcare provider, and side effects of medication. The intervention also focused on improving adherence to the DASH diet, weight loss, reduced sodium intake, regular moderate intensity PA, smoking cessation, and moderation of alcohol intake. Each encounter included a core group of modules potentially implemented during each call and additional modules activated at specific intervals. | HD + PA; Total contact hrs: 3.2; Total duration: 24 months | Nurse; Home | Usual care: Participants received usual hypertension care from their primary care provider.
Broekhuizen, 2012^54^ (PRO-FIT); Fair | IG1 | A combination of tailored web-based advice (PRO-FIT*advice) and one face-to-face counselling complemented with 1 to 5 telephone booster sessions (PRO-FIT*coach). The goal was to: 1) improve awareness of the cardiovascular disease risk through an increase of specific knowledge, cues to action and change in risk perception, 2) improve motivation with respect to healthy behavior through an increase of specific knowledge and a change in attitude, self-efficacy and social influences, 3) adopt and maintain a healthier lifestyle, specifically with regard to physical activity, saturated fat intake, fruit and vegetables intake, smoking and compliance to statin therapy, and 4) lower the level of LDL-C and other biological CVD risk indicators and thereby reducing the CVD risk. Thus, the intervention was a personalized health counseling intervention that included the use of a website on CVD risk communication and how to change these risks; and access to online PRO-FIT advice account, which had tailored advice regarding positive behaviors such as food intake, smoking, and compliance to statin therapy, presented according to the individual participants risk profile; and a lifestyle coach who delivered personal feedback and worked with participants to make action plans using motivational interviewing techniques. | HD + PA; Total contact hrs: 2.25; Total duration: 11 months | Trained lifestyle coach; Participants’ home | Usual care: Usual care (no intervention)
Bruckert, 2008^55^ (PEGASE (Effect of an Education Program)); Fair | IG1 | Assessment and six counseling for healthy diet and physical activity (4 45-min group sessions, 2 in-person individual sessions). Sessions focused on three stages: increasing awareness on CVD risks, start action, maintain action. Group sessions included self-reflection on risks and threats to health, physical activity & healthy diet education, and information on cholesterol management and barriers to drug adherence, plus written materials. Educational messages were reinforced during individual sessions, along with focusing on translating individual goals into small, achievable steps and actions related to healthy behaviors. | HD + PA; Total contact hrs: 4; Total duration: 6 months | Physician, nurse, nutritionist; Medical centers specializing in CVD prevention | Usual care: Physicians received no training; patients received usual care
Burke, 2006^56^ (ADAPT); Fair | IG1 | 6 group workshops with printed materials for behavioral self-management of nutrition, physical activity and weight loss with emphasis on barriers, costs and benefits of a healthy lifestyle, goal setting, and time management. The DASH diet was the model for dietary advice with the following goals: sodium intake <2 g per day, increased intake of fruit, vegetables, and low-fat dairy, reduced intake of total and saturated fats, sweets, and sugary drinks; eating ≥4 fish meals per week; participating in ≥30 min of physical activity most days and increasing incidental activity; weight loss of ≥5%; reduced alcohol (consuming ≤2 drinks per day), and smoking cessation. Social support was encouraged by allowing a partner, relative, or friend to accompany participants during group sessions and involving them in grocery shopping, meal prep, and physical activity. Diet and physical activity calendars were used to track behaviors. Individual counselling sessions with dietician or program coordinator were offered, but few participated (5 individuals attended with 2 sessions each). A newsletter was issued every 3 months. Participants with 24-hr ambulatory BP <130/85 mm Hg at the end of 4 months had anti-HTN medications withdrawn; these participants then measured their BP using a home monitor with regular phone contact with study facilitators to report results of home-monitored BP. | HD + PA; Total contact hrs: 6; Total duration: 16 months | Dietitian, program coordinators; Medical center | Attention control: Usual care; publications from the National Heart Foundation of Australia & the Health Department of Australia; attention control with 4 seminars on topics unrelated to ADAPT were held as well.
Chirinos, 2016^57^ (Community Health and Risk-reduction for Metabolic Syndrome (CHARMS)); Fair | IG1 | 17 (90-min) diet and physical activity group counseling sessions. Intervention was DPP-based and tailored to population by Spanish translation of materials, delivery in English or Spanish according to individual language preferences, and culturally relevant examples and dietary recommendations. Intervention had a 3-month core curriculum of eight sessions (four weekly and four bi-weekly) followed by a maintenance phase with 9-monthly sessions. Calorie goals were set based on participant’s baseline weight; however, participants were not prescribed a structured dietary program. Unsupervised exercise, which consisted of brisk walking, was initiated at week 1, starting with four 15-min weekly sessions, increasing progressively to five 30-min weekly sessions by week 5. Dietary and exercise goals were aligned to national recommendations. Participants were asked to record their food intake in food logs and wear a pedometer for at least one week prior to each sessions. Sessions targeted a broad range of material related to diet, physical activity and psychosocial well-being. | HD + PA; Total contact hrs: 25.5; Total duration: 12 months | Master and doctoral level clinicians; Research clinic | Usual care: At baseline and 6 months, received detailed description of their lab values and met with a medical provider for lifestyle modification advice, which is recommended management of the metabolic syndrome.
Christian, 2011^58^; Fair | IG1 | Patients completed a computer-based assessment of their motivational readiness to increase physical activity and make dietary changes just before a usual care visit. The assessment (<10 minutes) solicited information on usual dietary habits, weight-management history, and awareness of the role of diet and exercise in the prevention of diabetes. Upon completion of the assessment, the computer system generated a tailored report providing feedback addressing participant-identified barriers to improving their physical activity and diet. The purpose of this feedback was to enhance participants’ motivation to increase PA and reduce caloric intake; to identify potential barriers to making lifestyle changes, and to provide tailored counseling suggestions to enhance readiness, decision-making, and self-efficacy. Before the baseline clinic visit, participants read their report and listed 2-3 dietary and/or PA self-management goals they want to achieve and were also given a 30-page planning guide that provided general supplemental information on preventing diabetes and achieving goals. The computer expert system also generated a companion report for the patient’s physician, which consisted of a less than 1-page bulleted summary of the findings from the patient’s assessment and provided the physician with patient-specific counseling recommendations based on an MI approach. Participants reassessed goals at 6 months and again reviewed their goal sheet with their physician, who reinforced patients’ goals. | HD + PA; Total contact hrs: 0.83; Total duration: 6 months | Computer expert system and PCP; Community health center | Usual care: Given a packet of health education materials addressing diabetes, diet, and exercise before completing their usual care visit
Cicolini, 2014^59^; Fair | IG1 | 1 60-minute educational session on healthy lifestyle and hypertension management; 26 weekly email messages and phone calls; and two booklets. For 6 months, participants received weekly emails containing a reminder program on the compliance with healthy lifestyle. And, in case of no read receipt, nurse care manage phoned participants to press for reading. The attached program to the emails contained recommendations on healthy lifestyle, including a diet high in vegetables and low in salt, saturated fat intake and cholesterol, moderate aerobic exercise, smoking cessation and/or replacement with nicotine/bupropion, moderate alcohol consumption, blood pressure self-monitoring (with instructions) and medication adherence. | HD + PA; Total contact hrs: 1; Total duration: 6 months | Nurse care manager; Home | Usual care: Received 1-hour educational session on healthy lifestyle and hypertension management.
Cochrane, 2012^60^; Fair | IG1 | Health check plus 1 individual 45–60 minute lifestyle counseling/motivational interviewing session with lifestyle coach. The coach offered an additional maximum of 6 hours of support over 6 months and a final review at 12 months; subsequent contacts could be face-to-face, by telephone, or text message based on patient preference. Initial consultation session was used to discuss, develop, and negotiate a personalized health improvement plan and lifestyle improvement priorities identified by the patient. Referrals to free support sessions were offered, including PA sessions (free 20-week program), weight management support (free Weight Watchers vouchers), cooking and eating and positive thinking sessions, and access to smoking cessation support.; Primary care toolkit publicly available at:; https://www.healthcheck.nhs.uk/ | HD + PA; Total contact hrs: 3.5; Total duration: 12 months | Lifestyle coach; Medical center | Minimal intervention: NHS health check plus usual general practice care, including medication or treatment for raised BP and/or cholesterol and newly diagnosed diabetes and referral to smoking cessation services, but did not receive additional lifestyle support. May have received lifestyle advice from the GP team.
Cohen, 1991^61^; Fair | IG1 | 12 monthly diet counseling visits with family practice resident. The goal of the dietary advice was to reduce the caloric content of the diet without radically changing the patient’s lifestyle; suggested diets were not specifically intended to be salt-reducing. At the initial visit, the resident reviewed the patient’s diet using a questionnaire. Information was provided about the calorie content of foods and suggestions for changes made as appropriate. Patients were encouraged to use a diet history sheet to evaluate and modify diet. At each visit the patient’s weight was recorded and any weight change noted, and dietary analysis and advice repeated. Short-term goals were set for the patient to meet by the next visit. The amount of weight gained or lost at each visit was used as feedback. Management of the patient’s hypertension medication was left to the PCP. | HD only; Total contact hrs: 6; Total duration: 12 months | Family practice resident; Primary care | Usual care: Physicians received no special instructions or materials. Participants received usual care; physicians could provide or refer participants for dietary advice. Participants were instructed about the importance of blood pressure control.
Coleman, 2012^62^ (Wisewoman California); Fair | IG1 | Three individual tailored counseling sessions (averaged 50 min) for healthy diet and physical activity; comprised of assessment, tailored feedback, collaborative goal setting, identifying strategies for overcoming barriers, and outlining small, achievable steps. Emphasis on self-efficacy, self-monitoring, reinforcement, readiness for change, and the importance of social support. Delivered in language of choice. Visual aids and hands on tools used (e.g. food models showing appropriate portions) along with a curriculum binder. Community health workers followed up via telephone in between sessions to encourage healthy behaviors, give referrals to health education classes (e.g. smoking cessation, nutrition, physical activity), and give appointment reminders. Received the same access to usual care and incentives (e.g. tote bags, water bottles, transportation tokens, grocery store vouchers) during assessments and sessions. | HD + PA; Total contact hrs: 3.25; Total duration: 6 months | Bilingual (English/Spanish) community health workers (from same community as participants); medical center (4 sites) | Usual care: Usual care for elevated blood pressure and cholesterol. May have included brief healthy behavior education, healthy lifestyle handouts (general, related to hypertension/hyperlipidemia), and/or referral to education classes. Received incentives during assessments.
Delahanty, 2001^63^; Good | IG1 | Participants received cholesterol lowering nutritional counseling and treatment according to NCEP-based cholesterol lowering protocol (e.g., progressively reducing intake of saturated fat and cholesterol and to promote weight loss for participants who are overweight by eliminating excess total calories and increasing physical activity). Participants were required to meet with a registered dietitian for a minimum of 2 to 3 visits over a 2- to 3-month period (average 90-min/session, range 60–140 min, average of 2.5 sessions), followed by an additional 2–3 visit over the next 3 months of lipids were not in the target range, average 30 min/session, average of 1.5 sessions). The number of visits each participant received was based on an assessment of each volunteer’s eating habits, lifestyle, capabilities, and motivation for change, in addition to usual care from PCPs. | HD + PA; Total contact hrs: 4; Total duration: 6 months | Registered dietitian; Medical center | Usual care: Participants received usual care and were instructed not to use lipid-lowering drugs or to seek additional dietary counseling.
Eakin, 2009^64^ (Logan Healthy Living); Fair | IG1 | The intervention was delivered over 18 months with 18 phone calls (10 over 12-month implementation period and 8 over 8-month maintenance period), during which participants received counseling with motivational interviewing techniques to promote healthy diet and physical activity. Participants were also mailed a detailed workbook, pedometer, self-monitoring form, and a stretch band prior to the first counseling call. During the counseling calls, participants were guided through a series of steps, beginning with a detailed assessment of their current physical activity and dietary behaviors, followed by feedback on their health behaviors in relation to national recommendations. The feedback highlighted the discrepancy between their health goals and current health behaviors. Participants set collaborative goals for PA and dietary change with their telephone counselor, which was incorporated into a behaviorally-specific action plan specifying exactly what was to be done and when. Discussions included barriers and supports to behavior change, confidence in ability to change, and problem-solving as needed. Other components covered included goal setting, problem-solving, self-rewards, social support, positive self-talk, relapse, and action plans. Counseling followed the 4As approach: assessment, advice, assistance, and arranging followup. Participants were encouraged to meet the Australian dietary recommendations (5 servings/day of vegetables, 2 servings/day of fruit, | HD + PA; Total contact hrs: 5.4; Total duration: 12 months | Graduate-level counselors; Home | Minimal intervention: After each assessment, participants received a brief and tailored letter with feedback on their results. They also received generic brochures on a variety of health topics, including physical activity and diet, and a project newsletter with general health tips.
Edelman, 2006^65^; Fair | IG1 | 52 total sessions of diet, physical activity, and mind-body approaches to reduce CVD risk (2 individual in-person sessions providing feedback on CVD risk assessment results, 28 120-min group sessions, 20 20–30 min phone calls, and 2 individual nutrition counseling sessions). Baseline CVD risk assessment using “Know Your Number” with individualized feedback at baseline and 5-months from physician or physician assistant. With support of health coach, participants prioritized 1–3 goals for behavior change, and new goals were added once previous goals were achieved. Group sessions included mind-body approaches to self-care, nutrition education, physical activity education, and strategies for behavior change such as goal-setting, communication skills, and relapse prevention. Every two weeks, participants had individual telephone sessions (20–30 min) with their coach to reinforce group session techniques, to clarify priorities and set or update goals, and enhance motivation. Participants had 2 opportunities to meet with a nutritionist for individualized support and recommendations. | HD + PA; Total contact hrs: 68; Total duration: 10 months | Master’s level trained health coaches, nutritionists, physician, physician assistant; Academic “integrative” medical center | Usual care: The group received a mailed report including their health assessment and baseline blood test results.
Ellsworth, 2016^66^; Fair | IG1 | Participants first received a 3-month therapeutic education and lifestyle workshop in which they developed individualized lifestyle plans to reduce metabolic risk. Lifestyle plans focused on a Mediterranean-style diet that included moderate carbohydrate and animal/vegetable fat, weight loss, strength and endurance, and stress reduction. Participants first attended a 4-h orientation that outlined objectives, requirements and expectations and then met individually with a registered dietitian, exercise physiologist, stress management instructor and psychologist to learn effective strategies for integrating healthy changes into their current lifestyle. Subjects met monthly with each specialty provider to receive reinforcement for implementing recommended lifestyle changes and guidance for maintaining success on their own. Over the next 9 months, participants received additional instruction for integrating healthy behaviors into daily life through monthly contact with an integrative health coach. | HD + PA; Total contact hrs: 20.5; Total duration: 12 months | Registered dietitian, exercise physiologist, stress management instructor, psychologist, and integrative health coach; NR | Usual care: Participants received standard care from their PCPs, but did not participate in any component of the lifestyle programs or receive any advice or counseling beyond routine care information regarding healthy lifestyle behaviors.
Estruch, 2018^67^ (Primary Prevention of Cardiovascular Disease with a Mediterranean Diet (PREDIMED)); Fair | IG1 | Following randomization, all participants met with a dietitian to complete a questionnaire regarding adherence to the Mediterranean diet and discussed individual recommendations for changes to their diet in order to achieve a personalized goal depending on group assignment. The dietitian provided reasons to adopt a Mediterranean diet, highlighting the advantages of following this diet rather than the risks of not adhering to it, and transmitting a positive message emphasizing the benefits for the high CV risk of the participants. The dietitian personalized the message by adapting it to the participant’s clinical condition, preferences, and beliefs. The visit ended with an agreement to participate in the group session, which was scheduled in the next 1–2 weeks. The group sessions were facilitated by the dietitians and were scheduled regularly and attended by ≤20 participants per session. During the group sessions, the dietitian gave an informative talk regarding dietary goals, description and clarification of written materials (descriptions of 4 to 5 foods typical of the high-olive oil dietary pattern), a quantitative 1-week shopping list of food items according to the season of the year, a weekly plan of meals (with detailed menus) corresponding to the shopping list, and the recipes for preparing the meals of the suggested menus), allotments of supplemental foods (15-liter supply of extra-virgin olive oil), and an agreement to participate in the next visit 3 months later.; The individual motivational interviews included three steps: assessment, intervention, and future directions. Interventionists emphasized the holistic approach to lifestyle change in order to tailor the intervention to nutritional assessment and individual needs, encourage adherence to the MedDiet, transmit a sense of empowerment, and, importantly, feel a self-reward for each upward step in the 14-point MedDiet score. The focus was shifted from changing portion sizes to changing frequency of intake or to changes in cooking methods. Accomplishments in the previous months, even if minor, are considered as support to provide further empowerment and self-reward. The general guidelines to follow the Mediterranean diet included: a) abundant use of olive oil for cooking and dressing dishes; b) consumption of ≥2 daily servings of vegetables (at least one of them as fresh vegetables in a salad), discounting side dishes; c) ≥2–3 daily servings of fresh fruits (including natural juices); d) ≥3 weekly servings of legumes; e) ≥ 3 weekly servings of fish or seafood (at least one serving of fatty fish); f) ≥1 weekly serving of nuts or seeds; g) select white meats (poultry without skin or rabbit) instead of red meats or processed meats (burgers, sausages); h) cook regularly (at least twice a week) with tomato, garlic and onion adding other aromatic herbs, and dress vegetables, pasta, rice and other dishes with tomato, garlic and onion. Participants were encouraged to eliminate or limit the consumption of food products high in saturated fat, simple carbohydrates, and sugar. The dietitians insisted that two main meals per day should be eaten (seated at a table, lasting more than 20 minutes). For usual drinkers, the dietitian’s advice was to use wine as the main source of alcohol (maximum 300 ml, 1-3 glasses of wine per day); Interventionists applied common cognitive behavioral techniques, including goal setting, self-monitoring, feedback and reinforcement, self-efficacy enhancement, incentives, problem solving, relapse prevention, and motivational interviewing in individual and group sessions. Measurable realistic goals easily identifiable by the participant and attainable in specified time frames were set. | HD only; Total contact hrs: 30.5; Total duration: 60 months | Registered dietitians; Primary care centers, university health care centers, hospitals | Minimal intervention: During the first three years, participants received one dietary counseling session with a dietitian at baseline and an annual leaflet explaining the low-fat diet. Thereafter, participants had quarterly individual and group sessions with the delivery of food descriptions, shopping lists, meal plans and recipes (adapted to the low-fat diet) in such a way that the intensity of the intervention was similar to that of the Mediterranean diet groups, except for the provision of free supplemental olive oil or nuts.
Estruch, 2018^67^ (Primary Prevention of Cardiovascular Disease with a Mediterranean Diet (PREDIMED)); Fair | IG2 | Following randomization, all participants met with a dietitian to complete a questionnaire regarding adherence to the Mediterranean diet and discussed individual recommendations for changes to their diet in order to achieve a personalized goal depending on group assignment. The dietitian provided reasons to adopt a Mediterranean diet, highlighting the advantages of following this diet rather than the risks of not adhering to it, and transmitting a positive message emphasizing the benefits for the high CV risk of the participants. The dietitian personalized the message by adapting it to the participant’s clinical condition, preferences, and beliefs. The visit ended with an agreement to participate in the group session, which was scheduled in the next 1–2 weeks. The group sessions were facilitated by the dietitians and were scheduled regularly and attended by ≤20 participants per session. During the group sessions, the dietitian gave an informative talk regarding dietary goals, description and clarification of written materials (descriptions of 4 to 5 foods typical of the high-nut dietary pattern), a quantitative 1-week shopping list of food items according to the season of the year, a weekly plan of meals (with detailed menus) corresponding to the shopping list, and the recipes for preparing the meals of the suggested menus), allotments of supplemental foods (3-month supply of nuts consisting of 1350 g walnuts, 675 g hazelnuts, 675 g hazelnuts [additional 1000 g packs of mixed nuts provided to each family unit]), and an agreement to participate in the next visit 3 months later. The individual motivational interviews and group sessions were repeated every 3 months with the same content. Each visit included three steps: assessment, intervention, and future directions. The general guidelines to follow the Mediterranean diet included: a) abundant use of olive oil for cooking and dressing dishes; b) consumption of ≥2 daily servings of vegetables (at least one of them as fresh vegetables in a salad), discounting side dishes; c) ≥2–3 daily servings of fresh fruits (including natural juices); d) ≥3 weekly servings of legumes; e) ≥ 3 weekly servings of fish or seafood (at least one serving of fatty fish); f) ≥1 weekly serving of nuts or seeds; g) select white meats (poultry without skin or rabbit) instead of red meats or processed meats (burgers, sausages); h) cook regularly (at least twice a week) with tomato, garlic and onion adding other aromatic herbs, and dress vegetables, pasta, rice and other dishes with tomato, garlic and onion. Participants were encouraged to eliminate or limit the consumption of food products high in saturated fat, simple carbohydrates, and sugar. The dietitians insisted that two main meals per day should be eaten (seated at a table, lasting more than 20 minutes). For usual drinkers, the dietitian’s advice was to use wine as the main source of alcohol (maximum 300 ml, 1–3 glasses of wine per day).; Interventionists applied common cognitive behavioral techniques, including goal setting, self-monitoring, feedback and reinforcement, self-efficacy enhancement, incentives, problem solving, relapse prevention, and motivational interviewing in individual and group sessions. Measurable realistic goals easily identifiable by the participant and attainable in specified time frames were set. | HD only; Total contact hrs: 30.5; Total duration: 60 months | Registered dietitians; Primary care centers, university health care centers, hospitals | Minimal intervention: During the first three years, participants received one dietary counseling session with a dietitian at baseline and an annual leaflet explaining the low-fat diet. Thereafter, participants had quarterly individual and group sessions with the delivery of food descriptions, shopping lists, meal plans and recipes (adapted to the low-fat diet) in such a way that the intensity of the intervention was similar to that of the Mediterranean diet groups, except for the provision of free supplemental olive oil or nuts.
Fagerberg, 1998^68^ (Risk Factor Intervention Study (RIS)); Good (KQ1); Fair (KQ2) | IG1 | Aims to reduce total cholesterol to <6.0 mmol/L, help current smokers quit, prevent nonsmokers from starting, reduce hemoglobin A1c to <6.0% in those with diabetes, and lower DBP to <90 mm Hg. Dietary advice was consistent with NCEP guidelines. After an initial informational group meeting, weekly group lessons for 5 weeks for 10–20 patients (and spouses) to change eating habits. Basic nutrition, purchase and preparation of food discussed using a slide series, a specially developed textbook and food/beverage exhibition. Overweight patients set a weight goal and restriction of alcohol intake encouraged for high consumers. Those with diabetes taught self-monitoring of glucose. Information provided about physical activity. At 4 months, individual follow-up visit with nurse to discuss results and further changes in dietary habits. Smoking cessation program consisting of 1 physician visit and weekly 1-hour group sessions were offered to smokers. Sessions included discussion of smoking habits, symptoms and diseases secondary to nicotine usage, psychological and social factors, and motivation for quitting. Nicotine gum was offered. At the 6 month visit, physicians started treatment with lipid lowering drugs and diabetes drugs if TC and/or HbA1c goals were not met. | HD + PA; Total contact hrs: 11.5; Total duration: 4 months | Physician, nurses, and dietitian; Hypertension outpatient clinic | Usual care: Usual care. Primary care provider treated hypercholesterolemia, diabetes, and smoking according to normal practice. Similar to IG, goal was to reduce DBP to <90 mm Hg so that differences in endpoint rates were not attributable to difference in BP.
Gill, 2019^69^ (Heartmatters Challenge - First Responders); Fair | IG1 | Personalized diet and exercise plan via an online portal based on combination of laboratory results and personal references; lifestyle plans reviewed during telephone coaching with registerd dietitians and online tools for tracking diet, exercise, and weight, including gamification apps to promote participaton. Recommended carbohydrate intakes 30% to 60%, saturated fat intake 5% to 10% with no more than 7% for known CVD or LDL-C ≥160 mg/dL, and total calorie intake set to facilitate health weight as determined by waist to height ratio. Carbohydrates recommendation were based on the severity of metabolic syndrome, and promoted unrefined natural sources such as vegetables, legumes, fruits, low-fat dairy, and whole grains. Dietary cholesterol was limited to 300 mg/dL, or 200 mg/dL for subjects with CVD, LDL ≥160 mg/dL or abnormally high cholesterol absorption. A 30% reduction in total energy intake was recommended to those requiring weight loss. Online food journals were reviewed during 20-minute one-on-one telephone lifestyle coaching sessions. | HD + PA; Total contact hrs: 10; Total duration: 12 months | Registered dietitian; Home | Minimal intervention: Completed 3-day food journals prior to each blood draw at FUP timepoints.
Gill, 2019^70^ (HealtheSteps); Fair | IG1 | 4 in-person individual sessions of diet and physical activity counseling (4 35-min sessions), print materials, and health technology tools and resources (e.g., phone coaching, online HealtheSteps social network, smartphone app, HealtheSteps website). Participants received ‘Eating Well with Canada’s Food Guide’ and the ‘Canadian Physical Activity Guidelines for Adults’ and met with their coach to set their exercise (moderate to vigorous intensity), physical activity (steps/day) and healthy eating prescriptions and discuss strategies to achieve their goals. Specifically, sessions were personalized to the participant focusing on setting S.M.A.R.T. (specific, measurable, attainable, realistic, and timely) goals. For the exercise prescription, participants completed a validated Step and Exercise Prescription providing a personalized target heart rate to measure and assist participants meeting their personal recommendations for moderate to vigorous activity. Coaches also discussed and encouraged strategies with participants on how to increase the amount of time that they spent exercising at their target heart rate. For the physical activity prescription, participants used a pedometer to record their average daily step count for 1 week (baseline). A paper chart was used to guide participants to incrementally increase their step count up to 10,000 steps per day. For aiding in further reducing sedentary behaviour, participants were instructed to reduce their sitting time in addition to increasing their step count daily. Lastly, a heathy eating prescription was planned so that the participant would increase (or decrease) their intake of fruits and vegetables, fats, carbohydrates and protein until they met the recommendations set out by Health Canada through Eating Well with Canada’s Food Guide. | HD + PA; Total contact hrs: 2.3; Total duration: 6 months | Health coach; Primary care community clinic sites | Waitlist: At allocation, participants were provided with copies of ‘Eating Well with Canada’s Food Guide’ and the ‘Canadian Physical Activity Guidelines for Adults’.
Greaves, 2015^71^ (Waste the Waist); Fair | IG1 | Four 2-hr group-based sessions in the first month to support initial behavioral change then five 90-min maintenance support sessions at 1.5, 2, 4, 6, and 9 months. Goals included increasing PA, reducing intake of total and saturated fat, increasing fiber intake, and other dietary changes to achieve 5% weight loss, although specific goals were chosen by each participant. Participants were invited to bring along a partner if they wished. Each session comprised a series of short sections to elicit and exchange ideas (e.g., about the importance of exercise, risks of excess weight, healthy eating etc.), learn key facts about diet and physical activity and skills of action/coping planning, self-monitoring and problem-solving. Early sessions focused on the skills and information required to adopt a new behavior, and later sessions introduced discussions more relevant to the maintenance of behavior, such as dealing with stress and challenging situations, and how to maintain motivation if weight loss ‘plateaus’. Sessions also encouraged emotional self-regulation, and included a cognitive behavioral therapy technique for impulse control. The main focus of sessions was to equip participants with a better understanding of what a healthy lifestyle is and it is importance, as well as to encourage them towards the continued use of self-regulatory activities (goal-setting, self-monitoring of behavior and weight, reviewing progress, problem-solving and review of goals) and to help them to better understand the process of behavior change over the long term. At the start and end of each session participants were reminded of the program’s two key messages designed to encourage sustainable lifestyle change; (i) small changes can make a big difference to their weight and your health, and (ii) aim for a lifestyle that is both healthy and enjoyable (make changes that they can live with). Participants were provided with a handbook including information for reference, and were given tasks each week; these usually included implementing action plans set during session time. | HD + PA; Total contact hrs: 15.5; Total duration: 9 months | Lifestyle coach; Community | Usual care: Brief advice from usual PCP care. Received standard pack of written information on cardiovascular risk and the effects of diet and physical activity on such risk. After 12 months, participants were offered condense (two sessions) version of the intervention.
Groeneveld, 2010^72^ (Health Under Construction); Fair | IG1 | Participants received a 6-month motivational interviewing (MI) intervention led by occupational physicians and occupational nurses trained to be lifestyle counselors. Using MI, the counselors guided participants through the process of becoming aware of their CVD risk, changing their behavior, and maintaining the changed behavior delivered in three 45–60 minute in-person counseling sessions and four 15–30 minute telephone counseling sessions. Participants’ wives or partners were invited to accompany them to the in-person sessions. During the first in-person session, the counselor explained the goals and procedure of the intervention and discussed the participant’s knowledge about CVD risk factors and health consequences, their personal risk profile, current lifestyle, and family history. Also during the first session, participants were offered two types of interventions: (1) Energy balance - Both diet and PA were addressed. Depending on the current PA and dietary behavior of the participant, the focus was on both diet and daily PA; (2) smoking cessation. After choosing the intervention type, pros and cons of behavior change, and willingness, readiness, and perceived confidence in the ability to change were discussed. Last, the participant set long- and short-term goals, and formulated implementation intentions. In subsequent sessions, progress and barriers were discussed and short-term goals could be adjusted. No specific weight loss advice was given. In addition to the in-person and telephone sessions, counselors provided several brochures to each participant containing educational materials on lifestyle risk factors for CVD, smoking cessation, PA, healthy diet, and dietary guidelines of the Dutch Nutrition Center. Participants were also provided a leaflet describing products high in saturated fat and low-fat alternatives, a leaflet with caloric values of common food products, and a brochure with recipes for healthy meals. | HD + PA; Total contact hrs: 5.5; Total duration: 6 months | Occupational physicians and occupational nurses in the role of lifestyle counselors; Occupational health clinic | Usual care: Participants received usual care in which an occupational physician (OP) informed them of their CVD risk profile in person or by mail. In some cases the OP provided brochures about CVD risk factors and/or lifestyle. The OP could provide advice on the participant’s lifestyle or refer them to a general practitioner, depending on the seriousness of the risk and the OP’s usual practice.
Hardcastle, 2008^73^; Fair | IG1 | 1 motivational interviewing session of diet and/or physical activity counseling (20–30 mins) with up to 4 optional MI sessions offered over the following 6 months (20–30 mins per session); average 2.0 sessions attended. MI sessions conducted by a registered dietician and/or physical activity specialist. Stage-matched motivational interviewing approach in which the focus on diet or physical activity depended on the participant’s priorities and readiness to change. Techniques included agenda setting, exploring pros and cons, exploring concerns/building confidence, providing information, asking key questions, and negotiating a change plan. Standard leaflet about exercise and nutrition provided at baseline assessment. | HD + PA; Total contact hrs: 1; Total duration: 6 months | Physical activity specialist and a registered dietician; Primary care | Usual care: Standard leaflet about exercise and nutrition provided at baseline assessment; included food and activity quiz which advice depending on score.
Harris, 2012^74^ (Health Improvement and Prevention Study (HIPS)); Fair | IG1 | This brief intervention with the PCP was modeled on the 5As framework (ask, advise, assess, assist, arrange). At the patient’s health-check visit, the GP and practice nurse reviewed behavioral and physiological risk factors and provided brief lifestyle counseling. Patients were referred to the lifestyle-modification program if they were found to be at high risk, defined as including one or more of the following characteristics: (1) a history of gestational diabetes mellitus, or impaired glucose tolerance or impaired fasting glycemia; (2) hypertension (blood pressure [BP] ≥140/90 mm/Hg on two occasions) or already treated for hypertension; (3) dyslipidemia (any of: TC >4.5 mmol/L, LDL >2.5 mmol/L, TG >2.0 mmol/L, or already treated for dyslipidemia); (4) overweight (BMI ≥kg/m^2^); (5) waist circumference >102 cm in males or >88 cm in females; (6) current smoker. The lifestyle program included an initial visit with a dietitian or exercise physiologist for an assessment and individual goal setting, followed by attendance at a group education program, “CHANGE for HIPS”, adapted from the patient education component of the Counterweight program. This comprised four 1.5-hour sessions over the first 3 months and a further two follow-up sessions at 6 and 9 months. Group sessions included education, physical activity (20–30 minutes of walking or resistance exercise) and self-management strategies (goal setting, self-monitoring, developing practical skills and problem solving) aimed at promoting positive dietary and physical activity changes and weight loss. Patients were encouraged to keep a food and physical activity diary and use a pedometer between sessions. | HD + PA; Total contact hrs: 10.25; Total duration: 12 months | GP and practice nurse, dietitian or exercise physiologist, intervention officer; Primary care | Waitlist: After 12 months of usual care, control practices were offered to join intervention.
Haufe, 2019^75^; Fair | IG1 | 6 sessions of physical activity counseling and 1 session of diet counseling. Based on data from initial exercise tests, activity questionnaires, and medical history, the intervention group received counseling with recommendations aimed to perform 150 min of moderately intense physical activity per week with individualized heart rate goals provided based on results of treadmill test. Participants were also instructed to maintain a high level of daily activity and were provided tips for their daily routine, including information on potential training facilities at their home and at the workplace. Activity monitors were also provided, and participants were instructed to download the monitor’s smartphone application and to wear the monitors throughout the duration of the intervention. The smartphone application provided general information about the study, individual training goals, recommended heart rates for endurance activities, tips for increased physical activity in everyday life, and the exercise scientist’s contact information. The exercise scientist monitored participants’ physical activity levels using data from the application and provided feedback and adaptations to their further training schedule during monthly meetings. Participants were free to contact the exercise scientist by telephone or email at any time with questions. Adherence to the goal of 150 min of activity per week was assessed from self-started activities using the provided activity monitor. In addition to the exercise intervention, participants received nutritional counseling, which provided background information on healthy food choices based on general recommendations issued by the German Society for Nutrition. | HD + PA; Total contact hrs: 3.5; Total duration: 6 months | Exercise scientist; Community/home | Waitlist: Participants were instructed to maintain their current lifestyle and were offered the intervention following the completion of the study.
Hinderliter, 2014^76^ (Exercise and Nutrition interventions for CardiOvasculaR hEalth (ENCORE)); Good | IG1 | 4 in-person individual instructional sessions on diet and 14 (30–45 min) group sessions of diet counseling. Intervention began with 2 week controlled feeding period followed by 14 weekly 30–45 minute small group sessions with nutritionist. Participants were asked not to exercise or attempt to lose weight. During controlled feeding period, provided study meals were isocaloric to prevent weight gain or loss and participant met twice weekly with nutritionist to learn about the DASH dietary pattern. Following feeding period, participants instructed to maintain DASH diet on their own. The goal of weekly group counseling sessions was to assist participants in learning how to buy and prepare appropriate foods, to enhance motivation to choose to eat those foods, and to overcome obstacles to following the diet. Participants weighed each week to monitor weight and make adjustments in the recommended servings so that weight would remain stable during the intervention period. | HD only; Total contact hrs: 11.5; Total duration: 4 months | Nutritionist; Medical research center | Usual care: Asked to maintain their usual dietary and exercise habits
HPT, 1990^77^ (Hypertension Prevention Trial (HPT)); Good | IG1 | 28 60-min group diet counseling sessions and 16 bimonthly newsletters: The HPT dietary intervention consisted of two phases: initial and maintenance. The initial phase consisted of 12 group sessions held during a 4-month period. Participants were given a goal to increase potassium intake to approximately 3,900 mg or more per day and reduce daily sodium intake to approximately 1,600 mg or less per day. Participants received counseling related to meal planning and preparation, food purchasing, and label reading to assist them in making the required changes. Participants were asked to complete daily food records for the basis to encourage participants to make further changes or to maintain their dietary changes. Behavioral strategies included: (1) setting realistic daily and weekly goals for diet change; (2) assessing your diet at regular intervals to track your progress; (3) rewarding yourself for adhering to your diet; (4) Planning ahead, especially for meals away from home; (5) discussing your diet with family and friends and enlisting their help; (6) asking, when eating out, what is being served and request modifications as needed; (7) recognizing negative moods and thoughts that interfere with diet adherence and practicing a positive attitude; and (8) analyzing causes of recurrent dietary mistakes and taking steps to minimize them. Other specific content included building motivation, social eating strategies, assertiveness, problem solving, food cues, maintenance/relapse prevention strategies.; The maintenance phase followed the initial phase and continued to the end of the study. It consisted of group sessions every second month. Participants who did not attend the group sessions were contacted by telephone and were provided a makeup with an individual session. The telephone contact included a qualitative assessment of the participant’s dietary compliance based on self-report. Throughout the maintenance phase, participants also received a bimonthly newsletter containing relevant dietary information and recipes. | HD only; Total contact hrs: 28; Total duration: 36 months | Nutritionists and behavioral specialists; Research clinic | No advice: No dietary counseling
HPT, 1990^77^ (Hypertension Prevention Trial (HPT)); Good | IG2 | 28 60-min group diet counseling sessions and 16 bimonthly newsletters: The HPT dietary intervention consisted of two phases: initial and maintenance. The initial phase consisted of 12 group sessions held during a 4-month period. Participants were given a goal to reduce daily sodium intake to approximately 1,600 mg or less per day (individual goal: urine sodium excretion ≤70 mmol/d). Participants received counseling related to meal planning and preparation, food purchasing, and label reading to assist them in making the required changes. Participants were asked to complete daily food records for the basis to encourage participants to make further changes or to maintain their dietary changes. Same behavioral components as IG1.; The maintenance phase followed the initial phase and continued to the end of the study. It consisted of group sessions every second month. Participants who did not attend the group sessions were contacted by telephone and were provided a makeup with an individual session. The telephone contact included a qualitative assessment of the participant’s dietary compliance based on self-report. Throughout the maintenance phase, participants also received a bimonthly newsletter containing relevant dietary information and recipes. | HD only; Total contact hrs: 28; Total duration: 36 months | Nutritionists and behavioral specialists; Research clinic | No advice: No dietary counseling
HPT, 1990^77^ (Hypertension Prevention Trial (HPT)); Good | IG3 | 28 60-min group diet counseling sessions and 16 bimonthly newsletters: The HPT dietary intervention consisted of two phases: initial and maintenance. The initial phase consisted of 12 group sessions held during a 4-month period. Participants were given a goal to reduce their weight by 5% through calorie restriction. Participants received counseling related to meal planning and preparation, food purchasing, and label reading to assist them in making the required changes. Participants were asked to complete daily food records for the basis to encourage participants to make further changes or to maintain their dietary changes. Same behavioral components as IG1.; The maintenance phase followed the initial phase and continued to the end of the study. It consisted of group sessions every second month. Participants who did not attend the group sessions were contacted by telephone and were provided a makeup with an individual session. The telephone contact included a qualitative assessment of the participant’s dietary compliance based on self-report. Throughout the maintenance phase, participants also received a bimonthly newsletter containing relevant dietary information and recipes. | HD only; Total contact hrs: 28; Total duration: 36 months | Nutritionists and behavioral specialists; Research clinic | No advice: No dietary counseling
HPT, 1990^77^ (Hypertension Prevention Trial (HPT)); Good | IG4 | 28 60-min group diet counseling sessions and 16 bimonthly newsletters: The HPT dietary intervention consisted of two phases: initial and maintenance. The initial phase consisted of 12 group sessions held during a 4-month period. Participants were given a goal to reduce their weight by 5% through calorie restriction and reduce daily sodium intake to approximately 1,600 mg or less per day. Participants received counseling related to meal planning and preparation, food purchasing, and label reading to assist them in making the required changes. Participants were asked to complete daily food records for the basis to encourage participants to make further changes or to maintain their dietary changes. Same behavioral components as IG1.; The maintenance phase followed the initial phase and continued to the end of the study. It consisted of group sessions every second month. Participants who did not attend the group sessions were contacted by telephone and were provided a makeup with an individual session. The telephone contact included a qualitative assessment of the participant’s dietary compliance based on self-report. Throughout the maintenance phase, participants also received a bimonthly newsletter containing relevant dietary information and recipes. | HD only; Total contact hrs: 28; Total duration: 36 months | Nutritionists and behavioral specialists; Research clinic | No advice: No dietary counseling
Hyman, 1998^78^; Fair | IG1 | Patients were offered and encouraged to use multi-modal counseling: up to 12 mailed dietary questionnaires with individualized mailed feedback, up to 12 computer-interactive phone calls, and 4-weekly 1-hr classes. All three components of counseling encouraged to make dietary changes to reduce cholesterol levels. Intervention focused on improving practical skills like reading labels, eating out, modifying recipes and self-monitoring, while being practical for primary care. Phone calls included 1 to 4 questions asking about recent dietary behaviors, goals, intentions, or nutritional knowledge, and received an appropriate pre-recorded message. Class components included videos featuring practical skills to reduce fat and cholesterol intake and included cooking and tasting, recipe modification, role playing to restaurant ordering and dealing with pressure to eat high-fat meals. | HD only; Total contact hrs: 4.59999990463257; Total duration: 6 months | Registered dietitian; CHC | Usual care: Usual care by primary care physician, hypercholesterolemic patients could be referred to clinic registered dieticians. After trial, offered the series of classes (waitlist control)
Hyman, 2007^79^; Fair | IG1 | Simultaneous counseling addressed smoking cessation, sodium reduction, and increasing PA during each of 3 brief individual in-clinic counseling sessions held every 6 months. Each counseling visit was followed by 7 15-minute motivational interviewing telephone counseling sessions scheduled 2, 4, 6, 8, 12, 16, and 20 weeks later. Participants also received home-based instructional materials including a printed manual and motivational videotape. Primary goals for target areas included: stop smoking, reduce sodium levels to 10,000 per week) where were all measured objectively. After each 6-month measurement visit, a postcard was mailed to participants to report how their measures compared to goals. | HD + PA; Total contact hrs: 6; Total duration: 18 months | Health educator; Primary care clinic, home (phone sessions) | Minimal intervention: Brief educational session on 3 target behaviors (smoking cessation, sodium intake reduction, increased physical activity). Postcards mailed after each 6-month measurement to report how measures compared to goals.
Hyman, 2007^79^; Fair | IG2 | Sequential counseling addressed 1 behavior change at a time (smoking cessation, sodium reduction, or increasing PA) during each of 3 brief individual in-clinic counseling sessions held every 6 months. Each counseling visit was followed by 7 15-minute motivational interviewing telephone counseling sessions scheduled 2, 4, 6, 8, 12, 16, and 20 weeks later. Participants also received home-based instructional materials including a printed manual and motivational videotape. Primary goals for target areas included: stop smoking, reduce sodium levels to 10,000 per week) where were all measured objectively. After each 6-month measurement visit, a postcard was mailed to participants to report how their measures compared to goals. | HD + PA; Total contact hrs: 6; Total duration: 18 months | Health educator; Primary care clinic, home (phone sessions) | Minimal intervention: Brief educational session on 3 target behaviors (smoking cessation, sodium intake reduction, increased physical activity). Postcards mailed after each 6-month measurement to report how measures compared to goals.
Ives, 1993^80^ (Rural Health Promotion Project (RHPP) Trial); Fair | IG1 | 5 visits of diet and physical activity counseling. Health Risk Appraisal and review of risk factors identified by the appraisal. Participants received 5 vouchers redeemable for cholesterol-lowering program which were presented at each visit. There was no specified content or structure to the visits; providers were given training and education in nonpharmacological methods for cholesterol reduction and offered potential program content but the intervention was not controlled. Interventionist training covered government and professional society recommendations (AHA, NHLBI, NCEP) for lowering cholesterol. | HD + PA; Total contact hrs: 2.5; Total duration: 12 months | Hospital staff; Hospital | Usual care: Usual care; completed Health Risk Appraisal but results were not reviewed and not offered vouchers for screening or health education
Ives, 1993^80^ (Rural Health Promotion Project (RHPP) Trial); Fair | IG2 | 5 visits of diet and physical activity counseling. Health Risk Appraisal and review of risk factors identified by the appraisal. Participants received 5 vouchers redeemable for cholesterol-lowering program which were presented at each visit. There was no specified content or structure to the visits; providers were given training and education in nonpharmacological methods for cholesterol reduction and offered potential program content but the intervention was not controlled. Clinicians at primary care sites could refer their eligible participants to the hospital for the intervention rather than conducting it in their own offices. | HD + PA; Total contact hrs: 2.5; Total duration: 12 months | PCP; Primary care clinic | Usual care: Usual care; completed Health Risk Appraisal but results were not reviewed and not offered vouchers for screening or health education
Johnston, 1995^81^; Fair | IG1 | 3 90-min group sessions of diet counseling in groups of 2 to 6. Content included source and function of dietary cholesterol, risk associated with high cholesterol intake, debunking of dietary misconceptions, advice for eating out, and benefits of exercise. Partners invited to attend. At study entry, all patients completed a simple health questionnaire which included basic info on diet and exercise; received verbal advice (~3 minutes) and a pamphlet about diet modification, cooking methods and physical exercise. | HD only; Total contact hrs: 4.5; Total duration: 6 months | Dietitian/nutritionist; NR | Usual care: All patients completed a simple health questionnaire which included basic info on diet and exercise; received verbal advice (~3 mins) and a pamphlet about diet modification, cooking methods and physical exercise. No further counseling. Incidental queries from the subjects were answered briefly on their return to clinic.
Johnston, 1995^81^; Fair | IG2 | 3 in-person individual sessions of diet counseling. Content included detailed diet history, food planning, cooking methods, recipe modification, shopping for food and exercise. At study entry, all patients completed a simple health questionnaire which included basic info on diet and exercise; received verbal advice (~3 mins) and a pamphlet about diet modification, cooking methods and physical exercise. | HD only; Total contact hrs: 1.5; Total duration: 6 months | Dietitian/nutritionist; NR | Usual care: All patients completed a simple health questionnaire which included basic info on diet and exercise; received verbal advice (~3 mins) and a pamphlet about diet modification, cooking methods and physical exercise. No further counseling. Incidental queries from the subjects were answered briefly on their return to clinic.
Jones, 1999^82^ (Hypertension Optimal Treatment (HOT)); Fair | IG1 | 2 in-person individual counseling sessions on diet and 11 in-person group support sessions. Intervention began with two individual counseling sessions on food selection and preparation and establishment of weight reduction goals. Total caloric restriction and reduction of fat intake were the only methods used for weight reduction. Six group support sessions in first 3 months and then every 3 to 6 months for duration of the study. Participants were not counseled to exercise. | HD only; Total contact hrs: 12; Total duration: 30 months | Registered dietitian; NR | Usual care: Research nurse informed participants to lose weight but no counseling or group support provided.
Kandula, 2015^83^ (South Asian Heart Lifestyle Intervention (SAHELI)); Fair | IG1 | After randomization, all participants were given a primary care referral by CBO staff. Following the primary care referral, participants received a 16-week lifestyle intervention that included group classes, experiential activities, behavior change counseling, and telephone support. The 60–90 minute group classes were held weekly for 6 weeks. Each class covered a different topic (#1: What is Heart Disease and Understanding Your Risk Factors; #2: How to Get More Exercise; #3: Eat Less Fat and Salt; #4: Enjoy Fruits, Vegetables, & Grains; #5: Maintain A Healthy Weight; #6: Taking Care of Stress and Tension). During the classes, participants watched a video pertaining to the class topic, followed by a discussion, experiential activities, goal-setting, and closing review. Participants were taught about national physical activity guidelines (e.g. 150 minutes of moderate intensity physical activity per week) and diet (e.g. 7 servings of fruits and vegetables per day) recommendations and were encouraged to set a realistic goal based on their current behaviors using the recommendations as a guide. Individual telephone support started after the group classes ended and ran to 10 weeks, biweekly and then monthly (6 total calls). The 15-min phone counseling used a motivational interviewing framework to focus on self-reflection, behavior goals, and problem-solving. In addition to the group classes and phone support calls, participants had to option to attend 4 heart healthy “melas” (festive gatherings) over the course of 12 months that incorporated culturally-salient activities (yoga, healthy cooking with a South Asian chef, aerobic exercise that built on South Asian folk dance, and competitions with prices), which were designed to reinforce healthy behaviors and increase group cohesion and support. Melas were offered over 12 months to capture multiple intervention group cohorts, we assumed only two of the melas occurred prior to the final (6 month) followup for any given intervention cohort. | HD + PA; Total contact hrs: 12.5; Total duration: 4 months | Health educators; Community (classes and melas), home (phone calls) | Usual care: After randomization, all participants were given a primary care referral by CBO staff. In addition to the primary care referral, participants received their baseline screening results and monthly mailing of National Heart, Lung, and Blood Institute’s print education materials on heart disease, diet, exercise, and weight (translated into Hindi and Urdu by academic and CBO staff). Participants were advised to followup with their PCP for further advice.
Kanke, 2015^84^; Fair | IG1 | 12 7-min sessions of diet and physical activity counseling (1 introductory session followed by 11 monthly or bimonthly routine consultations). At the first consultation, the PCP counseled participants on their ideal body weight (BMI 22 kg/m^2^) and weight reduction target (5% of baseline body weight), as well as the positive effect of weight reduction for the participant’s specific disease (dyslipidemia, hypertension, or T2DM). In addition to the counseling, the PCP provided participants with an informational leaflet. Following the first consultation, participants received routine consultations every 1 or 2 months for the participant’s specific disease based on the Japanese guidelines. During these visits, the PCP questioned the participant on key lifestyle factors for weight reduction (i.e., eating, exercising, and weight monitoring) and provided the participant with information on the standard lifestyle changes: (1) reduce calorie intake to 25 kcal/kg ideal body weight/day; (2) eat a well-balanced diet (calorie balance: protein, 10–15%; fat, 20–25%; carbohydrate, 60%); (3) exercise for 20–30 min at least 3 times per week. The physician advice focused on weight reduction adjusted to each participant’s circumstances and lifestyle. Participants were weighed at all consultations. | HD + PA; Total contact hrs: 1.4; Total duration: 12 months | PCP; Primary care | Minimal intervention: Participants received same initial intervention as IG1 at first consultation and usual care was provided at subsequent (every 1–2 month) consultations. The physician was not required to measure body weight or discuss weight reduction at every consultation.
Kastarinen, 2002^85^ (Lifestyle Intervention against Hypertension in Eastern Finland (LIHEF)); Fair | IG1 | 7 individual sessions of individualized diet and physical activity counseling and 2 120-minute group counseling sessions. Intervention goals were to achieve a normal weight (BMI <25 kg/m^2^), sodium intake <5 g daily, <2 alcoholic drinks per day, moderate intensity exercise ≥3 times per week for 30 minutes, and to stop smoking if a smoker. During individual counseling visits with nurses, participants were instructed to change health behaviors on the basis of their individual situation. At each counseling visit, BP and weight were measured and the values, as well as changes in lifestyle factors to be reached before the next study visit, were written down in a followup card. The 2 120-minute group sessions focused on advice targeting reduction of salt intake and overweight. | HD + PA; Total contact hrs: 7.5; Total duration: 21 months | Public health nurses; Primary health care center | Usual care: Participants were instructed to see their primary care providers according to usual care practice.
Keyserling, 1997^86^ (Southeast Cholesterol Project); Fair | IG1 | 3 5–10 min in-person individual diet counseling visits with PCP and referral to 3 30-min in-person individual diet counseling with dietician and 1 reinforcement mailing. Diet counseling was based on the Food for Heart Program which consisted of a Dietary Risk Assessment (DRA), a color and number-coded educational strategy corresponding to the DRA to guide clinician counseling without requiring extensive knowledge of behavior-change theory or food composition, and easy-to-read illustrated patient educational materials that are culturally and regionally specific to the population. Includes identification of major sources of saturated fat and cholesterol and rates the atherogenicity of individual foods, weekly consumption for each food or preparation practice. If LDL-C remained elevated at 4 months, participants were referred to dietician or health educator for up to 3 30-minute sessions where the Food for Heart Program materials were used in greater depth along with other materials as appropriate. If LDL remained elevated at 7 months, the clinician received a prompt (a letter) to consider initiation of drug therapy. A mailing was sent to participants with recipes and health tips at 7 months. | HD only; Total contact hrs: 2; Total duration: 12 months | PCPs; dieticians; health educators; Community and rural health centers, local health department, hospital outpatient services | Usual care: Usual care clinicians were advised to manage their patient’s hypercholesterolemia according to usual practices.
Khanji, 2019^87^ (HAPPY London); Good | IG1 | Diet and physical activity counseling (1 25-min physician-delivered counseling and instructional session and auto-generated personalized web-based counseling). At baseline participants received a 10–15 min physician-delivered personalized face-to-face counseling session on suboptimal lifestyle and cardiovascular risk factors based on guideline recommendations. The counseling was based on a lifestyle questionnaire and baseline measurements, and included advice on factors including blood pressure, cholesterol, glucose readings, smoking, weight, physical activity, fruit and vegetable intake, alcohol intake, and stress. During the same visit, participants received instructions on how to use the website for the HAPPY London web-based tool (5–10 min). The web-based tool provided a personalized score for the participant’s lifestyle, 10-year risk score, and tailored advice and information specifically for the participant’s relevant suboptimal risk factors. Ideal targets were highlighted as goals and updated during the 3 and 6-month visits. Additional regular email reminders were sent to encourage achievement of goals. | HD + PA; Total contact hrs: 0.42; Total duration: 6 months | Study physician; Primary care, home | Usual care: Participants received a 10–15 min physician-delivered personalized face-to-face counseling session on suboptimal lifestyle and cardiovascular risk factors based on guideline recommendations during the baseline visit. The counseling was based on a lifestyle questionnaire and baseline measurements, and included advice on factors including blood pressure, cholesterol, glucose readings, smoking, weight, physical activity, fruit and vegetable intake, alcohol intake, and stress.
Koelewijn-van Loon, 2009^88^ (Improving Patient Adherence to Lifestyle Advice (IMPALA)); Fair | IG1 | 2 (15–20 min) in-person individual diet and physical activity counseling sessions with practice nurse, 1 (10-min) follow-up telephone call, and printed materials. During the first meeting with the practice nurse, a risk communication tool was used with patients to explain 10-year CVD mortality risk. Options for risk reduction were presented to patients with increased risk and a decision aid was provided for review at home. During the second meeting approximately 2 weeks later, the nurse asked questions about the decision aid and asked the patient what they wanted to discuss with the help of an agenda-setting chart. Nurses guided patients in formulating personal goals for lifestyle change, focusing on one or more of smoking, physical exercise, dietary behavior (fruits and vegetables, fat intake), alcohol consumption, and adherence to medical treatment. A follow-up phone call using motivational interviewing was made approximately 2 weeks later to explore the importance of the lifestyle goal, increase patient confidence, and refer to local facilities as necessary. | HD + PA; Total contact hrs: 0.83; Total duration: 1 months | Nurses; General practice | Usual care: Patients received usual care after risk assessment step. [Nurses received a 2-hour training session on risk assessment.]
Kramer, 2018^89^ (Healthy Lifestyle Project); Fair | IG1 | Participant could choose between 16 (1-hr) group lifestyle counseling sessions or 12 (1-hr) individually-viewed lifestyle DVD sessions followed by brief telephone sessions (5-min); both options included health-related handouts, self-monitoring logs, a fat and calorie counter, a pedometer and exercise bands. DVD sessions were made available to participants who missed a group session. Intervention was DPP-based and adapted to a group format with goals to achieve and maintain 7% weight loss and safely and progressively increase to 150 min/wk of moderately intense PA. Participants who chose face-to-face group delivery attended 12 weekly 1-hour sessions; followed by biweekly and then monthly meetings. Participants who chose the DVD watched 1 session each week for 12 weeks and received a brief weekly telephone call to assess weight and PA and ascertain understanding of the program content; these participants were also invited to attend monthly group meetings. | HD + PA; Total contact hrs: 16; Total duration: 6 months | Registered dietitians and exercise specialist; Senior community centers | Waitlist: Received periodic health-related handouts via mail; will begin intervention in 6 months.
Lakerveld, 2013^90^ (HOORN); Fair | IG1 | Participants received a cognitive behavioral program, which combined several elements of both the theory of planned behavior & self-regulation. The intervention was provided by practice nurses in the participating general practices and consisted of six individual 30-min counseling sessions followed by three monthly booster sessions by phone over the period of one year. The counseling techniques included motivational interviewing and problem-solving treatment, with development of SMART goals and implementation plans. The aim of counseling was to increase motivation & ability to change dietary (fruit, vegetable, fiber, alcohol consumption, saturated fat), PA, & smoking behaviors (participants chose which behavior[s] they wanted to focus on). Motivational interviewing & problem-solving treatment were used to help patients find solutions to overcoming barriers & increase perceived control. | HD + PA; Total contact hrs: 4.5; Total duration: 16 months | Practice nurses; Diabetes research center | Usual care: Participants received written information about their risk of developing T2DM and CVD, and existing brochures containing health guidelines regarding physical activity, a healthy diet, and how to stop smoking. Patients with SBP >160 mm Hg and/or hypercholesterolemia (>8 mmol/L) were referred to their GP for additional medication.
Langford, 1991^91^ (Trial of Antihypertensive Interventions and Management (TAIM)); Fair | IG1 | 10 group sessions and 2 individual sessions of lifestyle counseling for weight loss and 6 individual BP medication management visits. Participants additionally randomized to either a diuretic (chlorthalidone 25 mg), a beta-blocker (atenolol 50 mg), or a placebo, as well as counseling for weight loss, consisting of 10 weekly group sessions followed by individual sessions every 6–12 weeks. The weight loss goal was a reduction of 10% of baseline weight or 4.54 kg. In addition, participants had monthly BP management clinical visits, which included (1) blood pressure and weight measurements; (2) review of interim history and symptoms, treatment status, compliance; and (3) dispensing of study drugs. Participants who failed to achieve adequate blood pressure control were stepped up to additional therapy at 6 months or sooner if emergency failure criteria were met. The additional step-up therapy included either 25 mg chlorthalidone or 50 mg atenolol for placebo failures; combined 25 mg chlorthalidone-50 mg atenolol therapy was given to the chlorthalidone or atenolol failures. Medication was increased during the first 6 months if DBP was ≥100 mm Hg for three visits at 2-wk intervals, ≥105 mm Hg at two visits a week apart; or ≥115 mm Hg at any visit. If the additional step-up therapy did not adequately control DBP, open-label therapy (antihypertensive medication) was used. | HD + PA; Total contact hrs: 14; Total duration: 6 months | Nutritionists and therapists (nutritional intervention); NR (medical intervention); NR | Minimal intervention: No further nutritional counseling beyond the initial explanation of the allocation and general consultation provided to all participants. Participants additionally randomized to either a diuretic (chlorthalidone 25 mg), a beta-blocker (atenolol 50 mg), or a placebo. In addition, participants had monthly BP management clinical visits, which included (1) blood pressure and weight measurements; (2) review of interim history and symptoms, treatment status, compliance; and (3) dispensing of study drugs. Participants who failed to achieve adequate blood pressure control were stepped up to additional therapy at 6 months or sooner if emergency failure criteria were met. The additional step-up therapy included either 25 mg chlorthalidone or 50 mg atenolol for placebo failures; combined 25 mg chlorthalidone-50 mg atenolol therapy was given to the chlorthalidone or atenolol failures. Medication was increased during the first 6 months if DBP was ≥100 mm Hg for three visits at 2-wk intervals, ≥105 mm Hg at two visits a week apart; or ≥115 mm Hg at any visit. If the additional step-up therapy did not adequately control DBP, open-label therapy (antihypertensive medication) was used.
Langford, 1991^91^ (Trial of Antihypertensive Interventions and Management (TAIM)); Fair | IG2 | 10 group sessions and 2 individual sessions of nutrition counseling for reducing sodium intake and increasing potassium intake and 6 individual BP medication management visits. Participants additionally randomized to either a diuretic (chlorthalidone 25 mg), a beta-blocker (atenolol 50 mg), or a placebo, as well as nutritional counseling for reducing sodium intake and increasing potassium intake, consisting of 10 weekly group sessions followed by individual sessions every 6–12 weeks. Sodium and potassium goals were individualized by weight and ranged from 52–100 mmol/day for sodium (average 87 mmol/day), and from 62–115 mmol/day for potassium (average 103 mmol/day). In addition, participants had monthly BP management clinical visits, which included (1) blood pressure and weight measurements; (2) review of interim history and symptoms, treatment status, compliance; and (3) dispensing of study drugs. Participants who failed to achieve adequate blood pressure control were stepped up to additional therapy at 6 months or sooner if emergency failure criteria were met. The additional step-up therapy included either 25 mg chlorthalidone or 50 mg atenolol for placebo failures; combined 25 mg chlorthalidone-50 mg atenolol therapy was given to the chlorthalidone or atenolol failures. Medication was increased during the first 6 months if DBP was ≥100 mm Hg for three visits at 2-wk intervals, ≥105 mm Hg at two visits a week apart; or ≥115 mm Hg at any visit. If the additional step-up therapy did not adequately control DBP, open-label therapy (antihypertensive medication) was used. | HD only; Total contact hrs: 14; Total duration: 6 months | Nutritionists and therapists (nutritional intervention); NR (medical intervention); NR | Minimal intervention: No further nutritional counseling beyond the initial explanation of the allocation and general consultation provided to all participants. Participants additionally randomized to either a diuretic (chlorthalidone 25 mg), a beta-blocker (atenolol 50 mg), or a placebo. In addition, participants had monthly BP management clinical visits, which included (1) blood pressure and weight measurements; (2) review of interim history and symptoms, treatment status, compliance; and (3) dispensing of study drugs. Participants who failed to achieve adequate blood pressure control were stepped up to additional therapy at 6 months or sooner if emergency failure criteria were met. The additional step-up therapy included either 25 mg chlorthalidone or 50 mg atenolol for placebo failures; combined 25 mg chlorthalidone-50 mg atenolol therapy was given to the chlorthalidone or atenolol failures. Medication was increased during the first 6 months if DBP was ≥100 mm Hg for three visits at 2-wk intervals, ≥105 mm Hg at two visits a week apart; or ≥115 mm Hg at any visit. If the additional step-up therapy did not adequately control DBP, open-label therapy (antihypertensive medication) was used.
Lee, 2007^92^; Fair | IG1 | Median of 6 sessions of individual in-person and telephone physical activity counseling. Six-month community-based walking intervention delivered by a public health nurse. The intervention involved a series of regular individual contacts, provided through telephone and face-to-face visits in both local community activity centers and participants’ homes according to their preference. The first intervention contact occurred within one month of randomization. The primary aim of the intervention was to increase the frequency and time participants spent walking. Participants were provided with a pedometer, walking log, and advice about regular walking based on established PA guidelines. The intervention was individualized according to each participant’s baseline exercise stage of change. Content areas for discussion for each participant varied, but mainly included perceived benefits of increased walking, ideas for overcoming perceived barriers and sharing practical information gleaned from others about pleasant walking routes and pedometer usage. More frequent contacts were arranged during the first three months of the intervention period in order to facilitate and reinforce regular walking and less frequently during the last three months. | PA only; Total contact hrs: 3; Total duration: 6 months | Public health nurse; Community centers, home | Usual care: Participants received usual primary health care involving self-initiated contact with health services as required.
Liira, 2014^93^; Fair | IG1 | Participants received a one-time 90-minute health promotion check-up delivered by a public health nurse. The nurse used a type 2 diabetes risk assessment form (produced by the Finnish Diabetes Association) and a cardiovascular risk assessment (produced by the Finnish Heart Association). The intervention included an assessment of individual risks, dietary habits, physical activity, and a motivational talk about those health habits. If participants had elevated blood sugar, total cholesterol >7.0 mmol/L, uncontrolled hypertension, or another reason for medical assessment, the nurse referred them to a physician for consideration of medication. In addition to the intervention, participants received usual care at a municipal public primary care unit where, if necessary, they were referred to a PCP. | HD + PA; Total contact hrs: 1.5; Total duration: 0.03 months | Public health nurses; Primary care | Usual care: Participants received usual care at a municipal public primary care unit where, if necessary, they were referred to a PCP. Participants were offered the health counseling intervention after the study period.
Migneault, 2012^94^; Fair | IG1 | Prior to randomization, participants had an in-home visit for health education, which consisted of a 75-page resource manual that described hypertension, listed dietary recommendations, heart healthy food recipes, and local resources for exercise, and provided information to support antihypertensive medication adherence. In addition to the resource manual, all participants received a 20-minute education session based on the content of the manual and were given a pedometer and digital weight scale. Following randomization, a Telephone-Linked Care- automated system delivered three tailored behavior intervention modules using social-cognitive theory, transtheoretical model of behavioral change, and motivational interviewing. The intervention was culturally tailored, both matching intervention materials and messages to include familiar or preferred people, places, languages, music, food locations, and clothing and incorporating cultural values, social, historical, and psychological forces relevant to African American populations. The first three calls introduced targeted behaviors, how they help with blood pressure control, and oriented users to the system. Subsequent calls were modules on medication adherence (8 calls), physical activity (12 calls), and diet (9 calls, covering fruits and vegetables, fiber, sodium, and fat). Each call consisted of a (1) introduction; (2) section for reporting health information collected on study-issued home measurement devices (pedometers, sphygmomanometers, weight scales); (3) theory-based interactive education and counseling on the targeted behavior. The physical activity module focused on increasing moderate or greater intensity physical activity. The diet module focused on fruits/vegetables, fiber, sodium, and fat and intended to promote the Dietary Approaches to Stop Hypertension (DASH) diet. Participants and their primary care providers received printouts of their tracked health behaviors, which were sent at the beginning and end of each of the three behavioral modules and were designed to reinforce the intervention. | HD + PA; Total contact hrs: 8.3; Total duration: 8 months | NA (automated phone system), PCP; Home | Minimal intervention: Prior to randomization, participants had an in-home visit for health education, which consisted of a 75-page resource manual that described hypertension, listed dietary recommendations, heart healthy food recipes, and local resources for exercise, and provided information to support antihypertensive medication adherence. In addition to the resource manual, participants received a 20-minute education session based on the content of the manual and were given a pedometer and digital weight scale.
Moreau, 2001^95^; Fair | IG1 | Participants were given a pedometer to wear throughout the day for a 1- to 2-wk period before beginning the 24-wk walking program in order to document preintervention daily lifestyle walking activity. Participants wore the pedometer on their belt or waistband as soon as they awoke in the morning, removed it before going to bed each night, and recorded the number of steps they accumulated each day. Participants were provided with a target number of steps that could lead to a 3-km increase in daily walking. The target steps were added onto their baseline step value to prevent a decline in their current daily lifestyle activity. Initially, all women were prescribed a distance of 1.4 km per day above their baseline walking during week 1. Distance was then increased by 0.5 km per day until the desired walking distance was achieved by the third week. Participants were instructed to walk at a self-selected comfortable pace and were allowed to accumulate their steps in whatever pattern best fit their lifestyle. Other than walking, subjects were asked not to make any changes in their current lifestyle activities. | PA only; Total contact hrs: 0; Total duration: 6 months | NR; Home | No advice: Participants were given a pedometer to wear throughout the day for a 1- to 2-wk period before beginning the 24-wk walking program in order to document preintervention daily lifestyle walking activity. Participants were asked not to change daily activity and subsequently wore a pedometer 1 wk each month to document their walking.
Moy, 2001^96^; Fair | IG1 | Participants received individualized instructions to lower fat intake (based on Adult Treatment Panel III guidelines), focusing on total fat consumption and daily monitoring (usually a goal <40 g total fat). Participants were initially given a total “fat allowance” based on their intake at baseline and were taught how to read food labels, use fat counter to monitor and record total daily fat intake. Self-monitoring logs were used to record daily fat intake. Participants were seen individually and with family members every 6–8 weeks to reinforce the diet, evaluate dietary compliance, and measure lipids. Physicians were asked to explicitly not to manage dietary interventions as recommended based on results and feedback from baseline screening. At each visit, a dietary fat screening instrument was used to identify potential problems. Counseling was individualized based on initial dietary habits, lifestyles, and progress. | HD only; Total contact hrs: 14; Total duration: 24 months | Nurse; NR | Usual care: Participants received usual care from a primary care physician. Physicians received patient-specific recommendations from results and feedback from the baseline screening for risk factor management on three occasions.
Muhlhauser, 1993^97^ (Hypertension Treatment and Teaching Program (HTTP)); Fair | IG1 | Participants received 4 consecutive weekly group 60–90 min counseling sessions, for groups of 4–6 participants. The objectives of the intervention were: assumption of greater responsibility for disease management, including blood pressure self-monitoring and treatment decision making; confirming the diagnosis of hypertension and treatment using at home blood pressure monitoring; and emphasis on non-pharmacological treatments. The first session focused on group discussions and patients were provided with blood pressure monitors and logbooks. During the second session, blood pressure monitoring and logbooks were assessed, as well as strategies for achieving blood pressure control (including dietary and physical activity recommendations; details of dietary advice NR). The last two sessions began with a presentation and discussion about participants’ experiences with nutrition, weight change, and blood pressure self-monitoring. Participants discussed their experiences and fears related to the side effects of antihypertensive drug therapy during the third session. Information leaflets about drugs currently used by the participants were discussed, as well as possibilities of avoiding side effects of blood pressure lowering therapy. Participants following non-drug treatment regimens were encouraged to try to reduce the dosages of their antihypertensive drugs. If indicated, drug therapy was started by the physician at the end of the third session. During the fourth session, the effects of antihypertensive drug therapy on blood pressure control was discussed, as well as psychological aspects and smoking. | HD + PA; Total contact hrs: 6; Total duration: 1 months | Physicians and practice staff; Primary health care | Minimal intervention: Physicians and staff at CG practices received the same training on BP measurement as those in IG practices but did not deliver HTTP intervention. Additionally, 20 patients at each CG site had their medical files marked with a red dot to remind clinic staff to take BP, weight, and medication information at each visit.
Murphy, 2012^98^ (National Exercise Referral Scheme (NERS)); Fair | IG1 | 3 individual in-person sessions of physical activity counseling with 2 telephone calls focused on relapse prevention and discounted access to 1-on-1 exercise instruction or group classes. The initial consultation with the exercise professional included a lifestyle questionnaire, health check, motivational interview and physical activity goal setting using patient-centered approach, and introduction to leisure centers (sporting/community centers). The primary goal was to achieve 30 min of moderate physical activity on ≥5 days/week. Participants were given discounted access to 1-on-1 exercise instruction or group classes (£1 per session). Two telephone followups were made at 4 weeks and 8 months to review goals and prevent relapse. At 16 weeks, an individual consultation included review of goals, motivational interview, health check, lifestyle questionnaire, and advice on continuing with exercise after the program. At 12 months, a program review was held with a repeat of the health check and a fitness stop test. | PA only; Total contact hrs: 2; Total duration: 12 months | Exercise professional; Leisure center, home (phone) | Waitlist: Usual care and a leaflet highlighting the benefits of exercise and including a website address listing locations of local leisure facilities.
Neil, 1995^99^; Fair | IG1 | Participants attended a 30-minute appointment with a dietitian the general practice at which a standard diet history was taken and participants were given individual advice on their dietary habits and weight. Participants were advised to reduce the percentage of total dietary energy from fat to 30% or less; consume up to 10% of energy from saturated, monounsaturated, and polyunsaturated fatty acids; 50–60% energy derived from carbohydrates, protein 10–20%; daily intake of <300 mg cholesterol; 35 g fiber. Participants met with the dietitian at a 10-minute followup appointment where further dietary advice was given. | HD only; Total contact hrs: 0.67; Total duration: 2 months | Dietitian; General practice clinic | Usual care: Participants received a pamphlet containing dietary guidance consistent with advice provided by dietitian. Additional written advice was provided after 2 months.
Neil, 1995^99^; Fair | IG2 | Participants attended a 30-minute individual appointment with the study nurse at which they were advised to make changes in food intake to reduce the amount of total and saturated fat; increase amount of dietary fiber and complex carbohydrates. Habitual diet was estimated by prescored food frequency questionnaire that combined groups of food with similar nutrient content and dietary use and assigned each group a score proportional to the fat or fiber content of standard portion size. The total score and pattern of individual food sources used to suggest specific changes in food choices. Participants met with the nurse at a 10-minute followup appointment where further dietary advice was given. | HD only; Total contact hrs: 0.67; Total duration: 2 months | Nurse; General practice clinic | Usual care: Participants received a pamphlet containing dietary guidance consistent with advice provided by dietitian. Additional written advice was provided after 2 months.
Niiranen, 2014^100^; Fair | IG1 | 3 sessions of diet and physical activity counseling (2 30-min individual counseling sessions and 1 60-min group session) and 5 PCP BP medication management calls that included individualized lifestyle advice. Lifestyle guidance from nurse during two 30-min individual counseling sessions held at 4-week intervals and at a 60-min group session of 10–12 participants held 4 weeks later. In addition, written instructions were distributed to the participants. During the counseling sessions, participants were instructed to avoid added salt, use low-salt food ingredients, increase intake of fruits, vegetables, and berries, favor unsaturated fat over saturated fat, use low-fat dairy products, eat fish for 1–2 meals per week, exercise at least 3 hours per week, lose weight if necessary, and use no more than moderate amounts of alcohol. The lifestyle goals were: (i) BMI 5% among the obese (body mass index ≥30 kg/m^2^); (ii) >180 minutes per week of moderate-intensity physical activity; (iii) daily intake of 3/3.5 grams of dietary potassium for women/men; (v) smoking cessation; (vi) 1% of daily energy intake from omega-3 fatty acids; and (viii) daily intake of ≤3 drinks of alcohol for men and ≤2 drinks for women. In addition to the lifestyle counseling, the participants’ antihypertensive treatment was guided by systematic home BP measurements. The target BP was home BP <135/83 mm Hg. Participants self-measured their BP at 0, 3, 6, 9, and 12 months and additionally 1 month after any changes in their medication. The BP readings were mailed to the treating physician, and the participant was contacted by phone. During the calls, results of the participant’s lifestyle questionnaire (on exercise, nutrition, alcohol use, and smoking; administered at 0, 3, 6, 9, and 12 months) were examined at the same time, and lifestyle guidance was given. Face-to-face PCP appointments were scheduled if deemed necessary, and if home BP was greater than the target pressure, the drug therapy was intensified. Physicians had free choice of which medications to use, but they had been educated on rational drug choices and combinations. | HD + PA; Total contact hrs: 3.25; Total duration: 12 months | PCPs and nurses; Primary care, home | Usual care: No intervention was offered to patients or staff at the control site. No contact between the control group and the study organization occurred between the baseline examinations and the follow-up examinations at 12 months, and hypertension treatment continued according to conventional practice.
Nolan, 2018^101^ (Reducing Risk with E-based Support for Adherence to Lifestyle Change in Hypertension (REACH)); Fair | IG1 | Participants were contacted by email weekly for months 1 to 4, biweekly for months 5 to 8, and monthly for months 9 to 12. Each email contained an e-link to lifestyle counseling activities including videos, online handouts, and monitoring forms to help participants with blood pressure management. Initially, participants assessed their stage of readiness to adhere to self-care according to the Transtheoretical Model. Then they selected their behavior change priority from a list that included exercise, diet, smoke-free living, and adherence to antihypertensive medications. Motivational components helped participants by validating their initial stage of readiness, build their readiness by guiding them to select a goal that matched their readiness stage, reinforcing their active and collaborative role in the intervention, and helping them resolve ambivalence for change by linking their behavior change goal to a salient personal priority. For participants with elevated readiness, cognitive-behavioral strategies reinforced their efficacy for initiating and sustaining change by (1) educating them about how to set manageable behavioral goals for self-care adherence, (2) outlining progressive steps in the change plan for self-care, (3) facilitating performance-based feedback with self-monitoring tools for BP and self-care behavior, (4) providing rewarding feedback about progress in initiating or sustaining behavior change, (5) maintaining virtual peer support and positive behavioral modeling via video material, and (6) reviewing guidelines to manage stress to sustain therapeutic change in self-care. The 14 intervention videos developed for the e-counseling sessions included (1) expert-type presentations with self-help guidelines for adhering to self-care behavior; (2) an unscripted discussion among peers that provided positive role modeling and guidance as they spoke about how heart healthy living was connected to their personal priorities and how they managed barriers to change; and (3) dramatic vignettes that reflected and validated participant experiences as fictional characters learned to accept the diagnosis of hypertension and then as they planned and carried out lifestyle changes with the support of a healthcare professional or peer. | HD + PA; Total contact hrs:; Total duration: 12 months | NA (counseling fully automated); Home | Minimal intervention: Participants received the same amount of automated emails as intervention group participants, but were instead linked to publicly available content on self-help skills for managing BP from the resource section of the Blood Pressure Action Plan of the Heart and Stroke Foundation of Canada. Participants were also permitted to log into the Heart and Stroke Foundation website to access heart healthy recipes, as well as e-tools and self-monitoring forms to track BP and changes in self-care behaviors.
Ogedegbe, 2014^102^ (Counseling African Americans to Control Hypertension (CAATCH)); Fair | IG1 | Intervention comprising three components: (1) interactive computerized self-paced programmed instruction (4 modules) for educating patients about the causes, complications and treatment of HTN; expected side effects of medications, and methods for adoption of lifestyle changes; (2) home BP monitoring; and (3) individual and group behavioral counseling sessions on the adoption of lifestyle modifications conducted by trained study staff, community health center dieticians and health educators. The content of the computer tutorial is based on two NHLBI publications, “Your Guide to Lowering Blood Pressure” and “Facts about the DASH Eating Plan”. The tutorial is broken down into several modules that are written at an appropriate reading level. The computer program gives patients control of the pace of learning and they are asked questions on the material and given feedback to verify their understanding of the material. For home BP monitoring, participants received an automated home BP monitor and instructions on its use. Participants were encouraged to record their weekly BP readings (twice daily, three times per week) in a diary that they brought with them to each study visit. The behavioral counseling involved six monthly group behavioral counseling sessions on adoption of recommended lifestyle modifications conducted by trained community health center staff and/or study staff (nutritionists, nurses, and health educators). Behavior change strategies involved motivational interviewing, goal setting, problem solving, stimulus control, cognitive strategies, and self-monitoring. The specific behavior goals set in collaboration with the patients included dietary changes, weight loss, reduction of sodium intake, increased physical activity, moderation of alcohol intake, and adherence to prescribed BP medications. In addition to the patient intervention, their primary care providers received monthly onsite continuing medical education based on the Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure guidelines; HTN case rounds; and quarterly chart audits of their patient office BP readings. They were also provided quarterly feedback on the values of their patient’s home BP readings, which were obtained from the patient diaries. | HD + PA; Total contact hrs: 6; Total duration: 6 months | Nutritionists, nurses, and health educators (from study and community health center), physicians; Community health center | Minimal intervention: Participants received a single HTN patient education session plus printed versions of the NHLBI patient education material, “Your Guide to Lowering Blood Pressure” and “Facts about the DASH Eating Plan”. Primary care providers received print versions of the Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure guidelines.
Reid, 2014^103^; Fair | IG1 | The heart health intervention included feedback about the results of the baseline and 3 month assessments; goal setting; 17 counseling sessions with a health educator; and the communication of reports and recommendations to the participant’s PCP. Counseling sessions occurred weekly for the first 12 weeks, and then at weeks 16, 20, 26, 39, and 52. The first 2 counseling sessions were 45-min; the remaining 15 were 15–20-min long. All counseling sessions were delivered via phone except for the second counseling session, which was delivered in-person. During the first two sessions, participants received feedback about their risk levels relative to recommendations. The health educators helped participants set goals for reducing their risks and create action plans. An assessment summary and indications for the participant’s medical care were mailed to their PCP. Medical care was suggested if the participant’s BP or lipid levels exceeded threshold values (BP >140/90 mm Hg; LDL-C >2.0 mmol/L and Framingham Risk Score (FRS) 20%; LDL-C 3.5 mmol/L and FRS 10–19%; or LDL-C >5.0 mmol/L and FRS <10%). Participants received printed materials about smoking cessation, healthy eating, weight management, and physical activity. During sessions 3–12, 16, 20, 26, 39, and 52, the health educators engaged participants in a dialog about progress toward their goals and recommended strategies to overcome any barriers. During the week 16 session, participants received results from their 3 month assessment. The summary of this assessment and recommendations for medical care were mailed to the participant’s PCP. | HD + PA; Total contact hrs: 6.5; Total duration: 12 months | Health educators; Tertiary care cardiac center | Usual care: Participants received printed materials about smoking cessation, healthy eating, weight management, and physical activity. A report was sent to their PCP if the critical thresholds for BP or lipids were exceeded.
Rodriguez, 2012^104^; Fair | IG1 | 6 monthly telephone sessions of diet, medication, and physical activity counseling individualized based on stage of change. Stage of change, decisional balance, and self-efficacy was evaluated at each session for diet, physical activity, and medication adherence, and a computer system was used to deliver standardized interventions. Calls covered problem solving; tips and information for each behavior; and review of a medication log (participants used a calendar to track medication use). Diet counseling focused on low sodium and total fat intake, high intake of fruits and vegetables and low or nonfat dairy products. | HD + PA; Total contact hrs: 1.5; Total duration: 6 months | Counselors (Master’s degree or higher in psychology or social work); Home | Usual care: Participated in in-person assessment visits only
Rodriguez-Cristobal, 2012^105^; Fair | IG1 | 24 sessions of individual lifestyle counseling on diet, PA, and smoking cessation (12 physician-delivered in-person sessions and 12 psychologist follow-up calls). Psychologists made phone calls to remind intervention group of upcoming physician visits (every 2 months) and to provide encouragement about maintaining lifestyle changes. Participants who smoked were motivated to give up smoking and received clear and tailored advice as well as medication when indicated. For physical activity, participants received advice to start, maintain, or increase their current level of physical activity. Participants with overweight or obesity (BMI 25–30 and ≥30 kg/m^2^, respectively) received advice on gradual weight loss (0.51 kg per week) and maintaining a healthy diet after healthy weight achieved with the objective of achieving a BMI 20–25 kg/m^2^. Participants with hypertension received dietary and pharmacological treatment according to guidelines with the objective of achieving BP <7%. | HD + PA; Total contact hrs: 9; Total duration: 24 months | Physician, psychologist; Primary care | Usual care: Participants received standard advice from their physician about their lifestyle (diet, physical activity, smoking cessation) according to current practice guidelines.
Rosas, 2015^106^ (Vivamos Activos Fair Oaks (VAFO)); Good | IG1 | Participants received a case management intervention based on DPP and Heart to Heart trial tailored to local population plus home visits by community health workers. Intervention consisted of 12 group sessions (2 hrs) and 4 individual (30 min) sessions in the intensive phase (12 months) followed by 3 group sessions and 1 individual session in the maintenance phase (months 13–24). Key intervention components included motivational interviewing, building self-management and goal setting skills, proving hands-on cooking and physical activity demonstrations, fostering self-efficacy, leveraging group-based social support, identifying community resources, and coordinating with primary care providers. Take-home items included pedometers, exercise CDs, and free weights. Individual sessions focused on individualized goal setting based on the patient’s stage of behavior change, problem solving, medical and social service referrals. Participants also received 5 community health worker (CHW) home visits in the intensive phase and 2 CHW visits in the maintenance phase. Visits were semi-structured to allow the CHW to facilitate behavioral changes relevant to participant and their household, family, and neighborhood (e.g., navigating an obesogenic environment, fostering family support, enhancing participant success in food negotiations, mapping out neighborhood walking routes, using participant-taken photos of food/PA as triggers for goal setting and problem-solving. | HD + PA; Total contact hrs: 36; Total duration: 24 months | Research staff & community health workers; Community health center, home | Usual care: Routine primary care follow-ups with potential for referral to lifestyle counseling within a specialized diabetes clinic.
Rosas, 2015^106^ (Vivamos Activos Fair Oaks (VAFO)); Good | IG2 | Participants received a case management intervention based on DPP and Heart to Heart trial tailored to the local population. The intervention consisted of 12 group sessions (2 hrs) and 4 individual (30 min) sessions in the intensive phase (12 months) followed by 3 group sessions and 1 individual session in the maintenance phase (months 13–24). Key intervention components included motivational interviewing, building self-management and goal setting skills, proving hands-on cooking and physical activity demonstrations, fostering self-efficacy, leveraging group-based social support, identifying community resources, and coordinating with primary care providers. Take-home items included pedometers, exercise CDs, and free weights. Individual sessions focused on individualized goal setting based on the patient’s stage of behavior change, problem solving, medical and social service referrals. | HD + PA; Total contact hrs: 32.5; Total duration: 24 months | Research staff; Community health center | Usual care: Routine primary care follow-ups with potential for referral to lifestyle counseling within a specialized diabetes clinic.
Rubinstein, 2016^107^; Good | IG1 | 12 20–30 min telephone sessions of diet and physical activity counseling, 48 followup text messages, and an informational leaflet about healthy lifestyles. After a short introductory call, each participant received monthly motivational interviewing calls to their personal mobile phone by a trained nutritionist over 12 months. Each call focused on one of four target behaviors (reduction of dietary sodium intake, reduction of high-fat and high-sugar food intake, increase in fruit and vegetable intake, and promotion of physical activity). Each participant’s readiness to change a specified behavior was assessed by the caller, and the conversation was tailored to that behavior. Only one behavior change target, agreed to by the participant, was addressed in each call, but each of the four behaviors had to be discussed in the first four calls. For the remaining eight calls, participants could choose to discuss any of the four target behaviors, a strategy based on the motivational interviewing principle of autonomy support. Each call was followed by a weekly text message with contents related to the target behaviors and readiness to change that had been addressed in the previous call. Up to five text messages were sent per month. The information obtained during the calls was entered into a web-based platform to customize the set of weekly text messages delivered to the participant in the following month. In addition to the calls and text messages, participants received a leaflet with written information about the adoption of healthy lifestyles. | HD + PA; Total contact hrs: 6; Total duration: 12 months | Nutritionists; Home | No advice: Participants received a leaflet with written information about the adoption of healthy lifestyles. No further information was provided.
Salisbury, 2016^108^; Good | IG1 | In addition to usual NHS care, participants received support from the Healthlines service, which is a multifaceted intervention incorporating a range of strategies to address the various components of the TECH conceptual model. The conceptual model emphasizes self-management (including using established approaches such as goal-setting, self-monitoring, information-sharing, decision-making, relapse prevention and regular review), optimization of treatment (particularly titration of medications following protocols), coordination of care between providers, and methods designed to enhance engagement of patients and GP. The intervention was based around regular telephone calls form a health advisor, supported by patient-specific tailored algorithms and standardized scripts generated through a computerized behavioral management program. The program included the following series of modules: knowledge about CVD risk and healthy lifestyles; review of drugs and side effects; optimization of drugs for BP lowering; home BP monitoring; review of statins; support for drug adherence; smoking and nicotine replacement therapy; healthy eating; weight loss and Orlistat; alcohol use; and exercise. The standardized scripts generated by the software were based on principles of behavior change (e.g., stimulus control, problem solving, cognitive restructuring, and goal setting). During the first call, health advisors discussed with participants their health needs and agreed on specific goal. Thereafter, participants received one call monthly for one year. Participants were also provided with access to a Healthlines web portal where they could obtain further information about CVD, access other online resources, request a call-back from Healthlines staff, see copies of letters sent to their GP, and use a BP monitoring system. Participants with baseline SBP ≥140 mm Hg were offered a validated home BP monitor by their practice nurse, requested to take their BP twice daily for the first week and weekly thereafter, and to upload their readings to the Healthlines portal. Using these readings, participants were automatically advised by the portal whether their BP was too high or too low. At each telephone contact, health advisors reviewed average BP meetings, and participants with above target readings were instructed to see their doctor to review their treatment. Advisors sent an email to the GP, attaching details of the participant’s recent BP readings and a summary of guidelines from NICE about recommended steps for intensifying treatment. | HD + PA; Total contact hrs: 3.6; Total duration: 12 months | Health advisors; Home | Usual care: Participants continued to receive care normally provided by the NHS (management of CVD risk factors by primary care clinicians, including, in some cases, referral to community services for advice about smoking cessation and weight management).
Schoenthaler, 2016^109^ (Individual Motivational Interviewing - Therapeutic Lifestyle Changes (MINT-TLC)); Fair | IG1 | 13 sessions of diet and physical activity counseling (10 60–90 minute group sessions and 3 30-min individual phone sessions). In addition to standard treatment recommendations as determined by their physicians, participants received an intervention based on established clinical practice guidelines for prevention and treatment of hypertension, which recommends weight loss (if overweight), regular physical activity, limiting and/or reducing sodium and alcohol intake, and eating a low-fat diet that is rich in fruit and vegetables. Stress management and medication adherence were also addressed. Participants attended 10 weekly classes over 12 weeks (intensive phase) followed by monthly, individual telephone-based motivational interviewing sessions for 3 months (maintenance phase). The intensive phase involved 60–90 minute group classes conducted by health educators, focusing on developing skills, goal-setting and generating strategies for behavior change as well as support for relapse prevention. Each session followed a similar structure and included the following components: 1) Overview of HTN and antihypertensive medications; 2) DASH eating plan 3) Goal setting and healthy living diaries; 4) Serving sizes, portion control and food labels (with emphasis on sodium monitoring); 5) Physical activity; 6) Building skills for meal planning and shopping; 7) Recipe modification and eating away from the home; 8) Stress Management; 9) Eating triggers and mindful eating; and 10) Planning for lasting change. The monthly 30-minute individual telephone-based sessions were also conducted by health educators with the purpose of helping participants focus on problem-solving, goal setting, and prevention of relapse with regard to each of the therapeutic lifestyle changes adopted during the intensive phase. The sessions focused on tailoring the intervention strategies to the participant’s individual needs and consisted of: 1) assessing the participant’s motivation and confidence in engaging in a given behavior; 2) eliciting barriers and concerns about adoption of each lifestyle modification; 3) summarizing in a non-threatening manner the pros and cons of the participant’s concerns; 4) providing a menu of options to the patient based on the nature of the barriers elicited by the patient; 5) assessing each participant’s values and goals. Each session ended with a global summary of what was discussed and a clarification of an agreed upon action plan. | HD + PA; Total contact hrs: 16.5; Total duration: 6 months | Health educators; Hospital, home | Minimal intervention: In addition to standard treatment recommendations as determined by their physicians, participants received a 30-minute individual counseling session on lifestyle modification, as well as content on stress management and medication adherence. Participants also received printed versions of the MINT-TLC intervention material.
Scott, 2018^110^; Fair | IG1 | 7 sessions of physical activity counseling (2 1-hr in-person sessions and 5 15–30 minute phone sessions). In-person sessions occurred at weeks 1 and 12 and telephone sessions were delivered in weeks 2–4, 6, and 8. During the sessions, eight theory-derived determinants were targeted: PA outcome expectations, PA outcome experiences, PA outcome expectations–experiences discrepancy, values, exercise barrier self-efficacy, social support and coping skills. MI was the underpinning counseling approach used to influence motivation, self-efficacy and discrepancies/ambivalence. A toolkit of 36 cognitive behavioral techniques derived from a taxonomy and a previous study were tailored to the individual. These included: providing information on consequences of behavior in general and to the individual; providing information about others’ approval; goal setting (behavior); goal setting (outcome); action planning; setting graded tasks; prompt review of behavioral goals; prompt review of outcome goals; prompt rewards contingent on effort or progress toward behavior; providing rewards contingent on successful behavior; shaping; prompt generalization of a target behavior; prompt self-monitoring of behavior; prompt self-monitoring of behavioral outcome; prompting focus on past success; providing feedback on performance; providing information on where and when to perform the behavior; providing instruction on how to perform the behavior; model/demonstrate the behavior; teach to use prompt cues; environmental restructuring; behavioral contract; prompt practice; use of follow-up prompts; facilitating social comparison; plan social support/social change; prompt identification as role mode/position advocate; prompt anticipated regret; fear arousal; prompt self-talk; prompt use of imagery; relapse prevention/coping planning; and stress management/emotional control training. | PA only; Total contact hrs: 4.5; Total duration: 3 months | PhD-level psychologist; NR (in-person sessions), home (phone sessions) | Usual care: Participants received usual care and no additional PA support throughout the study. Usual care participants received a one-hour feedback session on questionnaire results after the study ended.
Soto Rodriguez, 2016^111^; Fair | IG1 | Three 90-min interactive group educational workshops on the prevention of CVD, recommending the adoption and maintenance of healthy habits that favor a change in lifestyle. The importance of following a Mediterranean diet was emphasized, reducing consumption of saturated fats, sugar and alcohol, and increasing consumption of plant foods and foods rich in polyunsaturated fats. The three workshops were held over one week in groups of 15 participants. | HD only; Total contact hrs: 4.5; Total duration: 0.25 months | NR; Health care | No advice: Participants received a brochure mailed to their address with the information on the same subjects covered in the intervention group.
Stefanick, 1998^112^ (Diet and Exercise for Elevated Risk (DEER)); Fair | IG1 | Dietary recommendations, based on the goals of the NCEP Step 2 diet (less than 30 percent total fat, less than 7 percent saturated fat, and less than 200 mg of cholesterol per day), were presented to the subjects by registered dietitians. Participants entered a 12-week adoption phase in which an individualized counseling session was followed by eight one-hour, mixed-sex group lessons on replacing dietary sources of saturated fat with complex carbohydrates, low-fat dairy foods, and other alternatives, including lean meats. Weight loss was not emphasized in the group sessions, which averaged 15 persons per group. A six-to-eight-month maintenance phase consisted of monthly contacts with study dietitians, by mail or telephone or in group or private meetings. | HD only; Total contact hrs: 12.5; Total duration: 11 months | Registered dietitians; Research clinic, home | No advice: Participants were instructed to maintain usual diet and exercise.
Stevens, 2003^113^; Fair | IG1 | 2 45-min sessions of individual diet counseling (including 20-min computer assessment) and 2 10-min followup phone calls. The intervention combined motivational interviewing, problem-solving and social cognitive theory strategies. The first session described the overall goals: reduction in dietary fat and increased consumption of fruits, vegetables, and whole grains. Feedback was provided on baseline fat, fruit, and vegetable consumption relative to goals and participants were asked to select one or two goals for the first session. If dietary fat was selected, then a 20-minute touch-screen computer-assisted assessment provided feedback on fat intake and other dietary patterns based upon the modified Fat and Fiber Behavior Questionnaire. Participants then answered questions about their personal barriers to dietary change and were helped to select tailored strategies to address those barriers. An automated touch-screen program produced a personalized printout which the interventionist then reviewed with the participant. The participant took the printout with them in addition to nutrition education materials. Participants not selecting dietary fat at the first session received an individually tailored counseling session focused on increasing consumption of fruits, vegetables, and whole grains. At the second visit 2–3 weeks later, participants reported on their progress toward achieving their goals. If they had not selected dietary fat as a target in the first intervention session, they then completed the automated program described above. Those who completed the automated program in the first session were encouraged to focus on increasing fruit and vegetable consumption. The focus was on the parts of their personal eating pattern they were most willing to change, and on the barriers encountered. During this session, participants had made commitments to work on several dietary changes and identified personally tailored behavior change strategies for each. Two 5- to 10-min calls after the second session provided ongoing support and checks on participants’ behavior change plans. | HD only; Total contact hrs: 1.83; Total duration: 2 months | Health counselors; Research clinic | Attention control: Participants received an intervention focused on breast self-exam, which included a 9 minute American Cancer Society video, self-help pamphlets, barriers-based problem solving counseling regarding interest and motivation for conducting regular breast self-exam.
Svetkey, 2008^114^ (Weight Loss Maintenance (WLM)); Good | IG1 | All participants had successfully lost ≥4 kg in phase 1 of a 6-month nonrandomized initial weight loss intervention prior to enrollment. Phase 2, the maintenance portion, included monthly 5–15 minute phone sessions and every 4th month, a 45–60 individual face-to-face contact. Each contact began with self-reported or measured weight (for face-to-face contacts), review of progress, number of days a food diary was kept, frequency of weighing, average minutes of exercise, progress on additional goals and action plans, and problem-solving. Contacts provided opportunities to discuss barriers to weight loss maintenance and plans to overcome those barriers. The intervention reinforced key theoretical constructs (motivation, support, problem solving, relapse prevention). Participants were encouraged to continue adherence to the recommended dietary pattern and to increase moderate physical activity to at least 225 min per week.; Phase 3: At 30 months, 3 of 4 sites started an extended followup period for an additional 30 months. The extended intervention consisted of 4 weekly group sessions followed by monthly phone contacts that followed the same general content as in Phase 2. 98 of participants from IG1 were re-randomized to ongoing contact, 98 participants from IG1 were randomized to no contact, and 47 participants were not re-randomized (19.3% of participants from IG1 at participating sites opted-out of extended F/U; 11.4% of participants from CG at participating sites opted out of phase 3). In the extended F/U, the IG participants randomized to further contact vs no contact showed no differences so were combined in the analysis. | HD + PA; Total contact hrs: 12.75; Total duration: 60 months | Research interventionist; NR | Minimal intervention: Printed lifestyle guidelines with diet and physical activity recommendations at randomization and met briefly with a study interventionist after 12-month data collection visit.
Svetkey, 2008^114^ (Weight Loss Maintenance (WLM)); Good | IG2 | Unlimited access to a website designed to support weight loss maintenance and were encouraged to log in at least once per week. Participants were required to record their weight upon logging into the website. The website provided a number of intervention elements, including social support using a bulletin board feature, record-keeping tools, tracking options, accountability, diet and exercise information, and tailored feedback. The website also included interactive training modules that addressed problem solving and motivation. If participants missed a self-scheduled contact, they were sent an email reminder that was repeated after another week of no contact. If there was no response to the 2 email prompts, participants received 2 weekly automated telephone calls. If participants didn’t log into the website after that, they were contacted by study staff, who encouraged them to return to the website.; IG2 participants were not part of the phase 3 extended F/U. | HD + PA; Total contact hrs: 0; Total duration: 30 months | NA; Home | Minimal intervention: Printed lifestyle guidelines with diet and physical activity recommendations at randomization and met briefly with a study interventionist after 12-month data collection visit.
Svetkey, 2009^115^ (Hypertension Improvement Project (HIP)); Fair | IG1 | Participants received both the physician intervention (MD-I) and the patient intervention (Pt-I). For the MD-I, physicians received two 45-minute online training modules (Continuing Medical Education) aimed at Joint National Committee-7 guidelines and lifestyle modification for blood pressure control. An evaluation and treatment algorithm summarizing the major Joint National Committee-7 guidelines and formatted as a decision tree (laminated, color-coded, pocket-sized) was provided to each physician. Assessment and quarterly feedback was provided to physicians on their adherence to guidelines, including lifestyle counseling that assessed the proportion of patients with hypertension whose blood pressure was controlled, proportion not at goal, the proportion that received lifestyle counseling, the proportion with diabetes or chronic kidney disease who were at goal blood pressure and prescribed a thiazide diuretic or angiotensin-converting enzyme inhibitor/angiotensin receptor blocker, and comparisons of physicians with peers. For the Pt-I, patients received an intervention consisting of 20 weekly group sessions followed by 12 monthly phone contacts. The weekly group sessions focused on behavior change using the following strategies: frequent contact, group interaction and social support, goal setting and self-monitoring, identification of barriers and problem solving, and motivational interviewing. The behavior goals of Pt-I included weight loss if overweight, the Dietary Approaches to Stop Hypertension (DASH) dietary pattern, increased moderate-to-vigorous physical activity, reduced sodium intake, and moderation of alcohol intake. In addition, the intervention promoted adherence to antihypertensive medication regimen. Participants kept records of dietary intake, physical activity, and medication use. The group sessions and the participant manual emphasized diet, physical activity, and changing behaviors. Community health advisors attended and helped to lead group sessions and also provided one-on-one monthly telephone counseling during and after the group session period. | HD + PA; Total contact hrs: 24.5; Total duration: 18 months | Behavioral interventionists and community health advisors, PCP; Physician: Clinic, Patients: At or near participant’s clinic site | Usual care: Participants had a brief PC visit after randomization during which they received advice and brochures on lifestyle modification for blood pressure control consistent with Joint National Committee-7.
Svetkey, 2009^115^ (Hypertension Improvement Project (HIP)); Fair | IG2 | Participants received an intervention consisting of 20 weekly group sessions followed by 12 monthly phone contacts. The weekly group sessions focused on behavior change using the following strategies: frequent contact, group interaction and social support, goal setting and self-monitoring, identification of barriers and problem solving, and motivational interviewing. The behavior goals of Pt-I included weight loss if overweight, the Dietary Approaches to Stop Hypertension (DASH) dietary pattern, increased moderate-to-vigorous physical activity, reduced sodium intake, and moderation of alcohol intake. In addition, the intervention promoted adherence to antihypertensive medication regimen. Participants kept records of dietary intake, physical activity, and medication use. The group sessions and the participant manual emphasized diet, physical activity, and changing behaviors. Community health advisors attended and helped to lead group sessions and also provided one-on-one monthly telephone counseling during and after the group session period. | HD + PA; Total contact hrs: 23; Total duration: 18 months | Behavioral interventionists and community health advisors; At or near participant’s clinic site | Usual care: Participants had a brief PC visit after randomization during which they received advice and brochures on lifestyle modification for blood pressure control consistent with Joint National Committee-7.
Svetkey, 2009^115^ (Hypertension Improvement Project (HIP)); Fair | IG3 | Physicians received two 45-minute online training modules (Continuing Medical Education) aimed at Joint National Committee-7 guidelines and lifestyle modification for blood pressure control. An evaluation and treatment algorithm summarizing the major Joint National Committee-7 guidelines and formatted as a decision tree (laminated, color-coded, pocket-sized) was provided to each physician. Assessment and quarterly feedback was provided to physicians on their adherence to guidelines, including lifestyle counseling that assessed the proportion of patients with hypertension whose blood pressure was controlled, proportion not at goal, the proportion that received lifestyle counseling, the proportion with diabetes or chronic kidney disease who were at goal blood pressure and prescribed a thiazide diuretic or angiotensin-converting enzyme inhibitor/angiotensin receptor blocker, and comparisons of physicians with peers. | HD + PA; Total contact hrs: 1.5; Total duration: 18 months | NA (Physicians trained); Clinic | Usual care: Participants had a brief PC visit after randomization during which they received advice and brochures on lifestyle modification for blood pressure control consistent with Joint National Committee-7.
Ter Bogt, 2009^116^ (Groningen Overweight and Lifestyle (GOAL)); Good | IG1 | Participants completed a lifestyle questionnaire and had at least one visit with their general practitioner (GP) to discuss results of the baseline assessment and start treatment according to the GP’s guidelines. Participants then received nurse-practitioner (NP)-led physical activity and healthy diet counseling consisting of individual sessions focused on self-awareness, lifestyle education, individual motivation, and goal-setting. During the four individual sessions, the NP was guided by a standardized computer program that contained instructions on lifestyle counseling defined by international guidelines and allowed data entry of the measurements. The aim of the intervention was to achieve persistent lifestyle changes and prevent weight gain. Participants developed a tailored treatment plan based on goals. Ongoing evaluation of goals by nurse practitioners during sessions; modification of goals, as needed, as well as possible referral to dietician. Diet was assessed via food diaries and physical activity was measured using pedometers. Following the in-person sessions, the NP called participants to give them feedback on their lifestyle by critiquing their food diary, physical activity (pedometer), baseline questionnaires, and discussed finishing their treatment plan. During the second and third year, participants had one individual session with the NP and received two feedback phone calls per year. | HD + PA; Total contact hrs: 7.25; Total duration: 36 months | General practitioner, nurse practitioner; Primary care, home | Usual care: Participants were offered one GP consultation to discuss the results of their baseline measurements and thereafter received usual care by a GP according to national GP guidelines.
Tiessen, 2012^117^ (SPRING (Self-monitoring and Prevention of RIsk Factors by Nurse practitioners in the region of Groningen)); Fair | IG1 | 1 20-minute individual session with practice nurse using motivational interviewing and 6–12 follow-up visits with the number of follow-up visits determined by the presence of risk factors. Follow-up visits based on self-monitoring results (pedometer, scale, BP device). The first session was based on SCORE risk assessment, present risk factors and corresponding treatment goals. The number, length, and interval of follow-up visits was tailored to participants risk factors and the order in which risk factors were addressed depended on the participant’s preference and stage of change. Quitting smoking was the first treatment goal if applicable. Adapted motivational interviewing was used to help participants recognize and change unhealthy behavior. Overweight participants received a food diary, home weight scale, step diary, and pedometer, and were followed up three times at monthly intervals followed by 3-monthly intervals. Participants with low physical activity received a step diary and pedometer and were followed up three times at monthly intervals followed by 3-monthly intervals. Participants with hypertension received home blood pressure monitoring and medication with monthly follow-up. Participants with dyslipidemia received medication and follow-up at three-month intervals. Participants with current smoking were followed up monthly until planned date of quitting, and after that at increasing intervals. Any medication adjustments were made by nurse under supervision of GP. | HD + PA; Total contact hrs: 2.13; Total duration: 12 months | Trained nurses; Primary care | Minimal intervention: 1 20-minute individual session with nurse using motivational interviewing. The first session was based on SCORE risk assessment, present risk factors and corresponding treatment goals. Standard information leaflets were given to participants based on overweight, smoking, and physical activity status. More counseling or referral for these risk factors given only on patient’s request. After the initial visit, participants had follow-up visits based on the Dutch HTN and hypercholesterolemia guidelines if these risk factors were present.
Toft, 2008^118^ (Inter99); Fair | IG1 | Participants were offered three types of counseling: a smoking cessation course, a smoking reduction course, and a course on diet and physical activity counseling. Dietary recommendations included reducing fat intake (to 30% of energy/day); at least 300 g fish per week; at least 600 g fruit and vegetables (diabetics advised to limit fruit to maximum 3 pieces/day) per day; increase consumption of complex carbohydrates and dietary fiber; limit alcohol intake to 14/21 [F/M] units/week; limit salt consumption for participants with high blood pressure; and limit energy consumption for obese participants. For physical activity, participants were advised to engage in at least 30 min of moderate physical activity per day. Recommendations were adjusted over the 5-year intervention period, but were generally consistent over time. The choice of group depended on risk factors and the preference of the individual. Those who were not ready to decide whether or not they wanted to participate in group counseling were encouraged to consider the invitation and were contacted by mail after 3 months and offered participation in a group. Relatives of participants were offered to participate in 1 of the meetings. After 1 and 3 years, individuals still fulfilling high-risk criteria were again offered group counseling. Groups were led by a nurse or dietitian and included didactic and open-ended discussion and participants committing to specific diet and PA goals; dietary and physical activity advice mirrored advice in individual sessions. In group sessions, the general physical activity aim was to achieve small positive changes in physical activity in everyday life.; Participants also received same health assessment and 45-min (baseline) or 15-min (years 1,3,5) individual counseling session provided to control participants. | HD + PA; Total contact hrs: 14; Total duration: 60 months | Doctors, nurses, and dietitians; Research center | Minimal intervention: Assessment and individual counseling at baseline, 1, 3, and 5 years. Based on a personal risk assessment, each participant received an individual ‘lifestyle counseling talk’ focusing on smoking, PA, diet and alcohol. Counseling addressed all individuals who smoked, had 14 drinks/week for women and >21 for men. Written materials provided as appropriate. Overall goal was to achieve small but sustained dietary changes. Specifically, decreasing total SF intake, substituting SF for unsaturated fat, and increasing intake of F/V and fish. Participants advised to aim for 4 hours/week PA (some papers report 30 mins/day); only minimal counseling time spent on PA. Participants were re-invited after 1 and 3 years for risk assessment and counseling and at 5 years for a short finishing lifestyle counseling.
TOHP I CRG, 1992^119^ (Trials of Hypertension Prevention Phase I (TOHP I)); Good | IG1 | The intervention consisted of group educational sessions supplemented by individual counseling. Demonstrations and practice were incorporated into each meeting. There was a 3-month initial (intensive) period consisting of 10 weekly sessions (8 group and 2 individual) lasting 90 minutes each. Interventions focused on shopping, cooking, and food selection behaviors aimed at reducing sodium intake. The individual sessions focused on a goal to reduce 24-hour sodium intake to 60 mmol (1400 mg). Food diaries were provided to participants and used to facilitate self-monitoring of sodium intake; intervention staff reviewed and commented on food diaries. 16 followup sessions offered after intensive intervention. Followup was implemented to provide continued information, support, and counseling through telephone, mail and at minimum, bimonthly in-person group or individual meetings (90 minutes each) throughout the trial.; Participants were guided through a behavioral change process that focused on action goals and implementation steps specific to social, emotional, or practical problems encountered in sodium reduction. Group meetings included discussions to generate peer support and share effective strategies for achieving sodium-related behavior changes. Additional motivational strategies included special presentations about the importance of and rationale for the study and incentives in the form of food products and cooking demonstrations, and as some sites, contests (low-sodium “cook-offs”) or door prizes at group meetings. | HD only; Total contact hrs: 39; Total duration: 18 months | Registered dietitian and psychologist or exercise psychologist; Research center | Usual care: Participants received usual care.
TOHP I CRG, 1992^119^ (Trials of Hypertension Prevention Phase I (TOHP I)); Good | IG2 | Participants attended an individual counseling session followed by 14 weekly 90 minute group sessions (intensive phase), which were followed by monthly group meetings (extended intervention). Sessions presented information basic nutrition, social eating, self-management techniques, exercise demonstrations, supervised exercise, and relapse prevention. Participants reviewed progress and made plans for the next week. During the extended intervention participants had the option of monthly group sessions, group weigh-in session, individual weigh-in sessions, and individual counseling sessions according to individual needs. Food diaries were kept for the first 14 weeks and reviewed by nutrition staff who provided comments. Participants were asked to make a moderate reduction in total energy intake with the goal of achieving gradual weight loss not to exceed 0.9 kg (2 lb) a week with intake to not to fall below 1200 kcal. After reaching weight loss goal they were asked to adjust intake to maintain weight. Participants were encouraged maintain a graph of weight change from baseline and record daily exercise time as a bar graph. Participants were encouraged to increase activity, principally through walking at least 20 minutes 3 times per week. As intervention progressed, they were asked to adopt moderate exercise of 4 to 5 days per week between 30–45 minutes with an intensity of 40–55% of heart rate reserve.; Behavioral self-management strategies employed included setting reasonable short-term goals, formulating specific plans of action to achieve these goals, developing reinforcement and social support for each major element of the plan, keeping records to assess progress, and regularly evaluating and modifying action plans. Small group sessions took place at every group where participants shared their goals and progress and worked on/problem-solved specific and detailed goals for the following week. Relapse prevention was also discussed and strategies developed. | HD + PA; Total contact hrs: 36.5; Total duration: 18 months | Registered dietitian and psychologist or exercise psychologist; Clinical center | Usual care: Participants received usual care.
TOHP II CRG, 1997^120^ (Trial of Hypertension Prevention II (TOHP II)); Good | IG1 | 57 weight loss and sodium reduction counseling sessions (1 individual introductory session, 14 90-min weekly group sessions, 6 90-min biweekly group sessions and 3–6 “minimodules” consisting of up to 6 sessions each [36 available sessions], and optional participant-initiated individual counseling sessions. Goal was to achieve ≥4.5 kg weight loss and mean sodium intake of ≤80 mmol/L with the aim to achieve goals during initial 6 months and to maintain goal thereafter. Behavioral objectives for weight loss intervention emphasized reducing caloric intake by decreasing consumption of excess fat, sugar, and alcohol and included daily food diaries and encouragement of moderately increasing physical activity. The physical activity goal was to gradually increase moderate intensity activity to 30–45 min per day, four to five days per week. Intervention was delivered in four phases. The pre-intensive phase consisted of one individual counseling session to prevent weight gain prior to initiation of group sessions. The intensive phase followed with 14 weekly 90-min group meetings led by dietitians or health educators and focused on core knowledge and skills for weight loss and sodium reduction. After the 14-week intensive phase, the transitional phase consisted of participants attending 6 biweekly group meetings and then monthly group meetings. Beginning in the 18th month, participants were offered optional individual counseling sessions and special group sessions focused on selected weight loss and sodium reduction topics. The program covered behavioral self-management, nutrition education, information on PA, social support, self-monitoring (food diaries and graphs of PA), goal-setting with action plans, strategies for situations that trigger problem eating. | HD + PA; Total contact hrs: 48.5; Total duration: 36 months | Centrally trained staff (dietitians, psychologists, or health counselors); Research clinic | No advice: Assessment only, received no further intervention.
TOHP II CRG, 1997^120^ (Trial of Hypertension Prevention II (TOHP II)); Good | IG2 | 57 weight loss counseling sessions (1 individual introductory session, 14 90-min weekly group sessions, 6 90-min biweekly group sessions and 3–6 “minimodules” consisting of up to 6 sessions each [36 available sessions], and optional participant-initiated individual counseling sessions). Goal was to achieve ≥4.5 kg weight loss with the aim to achieve goal during initial 6 months and to maintain goal thereafter. Behavioral objectives for weight loss intervention emphasized reducing caloric intake by decreasing consumption of excess fat, sugar, and alcohol and included daily food diaries and encouragement of moderately increasing physical activity. The physical activity goal was to gradually increase moderate intensity activity to 30–45 min per day, four to five days per week. Intervention was delivered in four phases. The pre-intensive phase consisted of one individual counseling session to prevent weight gain prior to initiation of group sessions. The intensive phase followed with 14 weekly 90-min group meetings led by dietitians or health educators and focused on core knowledge and skills for weight loss. After the 14-week intensive phase, the transitional phase consisted of participants attending 6 biweekly group meetings and then monthly group meetings. Beginning in the 18th month, participants were offered optional individual counseling sessions and special group sessions focused on selected weight loss topics. The program covered behavioral self-management, nutrition education, information on PA, social support, self-monitoring (food diaries and graphs of PA), goal-setting with action plans, strategies for situations that trigger problem eating. | HD + PA; Total contact hrs: 48.5; Total duration: 36 months | Centrally trained staff (dietitians, psychologists, or health counselors); Research clinic | No advice: Assessment only, received no further intervention.
TOHP II CRG, 1997^120^ (Trial of Hypertension Prevention II (TOHP II)); Good | IG3 | 53 sodium reduction counseling sessions (1 individual introductory session, 10 90-min weekly group sessions, 6 90-min biweekly group sessions and 3–6 “minimodules” consisting of up to 6 sessions each [36 available sessions], and optional participant-initiated individual counseling sessions). The group goal was average sodium intake ≤80 mmol/24h, and the individual goal was sodium intake ≤70 mmol/24h with the aim to achieve goals during initial 6 months and to maintain goal thereafter. Intervention focused on identifying sodium content of foods, preparing lower sodium foods, modifying recipes, and making lower sodium food selections at and between meals and when eating out; taste-testing, making small, progressive sodium intake changes; alternatives to high-sodium eating behaviors; general behavioral modification and relapse prevention techniques, including self-monitoring of sodium intake; and feedback on food records and urinary sodium excretion. Intervention was delivered in four phases. The pre-intensive phase consisted of one individual counseling session. During this phase, the primary goal was to provide participants with core knowledge and behavioral skills necessary to make and maintain reductions in sodium intake. The intensive phase followed with 10 weekly 90-min group meetings led by dietitians or health educators and focused on core knowledge and skills for reducing dietary sodium. After the 10-week intensive phase, the transitional phase consisted of participants attending 6 biweekly group meetings and then monthly group meetings. A transitional phase consisting of 4 monthly sessions was designed to prevent relapse and to ease transition from weekly to less frequent contacts. The final extended phase was to maintain participants’ behavior changes. As a routine, this included 1 to 2 monthly contacts and a series of 3 to 6 refresher sessions that was offered on intervention-related topics to promote contact and adherence with the intervention. | HD only; Total contact hrs: 42.5; Total duration: 36 months | Centrally trained staff (dietitians, psychologists, or health counselors); Research clinic | No advice: Assessment only, received no further intervention.
Tomson, 1995^121^; Fair | IG1 | 6 sessions diet counseling, including 3 sessions with primary care physician and 3 sessions with dietician (1 individual, 1 with spouse, and 1 group session with trip to grocery store). Counseling intervention aimed at non-pharmacological management of high cholesterol. The first session with the dietician involved a diet history and individualized suggestions for dietary modification based on the ‘Step I’ diet, which recommended: total fat <30% of calories, ratio of polyunsaturated fat to saturated fat of 1.0, dietary cholesterol <200 mg/day, and caloric restriction to achieve desirable weight. Spouses were invited to the second dietician session, and the third dietician session was a small group trip to the grocery store to learn how to identify low-fat and high-fiber foods. | HD only; Total contact hrs: 3; Total duration: 12 months | PCP, dietician; Medical center | Usual care: Results of screening were communicated to participant by letter from GP explaining that cholesterol values were too high and therapy is to modify diet. A booklet with diet information was sent with the letter and dietary recommendations based on the patient’s weight were included. For those who were overweight: increase fiber and decrease fat intake to 30% of total daily calories. For those of healthy weight: focus on switching to mono and polyunsaturated fats. If participant had to visit health center for other reasons during the intervention period, there was no restriction on discussion of hypercholesterolemia.
van der Veen, 2002^122^ (Nijmegen Family Practices Monitoring Project (NFPMP)); Fair | IG1 | Maximum of 3 10-minute family physician nutrition counseling sessions with referral to dietician for 3 sessions (initial consultation of 30–40 minutes and 10–15 minutes for second and third consultation). Stages-of-change-based intervention with content tailored to participant’s stage; the intervention stopped if no progress was made to the next stage or relapse to former stage. Participants in the precontemplation stage received feedback on baseline dietary intake, lipids, and anthropometry as well as a counseling session focused on raising awareness of dietary behavior and a fill-in-at-home worksheet. Participants in the contemplation stage were given feedback on baseline measures and a counseling session focused on motivation to change dietary behavior and a list of food substitutions. Participants in the action stage received feedback on baseline measures and counseling session focused on practical behavior changes for reducing saturated fat and increasing unsaturated fat, and advised to reduce total energy and total fat if high in body weight. Additional counseling sessions in the action stage included discussion of progress and barriers, discussion of results of second measurements, and expectations. | HD only; Total contact hrs: 1.7; Total duration: 2.5 months | Family physician; dietician; Family practice | Usual care: No details provided
van Keulen, 2011^123^ (Vitalum); Fair | IG1 | Participants received four 20-minute telephone calls based on motivational interviewing on physical activity, and fruit/vegetable consumption. During each call, the counselor assessed the participant’s current behaviors and progress, summarized the participant’s behavior based on a participant profile generated from a questionnaire; discussed public health guidelines related to participant’s health behaviors; assessed and enhanced motivation and self-efficacy for behavior change; assessed readiness to change. Half of the participants in each group received pedometers at week 29 (along with instructions to gradually increase their number of steps to 10,000 per day) and the remainder received one after the last followup. | HD + PA; Total contact hrs: 1.3; Total duration: 10 months | Counselors (students of Health Education and Health Promotion, Mental Health Sciences, or Psychology); Home | Usual care: After the intervention period, participants received one tailored letter addressing physical activity and fruit/vegetable consumption based on results from previous followup questionnaire.
van Keulen, 2011^123^ (Vitalum); Fair | IG2 | Participants received both tailored print communication and two 20-minute telephone-based motivational interviewing calls. One letter and 1 call focused on physical activity; the other two focused on fruit/veggie consumption. Half of the participants in each group received pedometers at week 29 (along with instructions to gradually increase their number of steps to 10,000 per day) and the remainder received one after the last followup. | HD + PA; Total contact hrs: 0.67; Total duration: 10 months | Counselors (students of Health Education and Health Promotion, Mental Health Sciences, or Psychology); Home | Usual care: After the intervention period, participants received one tailored letter addressing physical activity and fruit/vegetable consumption based on results from previous followup questionnaire.
van Keulen, 2011^123^ (Vitalum); Fair | IG3 | Participants received four tailored letters based on baseline and followup survey data (variables included current behavior, awareness, age, gender, stage of change, attitude, self-efficacy expectations, and action plans): letters 1 & 3 focused on physical activity (3–6 pages) and letters 2 & 4 focused on fruit and vegetable consumption (4–6 pages). Letters included feedback on the targeted behavior and stage-matched advice to change behavior. Letters 3 and 4 reinforced tailored feedback on behavioral progress based on intermediate survey data. Half of the participants in each group received pedometers at week 29 (along with instructions to gradually increase their number of steps to 10,000 per day) and the remainder received one after the last followup. | HD + PA; Total contact hrs: 0; Total duration: 10 months | NA; Home | Usual care: After the intervention period, participants received one tailored letter addressing physical activity and fruit/vegetable consumption based on results from previous followup questionnaire.
van Sluijs, 2005^124^ (Physician-based Assessment and Counseling for Exercise (PACE)); Fair | IG1 | Participants had 2 visits with their provider and 2 “booster” followup phone calls with a PACE counselor. At the initial visit patients met with their general practitioner or nurse practitioner for a 10-minute consultation to discuss the patients’ medical condition(s), to offer advice about becoming more physically active, and to assess their stage of change for physical activity, using the PACE physical activity program materials, which included a stage-specific protocol to guide the clinician. The goal of PACE intervention was to “promote long-term participation in regular physical activity by altering social and psychological factors known to influence physical activity, such as social support, increased self-efficacy, reduced perceived barriers, and increased awareness of the benefits of physical activity”. After initial visit, 1 follow-up visit with provider (4 weeks), where they focused on stage-specific protocols and checked in on participant progress. At 4 wk visit physical activity counselors offered new counseling protocol for those who had either progressed or regressed through stages of change. PACE physical activity counselors (separate from general practitioner/nurse practitioner) provided 2 “booster” phone call consultations (2 and 8 weeks after initial provider visit), to offer support and resolve possible problems or questions. | PA only; Total contact hrs: 0.83; Total duration: 2 months | GP/NP and PA counselor; Clinic, home (phone) | Usual care: GPs discussed patient’s current level of physical activity and, as appropriate, encouraged patient to become more active. Standard text on physical activity promotion was provided.
Viglione, 2019^125^ (Goals for Eating and Moving (GEM)); Fair | IG1 | 13 sessions of diet and physical activity counseling delivered by health coaches (1 60-min in-person counseling session and 12 25-min coaching calls) and an average of 2.3 counseling sessions with PCP. Participants attended an hour-long baseline visit with a health coach, in which the health coach provided an overview of the tablet-delivered GEM tool, as well as instructions for using the pedometer and food/physical activity diary. Health coaches also used the baseline visit to counsel participants, using motivational interviewing techniques, to explore motivation and barriers for losing weight, increasing physical activity, and making dietary changes. Participants were encouraged to attend MOVE! Sessions (weight management program comprised of support and skill-building lessons focused on self-monitoring, diet, physical activity, and weight loss for veterans seen at the VA). Participants used the GEM tool at baseline to answer a series of questions and complete a goal-setting algorithm, which the tool used to generate tailored educational materials (SMART goal worksheets, standardized MOVE! Handouts, information on health resources, GEM summary report), which were given to participants in a binder as a personalized care plan. Following the baseline visit, participants received up to 12 25-minute coaching calls in which health coaches reminded them to use food records and pedometers three days prior to each coaching session. Health coaches documented their encounters in the participant’s medical record with a note to generate a clinical reminder for the PCP. PCPs were trained on the GEM tool, supporting participant goals and addressing barriers, the role of the health coach, and the electronic clinical reminders. PCPs were asked to discuss goal and address barriers, communicate with health coaches, and document weight loss counseling. | HD + PA; Total contact hrs: 6.6; Total duration: 12 months | Health coaches (trained students), PC team; Primary care (baseline and PCP visits), home (calls) | Usual care: Participants received a printed flyer about MOVE! and a “VA Healthy Living” brochure from a health coach. The pamphlet covered screening tests and immunizations, stress management, tobacco and alcohol use, and physical activity. Handouts encouraged participants to discuss goals with their PCPs.
Voils, 2013^126^ (CouPLES); Fair | IG1 | 9 phone counseling sessions for the patient and 9 phone counseling sessions for their spouse. Patient phone sessions addressed goal-setting and problem solving and the topic was selected by the patient at the beginning of the call from among: diet, physical activity, patient-physician communication, and medication adherence. In the first session, patients and spouses received information about hypercholesterolemia and an overview of self-management principles. Spouses also received an orientation on strategies to support patient goal achievement. Subsequent phone sessions allowed each patient to choose a behavior on which to focus and set their own goals and action plans according to what they felt they could accomplish. Spouse calls occurred within one week of patient calls and included a review of patients’ success in meeting previous goals; spouses were asked to create a behavior plan for supporting achievement of new goals. For diet and physical activity goals, spouses were asked if they planned to make the same changes that patients planned to make. Patients selected diet for 51% of calls and physical activity for 49% of calls. Spouses agreed to make the same changes as patients in 97% of calls in which the patient sets dietary change goals and 65% of calls in which the patient set exercise goals. The patient–physician communication topic was only selected for 2 calls, and the medication management topic was never selected. | HD + PA; Total contact hrs: 3.5; Total duration: 11 months | Research nurse; Home | Minimal intervention: Clinical management of lipid disorders using Adult Treatment Panel III guidelines. Reminders for physicians were embedded in 11 emails, electronic medical records, and performance measures. Emails emphasized the use of lipid lowering medications. Physicians also had access to 2 referral clinics: a subspecialty lipid clinic for difficult to manage cases and a subspecialty risk factor management clinic that enrolled high-risk patients whose LDL-C was above goal. These clinics provided lifestyle behavior counseling, medication management, and followup.
Wadden, 2011^127^ (Practice-based Opportunities for Weight Reduction at the University of Pennsylvania (POWER-UP)); Good | IG1 | Participants whose weight was less than 113.4 kg were prescribed a balanced diet of 1200 to 1500 kcal per day (1500 to 1800 kcal per day for participants who weighed 113.4 or more), which consisted of approximately 15 to 20% kcal from protein, 20 to 35% kcal from fat, and the remainder from carbohydrates. All participants were instructed to gradually increase their PA to 180 min/week and were given a pedometer, a calorie-counting book, and handouts from Aim for a Healthy Weight. Attended quarterly 10–15 min PCP visits, at which they reviewed their health status and were provided handouts from Aim for a Healthy Weight. In addition, participants attended monthly visits with a medical assistant (referred to as lifestyle coach [LC]), who delivered abbreviated DPP treatment. Participants attended 14 LC visits in year 1, followed by 12 LC visits in year 2. During month 1, this included 2 counseling visits to learn how record food and calorie intake in diaries provided. Visits began with a weigh-in and then a review of food intake, PA and other goals prescribed in monthly handouts. In year 2, they were permitted, every other month, to complete counseling visits by telephone (although <5% of visits were made by telephone).; The intervention views participants as active problem solvers who are capable of regulating their affect, behavior, and cognition. Self-monitoring is used to identify times, places, emotions, people, and events associated with eating (or exercising) appropriately or inappropriately. Goal setting is facilitated by specifying behaviors to be adapted and when, where, how, and with whom they will be performed. Behavior change is reinforced by increased self-efficacy, by the inherent rewards in reaching a goal (i.e., weight loss or improved fitness), by social support (including encouragement from medical personnel) or by the use of external rewards.; The intervention will include other traditional lifestyle modification topics (e.g., challenging negative thoughts, obtaining social support), most of which will be accompanied by a homework assignment to be completed before the next visit with the Lifestyle Coach. An important behavior will be having participants weigh themselves at least once a week and record their weight. Participants who do not have access to a scale for weekly weigh-ins will be provided an inexpensive bathroom scale. | HD + PA; Total contact hrs: 6.9; Total duration: 24 months | Medical assistant (lifestyle coach) and PCP; Primary care | Minimal intervention: Participants attended eight quarterly 5–7 min PCP visits to review their weight change and to discuss information in the Aim for a Healthy Weight handouts. Same dietary and PA goals as IG.
Whelton, 1998^128^ (Trial of Nonpharmacologic Interventions in the Elderly (TONE)); Good | IG1 | (Limited to patients with obesity) 25 sessions of individual and group counseling over 8 months, followed by 28 monthly maintenance sessions, focused on reducing dietary sodium intake to ≤1800 mg per day and achieving weight loss of ≥10 lbs. Weight loss was to be achieved by a caloric deficit from both dietary restriction and increased physical activity. Withdrawal of antihypertensive medication was a goal for all participants and was initiated 3 months after the first group counseling session. Counseling interventionists provided information using both centrally and locally prepared materials, motivated participants to make and sustain long-term lifestyle changes, monitored individual and group progress at frequent intervals, and helped participants customize intervention to meet individual needs. Centrally prepared materials included food counters, scorekeepers, manuals, and audiovisual aides. Intervention consisted of 3 phases (intensive, extended, and maintenance). Primary goal during intensive phase was to provide core knowledge and behavior skills necessary to achieve and maintain reductions in sodium reduction and body weight. During extended phase, focus was on problem solving and relapse prevention. During maintenance phase, continued attempts were made to maintain or re-engage participant interest in the intervention. Telephone and mail contacts are suggested in the protocol during the maintenance phase without specific details provided. | HD + PA; Total contact hrs: 49.5; Total duration: 36 months | Nutritionists and exercise counselors; Academic health center | Minimal intervention: Usual care groups received no study-related counseling in lifestyle change techniques but were invited to meetings on topics unrelated to diet, physical activity, and cardiovascular disease.
Whelton, 1998^128^ (Trial of Nonpharmacologic Interventions in the Elderly (TONE)); Good | IG2 | (Limited to patients with obesity) 25 sessions of individual and group counseling over 8 months, followed by 28 monthly maintenance sessions, focused on achieving weight loss of ≥10 lbs. Weight loss was to be achieved by a caloric deficit from both dietary restriction and increased physical activity. Withdrawal of antihypertensive medication was a goal for all participants and was initiated 3 months after the first group counseling session. Counseling interventionists provided information using both centrally and locally prepared materials, motivated participants to make and sustain long-term lifestyle changes, monitored individual and group progress at frequent intervals, and helped participants customize intervention to meet individual needs. Centrally prepared materials included food counters, scorekeepers, manuals, and audiovisual aides. Weight loss group received information on techniques and group practice in safe low-level exercise. Intervention consisted of 3 phases (intensive, extended, and maintenance). Primary goal during intensive phase was to provide core knowledge and behavior skills necessary to achieve and maintain reductions in body weight. During extended phase, focus was on problem solving and relapse prevention. During maintenance phase, continued attempts were made to maintain or re-engage participant interest in the intervention. Telephone and mail contacts are suggested in the protocol during the maintenance phase without specific details provided. | HD + PA; Total contact hrs: 49.5; Total duration: 36 months | Nutritionists and exercise counselors; Academic health center | Minimal intervention: Usual care groups received no study-related counseling in lifestyle change techniques but were invited to meetings on topics unrelated to diet, physical activity, and cardiovascular disease.
Whelton, 1998^128^ (Trial of Nonpharmacologic Interventions in the Elderly (TONE)); Good | IG3 | 25 sessions of individual and group counseling over 8 months focused on reducing dietary sodium intake to ≤1800 mg per day, followed by 28 monthly maintenance sessions. Withdrawal of antihypertensive medication was a goal for all participants and was initiated 3 months after the first group counseling session. Counseling interventionists provided information using both centrally and locally prepared materials, motivated participants to make and sustain long-term lifestyle changes, monitored individual and group progress at frequent intervals, and helped participants customize intervention to meet individual needs. Centrally prepared materials included food counters, scorekeepers, manuals, and audiovisual aides. Intervention consisted of 3 phases (intensive, extended, and maintenance). Primary goal during intensive phase was to provide core knowledge and behavior skills necessary to achieve and maintain reductions in sodium and body weight. During extended phase, focus was on problem solving and relapse prevention. During maintenance phase, continued attempts were made to maintain or re-engage participant interest in the intervention. Telephone and mail contacts are suggested in the protocol during the maintenance phase without specific details provided. | HD only; Total contact hrs: 49.5; Total duration: 36 months | Nutritionists and exercise counselors; Academic health center | Minimal intervention: Usual care groups received no study-related counseling in lifestyle change techniques but were invited to meetings on topics unrelated to diet, physical activity, and cardiovascular disease.
Wister, 2007^129^; Good | IG1 | 2 30-minute phone sessions (4 additional 20–30 minute sessions for smokers) of diet and physical activity counseling and 3 mailings. The mailing consisted of an initial report card with CVD risk profile and mailings of counseling summaries and educational materials after each phone session. The report card was sent to the participant and primary care provider, with the participant’s risk profile. The Framingham risk score was used to calculate global CVD risk. The first phone session occurred about 10 days after receiving their risk profile, followed by another phone session approximately 6 months later. A letter grading system (A, B, C, D, F) was developed for the risk scores, which guided recommendations. Smoking was considered top priority for lifestyle counseling, followed by physical activity, dietary habits, weight management and stress. Counselors addressed the areas where the grade was lowest first and comparisons with previous report cards were discussed with the participant to set new goals. Smokers prepared to quit received additional 20- to 30-minute sessions at 2, 4, 8 and 12 weeks according to US and Canadian guidelines. Summaries of each counseling session and supporting evidence-based educational materials were mailed to the participants. | HD + PA; Total contact hrs: 1; Total duration: 12 months | Clinical lifestyle counselors (were also kinesiologists); Home | Usual care: Participants received usual care from their physicians, based on their own determination of the need for visits.
Wong, 2015^130^; Good | IG1 | 1 3–5 min physician-delivered usual care session and 1 25-min dietitian-delivered DASH diet counseling session. Usual care consisted of a 3–5 minute physician-delivered counseling session based on a standard pamphlet for hypertensive patients used in all public primary care clinics in Hong Kong. Participants were educated on (i) the definition and nature of hypertension; (ii) the diagnosis of Grade 1 hypertension with its associated complications; (iii) causes of hypertension; the clinical tests needed for annual assessment; and (iv) non-pharmacological approaches to control BP (i.e., smoking cessation, reduction in alcohol use, maintenance of body weight, regular PA, balanced diet [low salt and low fat], and adequate rest). The DASH diet counseling session was delivered by a dietitian and included information about the nature of DASH, benefits, major components, and individualized meal plan tailored to Chinese culture. Participants were encouraged to achieve individualized DASH diet goals, with regard to higher intake of fruits (4–5 serves/day) and vegetables (4–5 serves/day), low-fat dairy products (2–3 serves/day), lean meats, poultry, and fish (≤6 serves/day), and nuts, seeds, and legumes (4–5 serves/week), while limiting the intake of sweets and added sugars (≤5 serves/week), and fats and oils (2–3 serves/day). Practical tips for decreasing salt intake were also emphasized, and participants were given an educational pamphlet on the DASH diet. Dietician checked all patients for comprehension of DASH advice offered and provided clarification to hose with inquires. | HD only; Total contact hrs: 0.5; Total duration: 0.03 months | Physician and dietitian; Primary care | Usual care: Participants received usual care consisting of a 3–5 minute physician-delivered counseling session based on a standard pamphlet for hypertensive patients used in all public primary care clinics in Hong Kong. Participants were educated on (i) the definition and nature of hypertension; (ii) the diagnosis of Grade 1 hypertension with its associated complications; (iii) causes of hypertension; the clinical tests needed for annual assessment; and (iv) non-pharmacological approaches to control BP (i.e., smoking cessation, reduction in alcohol use, maintenance of body weight, regular PA, balanced diet [low salt and low fat], and adequate rest). No advice was given on the DASH diet.
Wood, 2008^131^ (EUROACTION); Fair | IG1 | Individual nurse assessment with personal report card and family support pack plus 8 group workshops of diet, PA, and risk factor counseling. Motivational interviewing, stages of change, and family support were used to help participants and their partners achieve risk factor and lifestyle targets which included: not smoking, saturated fat 400 g/day, fish >20 g/day, oily fish >3 times/week, alcohol < 6.1 mmol/L (good glycemic control in diabetics); those with BMI >25 kg/m^2^ had a goal to reduce weight by 5% in 1 year. A pedometer was used to motivate PA. Nurse monitored BP, lipids, and glucose and reviewed results with physicians to treat to targets. Nurses educated families about medications to improve adherence. | HD + PA; Total contact hrs: 8; Total duration: 4 months | Nurses; family doctors; General practice center | Usual care: Centers randomized to usual care were informed that they would be audited. No other details reported.

Abbreviations: DPP = Diabetes Prevention Program; F/U = followup; g = grams; GP = general practitioner; HD = healthy diet only; HD + PA = healthy diet and physical activity; HDL = high-density lipoprotein cholesterol; hrs = hours; HTN = hypertension; IG = intervention group; Int arm = intervention arm; kg = kilograms; kg/m^2^ = kilograms per meter squared; LDL = low-density lipoprotein cholesterol; mg = milligrams; MI = motivational interviewing; min = minutes; ml = milliliters; mm Hg = millimeters of mercury; mmol/L = millimoles per liter; NCEP = National Cholesterol Education Program; NHLBI = National Heart, Lung, and Blood Institute; NHS = National Health Service (UK); NR = not reported; PA = physical activity only; PCP = primary care provider; PN = practice nurse; TC = total cholesterol; TG = triglycerides; wk = week