# Appendix E Observational Evidence on the Association Between Differences in Intermediate and Behavioral Outcomes and Health Outcomes

Building on the methods used in the recent USPSTF of lifestyle counseling in adults without CVD risk factors,^3^ we looked for new observational evidence to support the association between effects of the size seen in the included studies and health outcomes, and updated this evidence where it was available. However, it is always worth noting that observational evidence may overestimate the benefits of behavior change, due to the inherent difficulty in controlling for confounding factors in non-randomized studies. Biases in observational results may be even more pronounced when long-term adherence to drug or behavioral change is assumed in order to maintain benefits. Some have noted that this concern is particularly important for applying effects of observational evidence to preventive interventions in primary care settings.^4^ Moreover, observational evidence does not reflect changes in intermediate or behavioral outcomes based on counseling interventions.

## Blood Pressure

Overall, we found that behavioral counseling was associated with a greater decrease in SBP/DBP by 1.9/1.2 mm Hg after 12 to 24 months follow-up compared to individuals in control groups, which was typically usual care. In trials that were limited to persons with hypertension or prehypertension, there was an average greater reduction of 2.0/1.1 mm Hg SBP/DBP, compared to control participants. Median reductions in SBP/DBP were 5.1/3.4 mm Hg in the intervention groups and 2.9/1.6 mm Hg in the control groups for all included trials at 12–24 months, from a mean baseline SBP/DBP of 139/84 mm Hg.

Blood pressure declines of this magnitude have been associated with decreased risk of CVD-related mortality in epidemiologic literature.^5,^ ^6^ An IPD meta-analysis of 61 prospective observational cohort studies with nearly 1 million adults without CVD revealed a strong relationship between blood pressure and age-specific stroke deaths and ischemic heart disease deaths which persisted after adjusting for lipid levels, diabetes, weight, alcohol intake, and smoking.^6^ The positive associations between lowering blood pressures down to 115/75 mm Hg and outcomes were apparent through all age groups categorized by each decade of life. The hazard ratios were originally reported in incremental decreases in 20 mm Hg in SBP and 10 mm Hg in DBP. To allow for comparability to our results, we converted the blood pressures to smaller incremental decreases of 2 mm Hg in SBP and 1 mm Hg in DBP, respectively (Table 17). In adults between ages 40–49, a 2 mm Hg decrease in SBP was associated with lower mortality due to stroke by 10 percent (HR, 0.90 [95% CI, 0.89 to 0.91]) and mortality due to ischemic heart disease by 7 percent (HR, 0.93 [95% CI, 0.92 to 0.94]).

Similarly, a prospective cohort study of 63,000 patients with suspected hypertension found an association between increased in-clinic and ambulatory blood pressure measurements (ABPM) and increased cardiovascular mortality. The average age of the subjects was 58.4 years old and the results were adjusted for age, sex, smoking status, BMI, diabetes, dyslipidemia, history of CVD and number of antihypertensive drugs used. The study results reported hazard ratios per 1-SD (14 mm Hg) SBP increase in ABPM and 1-SD (19 mm Hg) SBP increase in the clinic. To comparably assess the effects of decreased SBP, the inverse of the HRs were calculated and converted to incremental 2 mm Hg decreases (Table 17). This resulted in a 6 percent (HR, 0.94 [95% CI, 0.93 to 0.94]) and a 4 percent (HR, 0.96 [95% CI, 0.95 to 0.96]) reduction in CVD mortality for ABPM and clinical BP measurements, respectively.^5^ Further, a IPD meta-analyses of randomized controlled trials and prospective studies supported the overall benefits of a broad class of antihypertensives in lowering blood pressure decreasing cardiovascular mortality risks.^7,^ ^8^ For example, one of these found that among trials with baseline SBP between 130 and 139 mm Hg, a 10 mm Hg reduction was associated with a 13% reduction in major CVD events (RR=0.87 [95% CI 0.82 to 0.92]), 27% reduction in strokes (RR=0.73 [95% CI 0.62 to 0.85]) and a 11% reduction in all-cause mortality (RR=0.89 [95% CI 0.82 to 0.98]).^8^

Similarly, CVD events were reduced in a combined analysis of long-term followup of the two TOHP trials, in which the average change in blood pressure was a 1.2/0.7 mm Hg greater reduction than control groups after 36 months, presumably due to restricted sodium intake found by the TOHP trials.^9^ In this follow-up study, risk of a cardiovascular event was 25% lower among those in the intervention group (RR= 0.75 [95% CI 0.57 to 0.99]), adjusted for trial, clinic, age, race, and sex, and was 30% lower after further adjustment for baseline sodium excretion and weight (RR=0.70 [95% CI 0.53 to 0.94]). This was after approximately 10 years for TOHP I and 5 years for TOHP II. However, there was not a statistically significant reduction in all-cause mortality in this combined analysis (RR=0.80 [95% CI 0.51 to 1.26]; 67 deaths total).

## Lipids

We found that behavioral counseling interventions were associated with a 3.7 mg/dL greater reduction in total cholesterol than control groups and a 2.3 mg/dL greater reduction in LDL compared to the control groups after 12 to 24 months of follow-up. Individuals with dyslipidemia experienced similar outcome in TC levels, decrease by 3.8 mg/dL and a decrease of 4.1 for LDL. The mean baseline LDL levels were 136 mg/dL across all included studies, and 160 in trials that were limited to persons with dyslipidemia or levels that were outside the optimal range. Median reductions in LDL were 4.8 mg/dL in the intervention groups and 4.2 mg/dL in the control groups for all studies, and absolute reductions were larger in trials limited to participants selected for lipid levels (median 11.0 and 10.4 mg/dL reductions in the intervention and control groups, respectively). There was a minimal impact on HDL.

The variety in lipid components and their interactions with each other creates complications when determining the health impact of cholesterol levels, but epidemiologic evidence suggests that decreases in LDL can lead to decrease in cardiovascular mortality.^10,^ ^11^ However, evidence is mixed on the likelihood that changes of the magnitude found in our review are associated with long-term health benefits. In an IPD meta-analysis of 61 prospective observational studies consisting of 900,000 adults without a history of known diseases revealed a positive relationship between non-HDL cholesterol levels and IHD mortality after a median 13 years followup. This trend persisted through each decade of life beginning at age 40 but weakened through subsequent decades. An average decrease in non-HDL cholesterol of 3 mg/dL was associated with a 4 percent reduction in IHD mortality in adults ages 40 to 49 years old (HR, 0.96 [95% CI, 0.95 to 0.96]) (Table 17).^11^ This study did not find a relationship between non-HDL cholesterol levels and stroke mortality (e.g., HR=0.99 [95% CI 0.99 to 1.00] for adults ages 40 to 49 years). A separate meta-analysis of 34 trials with 135,000 subjects supported the usage of intensive statin therapy to decrease all-cause mortality and CVD mortality over less-intensive.^10^ For example, among persons with a baseline LDL between 100 and 129 mg/dL, 48 weeks of LDL lowering therapy was associated with a 12% lower risk of all-cause mortality (RR=0.88 [95% CI 0.79 to 0.98]). However, this analysis found that there was no benefit in trials with average absolute reductions of less than 35 mg/dL (RR=0.98 [95% CI 0.94 to 1.01]).

## Fasting Glucose

We excluded trials if 50% or more of participants had diabetes or prediabetes, but nevertheless found that behavioral counseling interventions were associated with a 2.4 mg/dL greater reduction in FBG and control groups after 12 to 24 months of follow-up. The mean baseline FBG levels were 86 mg/dL across all included studies, and the median change was a 2.9 mg/dL reduction in the intervention groups and 0.2 mg/dL increase in the control groups. The percent with diabetes at baseline ranged from 0 to 49 percent, with 12.7 percent of all participants having diabetes across all studies reporting diabetes prevalence.

Epidemiologic evidence suggests that maintaining a normoglycemic level is associated with the best cardiovascular outcomes and incremental increases beyond normoglycemia increases cardiovascular mortality. In an IPD meta-analysis of 54 prospective studies that included 284,686 individuals without known CVD, all-cause mortality and vascular death was not associated with a fasting blood glucose level between 70 and 100 mg/dL adjusted for age, smoking, and BMI.^12^ A different IPD meta-analysis generated similar results for coronary heart disease and stroke events, both fatal and nonfatal. An incremental 2 mg/dL increases in fasting blood glucose above 100 mg/dL was associated with a 1 percent decreased risk of fatal plus nonfatal coronary heart disease (HR, 0.99 [95% CI, 0.98 to 0.99]),^12^ vascular deaths (HR, 0.99 [95% CI, 0.98 to 0.99]),^12^ and all-cause mortality (HR, 0.99 [95% CI, 0.99 to 0.99]).^12^ The link between diabetes and cardiovascular events is well-established; the incidence rate is doubled for fatal and nonfatal coronary heart disease and stroke. The previous review on this topic found that counseling individuals with known impaired fasting glucose or glucose intolerance about interventions reduced their risk of progressing to diabetes by 42 percent in 12 to 24 months (pooled RR, 0.58 [95% CI, 0.37 to 0.89]; k=8; I^2^=32%).^13^ These results demonstrate the importance of preventing the progression to diabetes in risk populations.

## Adiposity

We found that behavioral counseling interventions were associated with a 0.4 kg/m^2^ greater reduction in BMI than control groups and a 1.6 cm greater reduction in waist circumference compared to the control groups after 12 to 24 months of follow-up. Among the weight loss trials in this review, the average BMI and waist circumference reductions were 0.9 kg/m^2^ and 2.5 cm, respectively. The mean baseline BMI was 29.8 across all included studies, 89.3% of all participants were either overweight or had obesity across all studies reporting the prevalence of excess weight. Median reductions in BMI were 0.5 kg/m^2^ in the intervention groups and 0.1 kg/m^2^ in the control groups, and absolute reductions were larger in weight loss trials (i.e., participants were selected on the basis of excess weight and all were given a weight loss goal: median 1.0 and 0.3 kg/m^2^ reductions in the intervention and control groups, respectively).

We found data to support that even modest changes in BMI may be associated with small reductions in cardiovascular related mortality. An IPD meta-analysis of 57 prospective studies that included 900,000 individuals found that all-cause mortality was lowest in BMI ranges between 22.5 to 25 kg/m^2^ in adults without CVD.^14^ Applying conversions to determine the impact of a BMI change comparable to that found in our review, a BMI decrease of 0.4 kg/m^2^ was associated with a 3 percent lower risk of death caused ischemic heart disease (HR, 0.97 [95% CI, 0.96 to 0.97]) and fatal strokes (HR, 0.97 [95% CI, 0.97 to 0.98]), among adults with a BMI above 25 kg/m^2^ and ranging from ages 35 to 59 years. These results were not adjusted for mechanisms which affect vascular mortality such as blood pressure levels, lipid levels, or diabetes.^14^ A Danish study published in 2016 investigated the relationship between BMI and mortality over time from three different cohorts and found smaller associations between BMI and mortality over time.^15^ In the most recent cohort, a BMI greater than 30 kg/m^2^ was not associated with an increased risk of all-cause mortality relative to a BMI of 18.5 to 24.9 (HR, 0.99 [95% CI, 0.92 to 1.07]), in contrast to earlier cohorts (1991–1994: HR, 1.13 [95% CI, 1.04 to 1.22]; 1976–1978: HR, 1.31 [95% CI, 1.23 to 1.39]).^15^ An analysis of the most recent cohort (2003–2013) revealed a BMI of 27.0 kg/m^2^ to have the lowest all-cause mortality, which is 3.3 kg/m^2^ higher than at was in the earliest cohort. They hypothesized that improved treatment for cardiovascular risk factors and CVD complications may have had a greater impact at higher BMI levels than at lower BMI levels. Body mass index is known to be associated with other cardiovascular risk factors such as blood pressure, lipid levels and diabetes and therefore the clinical significance of weight loss should also be considered when examining these outcomes.^15^

Evidence was not as extensive for waist circumference, however we did find prospective observational studies to support the association between waist circumference and future all-cause mortality^16^ and ischemic heart disease events.^17^ A pooled analysis of 11 prospective cohort studies (n=650,386) with mean followup of 9 years reported a 7% increase in the risk of all-cause mortality in men (HR=1.07 [95% CI 1.06 to 1.08]) and 9% increase in women (HR=1.09 [95% CI 1.08 to 1.09]) associated with a 5 cm increment in waist circumference. We inverted these figures and calculated the decline in risk associated with a 2 cm reduction in men and a 1 cm reduction in women, consistent with our findings; the result was a 3% lower risk for men (HR=0.97 [95% CI 0.96 to 0.98]) and a 1% lower risk for women (HR=0.99 [95% CI 0.98 to 0.99]).^16^ Similar calculations based on a pooled analysis of 6 prospective cohort studies from China and Australia (n=45,988) with a mean 6 years followup results in a 5% reduction in the risk of ischemic heart disease events (HR=0.95 [95% CI 0.95 to 0.98)] being associated with a 1.7 cm decrease in waist circumference.^17^

## Diet

We found that dietary counseling was associated with decrease in percentage of energy from saturated fats and monounsaturated fats and had no statistically significant effect on the percentage of energy coming from polyunsaturated fats. Between-group differences included a decrease in 1.5 percent and 1.7 percent of total energy consumed in saturated fats and mono-unsaturated fats, respectively. We also found that dietary counseling increased the consumption of fruits and vegetable combined by 0.7 servings a day more than control groups and consumption of fiber increased by 1.4 grams per day more than control groups. Urinary sodium was also decreased by 17.9 mmol/L more in the intervention groups than the control groups. In addition, several trials improved overall indices of diet, and two reported increased adherence with the Mediterranean diet.

There is some observational data to support the benefits of a healthful diet on cardiovascular and all-cause mortality. A 2014 study meta-analysis of 95 cohort studies with up to 2 million participants found that an increase in fruit and vegetable consumption of 200 g/d was associated with an decreased relative risk of cardiovascular disease by 8 percent (RR, 0.92 [95% CI, 0.90 to 0.95]), strokes by 16% (RR, 0.84 [95% CI, 0.76 to 0.92]), and all-cause mortality by 10% (RR, 0.90 [95% CI, 0.87 to 0.93]).^18^ However, 200 g/d is a considerably larger between-group effect than we found, which is more on the order of 30 g/day or less. A separate meta-analysis of 16 cohort studies that included over 800,000 individuals and 56,423 deaths found a 5 percent lower risk of all-cause mortality for an increment of one serving of fruit and vegetables per day (pooled HR=0.95 [95% CI 0.92 to 0.98]).^19^

Evidence also support increased fiber consumption. Incremental consumptions of 10 gram of dietary fiber per day has also been shown to decrease the all-cause mortality risk ratio by 11 percent [RR, 0.89 (95% CI 0.85 to 0.92)] according to a meta-analysis from 2014.^20^ Again, however, this was a nearly 10 times larger change in fiber consumption than the between-group differences that was observed in the included studies.

The findings on intake of different types of dietary fat are less clear, although evidence suggest that a low-fat diet may not assist with weight loss or decrease CVD and cancer mortalities.^21–24^ The results of a meta-analysis of two U.S.-based prospective cohort studies (the Nurses’ Health Study and the Health Professionals Followup Study) of individuals without diabetes, cardiovascular disease and cancer at baseline found that a replacement of 5 percent of energy from saturated fats to polyunsaturated fats, monounsaturated fats, or whole grain carbohydrates was associated with a 25 (HR, 0.75 [95% CI, 0.67 to 0.84]), 15 (HR, 0.85 [95% CI, 0.74 to 0.97]), and 8 percent (HR, 0.91 [95% CI, 0.85 to 0.98]) reduction in coronary heart disease, respectively.^25^ The reduction in saturated fat was substantially lower in the included studies, and it was unlikely that these calories were replaced with MUFA or PUFA, since those also either declined or health steady in the included studies. A 2017 publication from the American Heart Association’s review of the current evidence concluded that replacing saturated fats with unsaturated fats in lowers the incidences of cardiovascular disease,^26^ however some disagreement in the field remains.^27^ The U.S. Department of Health and Human Service has also began recommending substitution of saturated fats for poly- and monounsaturated fats.^28^

## Physical Activity

Our analysis found that physical activity counseling was associated with statistically nonsignificant increases in physical activity of 9.1 minutes per week and 83 MET-minutes per week compared to the control group. We also found that 22 percent of individuals were able to meet the set physical activity recommendation (150 minutes of moderate-intensity or 75 minutes of vigorous physical activity per week) compared to the control. However, there was substantial level of heterogeneity in our pooled analysis for this outcome.

The broader body of observational and trial literature support the benefits of exercise in decreasing cardiovascular disease even at levels below the national standard. The Physical Activity Guidelines for Americans, second edition, reaffirmed the strong evidence to support the benefits of physical activity on all-cause mortality.^29^ They recommend a minimum of 150 minutes of moderate intensity exercise or 75 minutes of vigorous-intensity exercise per week (approximately 500 to 1,000 MET-minutes/week). However, even physical activities below what is recommended show significant benefits,^29^ and the current guide states that the is no threshold that must be exceeded before benefits begin to occur. Compared to no activity, activity below the recommended 450-MET-minutes/week reduced both cardiovascular death and all-cause mortality by 20 percent (HR, 0.80 [95% CI, 0.77 to 0.84]), HR, 0.80 [95% CI, 0.78 to 0.82] respectively) after adjusting for clinical and demographic characteristics, including BMI. Physical activity at the level of the national recommendation (500 to 1000 MET-minute/week) is associated with a 33 percent reduction in the risk of cardiovascular mortality (HR, 0.67 [95% CI, 0.65 to 0.70]) and all-cause mortality is reduced by 31 percent (HR, 0.69 [95% CI, 0.67 to 0.70]).^30^ The benefits are observed regardless of whether the physical activity is recreational or non-recreational (e.g., housework, transportation and occupational).^31^ The benefits of physical activities are generalizable across subpopulations of age, sex, race/ethnicity, BMI smoking and history of heart disease according to a Taiwanese prospective cohort study of more than 400,000 individuals. The study found that low levels of activity (90 min/week or 15/min/day) was associated with a 19 percent reduction in cardiovascular mortality (HR, 0.81 [95% CI, 0.71 to 0.93]) and a 14 percent reduction in risk of all-cause mortality (HR, 0.86 [95% CI, 0.81 to 0.91]). Furthermore, additional 15 minutes/day was associated with a 4 percent risk reduction in all-cause mortality (95% CI, 2.5 to 7.0).^32^

Large cross-sectional studies have associated better quality of life and perceived health status with physical activity regardless of BMI,^33,^ ^34^ while results of longitudinal analyses showed a mixture of substantial improvements in the range of quality-of-life domains,^35^ and others showed limited impact.^36^ The results of cross-sectional associations were not reproducible by longitudinal analysis, however.^37^