# Appendix D List of Excluded Studies

Exclusion Code and Definition^*^
E1 Study relevance; E1c Not CVD focused
E2 Setting; E2a Not a “very high” development country; E2b Not generalizable to primary care
E3 Population; E3a Symptomatic, ≥50% with CHD or DM; E3b Participants not selected for CVD high-risk criteria; E3c Other (e.g., children, pregnant, etc.); E3d ≥50% with pre-DM
E4 Outcomes: No relevant outcomes
E5 Intervention: Not an included intervention; E5a Yoga or tai chi; E5b Supervised PA too extensive; E5c Food provision too extensive
E6 Study design; E6a Not a trial; E6b Less than 6 months followup; E6c Comparative effectiveness; E6d Control group told not to change diet or PA
E7 Study quality; E7a High or differential attrition
E8 Main outcomes published prior to 1990
E9 Publication not in English; E9a Publication type (e.g., conference abstract)

* Assigned at the full-text screening phase

1 Ackermann RT, Edelstein SL, Narayan KM, . Changes in health state utilities with changes in body mass in the Diabetes Prevention Program. Obesity (Silver Spring). 2009;17(12):2176–81. PMID: 19390518. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.19390518
2 Ambrosini GL, Solis-Trapala I, Ahern AL, . Greater improvements in diet quality among overweight participants following a group-based commercial weight loss programme than those receiving support to lose weight in primary care. Nutr J. 2018;17(1):64. PMID: 29973211. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.29973211
3 An M, Nahm ES, Shaughnessy M, . A pilot primary stroke prevention program for elderly Korean Americans. J Neurosci Nurs. 2018;50(6):327–33. PMID: 30407966. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.30407966
4 Anand S, Samaan Z, Middleton C, . A digital health intervention to lower cardiovascular risk: a randomized clinical trial. JAMA Cardiol. 2016;1(5):601–6. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.27438754
5 Arija V, Villalobos F, Pedret R, . Physical activity, cardiovascular health, quality of life and blood pressure control in hypertensive subjects: randomized clinical trial. Health Qual Life Outcomes. 2018;16(1):184. PMID: 30217193. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.30217193
6 Avanzini F, Marzona I, Baviera M, . Improving cardiovascular prevention in general practice: results of a comprehensive personalized strategy in subjects at high risk. Eur J Prev Cardiol. 2016;23(9):947–55. PMID: 26525065. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.26525065
7 Awoyemi A, Troseid M, Arnesen H, . Effects of dietary intervention and n-3 PUFA supplementation on markers of gut-related inflammation and their association with cardiovascular events in a high-risk population. Atherosclerosis. 2019;286:53–9. PMID: 31100620. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.31100620
8 Azar KM, Koliwad S, Poon T, . The Electronic CardioMetabolic Program (eCMP) for Patients With Cardiometabolic Risk: A Randomized Controlled Trial. J Med Internet Res. 2016;18(5):e134. PMID: 27234480. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.27234480
9 Baruth M, Wilcox S, Jake-Schoffman DE, . Effects of a self-directed nutrition intervention among adults with chronic health conditions. Health Educ Behav. 2018;45(1):61–7. PMID: 28580795. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.28580795
10 Baumann S, Toft U, Aadahl M, . The long-term effect of screening and lifestyle counseling on changes in physical activity and diet: the Inter99 Study - a randomized controlled trial. Int J Behav Nutr Phys Act. 2015;12:33. PMID: 25886540. KQ1E4, KQ2E4, KQ3E4, KQ4E4.25886540
11 Bayley A, Stahl D, Ashworth M, . Response bias to a randomised controlled trial of a lifestyle intervention in people at high risk of cardiovascular disease: a cross-sectional analysis. BMC Public Health. 2018;18(1):1092. PMID: 30180833. KQ1E4, KQ2E4, KQ3E4, KQ4E4.30180833
12 Bender AM, Jorgensen T, Pisinger C. Do high participation rates improve effects of population-based general health checks? Prev Med. 2017;100:269–74. PMID: 28526394. KQ1E4, KQ2E4, KQ3E4, KQ4E4.28526394
13 Birnie K, Thomas L, Fleming C, . An evaluation of a multi-component adult weight management on referral intervention in a community setting. BMC Res Notes. 2016;9:104. PMID: 26887321. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.26887321
14 Bloss CS, Wineinger NE, Peters M, . A prospective randomized trial examining health care utilization in individuals using multiple smartphone-enabled biosensors. Peerj. 2016;4:e1554. PMID: 26788432. KQ1E5, KQ2E5, KQ3E5, KQ4E5.26788432
15 Bo S, Ponzo V, Goitre I, . Predictive role of the Mediterranean diet on mortality in individuals at low cardiovascular risk: a 12-year follow-up population-based cohort study. J Transl Med. 2016;14:91. PMID: 27071746. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.27071746
16 Borkoles E, Carroll S, Clough P, . Effect of a non-dieting lifestyle randomised control trial on psychological well-being and weight management in morbidly obese pre-menopausal women. Maturitas. 2016;83:51–8. PMID: 26602363. KQ1E7a, KQ2E7a, KQ3E7a, KQ4E7a.26602363
17 Botteri E, de Lange T, Tonstad S, . Exploring the effect of a lifestyle intervention on cancer risk: 43-year follow-up of the randomized Oslo diet and antismoking study. J Intern Med. 2018;22:22. PMID: 29790221. KQ1E8, KQ2E8, KQ3E8, KQ4E8.29790221
18 Byfield CL. Development and evaluation of a lifestyle physical activity intervention for obese sedentary women. Colorado State University PhD Thesis. 2001. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.
19 Cezaretto A, Pakseresht M, Sharma S, . Influence of depression on cardiometabolic responses to a lifestyle intervention in at-risk individuals. J Affect Disord. 2015;174:516–21. KQ1E2, KQ2E2, KQ3E2, KQ4E2.25554997
20 Chang SH, Chen MC, Chien NH, . Effectiveness of community-based exercise intervention programme in obese adults with metabolic syndrome. J Clin Nurs. 2016;25(17–18):2579–89. PMID: 27501160. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.27501160
21 Chang SH, Chien NH, Yu CY. Long-term lifestyle intervention in elderly with metabolic syndrome. Clin Nurs Res. 2017:1054773817749923. PMID: 29276844. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.29276844
22 Chen ML. The effectiveness of a lifestyle-based intervention on physical activity, blood pressure, and health-related quality of life in older adults with hypertension. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2017;77(10-B(E)):No Pagination Specified. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.
23 Chen ML, Hu J, McCoy TP, . Effect of a lifestyle-based intervention on health-related quality of life in older adults with hypertension. J Aging Res. 2018;2018:6059560. PMID: 29854460. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.29854460
24 Chen YC, Tsao LI, Huang CH, . An Internet-based health management platform may effectively reduce the risk factors of metabolic syndrome among career women. Taiwan J Obstet Gynecol. 2013;52(2):215–21. PMID: 23915854. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.23915854
25 Choi BG, Dhawan T, Metzger K, . Image-based mobile system for dietary management in an american cardiology population: pilot randomized controlled trial to assess the efficacy of dietary coaching delivered via a smartphone app versus traditional counseling. JMIR Mhealth Uhealth. 2019;7(4):e10755. PMID: 31012860. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.31012860
26 Choi YY, Kim KY. Effects of physical examination and diet consultation on serum cholesterol and health-behavior in the Korean pilots employed in commercial airline. Ind Health. 2013;51(6):603–11. PMID: 24131872. KQ1E7, KQ2E7, KQ3E7, KQ4E7.24131872
27 Chomiuk T, Folga A, Mamcarz A. The influence of systematic pulse-limited physical exercise on the parameters of the cardiovascular system in patients over 65 years of age. Arch Med Sci. 2013;9(2):201–9. PMID: 23671429. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.23671429
28 Clare L, Nelis SM, Jones IR, . The Agewell trial: a pilot randomised controlled trial of a behaviour change intervention to promote healthy ageing and reduce risk of dementia in later life. BMC Psychiatry. 2015;15:25. PMID: 25880911. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.25880911
29 Cornelio ME, Godin G, Rodrigues RC, . Effect of a behavioral intervention of the SALdavel program to reduce salt intake among hypertensive women: a randomized controlled pilot study. Eur J Cardiovasc Nurs. 2016;15(3):e85–94. PMID: 26025215. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a.26025215
30 Crandall J, Schade D, Ma Y, . The influence of age on the effects of lifestyle modification and metformin in prevention of diabetes. J Gerontol A Biol Sci Med Sci. 2006;61(10):1075–81. PMID: 17077202. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.17077202
31 Critchley CR, Hardie EA, Moore SM. Examining the psychological pathways to behavior change in a group-based lifestyle program to prevent type 2 diabetes. Diabetes Care. 2012;35(4):699–705. PMID: 22338102. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.22338102
32 Crowley MJ, Bosworth HB, Coffman CJ, . Tailored Case Management for Diabetes and Hypertension (TEACH-DM) in a community population: study design and baseline sample characteristics. Contemp Clin Trials. 2013;36(1):298–306. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.23916915
33 Darviri C, Artemiadis AK, Protogerou A, . A HEALth Promotion and STRESS Management Program (HEAL-STRESS study) for prehypertensive and hypertensive patients: a quasi-experimental study in Greece. J Hum Hypertens. 2016;30(6):397–403. PMID: 26424102. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.26424102
34 Davis BR, Blaufox MD, Oberman A, . Reduction in long-term antihypertensive medication requirements. Effects of weight reduction by dietary intervention in overweight persons with mild hypertension. Arch Intern Med. 1993;153(15):1773–82. PMID: 8333814. KQ1E6, KQ2E6, KQ3E6, KQ4E68333814
35 Delahanty LM, Peyrot M, Shrader PJ, . Pretreatment, psychological, and behavioral predictors of weight outcomes among lifestyle intervention participants in the Diabetes Prevention Program (DPP). Diabetes Care. 2013;36(1):34–40. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.23129133
36 Diabetes Prevention Program Research Group, Crandall J, Schade D, . The influence of age on the effects of lifestyle modification and metformin in prevention of diabetes. J Gerontol A Biol Sci Med Sci. 2006;61(10):1075–81. PMID: 17077202. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.17077202
37 Dijk D, R CM, Empelen P, . Favourable outcomes of a preventive screening and counselling programme for older people in underprivileged areas in the Netherlands: the PRIMUS project. Prev Med Rep. 2017;6:258–64. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.28409087
38 Duda JL, Williams GC, Ntoumanis N, . Effects of a standard provision versus an autonomy supportive exercise referral programme on physical activity, quality of life and well-being indicators: a cluster randomised controlled trial. Int J Behav Nutr Phys Act. 2014;11:10. PMID: 24475766. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.24475766
39 Duncan S, Goodyear-Smith F, McPhee J, . Family-centered brief intervention for reducing obesity and cardiovascular disease risk: a randomized controlled trial. Obesity. 2016;24(11):2311–8. PMID: 27616217. KQ1E7, KQ2E7, KQ3E7, KQ4E7.27616217
40 Eaglehouse YL, Schafer GL, Arena VC, . Impact of a community-based lifestyle intervention program on health-related quality of life. Qual Life Res. 2016;25(8):1903–12. PMID: 26896960. KQ1E4, KQ2E4, KQ3E4, KQ4E4.26896960
41 Eakin EG, Bull SS, Riley KM, . Resources for health: a primary-care-based diet and physical activity intervention targeting urban Latinos with multiple chronic conditions. Health Psychol. 2007;26(4):392–400. PMID: 17605558. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.17605558
42 Eaton CB, Hartman S, Risica PM, . P119: Tailored lifestyle intervention for obese, sedentary patients in primary care: choose to lose study. American Heart Association’s Epidemiology and Prevention/Lifestyle and Cardiometabolic Health 2015 Scientific Sessions. 2015;131. PMID: None. KQ1E9a, KQ2E9a, KQ3E9a, KQ4E9a.
43 Edelman D, Dolor RJ, Coffman CJ, . Nurse-led behavioral management of diabetes and hypertension in community practices: a randomized trial. J Gen Intern Med. 2015;30(5):626–33. PMID: 25567758. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.25567758
44 Elley CR, Kerse N, Arroll B, . Effectiveness of counselling patients on physical activity in general practice: cluster randomised controlled trial. BMJ. 2003;326(7393):793. PMID: 12689976. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.12689976
45 Engberg E, Liira H, Kukkonen-Harjula K, . The effects of health counseling and exercise training on self-rated health and well-being in middle-aged men: a randomized trial. J Sports Med Phys Fitness. 2017;57(6):916–22. PMID: 27045739. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.27045739
46 Entezari MH, Salehi R, Kazemi M, . Comparison of the effect of the Dietary Approaches to Stop Hypertension diet with usual dietary advice on expression of peroxisome proliferators-activated receptor gamma gene in women: a randomized controlled clinical trial. ARYA Atheroscler. 2018;14(1):24–31. PMID: 29942335. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a.29942335
47 Eriksson J, Lindstrom J, Valle T, . Prevention of Type II diabetes in subjects with impaired glucose tolerance: the Diabetes Prevention Study (DPS) in Finland. Study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia. 1999;42(7):793–801. PMID: 10440120. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.10440120
48 Esposito K, Marfella R, Ciotola M, . Effect of a mediterranean-style diet on endothelial dysfunction and markers of vascular inflammation in the metabolic syndrome: a randomized trial. JAMA. 2004;292(12):1440–6. PMID: 15383514. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.15383514
49 Ferrara AL, Pacioni D, Di Fronzo V, . Lifestyle educational program strongly increases compliance to nonpharmacologic intervention in hypertensive patients: a 2-year follow-up study. J Clin Hypertens (Greenwich). 2012;14(11):767–72. PMID: 23126348. KQ1E7, KQ2E7, KQ3E7, KQ4E7.23126348
50 Fife-Schaw C, de Lusignan S, Wainwright J, . Comparing exercise interventions to increase persistence with physical exercise and sporting activity among people with hypertension or high normal blood pressure: study protocol for a randomised controlled trial. Trials. 2014;15:336. PMID: 25168762. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.25168762
51 Florez H, Pan Q, Ackermann RT, . Impact of lifestyle intervention and metformin on health-related quality of life: the Diabetes Prevention Program randomized trial. J Gen Intern Med. 2012;27(12):1594–601. PMID: 22692637. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.22692637
52 Fortier MS, Hogg W, O’Sullivan TL, . The physical activity counselling (PAC) randomized controlled trial: rationale, methods, and interventions. Appl Physiol Nutr Metab. 2007;32(6):1170–85. PMID: 18059592. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.18059592
53 Fortier MS, Hogg W, O’Sullivan TL, . Impact of integrating a physical activity counsellor into the primary health care team: physical activity and health outcomes of the Physical Activity Counselling randomized controlled trial. Appl Physiol Nutr Metab. 2011;36(4):503–14. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.21848444
54 Fujimoto WY, Jablonski KA, Bray GA, . Body size and shape changes and the risk of diabetes in the diabetes prevention program. Diabetes. 2007;56(6):1680–5. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.17363740
55 Garcia-Silva J, Navarette NN, Peralta-Ramirez MI, . Efficacy of cognitive behavioral therapy in adherence to the Mediterranean diet in metabolic syndrome patients: a randomized controlled trial. J Nutr Educ Behav. 2018;50(9):896–904. PMID: 30100127. KQ1E7, KQ2E7, KQ3E7, KQ4E7.30100127
56 Garcia-Toro M, Gili M, Ibarra O, . Metabolic syndrome improvement in depression six months after prescribing simple hygienic-dietary recommendations. BMC Res Notes. 2014;7:339. PMID: 24899528. KQ1E3c, KQ2E3c, KQ3E3c, KQ4E3c.24899528
57 Gerage AM, Bertoldo Benedetti TR, Ritti-Dias RM, . Effectiveness of a behavior change effectiveness of a behavior change program on physical activity and eating habits in patients with hypertension: a randomized controlled trial. J Phys Act Health. 2017;14(12):943–52. KQ1E2, KQ2E2, KQ3E2, KQ4E2.28682707
58 Gidlow CJ, Cochrane T, Davey R, . One-year cardiovascular risk and quality of life changes in participants of a health trainer service. Perspect Public Health. 2013. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.
59 Glozier N, Christensen H, Naismith S, . Internet-delivered cognitive behavioural therapy for adults with mild to moderate depression and high cardiovascular disease risks: a randomised attention-controlled trial. PLoS One. 2013;8(3). KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.
60 Goldberg RB, Temprosa M, Haffner S, . Effect of progression from impaired glucose tolerance to diabetes on cardiovascular risk factors and its amelioration by lifestyle and metformin intervention: the Diabetes Prevention Program randomized trial by the Diabetes Prevention Program Research Group. Diabetes Care. 2009;32(4):726–32. PMID: 19171717. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.19171717
61 Gomez-Huelgas R, Jansen-Chaparro S, Baca-Osorio AJ, . Effects of a long-term lifestyle intervention program with Mediterranean diet and exercise for the management of patients with metabolic syndrome in a primary care setting. Eur J Intern Med. 2015;26(5):317–23. PMID: 25907985. KQ1E7, KQ2E7, KQ3E7, KQ4E7.25907985
62 Gomez-Pardo E, Fernandez-Alvira JM, Vilanova M, . A comprehensive lifestyle peer group-based intervention on cardiovascular risk factors: the randomized controlled Fifty-Fifty Program.[Erratum appears in J Am Coll Cardiol. 2016 Mar 22;67(11):1385]. J Am Coll Cardiol. 2016;67(5):476–85. PMID: 26562047. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.26562047
63 Gong J, Xu Y, Chen X, . Persistent effect at 30-month post intervention of a community-based randomized trial of KM2H^2^ in reducing stroke and heart attack among senior hypertensive patients. Int J Behav Nutr Phys Act. 2018;15(1):1. PMID: 29291739. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a.29291739
64 Gonzalez-Sanchez J, Recio-Rodriguez JI, Fernandez-delRio A, . Using a smartphone app in changing cardiovascular risk factors: a randomized controlled trial (EVIDENT II study). Int J Med Inf. 2019;125:13–21. PMID: 30914176. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.30914176
65 Goodall M, Barton GR, Bower P, . Food for thought: pilot randomized controlled trial of lay health trainers supporting dietary change to reduce cardiovascular disease in deprived communities. J Public Health (Oxf). 2014;36(4):635–43. PMID: 24277778. KQ1E7, KQ2E7, KQ3E7, KQ4E7.24277778
66 Grimaldi M, Ciano O, Manzo M, . Intensive dietary intervention promoting the Mediterranean diet in people with high cardiometabolic risk: a non-randomized study. Acta Diabetol. 2018;55(3):219–26. PMID: 29218417. KQ1E5c, KQ2E5c, KQ3E5c, KQ4E5c.29218417
67 Hall KS, Pieper CF, Edelman DE, . Lessons learned when innovations go awry: a baseline description of a behavioral trial-the Enhancing Fitness in Older Overweight Veterans with Impaired Fasting Glucose study. Transl Behav Med. 2011;1(4):573–87. PMID: 22866170. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.22866170
68 Hammoudeh S, Bener A, Zirie M, . The effect of non-exercise activity thermogenesis on subjects with metabolic syndrome - a proof of concept study in Qatar. Qatar Med. 2013;2013(1):12–8. PMID: 25003052. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.25003052
69 Hassandra M, Lintunen T, Hagger MS, . An mHealth app for supporting quitters to manage cigarette cravings with short bouts of physical activity: a randomized pilot feasibility and acceptability study. JMIR Mhealth Uhealth. 2017;5(5):e74. PMID: 28550004. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.28550004
70 Herghelegiu AM, Moser A, Prada GI, . Effects of health risk assessment and counselling on physical activity in older people: a pragmatic randomised trial. PLoS One. 2017;12(7):e0181371. PMID: 28727796. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.28727796
71 Herman WH, Ma Y, Uwaifo G, . Differences in A1C by race and ethnicity among patients with impaired glucose tolerance in the Diabetes Prevention Program. Diabetes Care. 2007;30(10):2453–7. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.17536077
72 Hinrichs T, Bucker B, Klaasen-Mielke R, . Home-based exercise supported by general practitioner practices: ineffective in a sample of chronically ill, mobility-limited older adults (the HOMEfit randomized controlled trial). J Am Geriatr Soc. 2016;64(11):2270–9. PMID: 27676362. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.27676362
73 Holme I, Retterstol K, Norum KR, . Lifelong benefits on myocardial infarction mortality: 40-year follow-up of the randomized Oslo diet and antismoking study. J Intern Med. 2016;280(2):221–7. PMID: 26924204. KQ1E8, KQ2E8, KQ3E8, KQ4E8.26924204
74 Holzapfel C, Cresswell L, Ahern AL, . The challenge of a 2-year follow-up after intervention for weight loss in primary care. Int J Obes (Lond). 2014;38(6):806–11. PMID: 24030517. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.24030517
75 Hua K, Hao G, Li W. Cardiovascular outcomes of lifestyle intervention in hypertensive patients with antihypertensive agents. Int J Cardiol. 2017;227:751–6. PMID: 27810294. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a.27810294
76 Illamola Martin L, Rodriguez Cristobal J, Alonso-Villaverde C, . Long-term effects of intensive intervention on changes in lifestyle in patients with hyperfibrinogenaemia and moderate-high cardiovascular risk. Aten Primaria. 2017;(no pagination). KQ1E9, KQ2E9, KQ3E9, KQ4E9.
77 Jackson SL, Safo S, Staimez LR, . Reduced cardiovascular disease incidence with a national lifestyle change program. Am J Prev Med. 2017;52(4):459–68. PMID: 27939239. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.27939239
78 Jafar T, Tan N, Allen J, . Management of hypertension and multiple risk factors to enhance cardiovascular health - a feasibility study in singapore polyclinics. BMC Health Serv Res. 2016;16(1):229. PMID: 27391818. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.27391818
79 Jahangiry L, Shojaeizadeh D, Najafi M, . ‘Red Ruby’: an interactive web-based intervention for lifestyle modification on metabolic syndrome: a study protocol for a randomized controlled trial. BMC Public Health. 2014;14:748. PMID: 25059121. KQ1E2, KQ2E2, KQ3E2, KQ4E2.25059121
80 Jansons P, Robins L, O’Brien L, . Gym-based exercise was more costly compared with home-based exercise with telephone support when used as maintenance programs for adults with chronic health conditions: cost-effectiveness analysis of a randomised trial. J Physiother. 2018;64(1):48–54. PMID: 29289580. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.29289580
81 Janus ED, Best JD, Davis-Lameloise N, . Scaling-up from an implementation trial to state-wide coverage: results from the preliminary Melbourne Diabetes Prevention Study. Trials. 2012;13:152. PMID: 22929458. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.22929458
82 Jebb SA, Ahern AL, Olson AD, . Primary care referral to a commercial provider for weight loss treatment versus standard care: a randomised controlled trial. Lancet. 2011;378(9801):1485–92. PMID: 21906798. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.21906798
83 Jefferson K, Armstrong-Izzard A, Arcand J. Assessment of construct validity of a tool to measure the quality of brief advice for dietary sodium reduction by health care providers (P16-056-19). Curr Dev Nutr. 2019;3(Suppl 1). PMID: 31223701. KQ1E1, KQ2E1, KQ3E1, KQ4E1.
84 Jehn ML, Patt MR, Appel LJ, . One year follow-up of overweight and obese hypertensive adults following intensive lifestyle therapy. J Hum Nutr Diet. 2006;19(5):349–54. PMID: 16961681. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.16961681
85 Jilcott SB, Keyserling TC, Samuel-Hodge CD, . Linking clinical care to community resources for cardiovascular disease prevention: the North Carolina Enhanced WISEWOMAN project. J Womens Health (Larchmt). 2006;15(5):569–83. PMID: 16796484. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.16796484
86 Johnson W, Shaya FT, Khanna N, . The Baltimore Partnership to Educate and Achieve Control of Hypertension (The BPTEACH Trial): a randomized trial of the effect of education on improving blood pressure control in a largely African American population. J Clin Hypertens (Greenwich). 2011;13(8):563–70. PMID: 21806766. KQ1E7, KQ2E7, KQ3E7, KQ4E7.21806766
87 Juraschek SP, Miller ER, 3rd, Weaver CM, . Effects of sodium reduction and the DASH Diet in relation to baseline blood pressure. J Am Coll Cardiol. 2017;70(23):2841–8. PMID: 29141784. KQ1E5c, KQ2E5c, KQ3E5c, KQ4E5c.29141784
88 Kaholokula J, Look M, Mabellos T, . Cultural dance program improves hypertension management for Native Hawaiians and Pacific Islanders: a pilot randomized trial. J Racial Ethn Health Disparities. 2017;4(1):35–46. PMID: 27294768. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.27294768
89 Kallings LV, Sierra Johnson J, Fisher RM, . Beneficial effects of individualized physical activity on prescription on body composition and cardiometabolic risk factors: results from a randomized controlled trial. Eur J Cardiovasc Prev Rehabil. 2009;16(1):80–4. PMID: 19237997. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.19237997
90 Kanaya AM, Santoyo OJ, Gregorich S, . The Live Well, Be Well study: a community-based, translational lifestyle program to lower diabetes risk factors in ethnic minority and lower-socioeconomic status adults. Am J Public Health. 2012;102:1551–8. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.22698027
91 Kandula NR, Dave SS, Patel Y, . Translating a heart disease lifestyle intervention for use in south Asian immigrant communities: preliminary results of a pilot randomized controlled trial. J Gen Intern Med. 2014;29:S239. KQ1E9a, KQ2E9a, KQ3E9a, KQ4E9a.
92 Karwacki-Marugg C, Huddy K, Bernstein B, . Support for Women Achieving Cardiovascular Health Through Exercise And Nutrition (SWAN) study pilot. Conn Med. 2016;80(2):69–74. PMID: 27024976. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.27024976
93 Kerse N, Elley CR, Robinson E, . Is physical activity counseling effective for older people? A cluster randomized, controlled trial in primary care. J Am Geriatr Soc. 2005;53:1951–6. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.16274377
94 Keyserling TC, Samuel Hodge CD, Jilcott SB, . Randomized trial of a clinic-based, community-supported, lifestyle intervention to improve physical activity and diet: the North Carolina enhanced WISEWOMAN project. Prev Med. 2008;46(6):499–510. PMID: 18394692. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.18394692
95 Keyserling TC, Sheridan SL, Draeger LB, . A comparison of live counseling with a web-based lifestyle and medication intervention to reduce coronary heart disease risk: a randomized clinical trial. JAMA Intern Med. 2014;174(7):1144–57. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.24861959
96 Khare MM, Koch A, Zimmermann K, . Heart smart for women: a community-based lifestyle change intervention to reduce cardiovascular risk in rural women. J Rural Health. 2014;30(4):359–68. PMID: 24576081. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.24576081
97 Kim CJ, Schlenk EA, Kang SW, . Effects of an internet-based lifestyle intervention on cardio-metabolic risks and stress in Korean workers with metabolic syndrome: a controlled trial. Patient Educ Couns. 2015;98(1):111–9. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.25468401
98 Kim HR, Kim HS. Autonomy-supportive, web-based lifestyle modification for cardiometabolic risk in postmenopausal women: randomized trial. Nurs Health Sci. 2017;19(4):509–17. PMID: 29094434. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.29094434
99 Kim JY, Wineinger NE, Steinhubl SR. The influence of wireless self-monitoring program on the relationship between patient activation and health behaviors, medication adherence, and blood pressure levels in hypertensive patients: a substudy of a randomized controlled trial. J Med Internet Res. 2016;18(6):e116. PMID: 27334418. KQ1E5, KQ2E5, KQ3E5, KQ4E5.27334418
100 King HA, Jeffreys AS, McVay MA, . Spouse health behavior outcomes from a randomized controlled trial of a spouse-assisted lifestyle change intervention to improve patient low-density lipoprotein cholesterol. J Behav Med. 2014;37(6):1102–7. PMID: 24584818. KQ1E4, KQ2E4, KQ3E4, KQ4E4.24584818
101 Knowler WC, Barrett CE, Fowler SE, . Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. New Engl J Med. 2002;346(6):393–403. PMID: 11832527. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.11832527
102 Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Res Clin Pract. 2004;67(2):152–62. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.
103 Kouwenhoven-Pasmooij TA, Djikanovic B, Robroek SJW, . Design and baseline characteristics of the PerfectFit study: a multicenter cluster-randomized trial of a lifestyle intervention in employees with increased cardiovascular risk. BMC Public Health. 2015;15:715. KQ1E2, KQ2E2, KQ3E2, KQ4E2.26215589
104 Kouwenhoven-Pasmooij TA, Robroek SJW, Kraaijenhagen RA, . Effectiveness of the blended-care lifestyle intervention ‘PerfectFit’: a cluster randomised trial in employees at risk for cardiovascular diseases. BMC Public Health. 2018;18(1):766. PMID: 29921255. KQ1E2, KQ2E2, KQ3E2, KQ4E2.29921255
105 Krehbiel L, Layne A, Sandesara B, . Wearable technology to reduce sedentary behavior and CVD risk in older adults: design of a randomized controlled trial. Contemp Clin Trials Commun. 2017;6:122–6. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.28944304
106 Krein SL, Abdul-Wahab Y, Kadri R, . Adverse events experienced by participants in a back pain walking intervention: a descriptive study. Chronic Illn. 2016;12(1):71–80. PMID: 26289360. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.26289360
107 Kreman R, Yates BC, Agrawal S, . The effects of motivational interviewing on physiological outcomes. Appl Nurs Res. 2006;19(3):167–70. PMID: 16877197. KQ1E4, KQ2E6b, KQ3E4, KQ4E4.16877197
108 Krustrup P, Randers MB, Andersen LJ, . Soccer improves fitness and attenuates cardiovascular risk factors in hypertensive men. Med Sci Sports. 2013;45(3):553–60. PMID: 23059865. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.23059865
109 Krustrup P, Skoradal MB, Randers MB, . Broad-spectrum health improvements with one year of soccer training in inactive mildly hypertensive middle-aged women. Scand J Med Sci Sports. 2017;27(12):1893–901. PMID: 28124381. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.28124381
110 Kulzer B, Hermanns N, Gorges D, . Prevention of diabetes self-management program (PREDIAS): effects on weight, metabolic risk factors, and behavioral outcomes. Diabetes Care. 2009;32(7):1143–6. PMID: 19509014. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.19509014
111 Kwon I, Choi S, Mittman B, . Study protocol of “Worth the Walk”: a randomized controlled trial of a stroke risk reduction walking intervention among racial/ethnic minority older adults with hypertension in community senior centers. BMC Neurol. 2015;15:91. PMID: 26072359. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.26072359
112 Laake K, Seljeflot I, Fagerland MW, . Effects on serum fractalkine by diet and omega-3 fatty acid intervention: relation to clinical outcome. Mediators Inflamm. 2015;2015:373070. PMID: 25733777. KQ1E4, KQ2E4, KQ3E4, KQ4E4.25733777
113 Lankinen M, Schwab U, Kolehmainen M, . A healthy Nordic diet alters the plasma lipidomic profile in adults with features of metabolic syndrome in a multicenter randomized dietary intervention. J Nutr. 2016;09:09. PMID: 26962194. KQ1E4, KQ2E4, KQ3E4, KQ4E4.26962194
114 Laska MN, Sevcik SM, Moe SG, . A 2-year young adult obesity prevention trial in the US: process evaluation results. Health Promot Internation. 2016;31(4):793–800. PMID: 26135586. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.26135586
115 Leblanc V, Begin C, Hudon AM, . Gender differences in the long-term effects of a nutritional intervention program promoting the Mediterranean diet: changes in dietary intakes, eating behaviors, anthropometric and metabolic variables. Nutr J. 2014;13:107. PMID: 25416917. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.25416917
116 Leclerc J, Arsenault M, Despres JP, . Determinants of improvement in left ventricular diastolic function following a 1-year lifestyle modification program in abdominally obese men with features of the metabolic syndrome. Metab Syndr Relat Disord. 2016;14(10):483–91. PMID: 27754772. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.27754772
117 Lee CJ, Kim JY, Shim E, . The effects of diet alone or in combination with exercise in patients with prehypertension and hypertension: a randomized controlled trial. Korean Circ. 2018;48(7):637–51. PMID: 29968437. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.29968437
118 Lefler LL, McSweeney JC, Lensing SY, . 15978: The lifestyle physical activity for sedentary older women (LPAW) study: primary outcomes from a randomized controlled clinical trial. American Heart Association’s 2015 Scientific Sessions and Resuscitation Science Symposium 2015;132(no pagination). PMID: None. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.
119 Lieshout J, Huntink E, Koetsenruijter J, . Tailored implementation of cardiovascular risk management in general practice: a cluster randomized trial. Implement Sci. 2016;11:115. PMID: 27515970. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.27515970
120 Lim SS, Noakes M, Keogh JB, . Long-term effects of a low carbohydrate, low fat or high unsaturated fat diet compared to a no-intervention control. Nutr Metab Cardiovasc Dis. 2010;20(8):599–607. PMID: 19692216. KQ1E7, KQ2E7, KQ3E7, KQ4E7.19692216
121 Lin CH, Chiang SL, Heitkemper MM, . Effects of telephone-based motivational interviewing in lifestyle modification program on reducing metabolic risks in middle-aged and older women with metabolic syndrome: a randomized controlled trial. Int J Nurs Stud. 2016;60:12–23. PMID: 27297365. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.27297365
122 Lindstrom J, Absetz P, Hemio K, . Reducing the risk of type 2 diabetes with nutrition and physical activity - efficacy and implementation of lifestyle interventions in Finland. Public Health Nutr. 2010;13(6A):993–9. PMID: 20513271. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.20513271
123 Lindstrom J, Eriksson JG, Valle TT, . Prevention of diabetes mellitus in subjects with impaired glucose tolerance in the Finnish Diabetes Prevention Study: results from a randomized clinical trial. J Am Soc Nephrol. 2003;14(7 Suppl 2):S108–13. PMID: 12819313. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.12819313
124 Lindstrom J, Ilanne-Parikka P, Peltonen M, . Sustained reduction in the incidence of type 2 diabetes by lifestyle intervention: follow-up of the Finnish Diabetes Prevention Study. Lancet. 2006;368(9548):1673–9. PMID: 17098085. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.17098085
125 Lindstrom J, Louheranta A, Mannelin M, . The Finnish Diabetes Prevention Study (DPS): lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care. 2003;26(12):3230–6. PMID: 14633807. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.14633807
126 Lindstrom J, Peltonen M, Eriksson JG, . Improved lifestyle and decreased diabetes risk over 13 years: long-term follow-up of the randomised Finnish Diabetes Prevention Study (DPS). Diabetologia. 2013;56(2):284–93. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.23093136
127 Lo SW, Chair SY, Lee IF. Effects of lifestyle intervention on physiological outcomes in Chinese adults with, or at high risk of, metabolic syndrome. J Cardiovasc Nurs. 2017;32(6):514–21. PMID: 28060083. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.28060083
128 Luley C, Blaik A, Gotz A, . Weight loss by telemonitoring of nutrition and physical activity in patients with metabolic syndrome for 1 year. J Am Coll Nutr. 2014;33(5):363–74. PMID: 25105874. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.25105874
129 Ma J, King AC, Wilson SR, . Evaluation of lifestyle interventions to treat elevated cardiometabolic risk in primary care (E-LITE): a randomized controlled trial. BMC Fam Pract. 2009;10:71. PMID: 19909549. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.19909549
130 Ma J, Yank V, Xiao L, . Translating the Diabetes Prevention Program lifestyle intervention for weight loss into primary care: a randomized trial. JAMA Intern Med. 2013;173:113–21. PMID: 23229846. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.23229846
131 Martin-Borras C, Gine-Garriga M, Puig-Ribera A, . A new model of exercise referral scheme in primary care: is the effect on adherence to physical activity sustainable in the long term? A 15-month randomised controlled trial. BMJ Open. 2018;8(3):e017211. PMID: 29502081. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.29502081
132 Mateo K. Which is more effective for hypertension management: user- or expert-driven E-counseling? J Clin Outcomes Manage. 2018;25(4):153–6. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.
133 Mayer-Davis EJ, Sparks KC, Hirst K, . Dietary intake in the diabetes prevention program cohort: baseline and 1-year post randomization. Ann Epidemiol. 2004;14(10):763–72. PMID: 15573453. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.15573453
134 McRobbie H, Hajek P, Peerbux S, . Tackling obesity in areas of high social deprivation: clinical effectiveness and cost-effectiveness of a task-based weight management group programme - a randomised controlled trial and economic evaluation. Health Technol Assess. 2016;20(79):1–150. PMID: 27802843. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.27802843
135 Melchart D, Low P, Wuhr E, . Effects of a tailored lifestyle self-management intervention (TALENT) study on weight reduction: a randomized controlled trial. Diabetes Metab Syndr Obes. 2017;10:235–45. PMID: 28684917. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.28684917
136 Mensink M, Blaak EE, Corpeleijn E, . Lifestyle intervention according to general recommendations improves glucose tolerance. Obes Res. 2003;11(12):1588–96. PMID: 14694225. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.14694225
137 Mensink M, Corpeleijn E, Feskens EJ, . Study on lifestyle-intervention and impaired glucose tolerance Maastricht (SLIM): design and screening results. Diabetes Res Clin Pract. 2003;61(1):49–58. PMID: 12849923. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.12849923
138 Mensink M, Feskens EJ, Saris WH, . Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht (SLIM): preliminary results after one year. Int J Obes Relat Metab Disord. 2003;27(3):377–84. PMID: 12629566. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.12629566
139 Mensorio MS, Cebolla-Marti A, Rodilla E, . Analysis of the efficacy of an internet-based self-administered intervention ("Living Better") to promote healthy habits in a population with obesity and hypertension: an exploratory randomized controlled trial. Int J Med Inf. 2019;124:13–23. PMID: 30784422. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.30784422
140 Merriam PA, Tellez TL, Rosal MC, . Methodology of a diabetes prevention translational research project utilizing a community-academic partnership for implementation in an underserved Latino community. BMC Med Res Methodol. 2009;9:20. PMID: 19284663. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.19284663
141 Molitch ME, Fujimoto W, Hamman RF, . The diabetes prevention program and its global implications. J Am Soc Nephrol. 2003;14(7 Suppl 2):S103–S7. PMID: 12819312. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.12819312
142 Moore SM, Hardie EA, Hackworth NJ, . Can the onset of type 2 diabetes be delayed by a group-based lifestyle intervention? A randomised control trial. Psychol Health. 2011;26(4):485–99. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.20945253
143 Mora-Rodriguez R, Ortega JF, Guio de Prada V, . Effects of simultaneous or sequential weight loss diet and aerobic interval training on metabolic syndrome. Int J Sports Med. 2016;37(4):274–81. PMID: 26667921. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.26667921
144 Moreira AM, Londero TM, Goemann IM, . Cardiometabolic effects of CASCADE trial explained by Mediterranean diet. Ann Intern Med. 2016;164(8):573–4. PMID: 27089083. KQ1E9a, KQ2E9a, KQ3E9a, KQ4E9a.27089083
145 Morey MC, Pieper CF, Edelman DE, . Enhanced fitness: a randomized controlled trial of the effects of home-based physical activity counseling on glycemic control in older adults with prediabetes mellitus. J Am Geriatr Soc. 2012;60(9):1655–62. PMID: 22985140. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.22985140
146 Mourouti N, Panagiotakos DB. The beneficial effect of a Mediterranean diet supplemented with extra virgin olive oil in the primary prevention of breast cancer among women at high cardiovascular risk in the PREDIMED Trial. Evid Based Nurs. 2016;19(3):71. PMID: 27161276. KQ1E4, KQ2E4, KQ3E4, KQ4E4.27161276
147 Munakata M, Honma H, Akasi M, . Repeated counselling improves the antidiabetic effects of limited individualized lifestyle guidance in metabolic syndrome: J-STOP-METS final results. Hypertens Res. 2011;34(5):612–6. PMID: 21228781. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.21228781
148 Nakata Y, Sasai H, Tsujimoto T, . Web-based intervention to promote weight-loss maintenance using an activity monitor: a randomized controlled trial. Prev Med Rep. 2019;14:100839. PMID: 30906687. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.30906687
149 Nanri A, Tomita K, Matsushita Y, . Effect of six months lifestyle intervention in Japanese men with metabolic syndrome: randomized controlled trial. J Occup Health. 2012;54(3):215–22. PMID: 22790524. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.22790524
150 Nelson MS, Robbins AS, Thornton JA. An intervention to reduce excess body weight in adults with or at risk for type 2 diabetes. Mil Med. 2006;171(5):409–14. PMID: 16761891. KQ1E7, KQ2E7, KQ3E7, KQ4E7.16761891
151 Nilsson PM, Lindholm LH, Schersten BF. Life style changes improve insulin resistance in hyperinsulinaemic subjects: a one-year intervention study of hypertensives and normotensives in Dalby. J Hypertens. 1992;10(9):1071–8. PMID: 1328367. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.1328367
152 Nishijima H, Satake K, Igarashi K, . Effects of exercise in overweight Japanese with multiple cardiovascular risk factors. Med Sci Sports Exerc. 2007;39(6):926–33. PMID: 17545881. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.17545881
153 Nolan RP, Feldman RD, Dawes M, . Validity of self-rated motivation in a user-centered approach to preventive e-counselling for hypertension. Can J Cardiol. 2013;29(10 suppl. 1):S302. KQ1E9a, KQ2E9a, KQ3E9a, KQ4E9a.
154 Ockene IS, Tellez TL, Rosal MC, . Outcomes of a Latino community-based intervention for the prevention of diabetes: the Lawrence Latino Diabetes Prevention Project. Am J Public Health. 2012;102(2):336–42. PMID: 22390448. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.22390448
155 Ogedegbe G, Fernandez S, Fournier L, . The Counseling Older Adults to Control Hypertension (COACH) trial: design and methodology of a group-based lifestyle intervention for hypertensive minority older adults. Contemp Clin Trials. 2013;35(1):70–9. PMID: 23462343. KQ1E4, KQ2E4, KQ3E4, KQ4E4.23462343
156 Oh B, Cho B, Han MK, . The effectiveness of mobile phone-based care for weight control in metabolic syndrome patients: randomized controlled trial. JMIR Mhealth Uhealth. 2015;3(3):e83. PMID: 26293568. KQ1E7, KQ2E7, KQ3E7, KQ4E7.26293568
157 Oh EG, Bang SY, Hyun SS, . Effects of a 6-month lifestyle modification intervention on the cardiometabolic risk factors and health-related qualities of life in women with metabolic syndrome. Metabolism. 2010;59(7):1035–43. PMID: 20045151. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.20045151
158 Okada H, Onda M, Shoji M, . Effects of lifestyle advice provided by pharmacists on blood pressure: The COMmunity Pharmacists ASSist for Blood Pressure (COMPASS-BP) randomized trial. Biosci Trends. 2018;11(6):632–9. PMID: 29249774. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.29249774
159 Oldroyd JC, Unwin NC, White M, . Randomised controlled trial evaluating the effectiveness of behavioural interventions to modify cardiovascular risk factors in men and women with impaired glucose tolerance: outcomes at 6 months. Diabetes Res Clin Pract. 2001;52(1):29–43. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.11182214
160 Oldroyd JC, Unwin NC, White M, . Randomised controlled trial evaluating lifestyle interventions in people with impaired glucose tolerance. Diabetes Res Clin Pract. 2006;72(2):117–27. PMID: 16297488. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.16297488
161 Olson EA, Mullen SP, Raine LB, . Integrated social- and neurocognitive model of physical activity behavior in older adults with metabolic disease. Ann Behav Med. 2017;51(2):272–81. PMID: 27844326. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.27844326
162 Orchard TJ, Temprosa M, Barrett-Connor E, . Long-term effects of the Diabetes Prevention Program interventions on cardiovascular risk factors: a report from the DPP Outcomes Study. Diabetic Med. 2013;30(1):46–55. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.22812594
163 Orchard TJ, Temprosa M, Goldberg R, . The effect of metformin and intensive lifestyle intervention on the metabolic syndrome: the Diabetes Prevention Program randomized trial. Ann Intern Med. 2005;142(8):611–9. PMID: 15838067. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.15838067
164 Peacock OJ, Western MJ, Batterham AM, . Multidimensional individualised Physical ACTivity (Mi-PACT)-a technology-enabled intervention to promote physical activity in primary care: study protocol for a randomised controlled trial. Trials. 2015;16:381. PMID: 26314577. KQ1E4, KQ2E4, KQ3E4, KQ4E4.26314577
165 Peiris CL, Taylor NF, Hull S, . A group lifestyle intervention program is associated with reduced emergency department presentations for people with metabolic syndrome: a retrospective case-control study. Metab Syndr Relat Disord. 2018;16(2):110–6. PMID: 29360416. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.29360416
166 Penn L, White M, Oldroyd J, . Prevention of type 2 diabetes in adults with impaired glucose tolerance: the European Diabetes Prevention RCT in Newcastle upon Tyne, UK. BMC Public Health. 2009;9:342. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.19758428
167 Perl S, Niederl E, Kos C, . Randomized evaluation of the effectiveness of a structured educational program for patients with essential hypertension. Am J Hypertens. 2016;29(7):866–72. PMID: 26643687. KQ1E7, KQ2E7, KQ3E7, KQ4E7.26643687
168 Perreault L, Ma Y, Dagogo-Jack S, . Sex differences in diabetes risk and the effect of intensive lifestyle modification in the Diabetes Prevention Program. Diabetes Care. 2008;31(7):1416–21. PMID: 18356403. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.18356403
169 Petrella RJ, Stuckey MI, Shapiro S, . Mobile health, exercise and metabolic risk: a randomized controlled trial. BMC Public Health. 2014;14:1082. PMID: 25326074. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.25326074
170 Pettman TL, Misan GM, Owen K, . Self-management for obesity and cardio-metabolic fitness: description and evaluation of the lifestyle modification program of a randomised controlled trial. Int J Behav Nutr Phys Act. 2008;5:53. PMID: 18954466. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.18954466
171 Pouchain D, Lievre M, Huas D, . Effects of a multifaceted intervention on cardiovascular risk factors in high-risk hypertensive patients: the ESCAPE trial, a pragmatic cluster randomized trial in general practice. Trials. 2013;14:318. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.24083783
172 Prentice RL, Aragaki AK, Howard BV, . Low-fat dietary pattern among postmenopausal women influences long-term cancer, cardiovascular disease, and diabetes outcomes. J Nutr. 2019;08:08. PMID: 31175807. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.31175807
173 Proeschold-Bell RJ, Turner EL, Bennett GG, . A 2-year holistic health and stress intervention: results of an RCT in clergy. Am J Prev Med. 2017;53(3):290–9. PMID: 28641912. KQ1E2b, KQ2E2b, KQ3E2b, KQ4E2b.28641912
174 Radovanovic CA, Bevilaqua CA, Molena-Fernandes CA, . Multi-professional intervention in adults with arterial hypertension: a randomized clinical trial. Rev Bras Enferm. 2016;69(6):1067–73. PMID: 27925082. KQ1E2, KQ2E2, KQ3E2, KQ4E2.27925082
175 Redfern J, Usherwood T, Harris MF, . A randomised controlled trial of a consumer-focused e-health strategy for cardiovascular risk management in primary care: the Consumer Navigation of Electronic Cardiovascular Tools (CONNECT) study protocol. BMJ Open. 2014;4(2):e004523. PMID: 24486732. KQ1E4, KQ2E4, KQ3E4, KQ4E4.24486732
176 Rejeski WJ, Axtell R, Fielding R, . Promoting physical activity for elders with compromised function: the lifestyle Interventions and Independence for elders (LIFE) study physical activity intervention. Clin Interv Aging. 2013;8:1119–31. PMID: 24049442. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.24049442
177 Richardson CR, Goodrich DE, Larkin AR, . A comparative effectiveness trial of three walking self-monitoring strategies. Transl J Am Coll Sports Med. 2016;1(15):133–42. PMID: 28529971. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.28529971
178 Ritzwoller DP, Glasgow RE, Sukhanova AY, . Economic analyses of the Be Fit Be Well program: a weight loss program for community health centers. J Gen Intern Med. 2013;28(12):1581–8. KQ1E4, KQ2E4, KQ3E4, KQ4E4.23733374
179 Rodriguez MA, Friedberg JP, DiGiovanni A, . A tailored behavioral intervention to promote adherence to the DASH diet. Am J Health Behav. 2019;43(4):659–70. PMID: 31239010. KQ1E7, KQ2E7, KQ3E7, KQ4E7.31239010
180 Rodriguez-Cano A, Mier-Cabrera J, Balas-Nakash M, . Dietary changes associated with improvement of metabolic syndrome components in postmenopausal women receiving two different nutrition interventions. Menopause. 2015;22(7):758–64. PMID: 25563795. KQ1E2, KQ2E2, KQ3E2, KQ4E2.25563795
181 Ros E, Martinez-Gonzalez MA, Estruch R, . Mediterranean diet and cardiovascular health: teachings of the PREDIMED study. Adv Nutr (Bethesda). 2014;5(3):330S–6S. PMID: 24829485. KQ1E4, KQ2E4, KQ3E4, KQ4E4.24829485
182 Rosas LG, Lv N, Xiao L, . Evaluation of a culturally-adapted lifestyle intervention to treat elevated cardiometabolic risk of Latino adults in primary care (Vida Sana): a randomized controlled trial. Contemp Clin Trials. 2016;48:30–40. PMID: 26995280. KQ1E4, KQ2E4, KQ3E4, KQ4E4.26995280
183 Rosenkilde M, Rygaard L, Nordby P, . Exercise and weight loss effects on cardiovascular risk factors in overweight men. J Appl Physiol. 2018;15:15. PMID: 29543138. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.29543138
184 Roumen C, Feskens EJ, Corpeleijn E, . Predictors of lifestyle intervention outcome and dropout: the SLIM study. Eur J Clin Nutr. 2011;65(10):1141–7. PMID: 21587283. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.21587283
185 Ruzicka M, Ramsay T, Bugeja A, . Does pragmatically structured outpatient dietary counselling reduce sodium intake in hypertensive patients? Study protocol for a randomized controlled trial. Trials. 2015;16:273. PMID: 26081765 KQ1E4, KQ2E4, KQ3E4, KQ4E4.26081765
186 Saboya PP, Bodanese LC, Zimmermann PR, . Lifestyle intervention on metabolic syndrome and its impact on quality of life: a randomized controlled trial. Arq Bras Cardiol. 2017;108(1):60–9. PMID: 27982160. KQ1E2, KQ2E2, KQ3E2, KQ4E2.27982160
187 Saida T, Juul Sorensen T, Langberg H. Long-term exercise adherence after public health training in at-risk adults. Ann Phys Rehabil Med. 2017;60(4):237–43. PMID: 28462861. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.28462861
188 Salas-Salvado J, Diaz-Lopez A, Ruiz-Canela M, . Effect of a lifestyle intervention program with energy-restricted Mediterranean diet and exercise on weight loss and cardiovascular risk factors: one-year results of the PREDIMED-Plus trial. Diabetes Care. 2019;42(5):777–88. PMID: 30389673. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.30389673
189 Santos-Lozano A, Sanz-Ayan P, Gonzalez-Saiz L, . Effects of an 8-month exercise intervention on physical capacity, NT-proBNP, physical activity levels and quality of life data in patients with pulmonary arterial hypertension by NYHA class. Data Brief. 2017;12:37–41. PMID: 28374000. KQ1E3, KQ2E3, KQ3E3, KQ4E3.28374000
190 Schoenthaler A, Teresi J, Luerassi L, . Comparative effectiveness of a practice-based trial of blood pressure control in blacks: is less more? J Gen Intern Med. 2014;29:S54–s5. PMID: None. KQ1E9a, KQ2E9a, KQ3E9a, KQ4E9a.
191 Schroder H, Cardenas-Fuentes G, Martinez-Gonzalez MA, . Effectiveness of the physical activity intervention program in the PREDIMED-Plus study: a randomized controlled trial. Int J Behav Nutr Phys Act. 2018;15(1):110. PMID: 30424822. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.30424822
192 Seguin RA, Paul L, Folta SC, . Strong hearts, healthy communities: a community-based randomized trial for rural women. Obesity. 2018;26(5):845–53. PMID: 29634086. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.29634086
193 Sialvera TE, Papadopoulou A, Efstathiou SP, . Structured advice provided by a dietitian increases adherence of consumers to diet and lifestyle changes and lowers blood low-density lipoprotein (LDL)-cholesterol: the Increasing Adherence of Consumers to Diet & Lifestyle Changes to Lower (LDL) Cholesterol (ACT) randomised controlled trial. J Hum Nutr Diet. 2018;31(2):197–208. PMID: 28891084. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.28891084
194 Siu PM, Yu AP, Benzie IF, . Effects of 1-year yoga on cardiovascular risk factors in middle-aged and older adults with metabolic syndrome: a randomized trial. Diabetol Metab Syndr. 2015;7:40. PMID: 26000038. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a.26000038
195 Soares TS, Piovesan CH, Gustavo Ada S, . Alimentary habits, physical activity, and Framingham global risk score in metabolic syndrome. Arq Bras Cardiol. 2014;102(4):374–82. KQ1E2, KQ2E2, KQ3E2, KQ4E2.24652053
196 Sohl S, Wallston K, Watkins K, . Yoga for risk reduction of metabolic syndrome: patient-reported outcomes from a randomized controlled pilot study. Evid Based Complement Alternat Med. 2016;2016:3094589. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.27847524
197 Soto-Rodríguez A, García-Soidán J, Toro-Santos M, . Clinical trial with educational intervention in perimenopausal women with cardiovascular risk factor. Gac Sanit. 2017;31(1):48–52. PMID: 27793547. KQ1E9, KQ2E9, KQ3E9, KQ4E9.27793547
198 Souza RJ, Ireland C, Pellini C, . Association between changes in plant protein and mineral intakes and blood pressure as part of a dietary portfolio: a randomized controlled trial. FASEB J. 2013;27. KQ1E9a, KQ2E9a, KQ3E9a, KQ4E9a.
199 Spassova L, Vittore D, Droste DW, . Randomised controlled trial to evaluate the efficacy and usability of a computerised phone-based lifestyle coaching system for primary and secondary prevention of stroke. BMC Neurol. 2016;16:22. PMID: 26861865. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.26861865
200 Stewart KJ, Bacher AC, Turner K, . Exercise and risk factors associated with metabolic syndrome in older adults. Am J Prev Med. 2005;28(1):9–18. PMID: 15626550. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.15626550
201 Stuckey MI, Shapiro S, Gill DP, . A lifestyle intervention supported by mobile health technologies to improve the cardiometabolic risk profile of individuals at risk for cardiovascular disease and type 2 diabetes: study rationale and protocol. BMC Public Health. 2013;13:1051. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.24199747
202 Svendsen K, Telle-Hansen VH, Morch-Reiersen LT, . A randomized controlled trial in Norwegian pharmacies on effects of risk alert and advice in people with elevated cardiovascular risk. Prev Med Rep. 2018;12:79–86. PMID: 30191097. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.30191097
203 The Diabetes Prevention Program Research Group. Design and methods for a clinical trial in the prevention of type 2 diabetes. Diabetes Care. 1999;22(4):623–34. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.10189543
204 The Diabetes Prevention Program Research Group. The Diabetes Prevention Program: baseline characteristics of the randomized cohort. Diabetes Care. 2000;23(11):1619–29. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.11092283
205 The Diabetes Prevention Program Research Group. The Diabetes Prevention Program (DPP): description of lifestyle intervention. Diabetes Care. 2002;25(12):2165–71. PMID: 12453955. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.12453955
206 The Diabetes Prevention Program Research Group. Impact of intensive lifestyle and metformin therapy on cardiovascular disease risk factors in the Diabetes Prevention Program. Diabetes Care. 2005;28(4):888–94. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.15793191
207 Tully M, Kos A, Eastwood D, . Implementation of an adjunct strategy to reduce blood pressure in Blacks with uncontrolled hypertension: a pilot project. Ethn Dis. 2015;25(2):168–74. PMID: 26118144. KQ1E6a, KQ2E6a, KQ3E6a, KQ4E6a.26118144
208 Tuomilehto J, Lindstrom J, Eriksson JG, . Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. New Engl J Med. 2001;344:1343–50. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.11333990
209 Tyson CC, Appel LJ, Vollmer WM, . Impact of 5-year weight change on blood pressure: results from the Weight Loss Maintenance trial. J Clin Hypertens (Greenwich). 2013;15(7):458–64. PMID: 23815533. KQ1E4, KQ2E4, KQ3E4, KQ4E4.23815533
210 Uusitupa M, Louheranta A, Lindstrom J, . The Finnish Diabetes Prevention Study. Br J Nutr. 2000;83: Suppl 1:S137–S42. PMID: 10889804. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.10889804
211 Uusitupa M, Peltonen M, Lindstrom J, . Ten-year mortality and cardiovascular morbidity in the Finnish Diabetes Prevention Study-secondary analysis of the randomized trial. PLoS One. 2009;4(5):e5656. PMID: 19479072. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.19479072
212 Van Roie E, Delecluse C, Opdenacker J, . Effectiveness of a lifestyle physical activity versus a structured exercise intervention in older adults. J Aging Phys Act. 2010;18(3):335–52. PMID: 20651418. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.20651418
213 Varleta P, Acevedo M, Akel C, . Mobile phone text messaging improves antihypertensive drug adherence in the community. J Clin Hypertens (Greenwich). 2017;19(12):1276–84. PMID: 28941056. KQ1E5, KQ2E5, KQ3E5, KQ4E5.28941056
214 Vermunt PW, Milder IE, Wielaard F, . Lifestyle counseling for type 2 diabetes risk reduction in Dutch primary care: results of the APHRODITE study after 0.5 and 1.5 years. Diabetes Care. 2011;34(9):1919–25. PMID: 21775759. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d21775759
215 Vermunt PW, Milder IE, Wielaard F, . An active strategy to identify individuals eligible for type 2 diabetes prevention by lifestyle intervention in Dutch primary care: the APHRODITE study. Fam Pract. 2010;27(3):312–9. PMID: 20089573. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.20089573
216 Verrusio W, Andreozzi P, Renzi A, . Efficacy and safety of spinning exercise in middle-aged and older adults with metabolic syndrome: randomized control trial. Ann Ist Super Sanita. 2016;52(2):295–300. PMID: 27364407. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.27364407
217 Wade AT, Davis CR, Dyer KA, . A Mediterranean diet supplemented with dairy foods improves markers of cardiovascular risk: results from the MedDairy randomized controlled trial. Am J Clin Nutr. 2018;108(6):1166–82. PMID: 30351388. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.30351388
218 Wallace S, O’Neill R, McGowan L, . Can self-reported oral health status impact change in Mediterranean diet score and nutrient intake amongst adults at a high risk of cardiovascular disease in Northern Ireland? (P12-019-19). Curr Devel Nutr. 2019;3(Suppl 1). PMID: 31224675. KQ1E9a, KQ2E9a, KQ3E9a, KQ4E9a.
219 Wang J, Olendzki BC, Wedick NM, . Challenges in sodium intake reduction and meal consumption patterns among participants with metabolic syndrome in a dietary trial. Nutr J. 2013;12:163. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.24345027
220 Watanabe M, Yamaoka K, Yokotsuka M, . Randomized controlled trial of a new dietary education program to prevent type 2 diabetes in a high-risk group of Japanese male workers. Diabetes Care. 2003;26(12):3209–14. PMID: 14633803. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.14633803
221 Watson S, Woodside JV, Ware LJ, . Effect of a web-based behavior change program on weight loss and cardiovascular risk factors in overweight and obese adults at high risk of developing cardiovascular disease: randomized controlled trial. J Med Internet Res. 2015;17(7):e177. PMID: 26183659. KQ1E7, KQ2E7, KQ3E7, KQ4E7.26183659
222 Wilbur J, Miller AM, Buchholz SW, . African-American women’s long-term maintenance of physical activity following a randomized controlled trial. Am J Health Behav. 2017;41(4):484–96. PMID: 28601108. KQ1E6c, KQ2E6c, KQ3E6c, KQ4E6c.28601108
223 Williams SL, French DP. Theory of planned behaviour variables and objective walking behaviour do not show seasonal variation in a randomised controlled trial. BMC Public Health. 2014;14:120. PMID: 24499405. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.24499405
224 Williams SL, Michie S, Dale J, . The effects of a brief intervention to promote walking on Theory of Planned Behavior constructs: a cluster randomized controlled trial in general practice. Patient Educ Couns. 2015;98(5):651–9. PMID: 25677127. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.25677127
225 Wiseman LB. A study of autonomy support for recommended lifestyle changes with a vulnerable hypertensive sample: utility of self-determination theory. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2018;78(11-B(E)):No Pagination Specified. KQ1E6b, KQ2E6b, KQ3E6b, KQ4E6b.
226 Wong A, Figueroa A, Son WM, . The effects of stair climbing on arterial stiffness, blood pressure, and leg strength in postmenopausal women with stage 2 hypertension. Menopause. 2018;25(7):731–7. PMID: 29438269. KQ1E5b, KQ2E5b, KQ3E5b, KQ4E5b.29438269
227 Wong EM, Chair SY, Leung DY, . Home-based interactive e-health educational intervention for middle-aged adults to improve total exercise, adherence rate, exercise efficacy, and outcome: a randomised controlled trial. Hong Kong Med. 2018;24 Suppl 2(1):34–8. PMID: 29938656. KQ1E3a, KQ2E3a, KQ3E3a, KQ4E3a.29938656
228 Yamashiro T, Nishikawa T, Isami S, . The effect of group-based lifestyle interventions on risk factors and insulin resistance in subjects at risk for metabolic syndrome: the Tabaruzaka Study 1. Diabetes Obes Metab. 2010;12(9):790–7. PMID: 20649631. KQ1E6, KQ2E6, KQ3E6, KQ4E6.20649631
229 Yang Y, Tian CH, Cao J, . Research on the application of health management model based on the perspective of mobile health. Medicine (Baltimore). 2019;98(33):e16847. PMID: 31415411. KQ1E2a, KQ2E2a, KQ3E2a, KQ4E2a.31415411
230 Yates T, Davies M, Gorely T, . Rationale, design and baseline data from the Pre-diabetes Risk Education and Physical Activity Recommendation and Encouragement (PREPARE) programme study: a randomized controlled trial. Patient Educ Couns. 2008;73(2):264–71. PMID: 18653305. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.18653305
231 Yates T, Davies M, Gorely T, . Effectiveness of a pragmatic education program designed to promote walking activity in individuals with impaired glucose tolerance: a randomized controlled trial. Diabetes Care. 2009;32(8):1404–10. PMID: 19602539. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.19602539
232 Yates T, Davies MJ, Gorely T, . The effect of increased ambulatory activity on markers of chronic low-grade inflammation: evidence from the PREPARE programme randomized controlled trial. Diabet Med. 2010;27(11):1256–63. PMID: 20950383. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.20950383
233 Yates T, Davies MJ, Sehmi S, . The Pre-diabetes Risk Education and Physical Activity Recommendation and Encouragement (PREPARE) programme study: are improvements in glucose regulation sustained at 2 years? Diabet Med. 2011;28(10):1268–71. KQ1E3d, KQ2E3d, KQ3E3d, KQ4E3d.21672008
234 Young D, Camhi S, Wu T, . Relationships among changes in C-reactive protein and cardiovascular disease risk factors with lifestyle interventions. Nutr Metab Cardiovasc Dis. 2013;23(9):857–63. PMID: 22831953. KQ1E4, KQ2E4, KQ3E4, KQ4E4.22831953
235 Young DR, King AC, Sheehan M, . Stage of motivational readiness: predictive ability for exercise behavior. Am J Health Behav. 2002;26(5):331–41. PMID: 12206443. KQ1E4, KQ2E4, KQ3E4, KQ4E4.12206443
236 Zgibor JC, Ye L, Boudreau RM, . Community-based healthy aging interventions for older adults with arthritis and multimorbidity. J Community Health. 2017;42(2):390–9. PMID: 27900515. KQ1E3b, KQ2E3b, KQ3E3b, KQ4E3b.27900515
237 Ziv A, Vogel O, Keret D, . Comprehensive Approach to Lower Blood Pressure (CALM-BP): a randomized controlled trial of a multifactorial lifestyle intervention. J Hum Hypertens. 2013;27(10):594–600. PMID: 23595161. KQ1E5a, KQ2E5a, KQ3E5a, KQ423595161