# Appendix C List of Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

1. Ammerman AS, Keyserling TC, Atwood JR, . A randomized controlled trial of a public health nurse directed treatment program for rural patients with high blood cholesterol. Prev Med. 2003;36(3):340–51. PMID: 12634025.12634025
  a. Keyserling TC, Ammerman AS, Atwood JR, . A cholesterol intervention program for public health nurses in the rural southeast: description of the intervention, study design, and baseline results. Public Health Nurs. 1999;16(3):156–67. PMID: 10388332. 10.1046/j.1525-1446.1999.00156.x 10388332
2. Anderson JW, Garrity TF, Wood CL, . Prospective, randomized, controlled comparison of the effects of low-fat and low-fat plus high-fiber diets on serum lipid concentrations. Am J Clin Nutr. 1992;56(5):887–94. PMID: 1329482.1329482
3. Anderssen SA, Haaland A, Hjerman I, et al.. Oslo diet and exercise study: a one year randomized intervention trial. Efect on Haemostatic variables and other coronary risk factors. Nutr Metab Cardiovasc Dis. 1995;5:189–200. PMID: 8339552. 10.1016/0197-2456(93)90005-X 8339552
  a. Anderssen SA, Carroll S, Urdal P, . Combined diet and exercise intervention reverses the metabolic syndrome in middle-aged males: results from the Oslo Diet and Exercise Study. Scand J Med Sci Sports. 2007;17(6):687–95. PMID: 17331082. 10.1111/j.1600-0838.2006.00631.x 17331082
  b. Anderssen SA, Hjermann I, Urdal P, . Improved carbohydrate metabolism after physical training and dietary intervention in individuals with the “atherothrombogenic syndrome’. Oslo Diet and Exercise Study (ODES). A randomized trial. J Intern Med. 1996;240(4):203–9. PMID: None. 10.1046/j.1365-2796.1996.22848000.x 8918511
  c. Anderssen S, Holme I, Urdal P, . Diet and exercise intervention have favourable effects on blood pressure in mild hypertensives: the Oslo Diet and Exercise Study (ODES). Blood Press. 1995;4(6):343–9. PMID: None. 10.1111/j.1365-2796.1994.tb00858.x 8746601
  d. Jacobs DR, Jr., Sluik D, Rokling-Andersen MH, . Association of 1-y changes in diet pattern with cardiovascular disease risk factors and adipokines: results from the 1-y randomized Oslo Diet and Exercise Study. Am J Clin Nutr. 2009;89(2):509–17. PMID: 19116328. 10.3945/ajcn.2008.26371 19116328
  e. Odes Investigators. The Oslo Diet and Exercise Study (ODES): design and objectives. Control Clin Trials. 1993;14(3):229–43. PMID: 8339552. 10.1016/0197-2456(93)90005-X 8339552
  f. Reseland JE, Anderssen SA, Solvoll K, . Effect of long-term changes in diet and exercise on plasma leptin concentrations. Am J Clin Nutr. 2001;73(2):240–5. PMID: 11157319. 10.1093/ajcn/73.2.240\ 11157319
  g. Torjesen PA, Birkeland KI, Anderssen SA, . Lifestyle changes may reverse development of the insulin resistance syndrome. The Oslo Diet and Exercise Study: a randomized trial. Diabetes Care. 1997;20(1):26–31. PMID: 9028689.9028689
4. Appel L, Clark J, Yeh H, . Comparative effectiveness of weight-loss interventions in clinical practice. N Engl J Med. 2011;365(21):1959–68. PMID: 22085317. 10.1056/NEJMoa1108660 22085317
  a. Jerome GJ, Dalcin A, Coughlin JW, . Longitudinal accuracy of web-based self-reported weights: results from the Hopkins POWER Trial. J Med Internet Res. 2014;16(7):e173. PMID: 25042773. 10.2196/jmir.3332 25042773
  b. Rubin RR, Peyrot M, Wang NY, . Patient-reported outcomes in the practice-based opportunities for weight reduction (POWER) trial. Qual Life Res. 2013;22(9):2389–98. PMID: 23515902. 10.1007/s11136-013-0363-3 23515902
5. Appel LJ, Champagne CM, Harsha DW, . Effects of comprehensive lifestyle modification on blood pressure control: main results of the PREMIER clinical trial. JAMA. 2003;289(16):2083–93. PMID: 12709466. 10.1001/jama.289.16.2083 12709466
  a. Crist LA, Champagne CM, Corsino L, . Influence of change in aerobic fitness and weight on prevalence of metabolic syndrome. Prev Chronic Dis. 2012;9:E68. PMID: 22405475. 10.5888/pcd9.110171 22405475
  b. Elmer PJ, Obarzanek E, Vollmer WM, . Effects of comprehensive lifestyle modification on diet, weight, physical fitness, and blood pressure control: 18-month results of a randomized trial. Ann Intern Med. 2006;144(7):485–95. PMID: 16585662. 10.7326/ACPJC-2006-145-2-042 16585662
  c. Funk KL, Elmer PJ, Stevens VJ, . PREMIER-a trial of lifestyle interventions for blood pressure control: intervention design and rationale. Health Promot Pract. 2008;9(3):271–80. PMID: 16803935. 10.1177/1524839906289035 16803935
  d. Lien LF, Brown AJ, Ard JD, . Effects of PREMIER lifestyle modifications on participants with and without the metabolic syndrome. Hypertension. 2007;50(4):609–16. PMID: 17698724. 10.1161/HYPERTENSIONAHA.107.089458 17698724
  e. Lin PH, Appel LJ, Funk K, . The PREMIER intervention helps participants follow the Dietary Approaches to Stop Hypertension dietary pattern and the current Dietary Reference Intakes recommendations. J Am Diet Assoc. 2007;107(9):1541–51. PMID: 17761231. 10.1016/j.jada.2007.06.019 17761231
  f. Maruthur NM, Wang NY, Appel LJ. Lifestyle interventions reduce coronary heart disease risk: results from the PREMIER Trial. Circulation. 2009;119(15):2026–31. PMID: 19349322. 10.1161/CIRCULATIONAHA.108.809491 19349322
  g. Svetkey LP, Erlinger TP, Vollmer WM, . Effect of lifestyle modifications on blood pressure by race, sex, hypertension status, and age. J Hum Hypertens. 2005;19(1):21–31. PMID: 15385946. 10.1038/sj.jhh.1001770 15385946
  h. Young DR, Coughlin J, Jerome GJ, . Effects of the PREMIER interventions on health-related quality of life. Ann Behav Med. 2010;40(3):302–12. PMID: 20799005. 10.1007/s12160-010-9220-6 20799005
  i. Young DR, Vollmer WM, King AC, . Can individuals meet multiple physical activity and dietary behavior goals? Am J Health Behav. 2009;33(3):277–86. PMID: 19063649. 10.5993/AJHB.33.3.6 19063649
6. Applegate WB, Miller ST, Elam JT, . Nonpharmacologic intervention to reduce blood pressure in older patients with mild hypertension. Arch Intern Med. 1992;152(6):1162–6. PMID: 1599343. 10.1001/archinte.1992.00400180034005 1599343
7. Arroll B, Beaglehole R. Salt restriction and physical activity in treated hypertensives. N Z Med J. 1995;108(1003):266–8. PMID: 7637923.7637923
8. Babazono A, Kame C, Ishihara R, . Patient-motivated prevention of lifestyle-related disease in Japan: A randomized, controlled clinical trial. Dis Manage Health Outcomes. 2007;15(2):119–26. PMID: None. 10.2165/00115677-200715020-00007
9. Beckmann SL, Os I, Kjeldsen SE, . Effect of dietary counselling on blood pressure and arterial plasma catecholamines in primary hypertension. Am J Hypertens. 1995;8(7):704–11. PMID: 7546496.7546496
10. Bennett GG, Steinberg D, Askew S, . Effectiveness of an app and provider counseling for obesity treatment in primary care. Am J Prev Med. 2018;55(6):777–786. PMID: 30361140. 10.1016/j.amepre.2018.07.005 30361140
  a. Foley P, Steinberg D, Levine E, . Track: a randomized controlled trial of a digital health obesity treatment intervention for medically vulnerable primary care patients. Contemp Clin Trials. 2016;48:12–20. PMID: 26995281. 10.1016/j.cct.2016.03.006 26995281
  b. Steinberg D, Kay M, Burroughs J, . The effect of a digital behavioral weight loss intervention on adherence to the Dietary Approaches to Stop Hypertension (DASH) dietary pattern in medically vulnerable primary care patients: results from a randomized controlled trial. J Acad Nutr Diet. 2019;119(4):574–84. PMID: 30905430. 10.1016/j.jand.2018.12.011 30905430
11. Bennett GG, Warner ET, Glasgow RE, . Obesity treatment for socioeconomically disadvantaged patients in primary care practice. Arch Intern Med. 2012;172(7):565–74. PMID: 22412073 10.1001/archinternmed.2012.1 22412073
  a. Greaney ML, Quintiliani LM, Warner ET, . Weight management among patients at community health centers: the “Be Fit, Be Well” study. Obes Weight Manag. 2009;5(5):222–8. PMID: None. 10.1089/obe.2009.0507
12. Beune EJ, Moll van Charante EP, Beem L, . Culturally adapted hypertension education (CAHE) to improve blood pressure control and treatment adherence in patients of African origin with uncontrolled hypertension: cluster-randomized trial. PLoS One. 2014;9(3):e90103. PMID: 24598584. 10.1371/journal.pone.0090103 24598584
  a. Haafkens JA, Beune EJ, Moll van Charante EP, . A cluster-randomized controlled trial evaluating the effect of culturally-appropriate hypertension education among Afro-Surinamese and Ghanaian patients in Dutch general practice: study protocol. BMC Health Serv Res. 2009;9:193. PMID: 19849857. 10.1186/1472-6963-9-193 19849857
13. Blackford K, Jancey J, Lee AH, . Home-based lifestyle intervention for rural adults improves metabolic syndrome parameters and cardiovascular risk factors: a randomised controlled trial. Prev Med. 2016;89:15–22. PMID: 27196148. 10.1016/j.ypmed.2016.05.012 27196148
  a. Blackford K, Jancey J, Lee AH, . Effects of a home-based intervention on diet and physical activity behaviours for rural adults with or at risk of metabolic syndrome: a randomised controlled trial. Int J Behav Nutr Phys Act. 2016;13:13. PMID: 26830197. 10.1186/s12966-016-0337-2 26830197
  b. Blackford K, Jancey J, Lee AH, . A randomised controlled trial of a physical activity and nutrition program targeting middle-aged adults at risk of metabolic syndrome in a disadvantaged rural community. BMC Public Health. 2015;15:284. PMID: 25885657. 10.1186/s12889-015-1613-9 25885657
  c. Blackford K, Lee A, James AP, . Process evaluation of the Albany Physical Activity and Nutrition (APAN) program, a home-based intervention for metabolic syndrome and associated chronic disease risk in rural Australian adults. Health Promot J Austr. 2017;28(1):8–14. PMID: 27426475. 10.1071/HE16027 27426475
14. Bloemberg BP, Kromhout D, Goddijn HE, . The impact of the Guidelines for a Healthy Diet of The Netherlands Nutrition Council on total and high density lipoprotein cholesterol in hypercholesterolemic free-living men. Am J Epidemiol. 1991;134(1):39–48. PMID: 1853859.1853859
15. Bo S, Ciccone G, Baldi C, . Effectiveness of a lifestyle intervention on metabolic syndrome. A randomized controlled trial. J Gen Intern Med. 2007;22(12):1695–703. PMID: 17922167. 10.1007/s11606-007-0399-6 17922167
  a. Ponzo V, Gentile L, Gambino R, . Incidence of diabetes mellitus, cardiovascular outcomes and mortality after a 12-month lifestyle intervention: a 9-year follow-up. Diabetes Metab. 2018;44(5):449–51. PMID: 29773350. 10.1016/j.diabet.2018.04.008 29773350
16. Bosworth HB, Olsen MK, Grubber JM, . Two self-management interventions to improve hypertension control: a randomized trial. Ann Intern Med. 2009;151(10):687–95. PMID: 19920269. 10.7326/0003-4819-151-10-200911170-00148 19920269
17. Broekhuizen K, van Poppel MN, Koppes LL, . Can multiple lifestyle behaviours be improved in people with familial hypercholesterolemia? Results of a parallel randomised controlled trial. PLoS One. 2012;7(12):e50032. PMID: 23251355. 10.1371/journal.pone.0050032 23251355
  a. Broekhuizen K, Jelsma JG, van Poppel MN, . Is the process of delivery of an individually tailored lifestyle intervention associated with improvements in LDL cholesterol and multiple lifestyle behaviours in people with familial hypercholesterolemia? BMC Public Health. 2012;12:348. PMID: 22583789. 10.1186/1471-2458-12-348 22583789
  b. Broekhuizen K, van Poppel MN, Koppes LL, . No significant improvement of cardiovascular disease risk indicators by a lifestyle intervention in people with familial hypercholesterolemia compared to usual care: results of a randomised controlled trial. BMC Res Notes. 2012;5:181. PMID: 22490761. 10.1186/1756-0500-5-181 22490761
  c. Broekhuizen K, van Poppel MN, Koppes LL, . A tailored lifestyle intervention to reduce the cardiovascular disease risk of individuals with Familial Hypercholesterolemia (FH): design of the PRO-FIT randomised controlled trial. BMC Public Health. 2010;10:69. PMID: 20156339. 10.1186/1471-2458-10-69 20156339
18. Bruckert E, Giral P, Paillard F, . Effect of an educational program (PEGASE) on cardiovascular risk in hypercholesterolaemic patients. Cardiovasc Drugs Ther. 2008;22(6):495–505. PMID: 18830810. 10.1007/s10557-008-6137-4 18830810
19. Burke V, Beilin L, Cutt H, . A lifestyle program for treated hypertensives improves cardiovascular risk factors: a randomized controlled trial. Atheroscler Suppl. 2006;7:386. PMID: 17208119. 10.1016/j.jclinepi.2006.05.012 17208119
  a. Burke V, Beilin LJ, Cutt HE, . Effects of a lifestyle programme on ambulatory blood pressure and drug dosage in treated hypertensive patients: a randomized controlled trial. J Hypertens. 2005;23(6):1241–9. PMID: 15894901. 10.1097/01.hjh.0000170388.61579.4f 15894901
  b. Burke V, Beilin LJ, Cutt HE, . Moderators and mediators of behaviour change in a lifestyle program for treated hypertensives: a randomized controlled trial (ADAPT). Health Educ Res. 2008;23(4):583–91. PMID: 17890759. 10.1093/her/cym047 17890759
  c. Burke V, Mansour J, Beilin LJ, . Long-term follow-up of participants in a health promotion program for treated hypertensives (ADAPT). Nutr Metab Cardiovasc Dis. 2008;18(3):198–206. PMID: 17327140. 10.1016/j.numecd.2006.10.004 17327140
20. Chirinos DA, Goldberg RB, Llabre MM, . Lifestyle modification and weight reduction among low-income patients with the metabolic syndrome: the CHARMS randomized controlled trial. J Behav Med. 2016;39(3):483–92. PMID: 26846133. 10.1007/s10865-016-9721-2 26846133
21. Christian JG, Byers TE, Christian KK, . A computer support program that helps clinicians provide patients with metabolic syndrome tailored counseling to promote weight loss. J Am Diet Assoc. 2011;111(1):75–83. PMID: 21185968. 10.1016/j.jada.2010.10.006 21185968
22. Cicolini G, Simonetti V, Comparcini D, . Efficacy of a nurse-led email reminder program for cardiovascular prevention risk reduction in hypertensive patients: a randomized controlled trial. Int J Nurs Stud. 2014;51(6):833–43. PMID: 24225325. 10.1016/j.ijnurstu.2013.10.010 24225325
23. Cochrane T, Davey R, Iqbal Z, . NHS health checks through general practice: randomised trial of population cardiovascular risk reduction. BMC Public Health. 2012;12:944. PMID: 23116213. 10.1186/1471-2458-12-944 23116213
  a. Davey R, Cochrane T, Iqbal Z, . Randomised controlled trial of additional lifestyle support for the reduction of cardiovascular disease risk through primary care in Stoke-on-Trent, UK. Contemp Clin Trials. 2010;31(4):345–54. PMID: None. 10.1016/j.cct.2010.04.002 20430115
24. Cohen MD, D’Amico FJ, Merenstein JH. Weight reduction in obese hypertensive patients. Fam Med. 1991;23(1):25–8. PMID: 2001777.2001777
25. Coleman KJ, Farrell MA, Rocha DA, . Readiness to be physically active and self-reported physical activity in low-income Latinas, California WISEWOMAN, 2006-2007. Prev Chronic Dis. 2012;9:E87. PMID: 22515969. 10.5888/pcd9.110190 22515969
  a. Hayashi T, Farrell MA, Chaput LA, . Lifestyle intervention, behavioral changes, and improvement in cardiovascular risk profiles in the California WISEWOMAN project. J Womens Health (Larchmt). 2010;19(6):1129–38. PMID: 20509780. 10.1089/jwh.2009.1631 20509780
  b. Farrell MA, Hayashi T, Loo RK, . Clinic-based nutrition and lifestyle counseling for hispanic women delivered by community health workers: design of the California WISEWOMAN Study. J Womens Health (Larchmt). 2009;18(5):733–9. PMID: 19445619. 10.1089/jwh.2008.0871 19445619
26. Delahanty LM, Sonnenberg LM, Hayden D, . Clinical and cost outcomes of medical nutrition therapy for hypercholesterolemia: a controlled trial. J Am Diet Assoc. 2001;101(9):1012–23. PMID: 11573752. 10.1016/S0002-8223(01)00250-4 11573752
27. Eakin E, Reeves M, Lawler S, . Telephone counseling for physical activity and diet in primary care patients. Am J Prev Med. 2009;36(2):142–9. PMID: 19062240. 10.1016/j.amepre.2008.09.042 19062240
  a. Eakin E, Reeves M, Winkler E, . Maintenance of physical activity and dietary change following a telephone-delivered intervention. Health Psychol. 2010;29(6):566–73. PMID: 20954778. 10.1037/a0021359 20954778
  b. Eakin EG, Reeves MM, Lawler SP, . The Logan Healthy Living Program: a cluster randomized trial of a telephone-delivered physical activity and dietary behavior intervention for primary care patients with type 2 diabetes or hypertension from a socially disadvantaged community-rationale, design and recruitment. Contemp Clin Trials. 2008;29:439–54. PMID: 18055274. 10.1016/j.cct.2007.10.005 18055274
  c. Lawler SP, Winkler EA, Goode AD, . Moderators of health behavior initiation and maintenance in a randomized telephone counseling trial. Prev Med. 2014;61:34–41. PMID: 24412896. 10.1016/j.ypmed.2014.01.002 24412896
28. Edelman D, Oddone EZ, Liebowitz RS, . A multidimensional integrative medicine intervention to improve cardiovascular risk. J Gen Intern Med. 2006;21(7):728–34. PMID: 16808774. 10.1111/j.1525-1497.2006.00495.x 16808774
29. Ellsworth DL, Costantino NS, Blackburn HL, . Lifestyle modification interventions differing in intensity and dietary stringency improve insulin resistance through changes in lipoprotein profiles. Obes. 2016;2(3):282–92. PMID: 27708845. 10.1002/osp4.54 27708845
30. Estruch R, Ros E, Salas-Salvado J, . Primary prevention of cardiovascular disease with a Mediterranean diet supplemented with extra-virgin olive oil or nuts. N Engl J Med. 2018;378(25):e34. PMID: 29897866. 10.1056/NEJMoa1800389 29897866
  a. Babio N, Toledo E, Estruch R, . Mediterranean diets and metabolic syndrome status in the PREDIMED randomized trial. CMAJ. 2014;186(17):E649–57. PMID: 25316904. 10.1503/cmaj.140764 25316904
  b. Domenech M, Roman P, Lapetra J, . Mediterranean diet reduces 24-hour ambulatory blood pressure, blood glucose, and lipids: one-year randomized, clinical trial. Hypertension. 2014;64(1):69–76. PMID: 24799608. 10.1161/HYPERTENSIONAHA.113.03353 24799608
  c. Downer MK, Gea A, Stampfer M, . Predictors of short- and long-term adherence with a Mediterranean-type diet intervention: the PREDIMED randomized trial. Int J Behav Nutr Phys Act. 2016;13:67. PMID: 27297426. 10.1186/s12966-016-0394-6 27297426
  d. Estruch R, Martinez-Gonzalez MA, Corella D, . Effect of a high-fat Mediterranean diet on bodyweight and waist circumference: a prespecified secondary outcomes analysis of the PREDIMED randomised controlled trial. Lancet Diabetes Endocrinol. 2016;4(8):666–76. PMID: 27283479. 10.1016/S2213-8587(16)30085-7 27283479
  e. Estruch R, Martinez-Gonzalez MA, Corella D, . Effect of a high-fat Mediterranean diet on bodyweight and waist circumference: a prespecified secondary outcomes analysis of the PREDIMED randomised controlled trial. Lancet Diabetes Endocrinol. 2019;7(5):e6–e17. PMID: 31003626. 10.1016/S2213-8587(19)30074-9 31003626
  f. Estruch R, Ros E, Salas-Salvado J, . Primary prevention of cardiovascular disease with a Mediterranean diet.[Erratum appears in N Engl J Med. 2014 Feb 27;370(9):886]. New Engl J Med. 2013;368(14):1279–90. PMID: 23432189. 10.1056/NEJMoa1200303 23432189
  g. Lau CJ, Pisinger C, Husemoen LL, . Effect of general health screening and lifestyle counselling on incidence of diabetes in general population: Inter99 randomised trial. Prev Med. 2016;91:172–9. PMID: 27514243. 10.1016/j.ypmed.2016.08.016 27514243
  h. Martinez-Gonzalez MA, Salas-Salvado J, Estruch R, . Benefits of the Mediterranean diet: insights from the PREDIMED Study. Prog Cardiovasc Dis. 2015;58(1):50–60. PMID: 25940230. 10.1016/j.pcad.2015.04.003 25940230
  i. Martinez-Gonzalez MA, Toledo E, Aros F, . Extravirgin olive oil consumption reduces risk of atrial fibrillation: the PREDIMED (Prevencion con Dieta Mediterranea) trial. Circulation. 2014;130(1):18–26. PMID: 24787471. 10.1161/CIRCULATIONAHA.113.006921 24787471
  j. Mitjavila MT, Fandos M, Salas-Salvado J, . The Mediterranean diet improves the systemic lipid and DNA oxidative damage in metabolic syndrome individuals. A randomized, controlled, trial. Clin Nutr. 2013;32(2):172–8. PMID: 22999065. 10.1016/j.clnu.2012.08.002 22999065
  k. Ruiz-Canela M, Estruch R, Corella D, . Association of Mediterranean diet with peripheral artery disease: The PREDIMED randomized trial. JAMA. 2014;311(4):415–7. PMID: 24449321. 10.1001/jama.2013.280618 24449321
  l. Salas-Salvado J, Bullo M, Babio N, . Erratum. Reduction in the incidence of type 2 diabetes with the Mediterranean diet: results of the PREDIMED-Reus nutrition intervention randomized trial. Diabetes Care. 2018;41(10):2259–60. PMID: 30104300. 10.2337/dc18-er10 30104300
  m. Salas-Salvado J, Bullo M, Estruch R, . Prevention of diabetes with Mediterranean diets: a subgroup analysis of a randomized trial. Ann Intern Med. 2014;160(1):1–10. PMID: 24573661. 10.7326/M13-1725 24573661
31. Fagerberg B, Wikstrand J, Berglund G, . Mortality rates in treated hypertensive men with additional risk factors are high but can be reduced: a randomized intervention study. Am J Hypertens. 1998;11(1 Pt 1):14–22. PMID: None. 10.1016/S0895-7061(97)00363-4 9504445
  a. Agewall S, Fagerberg B, Berglund G, . Multiple risk intervention trial in high risk hypertensive men: comparison of ultrasound intima-media thickness and clinical outcome during 6 years of follow-up. J Intern Med. 2001;249(4):305–14. PMID: 11298850. 10.1046/j.1365-2796.2001.00818.x 11298850
  b. Agewall S, Fagerberg B, Samuelsson O, . Multiple cardiovascular risk factor intervention in treated hypertensive men: what can be achieved? Nutr Metab Cardiovasc Dis. 1993;3:128–35. PMID: None. 10.1111/j.1365-2796.1994.tb00858.x
  c. Agewall S, Wikstrand J, Dahlof C, . A randomized study of quality of life during multiple risk factor intervention in treated hypertensive men at high cardiovascular risk. J Hypertens. 1995;13(12 Pt 1):1471–7.8866910
  d. Agewall S, Wikstrand J, Samuelsson O, . The efficacy of multiple risk factor intervention in treated hypertensive men during long-term follow up. Risk Factor Intervention Study Group. J Intern Med. 1994;236(6):651–9. PMID: 7989900.7989900
32. Greaves C, Gillison F, Stathi A, . Waste the waist: a pilot randomised controlled trial of a primary care based intervention to support lifestyle change in people with high cardiovascular risk. Int J Behav Nutr Phys Act. 2015;12:1. PMID: 25592201. 10.1186/s12966-014-0159-z 25592201
  a. Gillison F, Greaves C, Stathi A, . ‘Waste the Waist’: the development of an intervention to promote changes in diet and physical activity for people with high cardiovascular risk. Br J Health Psychol. 2012;17(2):327–45. PMID: 22107451. 10.1111/j.2044-8287.2011.02040.x 22107451
  b. Gillison F, Stathi A, Reddy P, . Processes of behavior change and weight loss in a theory-based weight loss intervention program: a test of the process model for lifestyle behavior change. Int J Behav Nutr Phys Act. 2015;12(2). PMID: 25592314. 10.1186/s12966-014-0160-6 25592314
33. Gill DP, Blunt W, Boa Sorte Silva NC, . The HealtheStepsTM lifestyle prescription program to improve physical activity and modifiable risk factors for chronic disease: a pragmatic randomized controlled trial. BMC Public Health. 2019;19(1):841. PMID: 31253112. 10.1186/s12889-019-7141-2 31253112
  a. Gill DP, Blunt W, Bartol C, . HealtheStepsTM Study Protocol: a pragmatic randomized controlled trial promoting active living and healthy lifestyles in at-risk Canadian adults delivered in primary care and community-based clinics. BMC Public Health. 2017;17(1):173. PMID: 28173782. 10.1186/s12889-017-4047-8 28173782
34. Gill R, Superko HR, McCarthy MM, . Cardiovascular risk factor reduction in first responders resulting from an individualized lifestyle and blood test program: a randomized controlled trial. J Occup Environ Med. 2019;61(3):183–9. PMID: 30475306. 10.1097/JOM.0000000000001490 30475306
35. Groeneveld IF, Proper KI, van der Beek AJ, . Sustained body weight reduction by an individual-based lifestyle intervention for workers in the construction industry at risk for cardiovascular disease: results of a randomized controlled trial. Prev Med. 2010;51(3–4):240–6. PMID: 20692282. 10.1016/j.ypmed.2010.07.021 20692282
  a. Groeneveld IF, Proper KI, Absalah S, . An individually based lifestyle intervention for workers at risk for cardiovascular disease: a process evaluation. Am J Health Promot. 2011;25(6):396–401. PMID: 21721966. 10.4278/ajhp.091001-QUAN-319 21721966
  b. Groeneveld IF, Proper KI, van der Beek AJ, . Design of a RCT evaluating the (cost-) effectiveness of a lifestyle intervention for male construction workers at risk for cardiovascular disease: the health under construction study. BMC Public Health. 2008;8:1. PMID: 18173844. 10.1186/1471-2458-8-1 18173844
36. Hardcastle S, Taylor A, Bailey M, . A randomised controlled trial on the effectiveness of a primary health care based counselling intervention on physical activity, diet and CHD risk factors. Patient Educ Couns. 2008;70(1):31–9. PMID: 17997263. 10.1016/j.pec.2007.09.014 17997263
  a. Hardcastle SJ, Taylor AH, Bailey MP, . Effectiveness of a motivational interviewing intervention on weight loss, physical activity and cardiovascular disease risk factors: a randomised controlled trial with a 12-month post-intervention follow-up. Int J Behav Nutr Phys Act. 2013;10:40. PMID: 23537492. 10.1186/1479-5868-10-40 23537492
37. Harris MF, Fanaian M, Jayasinghe UW, . A cluster randomised controlled trial of vascular risk factor management in general practice. Med J Aust. 2012;197(7):387–93. PMID: 23025735. 10.5694/mja12.10313 23025735
  a. Fanaian M, Laws RA, Passey M, . Health improvement and prevention study (HIPS) - evaluation of an intervention to prevent vascular disease in general practice. BMC Fam Pract. 2010;11:57. PMID: 20687956. 10.1186/1471-2296-11-57 20687956
38. Haufe S, Kerling A, Protte G, . Telemonitoring-supported exercise training, metabolic syndrome severity, and work ability in company employees: a randomised controlled trial. Lancet Public Health. 2019;4(7):e343–e52. PMID: 31204284. 10.1016/S2468-2667(19)30075-1 31204284
39. Hinderliter AL, Sherwood A, Craighead LW, . The long-term effects of lifestyle change on blood pressure: One-year follow-up of the ENCORE study. Am J Hypertens. 2014;27(5):734–41. PMID: 24084586. 10.1093/ajh/hpt183 24084586
  a. Blumenthal JA, Babyak MA, Hinderliter A, . Effects of the DASH diet alone and in combination with exercise and weight loss on blood pressure and cardiovascular biomarkers in men and women with high blood pressure: the ENCORE study. Arch Intern Med. 2010;170(2):126–35. PMID: 20101007. 10.1001/archinternmed.2009.470 20101007
40. Hyman DJ, Ho KS, Dunn JK, . Dietary intervention for cholesterol reduction in public clinic patients. Am J Prev Med. 1998;15(2):139–45. PMID: 9713670. 10.1016/S0749-3797(98)00038-5 9713670
41. Hyman DJ, Pavlik VN, Taylor WC, . Simultaneous vs sequential counseling for multiple behavior change. Arch Intern Med. 2007;167(11):1152–8. PMID: 17563023. 10.1001/archinte.167.11.1152 17563023
42. Hypertension Prevention Trial Research Group. The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Hypertension Prevention Trial Research Group. Arch Intern Med. 1990;150(1):153–62. PMID: 2404477. 10.1001/archinte.1990.00390130131021 2404477
  a. Meinert CL, Borhani NO, Langford HG. Design, methods, and rationale in the Hypertension Prevention Trial. Hypertension Prevention Trial Research Group. Control Clin Trials. 1989;10:(3 Suppl):1S–29S. PMID: 2680271.2680271
  b. Shah M, Jeffery RW, Laing B, . Hypertension Prevention Trial (HPT): food pattern changes resulting from intervention on sodium, potassium, and energy intake. Hypertension Prevention Trial Research Group. J Am Diet Assoc. 1990;90(1):69–76. PMID: 2404050.2404050
43. Ives DG, Kuller LH, Traven ND. Use and outcomes of a cholesterol-lowering intervention for rural elderly subjects. Am J Prev Med. 1993;9(5):274–81. PMID: 8257616.8257616
  a. Ives DG, Kuller LH, Schulz R, . Comparison of recruitment strategies and associated disease prevalence for health promotion in rural elderly. Prev Med. 1992;21(5):582–91. PMID: 1438108.1438108
  b. Ives DG, Traven ND, Kuller LH, . Selection bias and nonresponse to health promotion in older adults. Epidemiology. 1994;5(4):456–61. PMID: 7918817.7918817
44. Johnston HJ, Jones M, Ridler-Dutton G, . Diet modification in lowering plasma cholesterol levels. A randomised trial of three types of intervention. Med J Aust. 1995;162(10):524–6. PMID: 7776913. 10.5694/j.1326-5377.1995.tb138510.x 7776913
45. Jones DW, Miller ME, Wofford MR, . The effect of weight loss intervention on antihypertensive medication requirements in the hypertension Optimal Treatment (HOT) study. Am J Hypertens. 1999;12(12 Pt 1-2):1175–80. PMID: 10619579. 10.1016/S0895-7061(99)00123-5 10619579
  a. Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study-patient characteristics: randomization, risk profiles, and early blood pressure results. Blood Press. 1994;3(5):322–7. PMID: 7866597.7866597
  b. The H.O.T. Study Group. The Hypertension Optimal Treatment Study (the HOT Study). Blood Press. 1993;2(1):62–8. PMID: 8193735.8193735
46. Kandula NR, Dave S, De Chavez PJ, . Translating a heart disease lifestyle intervention into the community: the South Asian Heart Lifestyle Intervention (SAHELI) study; a randomized control trial. BMC Public Health. 2015;15:1064. PMID: 26475629. 10.1186/s12889-015-2401-2 26475629
  a. Kandula NR, Patel Y, Dave S, . The South Asian Heart Lifestyle Intervention (SAHELI) study to improve cardiovascular risk factors in a community setting: design and methods. Contemp Clin Trials. 2013;36(2):479–87. PMID: 24060673. 10.1016/j.cct.2013.09.007 24060673
47. Kanke S, Kawai T, Takasawa N, . Interventions for body weight reduction in obese patients during short consultations: an open-label randomized controlled trial in the Japanese primary care setting. Asia Pac Fam Med. 2015;14(1):5. PMID: 26015773. 10.1186/s12930-015-0022-7 26015773
48. Kastarinen MJ, Puska PM, Korhonen MH, . Non-pharmacological treatment of hypertension in primary health care: a 2-year open randomized controlled trial of lifestyle intervention against hypertension in eastern Finland. J Hypertens. 2002;20(12):2505–12. PMID: 12473876. 10.1097/01.hjh.0000042893.24999.db 12473876
  a. Korhonen M, Kastarinen M, Uusitupa M, . The effect of intensified diet counseling on the diet of hypertensive subjects in primary health care: a 2-year open randomized controlled trial of lifestyle intervention against hypertension in eastern Finland. Prev Med. 2003;36(1):8–16. PMID: 12473420. 10.1006/pmed.2002.1120 12473420
49. Khanji MY, Balawon A, Boubertakh R, . Personalized e-coaching in cardiovascular risk reduction: a randomized controlled trial. Ann Glob Health. 2019;85(1). PMID: 31298823. 10.5334/aogh.2496 31298823
  a. Yousuf H, Reintjens R, Slipszenko E, . Effectiveness of web-based personalised e-Coaching lifestyle interventions. Neth Heart J. 2019;27(1):24–9. PMID: 30488381. 10.1007/s12471-018-1200-7 30488381
50. Keyserling TC, Ammerman AS, Davis CE, . A randomized controlled trial of a physician-directed treatment program for low-income patients with high blood cholesterol: the Southeast Cholesterol Project. Arch Fam Med. 1997;6(2):135–45. PMID: 9075448.9075448
51. Koelewijn-van Loon MS, van der Weijden T, van Steenkiste B, . Involving patients in cardiovascular risk management with nurse-led clinics: a cluster randomized controlled trial. CMAJ. 2009;181(12):E267–E74. PMID: 19948811. 10.1503/cmaj.081591 19948811
  a. Koelewijn-van Loon MS, van SB, Ronda G, . Improving patient adherence to lifestyle advice (IMPALA): a cluster-randomised controlled trial on the implementation of a nurse-led intervention for cardiovascular risk management in primary care (protocol). BMC Health Serv Res. 2008;8:9. PMID: 18194522. 10.1186/1472-6963-8-9 18194522
52. Kramer MK, Vanderwood KK, Arena VC, . Evaluation of a diabetes prevention program lifestyle intervention in older adults: a randomized controlled study in three senior/community centers of varying socioeconomic status. Diabetes Educ. 2018;44(2):118–29. PMID: 29514568. 10.1177/0145721718759982 29514568
  a. Eaglehouse YL, Rockette-Wagner B, Kramer MK, . Physical activity levels in a community lifestyle intervention: a randomized trial. Transl J Am Coll Sports Med. 2016;1(5):45–51. PMID: 27551690. 10.1249/TJX.0000000000000004 27551690
53. Lakerveld J, Bot SD, Chinapaw MJ, . Motivational interviewing and problem solving treatment to reduce type 2 diabetes and cardiovascular disease risk in real life: a randomized controlled trial. Int J Behav Nutr Phys Act. 2013;10:47. PMID: 23597082. 10.1186/1479-5868-10-47 23597082
  a. Lakerveld J, Bot SD, Chinapaw MJ, . Primary prevention of diabetes mellitus type 2 and cardiovascular diseases using a cognitive behavior program aimed at lifestyle changes in people at risk: design of a randomized controlled trial. BMC Endocr Disord. 2008;8:6. PMID: 18573221. 10.1186/1472-6823-8-6 18573221
  b. Lakerveld J, Bot SD, van der Ploeg HP, . The effects of a lifestyle intervention on leisure-time sedentary behaviors in adults at risk: the Hoorn Prevention Study, a randomized controlled trial. Prev Med. 2013;57(4):351–6. PMID: 23777672. 10.1016/j.ypmed.2013.06.011 23777672
54. Langford HG, Davis BR, Blaufox D, . Effect of drug and diet treatment of mild hypertension on diastolic blood pressure. The TAIM Research Group. Hypertension. 1991;17(2):210–7. PMID: 1671380. 10.1161/01.HYP.17.2.210 1671380
  a. Davis BR, Blaufox MD, Hawkins CM, . Trial of antihypertensive interventions and management. Design, methods, and selected baseline results. Control Clin Trials. 1989;10(1):11–30. PMID: 2649308. 10.1016/0197-2456(89)90016-0 2649308
  b. Oberman A, Wassertheil-Smoller S, Langford HG, . Pharmacologic and nutritional treatment of mild hypertension: changes in cardiovascular risk status. Ann Intern Med. 1990;112(2):89–95. PMID: 1967210. 10.1016/1047-2797(94)00060-7 1967210
55. Lee LL, Arthur A, Avis M. Evaluating a community-based walking intervention for hypertensive older people in Taiwan: a randomized controlled trial. Prev Med. 2007;44(2):160–6. PMID: 17055561. 10.1016/j.ypmed.2006.09.001 17055561
56. Liira H, Engberg E, Leppavuori J, . Exercise intervention and health checks for middle-aged men with elevated cardiovascular risk: a randomized controlled trial. Scand J Prim Health Care. 2014;32(4):156–62. PMID: 25434409. 10.3109/02813432.2014.984967 25434409
  a. From S, Liira H, Leppavuori J, . Effectiveness of exercise intervention and health promotion on cardiovascular risk factors in middle-aged men: a protocol of a randomized controlled trial. BMC Public Health. 2013;13:125. PMID: 23398957. 10.1186/1471-2458-13-125 23398957
57. Migneault JP, Dedier JJ, Wright JA, . A culturally adapted telecommunication system to improve physical activity, diet quality, and medication adherence among hypertensive African-Americans: a randomized controlled trial. Ann Behav Med. 2012;43(1):62–73. PMID: 22246660. 10.1007/s12160-011-9319-4 22246660
58. Moreau KL, Degarmo R, Langley J, . Increasing daily walking lowers blood pressure in postmenopausal women. Med Sci Sports. 2001;33(11):1825–31. PMID: 11689731.11689731
59. Moy TF, Yanek LR, Raqueño JV, . Dietary counseling for high blood cholesterol in families at risk of coronary disease. Prev Cardiol. 2001;4(4):158–64. PMID: 11832672. 10.1111/j.1520-037X.2001.00543.x 11832672
60. Muhlhauser I, Sawicki PT, Didjurgeit U, . Evaluation of a structured treatment and teaching programme on hypertension in general practice. Clin Exp Hypertens. 1993;15(1):125–42. PMID: 8467308.8467308
61. Murphy SM, Edwards RT, Williams N, . An evaluation of the effectiveness and cost effectiveness of the National Exercise Referral Scheme in Wales, UK: a randomised controlled trial of a public health policy initiative. J Epidemiol Community Health. 2012;66(8):745–53. PMID: 22577180. 10.1136/jech-2011-200689 22577180
  a. Edwards RT, Linck P, Hounsome N, . Cost-effectiveness of a national exercise referral programme for primary care patients in Wales: results of a randomised controlled trial. BMC Public Health. 2013;13:1021. PMID: 24164697. 10.1186/1471-2458-13-1021 24164697
  b. Littlecott HJ, Moore GF, Moore L, . Psychosocial mediators of change in physical activity in the Welsh national exercise referral scheme: secondary analysis of a randomised controlled trial. Int J Behav Nutr Phys Act. 2014;11:109. PMID: 25209188. 10.1186/s12966-014-0109-9 25209188
  c. Murphy S, Raisanen L, Moore G, . A pragmatic randomised controlled trial of the Welsh National Exercise Referral Scheme: protocol for trial and integrated economic and process evaluation. BMC Public Health. 2010;10:352. PMID: 20565846. 10.1186/1471-2458-10-352 20565846
62. Neil HA, Roe L, Godlee RJ, . Randomised trial of lipid lowering dietary advice in general practice: the effects on serum lipids, lipoproteins, and antioxidants. BMJ. 1995;310(6979):569–73. PMID: 7888933. 10.1136/bmj.310.6979.569 7888933
63. Niiranen TJ, Leino K, Puukka P, . Lack of impact of a comprehensive intervention on hypertension in the primary care setting. Am J Hypertens. 2014;27(3):489–96. PMID: 24186848. 10.1093/ajh/hpt204 24186848
64. Nolan RP, Feldman R, Dawes M, . Randomized Controlled Trial of E-Counseling for Hypertension: REACH. Circ Cardiovasc Qual Outcomes. 2018;11(7):e004420. PMID: 30006474. 10.1161/CIRCOUTCOMES.117.004420 30006474
  a. Nolan RP, Liu S, Feldman R, . Reducing risk with e-based support for adherence to lifestyle change in hypertension (REACH): protocol for a multicentred randomised controlled trial. BMJ Open. 2013;3(8):e003547. PMID: 23965936. 10.1136/bmjopen-2013-003547 23965936
65. Ogedegbe G, Tobin JN, Fernandez S, . Counseling African Americans to control hypertension: cluster-randomized clinical trial main effects. Circulation. 2014;129(20):2044–51. PMID: 24657991. 10.1161/circulationaha.113.006650 24657991
  a. Fernandez S, Tobin JN, Cassells A, . The Counseling African Americans to Control Hypertension (CAATCH) Trial: baseline demographic, clinical, psychosocial, and behavioral characteristics. Implement Sci. 2011;6:100. PMID: 21884616. 10.1186/1748-5908-6-100 21884616
  b. Forsyth JM, Schoenthaler A, Ogedegbe G, . Perceived racial discrimination and adoption of health behaviors in hypertensive Black Americans: The CAATCH trial. J Health Care Poor Underserved. 2014;25(1):276–91. PMID: 24509026. 10.1353/hpu.2014.0053 24509026
  c. Ogedegbe G, Tobin JN, Fernandez S, . Counseling African Americans to Control Hypertension (CAATCH) trial: a multi-level intervention to improve blood pressure control in hypertensive blacks. Circ Cardiovasc Qual Outcomes. 2009;2(3):249–56. PMID: 20031845. 10.1161/CIRCOUTCOMES.109.849976 20031845
66. Reid RD, McDonnell LA, Riley DL, . Effect of an intervention to improve the cardiovascular health of family members of patients with coronary artery disease: a randomized trial. CMAJ. 2014;186(1):23–30. PMID: 24246588. 10.1503/cmaj.130550 24246588
67. Rodriguez Cristobal JJ, Alonso-Villaverde Grote C, Trave Mercade P, . Randomised clinical trial of an intensive intervention in the primary care setting of patients with high plasma fibrinogen in the primary prevention of cardiovascular disease. BMC Res Notes. 2012;5:126. PMID: 22381072. 10.1186/1756-0500-5-126 22381072
68. Rodriguez MA. Is behavior change sustainable for diet, exercise, and medication adherence? Dissertation. 2012;73(3-B):1860. PMID: None.
  a. Friedberg JP, Rodriguez MA, Watsula ME, . Effectiveness of a tailored behavioral intervention to improve hypertension control: primary outcomes of a randomized controlled trial. Hypertension. 2015;65(2):440–6. PMID: 25403606. 10.1161/HYPERTENSIONAHA.114.03483 25403606
69. Rosas LG, Thiyagarajan S, Goldstein BA, . The effectiveness of two community-based weight loss strategies among obese, low-income US Latinos. J Acad Nutr Diet. 2015;115(4):537–50.e2. PMID: 25578925. 10.1016/j.jand.2014.10.020 25578925
  a. Drieling RL, Ma J, Stafford RS. Evaluating clinic and community-based lifestyle interventions for obesity reduction in a low-income Latino neighborhood: Vivamos Activos Fair Oaks Program. BMC Public Health. 2011;11:98. PMID: 21320331. 10.1186/1471-2458-11-98 21320331
70. Rubinstein A, Miranda JJ, Beratarrechea A, . Effectiveness of an mHealth intervention to improve the cardiometabolic profile of people with prehypertension in low-resource urban settings in Latin America: a randomised controlled trial. Lancet Diabetes Endocrinol. 2016;4(1):52–63. PMID: 26653067. 10.1016/S2213-8587(15)00381-2 26653067
71. Salisbury C, O’Cathain A, Thomas C, . Telehealth for patients at high risk of cardiovascular disease: pragmatic randomised controlled trial. BMJ. 2016;353:i2647. PMID: 27252245. 10.1136/bmj.i2647 27252245
  a. Thomas CL, Man MS, O’Cathain A, . Effectiveness and cost-effectiveness of a telehealth intervention to support the management of long-term conditions: study protocol for two linked randomized controlled trials. Trials. 2014;15:36. PMID: 24460845. 10.1186/1745-6215-15-36 24460845
72. Schoenthaler A, Luerassi L, Silver S, . Comparative effectiveness of a practice-based comprehensive lifestyle intervention vs. single session counseling in hypertensive Blacks. Am J Hypertens. 2016;29(2):280–7. PMID: 26135553. 10.1093/ajh/hpv100 26135553
  a. Schoenthaler A, Luerassi L, Teresi JA, . A practice-based trial of blood pressure control in African Americans (TLC-Clinic): study protocol for a randomized controlled trial. Trials. 2011;12:265. PMID: 22192273. 10.1186/1745-6215-12-265 22192273
73. Scott SE, Breckon JD, Copeland RJ. An integrated motivational interviewing and cognitive-behavioural intervention promoting physical activity maintenance for adults with chronic health conditions: a feasibility study. Chronic Illn. 2019;15(4):276–292. PMID: 29642707. 10.1177/1742395318769370 29642707
74. Soto RA, García SJ, Toro SM, . Benefits of an educational intervention on diet and anthropometric profile of women with one cardiovascular risk factor. Med Clin (Barc). 2016;146(10):436–9. PMID: 26897504. 10.1016/j.medcli.2015.12.013 26897504
75. Stefanick ML, Mackey S, Sheehan M, . Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med. 1998;339(1):12–20. PMID: 9647874. 10.1056/NEJM199807023390103 9647874
  a. Camhi SM, Stefanick ML, Katzmarzyk PT, . Metabolic syndrome and changes in body fat from a low-fat diet and/or exercise randomized controlled trial. Obesity. 2010;18(3):548–54. PMID: 19798074. 10.1038/oby.2009.304 19798074
76. Stevens VJ, Glasgow RE, Toobert DJ, . One-year results from a brief, computer-assisted intervention to decrease consumption of fat and increase consumption of fruits and vegetables. Prev Med. 2003;36(5):594–600. PMID: 12689805. 10.1016/S0091-7435(03)00019-7 12689805
77. Svetkey LP, Pollak KI, Yancy WS, Jr., . Hypertension improvement project: randomized trial of quality improvement for physicians and lifestyle modification for patients. Hypertension. 2009;54(6):1226–33. PMID: 19920081. 10.1161/HYPERTENSIONAHA.109.134874 19920081
  a. Dolor RJ, Yancy WS, Jr., Owen WF, . Hypertension Improvement Project (HIP): study protocol and implementation challenges. Trials. 2009;10:13. PMID: 19245692. 10.1186/1745-6215-10-13 19245692
  b. Lin PH, Yancy WS, Jr., Pollak KI, . The influence of a physician and patient intervention program on dietary intake. J Acad Nutr Diet. 2013;113(11):1465–75. PMID: 23999279. 10.1016/j.jand.2013.06.343 23999279
78. Svetkey LP, Stevens VJ, Brantley PJ, . Comparison of strategies for sustaining weight loss: the weight loss maintenance randomized controlled trial. JAMA. 2008;299(10):1139–48. PMID: 18334689. 10.1001/jama.299.10.1139 18334689
  a. Brantley PJ, Stewart DW, Myers VH, . Psychosocial predictors of weight regain in the Weight Loss Maintenance trial. J Behav Med. 2014;37(6):1155–68. PMID: 24722826. 10.1007/s10865-014-9565-6 24722826
  b. Champagne CM, Broyles ST, Moran LD, . Dietary intakes associated with successful weight loss and maintenance during the Weight Loss Maintenance trial. J Am Diet Assoc. 2011;111(12):1826–35. PMID: 22117658. 10.1016/j.jada.2011.09.014 22117658
  c. Coughlin JW, Brantley PJ, Champagne CM, . The impact of continued intervention on weight: five-year results from the Weight Loss Maintenance trial. Obesity. 2016;24(5):1046–53. PMID: 26991814. 10.1002/oby.21454 26991814
  d. Funk KL, Stevens VJ, Appel LJ, . Associations of internet website use with weight change in a long-term weight loss maintenance program. J Med Internet Res. 2010;12(3):e29. PMID: 20663751. 10.2196/jmir.1504 20663751
  e. Svetkey LP, Ard JD, Stevens VJ, . Predictors of long-term weight loss in adults with modest initial weight loss, by sex and race. Obesity (Silver Spring). 2012;20(9):1820–8. PMID: 21527896. 10.1038/oby.2011.88 21527896
  f. Svetkey LP, Clark JM, Funk K, . Greater weight loss with increasing age in the weight loss maintenance trial. Obesity (Silver Spring). 2014;22(1):39–44. PMID: 23640912. 10.1002/oby.20506 23640912
79. Ter Bogt NC, Bemelmans WJ, Beltman FW, . Preventing weight gain: one-year results of a randomized lifestyle intervention. Am J Prev Med. 2009;37(4):270–7. PMID: 19765497. 10.1016/j.amepre.2009.06.011 19765497
  a. Driehuis F, Barte JC, Ter Bogt NC, . Maintenance of lifestyle changes: 3-year results of the Groningen Overweight and Lifestyle study. Patient Educ Couns. 2012;88(2):249–55. PMID: 22560253. 10.1016/j.pec.2012.03.017 22560253
  b. Ter Bogt NC, Milder IE, Bemelmans WJ, . Changes in lifestyle habits after counselling by nurse practitioners: 1-year results of the Groningen Overweight and Lifestyle study. Public Health Nutr. 2011;14(6):995–1000. PMID: 21272417. 10.1017/S1368980010003708 21272417
80. The Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels. Results of the Trials of Hypertension Prevention, Phase I. JAMA. 1992;267(9):1213–20. PMID: 1586398. 10.1001/jama.1992.03480090061028 1586398
  a. Cook NR, Cutler JA, Obarzanek E, . Long term effects of dietary sodium reduction on cardiovascular disease outcomes: observational follow-up of the trials of hypertension prevention (TOHP). BMJ. 2007;334(7599):885–8. PMID: 17449506. 10.1136/bmj.39147.604896.55.1993.00410070039006 17449506
  b. Kumanyika SK, Hebert PR, Cutler JA, . Feasibility and efficacy of sodium reduction in the Trials of Hypertension Prevention, phase I. Trials of Hypertension Prevention Collaborative Research Group. Hypertension. 1993;22(4):502–12. PM8406655
  c. Satterfield S, Cutler JA, Langford HG, . Trials of hypertension prevention. Phase I design. Ann Epidemiol. 1991;1(5):455–71. PMID: 1669525. 10.1016/1047-2797(91)90014-4ID: 8406655.1669525
  d. Stevens VJ, Corrigan SA, Obarzanek E, . Weight loss intervention in phase 1 of the Trials of Hypertension Prevention. The TOHP Collaborative Research Group. Arch Intern Med. 1993;153(7):849–58. PMID: 8466377. 10.1001/archinte 8466377
  e. Whelton PK, Hebert PR, Cutler J, . Baseline characteristics of participants in phase I of the Trials of Hypertension Prevention. Ann Epidemiol. 1992;2(3):295–310. PMID: 1342280. 10.1016/1047-2797(92)90062-U 1342280
81. The Trials of Hypertention Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. The Trials of Hypertension Prevention, phase II. The Trials of Hypertension Prevention Collaborative Research Group. Arch Intern Med. 1997;157(6):657–67. PMID: 9080920.9080920
  a. Stevens VJ, Obarzanek E, Cook NR, . Long-term weight loss and changes in blood pressure: results of the Trials of Hypertension Prevention, phase II. Ann Intern Med. 2001;134(1):1–11. PMID: 11187414. 10.7326/0003-4819-134-1-200101020-00007 11187414
  b. Cook NR, Cutler JA, Obarzanek E, . Long term effects of dietary sodium reduction on cardiovascular disease outcomes: observational follow-up of the trials of hypertension prevention (TOHP). BMJ. 2007;334(7599):885–8. PMID: 17449506. 10.1136/bmj.39147.604896.55 17449506
  c. Hebert PR, Bolt RJ, Borhani NO, . Design of a multicenter trial to evaluate long-term life-style intervention in adults with high-normal blood pressure levels. Trials of Hypertension Prevention (phase II). Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):130–9. PMID: 7795831. 10.1016/1047-2797(94)00057-Z 7795831
  d. Hollis JF, Satterfield S, Smith F, . Recruitment for phase II of the Trials of Hypertension Prevention. Effective strategies and predictors of randomization. Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):140–8. PMID: 7795832. 10.1016/1047-2797(94)00058-2 7795832
  e. Kumanyika SK, Cook NR, Cutler JA, . Sodium reduction for hypertension prevention in overweight adults: further results from the Trials of Hypertension Prevention Phase II. J Hum Hypertens. 2005;19(1):33–45. PMID: 15372064. 10.1038/sj.jhh.1001774 15372064
  f. Lasser VI, Raczynski JM, Stevens VJ, . Trials of Hypertension Prevention, phase II. Structure and content of the weight loss and dietary sodium reduction interventions. Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):156–64. PMID: 7795834. 10.1016/1047-2797(94)00060-7 7795834
82. Tiessen AH, Smit AJ, Broer J, . Randomized controlled trial on cardiovascular risk management by practice nurses supported by self-monitoring in primary care. BMC Fam Pract. 2012;13:90. PMID: 22947269. 10.1186/1471-2296-13-90 22947269
83. Toft U, Kristoffersen L, Ladelund S, . The effect of adding group-based counselling to individual lifestyle counselling on changes in dietary intake. The Inter99 study - a randomized controlled trial. Int J Behav Nutr Phys Act. 2008;5:59. PMID: 19025583. 10.1186/1479-5868-5-59 19025583
  a. Aadahl M, Huth SL, Toft U, . Does a population-based multifactorial lifestyle intervention increase social inequality in physical activity? The Inter99 study. Br J Sports Med. 2011;45:209–15. PMID: 19850570. 10.1136/bjsm.2009.064840 19850570
  b. Huth SL, Ladelund S, Borch JK, . A randomized multifactorial intervention study for prevention of ischaemic heart disease (Inter99): the long-term effect on physical activity. Scand J Public Health. 2008;36:380–8. PMID: 18539692. 10.1177/1403494807085313 18539692
  c. Jørgensen T, Borch-Johnsen K, Thomsen TF, . A randomized non-pharmacological intervention study for prevention of ischaemic heart disease: baseline results Inter99. Eur J Cardiovasc Prev Rehabil. 2003;10(5):377–86. PMID: 14663300. 10.1097/01.hjr.0000096541.30533.82 14663300
  d. Jørgensen T, Jacobsen RK, Toft U, . Effect of screening and lifestyle counselling on incidence of ischaemic heart disease in general population: Inter99 randomised trial. BMJ. 2014;348:g3617. PMID: 24912589. 10.1136/bmj.g3617 24912589
  e. Lau C, Vistisen D, Toft U, . The effects of adding group-based lifestyle counselling to individual counselling on changes in plasma glucose levels in a randomized controlled trial: the Inter99 study. Diabetes Metab. 2011;37(6):546–52. PMID: 21900030. 10.1016/j.diabet.2011.06.001 21900030
  f. Toft U, Kristoffersen L, Ladelund S, . The impact of a population-based multi-factorial lifestyle intervention on changes in long-term dietary habits The Inter99 study. Prev Med. 2008;47(4):378–83. PMID: 18590758. 10.1016/j.ypmed.2008.05.013 18590758
84. Tomson Y, Johannesson M, Aberg H. The costs and effects of two different lipid intervention programmes in primary health care. J Intern Med. 1995;237(1):13–7. PMID: 7830025. 10.1111/j.1365-2796.1995.tb01134.x 7830025
  a. Tomson Y, Aberg H. Risk factors for cardiovascular disease-a comparison between Swedes and immigrants. Scand J Prim Health Care. 1994;12(3):147–54. PMID: 7997691. 10.3109/02813439409003691 7997691
85. van der Veen J, Bakx C, van den Hoogen H, . Stage-matched nutrition guidance for patients at elevated risk for cardiovascular disease: a randomized intervention study in family practice. J Fam Pract. 2002;51(9):751–8. PMID: 12366892.12366892
  a. Verheijden MW, van dV, Bakx JC, . Stage-matched nutrition guidance: stages of change and fat consumption in Dutch patients at elevated cardiovascular risk. J Nutr Educ Behav. 2004;36(5):228–37. PMID: 15707545. 10.1016/S1499-4046(06)60385-0 15707545
86. van Keulen HM, Mesters I, Ausems M, . Tailored print communication and telephone motivational interviewing are equally successful in improving multiple lifestyle behaviors in a randomized controlled trial. Ann Behav Med. 2011;41(1):104–18. PMID: 20878293. 10.1007/s12160-010-9231-3 20878293
  a. van Keulen HM, Bosmans JE, van Tulder MW, . “Cost-effectiveness of tailored print communication, telephone motivational interviewing, and a combination of the two: Results of an economic evaluation alongside the Vitalum randomized controlled trial”: Correction. Int J Behav Nutr Phys Act. 2010 Sep 3;7:64. PMID: 20815869. 10.1186/1479-5868-7-64 20815869
  b. van Keulen HM, Mesters I, Ausems M, . Tailored print communication and telephone motivational interviewing are equally successful in improving multiple lifestyle behaviors in a randomized controlled trial. Ann Behav Med. 2011;41(1):104–18. PMID: 20878293. 10.1007/s12160-010-9231-3 20878293
  c. van Keulen HM, Mesters I, Brug J, . Vitalum study design: RCT evaluating the efficacy of tailored print communication and telephone motivational interviewing on multiple health behaviors. BMC Public Health. 2008;8:216. PMID: 18565222. 10.1186/1471-2458-8-216 18565222
87. Van Sluijs EM, van Poppel MN, Twisk JW, . Effect of a tailored physical activity intervention delivered in general practice settings: results of a randomized controlled trial. Am J Public Health. 2005;95(10):1825–31. PMID: 16186461. 10.2105/AJPH.2004.044537 16186461
  a. Van Sluijs EM, Van Poppel MN, Twisk JW, . The positive effect on determinants of physical activity of a tailored, general practice-based physical activity intervention. Health Educ Res. 2005;20(3):345–56. PMID: 15479705. 10.1093/her/cyg129 15479705
88. Viglione C, Bouwman D, Rahman N, . A technology-assisted health coaching intervention vs. enhanced usual care for Primary Care-Based Obesity Treatment: a randomized controlled trial. BMC Obes. 2019;6:4. PMID: 30766686. 10.1186/s40608-018-0226-0 30766686
89. Voils CI, Coffman CJ, Yancy WS, Jr., . A randomized controlled trial to evaluate the effectiveness of CouPLES: a spouse-assisted lifestyle change intervention to improve low-density lipoprotein cholesterol. Prev Med. 2013;56(1):46–52. PMID: 23146744. 10.1016/j.ypmed.2012.11.001 23146744
  a. McVay MA, King HA, Jeffreys AS, . Mechanisms of patient health behavior change in a randomized controlled trial of a spouse-assisted intervention. Psychol Health Med. 2015;20(7):753–66. PMID: 25774698. 10.1080/13548506.2015.1020817 25774698
  b. Voils CI, Yancy WS, Jr., Kovac S, . Study protocol: Couples Partnering for Lipid Enhancing Strategies (CouPLES) - a randomized, controlled trial. Trials. 2009;10:10. PMID: 19200384. 10.1186/1745-6215-10-10 19200384
90. Wadden T, Volger S, Sarwer D, . A two-year randomized trial of obesity treatment in primary care practice. N Engl J Med. 2011;365(21):1969–79. PMID: 22082239 10.1056/NEJMoa1109220 22082239
  a. Sarwer DB, Moore RH, Diewald LK, . The impact of a primary care-based weight loss intervention on the quality of life. Int J Obes (Lond). 2013;37: Suppl 1:S25–30. PMID: 23921778. 10.1038/ijo.2013.93 23921778
  b. Vetter ML, Wadden TA, Chittams J, . Effect of lifestyle intervention on cardiometabolic risk factors: results of the POWER-UP trial. Int J Obes (Lond). 2013;37: Suppl 1:S19–24. PMID: 23921777. 10.1038/ijo.2013.92 23921777
  c. Volger S, Wadden TA, Sarwer DB, . Changes in eating, physical activity and related behaviors in a primary care-based weight loss intervention. Int J Obes (Lond). 2013;37: Suppl 1:S12–8. PMID: 23921776. 10.1038/ijo.2013.91 23921776
91. Whelton PK, Appel LJ, Espeland MA, . Sodium reduction and weight loss in the treatment of hypertension in older persons: a randomized controlled trial of nonpharmacologic interventions in the elderly (Trial of Nonpharmacologic Interventions in the Elderly (TONE)). TONE Collaborative Research Group. JAMA. 1998;279(11):839–46. PMID: 9515998. 10.1001/jama.279.11.839 9515998
  a. Appel LJ, Espeland M, Whelton PK, . Trial of Nonpharmacologic Intervention in the Elderly (Trial of Nonpharmacologic Interventions in the Elderly (TONE)). Design and rationale of a blood pressure control trial. Ann Epidemiol. 1995;5(2):119–29. PMID: 7795830. 10.1016/1047-2797(94)00056-Y 7795830
  b. Appel LJ, Espeland MA, Easter L, . Effects of reduced sodium intake on hypertension control in older individuals: results from the Trial of Nonpharmacologic Interventions in the Elderly (Trial of Nonpharmacologic Interventions in the Elderly (TONE)). Arch Intern Med. 2001;161(5):685–93. PMID: 11231700. 10.1001/archinte.161.5.685 11231700
  c. Bahnson JL, Whelton PK, Appel LJ, . Baseline characteristics of randomized participants in the Trial of Nonpharmacologic Intervention in the Elderly (Trial of Nonpharmacologic Interventions in the Elderly (TONE)). Dis Manag Clin Outcomes. 1997;1(2):61–8. PMID: None. 10.1016/S1088-3371(97)00005-3
  d. Espeland MA, Whelton PK, Kostis JB, . Predictors and mediators of successful long-term withdrawal from antihypertensive medications. TONE Cooperative Research Group. Trial of Nonpharmacologic Interventions in the Elderly. Arch Fam Med. 1999;8(3):228–36. PMID: 10333818.10333818
92. Wister A, Loewen N, Kennedy-Symonds H, . One-year follow-up of a therapeutic lifestyle intervention targeting cardiovascular disease risk.[see comment]. CMAJ. 2007;177(8):859–65. PMID: 17923653. 10.1503/cmaj.061059 17923653
93. Wong MC, Wang HH, Kwan MW, . Dietary counselling has no effect on cardiovascular risk factors among Chinese Grade 1 hypertensive patients: a randomized controlled trial. Eur Heart J. 2015;36(38):2598–607. PMID: 26264550. 10.1093/eurheartj/ehv329 26264550
  a. Wong MC, Wang HH, Kwan MW, . The effectiveness of Dietary Approaches to Stop Hypertension (DASH) counselling on estimated 10-year cardiovascular risk among patients with newly diagnosed grade 1 hypertension: a randomised clinical trial. Int J Cardiol. 2016;224:79–87. PMID: 27631719. 10.1016/j.ijcard.2016.08.334 27631719
94. Wood DA, Kotseva K, Connolly S, . Nurse-coordinated multidisciplinary, family-based cardiovascular disease prevention programme (EUROACTION) for patients with coronary heart disease and asymptomatic individuals at high risk of cardiovascular disease: a paired, cluster-randomised controlled trial. Lancet. 2008;371:1999–2012. PMID: 18555911. 10.1016/S0140-6736(08)60868-5 18555911