# Appendix B Literature Flow Diagram

This figure is a flow chart that summarizes the search and selection of articles. There were 24,683 citations identified through literature databases. An additional 426 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 14,409 unique citations were screened at the title/abstract stage. The full-text of 466 citations were examined for inclusion for one or more of the four Key Questions. The following number of articles were included for Key Question 1 (k=29), Key Question 2 (k=91), Key Question 3 (k=70), and Key Question 4 (k=20). Reasons for excluding the other articles are available in Appendix D.