# Appendix A Literature Search Strategies

Key:

- / = MeSH subject heading
- $ = truncation
- * = truncation
- ? = wildcard
- ab = word in abstract
- adj# = adjacent within × number of words
- bt = book title
- fs= floating subheading
- hw = subject heading word
- id =key phrase identifier
- kf= keyword heading [word not phrase indexed]
- kw = keyword
- md = methodology
- near/# = adjacent within × number of words
- pt = publication type
- ti = word in title

## Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL)

#1 diet:ti
#2 diets:ti
#3 dietary:ti
#4 (fruit* or vegetable*):ti
#5 exercis*:ti
#6 walking:ti
#7 "physical activity":ti,ab,kw
#8 pedometer*:ti,ab,kw
#9 fitbit*:ti,ab,kw
#10 "steps per":ti,ab,kw
#11 distance walked:ti,ab,kw
#12 (measuring next step*):ti,ab,kw
#13 (step next count*):ti,ab,kw
#14 (activity or fitness):ti,ab,kw near/1 track*:ti,ab,kw
#15 sedentary:ti,ab,kw next (lifestyle* or (life next style*) or behavior* or behaviour* or time):ti,ab,kw
#16 (sitting or lying):ti,ab,kw near/2 time:ti,ab,kw
#17 "screen time":ti,ab,kw
#18 (television or tv):ti,ab,kw next viewing:ti,ab,kw
#19 (watch* or view*):ti,ab,kw next (television or tv):ti,ab,kw
#20 (computer or internet):ti,ab,kw next (time or use or usage):ti,ab,kw
#21 (computer or video):ti,ab,kw next game*:ti,ab,kw
#22 (screen or screen-based):ti,ab,kw next (entertainment or behavior* or behaviour* or use or usage):ti,ab,kw
#23 (low next energy next expenditure*):ti,ab,kw
#24 (physical* next inactiv*):ti,ab,kw
#25 {or #15-#24}
#26 (reduce* or reduction* or decrease* or change* or target*):ti,ab
#27 #25 and #26
#28 {or #1-#14, #27}
#29 counsel*:ti,ab,kw
#30 (advice or advise or consultation*):ti,ab,kw
#31 Behavio*:ti,ab,kw near/2 (therap* or chang* or modification* or improv*):ti,ab,kw
#32 referral*:ti,ab,kw
#33 (set* near/2 goal*):ti,ab,kw
#34 (action next plan*):ti,ab,kw
#35 (self next monitor*):ti,ab,kw
#36 "follow up feedback":ti,ab,kw
#37 (assessment near/5 feedback):ti,ab,kw
#38 "support planning":ti,ab,kw
#39 "risk factor management":ti,ab,kw
#40 "life style":ti,ab,kw
#41 lifestyle:ti,ab,kw
#42 motivation*:ti,ab,kw
#43 health:ti,ab,kw next (coach* or behavio* or education):ti,ab,kw
#44 (education* next program*):ti,ab,kw
#45 "patient education":ti,ab,kw
#46 "health promotion":ti,ab,kw
#47 promot*:ti,ab,kw near/3 (exercise or physical activit* or weight loss):ti,ab,kw
#48 (nonpharmacologic or “non pharmacologic”):ti,ab,kw next intervention*:ti,ab,kw
#49 intervention*:ti
#50 {or #29-#49}
#51 (cardiovascular or cardiometabolic):ti
#52 #28 and (#50 or #51)
#53 (lifestyle near/2 intervention*):ti,ab,kw or ("life style" near/2 intervention*):ti,ab,kw or ((health* next lifestyle)
  or (health* next “life style”)):ti,ab,kw
#54 (cardiovascular or cardiometabolic or coronary or heart):ti,ab,kw
#55 (insulin or glucose or diabet*):ti,ab,kw
#56 (lipoprotein* or lipid* or triglyceride* or hyperlipidemia* or cholesterol):ti,ab,kw
#57 (bmi or body mass index or body weight):ti,ab,kw
#58 (hypertension or “blood pressure”):ti,ab,kw
#59 {or #54-#58}
#60 #53 and #59
#61 #52 or #60 Publication Year from 2016 to 2018

## Ovid Medline, Ovid MEDLINE In-Process & Other Non-Indexed Citations, Ovid MEDLINE Daily Update

1. Diet, Reducing/
2. Caloric Restriction/
3. Diet, Fat-Restricted/
4. Diet, Mediterranean/
5. Diet, Sodium-Restricted/
6. Diet, Carbohydrate-Restricted/
7. Diet, Carbohydrate Loading/
8. Diet, High-Protein Low-Carbohydrate/
9. Diet, Ketogenic/
10. Diet, Diabetic/
11. Diet, Gluten-Free/
12. Diet, High-Protein/
13. Diet, High-Protein Low-Carbohydrate/
14. Diet, Paleolithic/
15. Diet, Protein-Restricted/
16. Diet, Vegetarian/
17. Diet, Macrobiotic/
18. Diet, Vegan/
19. Fruit/
20. Vegetables/
21. Functional food/
22. Feeding behavior/
23. Healthy diet/
24. Healthy lifestyle/
25. Weight Reduction Programs/
26. Exercise/
27. physical conditioning, human/
28. circuit-based exercise/
29. high-intensity interval training/
30. plyometric exercise/
31. resistance training/
32. running/
33. jogging/
34. swimming/
35. walking/
36. stair climbing/
37. Fitness trackers/
38. Accelerometry/
39. Actigraphy/
40. Exercise Therapy/
41. Physical Fitness/
42. (diet or diets or dietary).ti,bt,kf.
43. (fruit* or vegetable*).ti,bt,kf.
44. (exercise or physical activity).ti,bt,kf.
45. walking.ti,bt,kf.
46. pedometer*.ti,ab,kf.
47. fitbit*.ti,ab,kf.
48. steps per.ti,ab,kf.
49. distance walked.ti,ab,kf.
50. measuring step*.ti,ab,kf.
51. step count*.ti,ab,kf.
52. ((activity or fitness) adj1 track*).ti,ab,kf.
53. Sedentary lifestyle/
54. (sedentary adj (lifestyle* or life style* or behavio* or time)).ti,ab,kf.
55. ((sitting or lying) adj2 time).ti,ab,kf.
56. Screen time.ti,ab,kf.
57. ((television or TV) adj viewing).ti,ab,kf.
58. ((watch* or view*) adj (television or TV)).ti,ab,kf.
59. ((computer or internet) adj (time or “use” or usage)).ti,ab,kf.
60. ((computer or video) adj game*).ti,ab,kf.
61. ((screen or screen based) adj (entertainment or behavio* or “use” or usage)).ti,ab,kf.
62. low energy expenditure*.ti,ab,kf.
63. physical* inactiv*.ti,ab,kf.
64. or/54-63
65. (reduce* or reduction* or decrease* or change* or target*).ti,ab.
66. 64 and 65
67. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or
  22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or
  41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 66
68. Counseling/
69. Directive Counseling/
70. "Behavior-Therapy"/
71. Cognitive Therapy/
72. "Referral and Consultation"/
73. Persuasive Communication/
74. Social Control, Informal/
75. Risk Reduction Behavior/
76. Life Style/
77. Healthy aging/
78. Motivation/
79. Social Support/
80. Feedback, Psychological/
81. Self Efficacy/
82. Health Knowledge, Attitudes, Practice/
83. Health Behavior/
84. Health Education/
85. Health Promotion/
86. Patient Education as Topic/
87. counsel*.ti,ab,kf.
88. (advice or advise or consultation*).ti,ab,kf.
89. (behavio* adj2 (therap* or chang* or modification* or improv*)).ti,ab,kf.
90. referral*.ti,ab,kf.
91. (set* adj2 goal*).ti,ab,kf.
92. action plan*.ti,ab,kf.
93. self monitor*.ti,ab,kf.
94. follow-up feedback.ti,ab,kf.
95. (assessment adj5 feedback).ti,ab,kf.
96. support planning.ti,ab,kf.
97. risk factor management.ti,ab,kf.
98. (life style or lifestyle).ti,ab,kf.
99. motivation*.ti,ab,kf.
100. health coach*.ti,ab,kf.
101. health behavio*.ti,ab,kf.
102. health education.ti,ab,kf.
103. education* program*.ti,ab,kf.
104. patient education.ti,ab,kf.
105. health promotion.ti,ab,kf.
106. (promot* adj3 (exercise or physical activit* or weight loss)).ti,ab,kf.
107. nonpharmacologic intervention*.ti,ab,kf.
108. non pharmacologic intervention*.ti,ab,kf.
109. intervention*.ti,bt.
110. or/68-109
111. (cardiovascular or cardiometabolic).ti,bt.
112. 67 and (110 or 111)
113. Healthy lifestyle/ or Healthy diet/
114. ((lifestyle adj2 intervention*) or (life style adj2 intervention*) or health* lifestyle or health* life style).ti,ab,kf.
115. 113 or 114
116. (cardiovascular or coronary or cardiometabolic or heart).ti,ab,kf,hw.
117. (insulin or glucose or diabet*).ti,ab,kf,hw.
118. (lipoprotein* or lipid* or triglyceride* or hyperlipidemia* or cholesterol).ti,ab,kf,hw.
119. (bmi or body mass index or body weight).ti,ab,kf,hw.
120. (hypertension or blood pressure).ti,ab,kf,hw.
121. or/116-120
122. 115 and 121
123. 112 or 122
124. limit 123 to “all child (0 to 18 years)”
125. limit 123 to “all adult (19 plus years)”
126. 124 not 125
127. 123 not 126
128. Animals/ not (Humans/ and Animals/)
129. 127 not 128
130. (clinical trial or controlled clinical trial or randomized controlled trial or adaptive clinical trial or equivalence
  clinical trial or pragmatic clinical trial or meta analysis).pt.
131. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or adaptive
  clinical trials as topic/ or equivalence clinical trials as topic/ or pragmatic clinical trials as topic/
132. Meta-Analysis as Topic/
133. Random allocation/
134. clinical trial*.ti,ab,kf.
135. (control* adj3 (study or studies or trial*)).ti,ab,kf.
136. random*.ti,ab,kf.
137. trial.ti.
138. or/130-137
139. 129 and 138
140. (harm or harms or harmful or harmed).ti,ab,kf.
141. (risky behavior* or risky behaviour*).ti,ab,kf.
142. (adverse effects or mortality).fs.
143. Mortality/
144. Morbidity/
145. death/
146. Athletic injuries/
147. Malnutrition/
148. nutritional defici*.ti,ab,kf.
149. (death or deaths).ti,ab,kf.
150. fracture*.ti,ab,hw.
151. or/140-150
152. 129 and 151
153. observational study/ or clinical study/ or case-control studies/ or cohort studies/ or longitudinal studies/ or
  follow-up studies/or prospective studies/
154. case control*.ti,ab,kf.
155. cohort.ti,ab,kf.
156. longitudinal.ti,ab,kf.
157. (follow-up or followup).ti,ab,kf.
158. prospective*.ti,ab,kf.
159. (comparison group* or control group*).ti,ab,kf.
160. observational.ti,ab,kf.
161. retrospective studies/
162. retrospective*.ti,ab,kf.
163. database*.ti,ab,kf.
164. nonrandomi*.ti,ab,kf.
165. population.ti,ab.
166. or/153-165
167. 152 and 166
168. 139 or 167
169. limit 168 to (english language and yr="2016 -Current")

## PsycInfo

1. Diets/
2. Dietary Restraint/
3. Eating Behavior/
4. fruit*.ti,ab,id.
5. vegetable*.ti,ab,id.
6. (diet or diets or dietary).ti,ab,id.
7. Exercise/
8. Physical Activity/
9. Aerobic Exercise/
10. Walking/
11. (exercise or physical activity).ti,ab,id.
12. walking.ti,ab,id.
13. (pedometer* or fitbit* or steps per or distance walked or measuring step* or step count*).ti,ab,id.
14. ((activity or fitness) adj1 track*).ti,ab,id.
15. Activity Level/
16. Sedentary behavior/
17. (sedentary adj (lifestyle* or life style* or behavio* or time)).ti,ab,id.
18. ((sitting or lying) adj2 time).ti,ab,id.
19. Screen time/
20. Television/
21. Television Viewing/
22. Computers/
23. Computer Games/
24. Role Playing Games/
25. Simulation Games/
26. screen time.ti,ab,id.
27. ((television or TV) adj viewing).ti,ab,id.
28. ((watch* or view*) adj (television or TV)).ti,ab,id.
29. ((computer or internet) adj (time or “use” or usage)).ti,ab,id.
30. ((computer or video) adj game*).ti,ab,id.
31. ((screen or screen based) adj (entertainment or behavio* or “use” or usage)).ti,ab,id.
32. low energy expenditure*.ti,ab,id.
33. physical* inactiv*.ti,ab,id.
34. or/1-33
35. behavior therapy/
36. cognitive behavior therapy/
37. cognitive therapy/
38. Cognitive Techniques/
39. Behavior Modification/
40. Behavior Change/
41. Lifestyle Changes/
42. Lifestyle/
43. Persuasive Communication/
44. Motivation/
45. Motivational Interviewing/
46. Self Efficacy/
47. Health Knowledge/
48. Health Behavior/
49. Health Education/
50. Health Promotion/
51. Client Education/
52. counseling/
53. counsel*.ti,ab,id,hw.
54. (advice or advise or consultation*).ti,ab,id,hw.
55. (behavio* adj2 (therap* or chang* or modification* or improv*)).ti,ab,id.
56. referral*.ti,ab,id.
57. (set* adj2 goal*).ti,ab,id.
58. action plan*.ti,ab,id.
59. self monitor*.ti,ab,id.
60. follow-up feedback.ti,ab,id.
61. (assessment adj5 feedback).ti,ab,id.
62. support planning.ti,ab,id.
63. risk factor management.ti,ab,id.
64. (life style or lifestyle).ti,ab,id.
65. motivation*.ti,ab,id.
66. (health adj (coach* or behavio* or education)).ti,ab,id.
67. education* program*.ti,ab,id.
68. patient education.ti,ab,id.
69. health promotion.ti,ab,id.
70. (promot* adj3 (exercise or physical activit* or weight loss)).ti,ab,id.
71. nonpharmacologic intervention*.ti,ab,id.
72. non pharmacologic intervention*.ti,ab,id.
73. intervention.ti.
74. or/35-73
75. (cardiovascular or cardiometabolic).ti.
76. 34 and (74 or 75)
77. ((lifestyle adj2 intervention*) or (life style adj2 intervention*) or health* lifestyle or health* life style).ti,ab,id.
78. (cardiovascular or coronary or cardiometabolic or heart).ti,ab,id.
79. (insulin or glucose or diabet*).ti,ab,id.
80. (lipoprotein* or lipid* or triglyceride* or hyperlipidemia* or cholesterol).ti,ab,id.
81. (bmi or body mass index or body weight).ti,ab,id.
82. (hypertension or blood pressure).ti,ab,id.
83. or/78-82
84. 77 and 83
85. 76 or 84
86. (control* adj3 (study or studies or trial*)).ti,ab,id,hw.
87. clinical trial*.ti,ab,id,hw.
88. random*.ti,ab,id,hw.
89. trial.ti.
90. (treatment outcome or clinical trial).md.
91. or/86-89
92. 85 and 91
93. (harm or harms or harmful or harmed).ti,ab,id,hw.
94. (risky behavior* or risky behaviour*).ti,ab,id,hw.
95. adverse effect*.ti,ab,id,hw.
96. mortality.ti,ab,id,hw.
97. morbidity.ti,ab,id,hw.
98. death.ti,ab,id,hw.
99. nutritional defici*.ti,ab,id,hw.
100. fracture*.ti,ab,id,hw.
101. or/93-100
102. 85 and 101
103. case control*.ti,ab,id,hw.
104. cohort.ti,ab,id,hw.
105. longitudinal.ti,ab,id,hw.
106. (follow-up or followup).ti,ab,id,hw.
107. prospective*.ti,ab,id,hw.
108. (comparison group* or control group*).ti,ab,id,hw.
109. observational.ti,ab,id,hw.
110. retrospective*.ti,ab,id,hw.
111. database*.ti,ab,id,hw.
112. nonrandomi*.ti,ab,id,hw.
113. population*.ti,ab,id,hw.
114. or/103-113
115. 102 and 114
116. 92 or 115
117. limit 116 to (100 childhood <birth to age 12 yrs> or 120 neonatal <birth to age 1 mo> or 140 infancy <2 to 23
  mo> or 160 preschool age <age 2 to 5 yrs> or 180 school age <age 6 to 12 yrs> or 200 adolescence <age 13
  to 17 yrs>)
118. limit 116 to ("300 adulthood <age 18 yrs and older>" or 320 young adulthood <age 18 to 29 yrs> or 340 thirties
  <age 30 to 39 yrs> or 360 middle age <age 40 to 64 yrs> or “380 aged <age 65 yrs and older>” or “390 very
  old <age 85 yrs and older>”)
119. 117 not 118
120. 116 not 119
121. limit 120 to animal
122. limit 120 to human
123. 121 not 122
124. 120 not 123
125. limit 124 to (english language and yr="2016 -Current")

Appendix A Table 1 Study Design-Specific Quality Rating Criteria*

| Include | Exclude
Condition definition | The current review will target populations at increased risk of cardiovascular disease due to hypertension or elevated blood pressure, dyslipidemia, or through examination of multiple risk factors. Examination of multiple risk factors may include 10-year CVD risk of >7.5% (e.g., using the Pooled Cohort Equations or Framingham risk calculators), presence of the metabolic syndrome, or mixed risk factors (i.e. studies that include persons with any of a number of CVD risk factors (e.g., hypertension, dyslipidemia, prediabetes, smoking, obesity, etc.). | Increased risk of cardiovascular disease solely due to prediabetes (trials in this population will be included in a concurrent review of screening for abnormal blood glucose and type 2 diabetes mellitus).
Populations | Adults age >18 with known hypertension or elevated blood pressure, dyslipidemia, the metabolic syndrome, or with 10-year CVD risk of 7.5% or greater based on a CVD risk assessment tool, or trial inclusion criteria specifies that population has one or more CVD risk factors | Trials limited to or predominantly:; - Children and adolescents; - Parents (if intended behavior change is directed towards children); - Persons with prediabetes; - Persons with known CVD or diabetes mellitus such that >50% of participants have known CVD, severe chronic kidney disease, or diabetes (including gestational diabetes); - Persons with medical conditions limiting their generalizability to primary care-based populations of persons with CVD risk factors (e.g., acute illness, cognitive impairment, severe and persistent mental illness, cancer, chronic pain); - Institutionalized persons
Settings | - Conducted in or recruited from primary care or a health care system or could feasibly be implemented in or referred from primary care.; - Trials in countries rated as “very high” on the UN Human Development Index (based on 2015 indicators): Andorra, Argentina, Australia, Austria, Bahrain, Belgium, Brunei Darussalam, Canada, Chile, Croatia, Cyprus, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Montenegro, Netherlands, New Zealand, Norway, Poland, Portugal, Qatar, Romania, Russia, Saudi Arabia, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States | - Settings not generalizable to primary care (e.g., inpatient hospital units, emergency departments, nursing home and other institutionalized settings, school classroom-based programs, occupational settings, dental clinics
Interventions | Behavioral counseling intervention alone or as part of a larger multicomponent intervention on diet and nutrition, physical activity, sedentary behavior, or a combination, including but not limited to: assessment with feedback, advice, collaborative goal-setting, assistance, exercise prescriptions (referral to exercise facility or program), or arranging further contacts; Interventions may be delivered via face-to-face contact, telephone, print materials, or technology (e.g., computer-based, text messages, remote video feed) and can be delivered by a number of potential interventionists, including but not limited to: physicians, nurses, exercise specialists, dietitians, nutritionists, and behavioral health specialists; Dietary counseling may involve any of:; - Increased consumption of fruits, vegetables, whole grains, fat-free or low-fat dairy, lean proteins; - Limited consumption of sodium, saturated fat, trans fat, sugar-sweetened food and beverages; Physical activity (PA) counseling may involve any of:; - Aerobic activities that involve repeated use of large muscles, such as walking, cycling, and swimming; - Resistance training designed to improve physical strength; - Reduction of sedentary behaviors; - Optional or access to guided physical activity or exercise classes allowed; Limited guided physical activity (i.e., 1-2 sessions) or provision of food samples allowed if intention is to teach or demonstrate healthy lifestyle principles | - Non-counseling interventions (e.g., use of incentives, supervised exercise with the goal of assessing effects of exercise);; - Interventions providing controlled diets;; - counseling interventions aimed at diabetes prevention, falls prevention, depression, cognitive functioning, or disease prevention other than CVD; - Prenatal or post-natal dietary counseling;; - Counseling interventions with components that are not feasible for implementation in healthcare settings, e.g., occupational/worksite, church, or school-based interventions that are conducted within existing social networks; social marketing (e.g., media campaigns); or policy (e.g., local or state public/health policy);; - Stress management interventions (e.g., meditation; yoga or tai chi-based interventions that have minimal aerobic or strength-building activities); - Dietary counseling solely focused on increasing specific vitamins, micronutrients or anti-oxidants through dietary change or supplementation, or on alcohol moderation; - Physical activity counseling solely focused on balance, flexibility, or gait
Comparisons | - No intervention (e.g., wait-list, usual care); - Minimal intervention (e.g., pamphlets, links to general information web sources, in-person counseling of no more than an estimated 60 minutes annually, presenting information similar to what individuals can receive through usual care in a primary care setting, but without personalized prescription based on standardized assessment); - Attention control (e.g., similar format and intensity intervention on a different content area) | - Comparative-effectiveness trials without a control (as defined in inclusion column); - PA only: studies in which the control group is instructed not to exercise
Outcomes | KQ1: Health outcomes; - Cardiovascular events and related morbidity (e.g., stroke, myocardial infarction, heart failure, heart failure); - Cardiovascular and all-cause mortality; - Quality of life measures and related outcomes (e.g., functioning, well-being); KQ2: Intermediate outcomes; - Blood pressure; - TC, LDL and HDL cholesterol; - Hba1c, fasting glucose, 1- and 2-hr glucose tolerance; - BMI, weight, waist circumference; - Dichotomized versions of CVD risk factors (hypertension, dyslipidemia, diabetes, overweight or obesity, incidence of metabolic syndrome); - Calculated 10-year CVD risk; - Cardiorespiratory fitness (e.g., VO2max, heart rate, exercise tolerance, 6 minute walk); KQ 3: Behavioral outcomes; - Dietary intake or patterns; - Physical activity; - Sedentary behavior; KQ4: Adverse outcomes; - Harms requiring medical attention (e.g., nutritional deficiencies, musculoskeletal injuries, cardiovascular events) | - Initiation or withdrawal of medication; - Knowledge, attitudes, self-efficacy,; - Mental health symptom scores; - Balance, flexibility; - Less than 6 months; - Less than 60% followup
Timing of outcome assessment | ≥6 months post-baseline | <6 months post-baseline
Study Designs | - Fair to good quality studies; - KQ1, 2, 3: RCT, CCT (Prior to 2001: RCTs only); - KQ4: systematic reviews, RCT, CCT, comparative cohort, population-based case-control studies | - Poor quality studies; - KQ1, 2: any observational studies; - KQ3: ecological studies, case-series, case reports
Publication Date | - Trials published from 1990 to present | - Trials whose primary results were published prior to 1990

Abbreviations: CCT = controlled clinical trial; CVD = cardiovascular disease; HDL = high-density lipoprotein; HTN = hypertension; KQ = key question; LDL = low-density lipoprotein; RCT = randomized, controlled trial; TC = total cholesterol; USPSTF = United States Preventive Services Task Force

Appendix A Table 2 Study Design-Specific Quality Rating Criteria^*^

Study Design | Adapted Quality Criteria
Randomized clinical trials, adapted from U.S. Preventive Services Task Force Manual^1^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported
Cohort studies, adapted from Newcastle-Ottawa Scale^2^ | Bias arising in randomization process or due to confounding; - Balance in baseline characteristics; - No baseline confounding; - No time-varying confounding; Bias in selecting participants into the study; - No evidence of biased selection of sample; - Start of followup and start of intervention coincide; Bias due to departures form intended interventions; - Participant intervention status is clearly and explicitly defined and measured; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome; Bias in classifying interventions; - Fidelity to intervention protocol; - Participants were analyzed as originally allocated; Bias from missing data; - Outcome data are reasonably complete and comparable between groups; - Confounding variables that are controlled for in analysis are reasonably complete; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported

* All randomized clinical trials were classified as good, fair, or poor according to the USPSTF Procedure Manual^1^