# References

1 U.S.Preventive Services Task Force. Hepatitis B Virus Infection: Screening, 2014. https://www.uspreventiveservicestaskforce.org/Page/Document/UpdateSummaryFinal/hepatitis-b-virus-infection-screening-2014?ds=1&s=hepatitis%20b. Accessed August 27, 2019.
2 LeFevre ML. Screening for hepatitis B virus infection in nonpregnant adolescents and adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;161(1):58–66. doi: 10.7326/m14-1018. PMID: 24863637.24863637
3 Chou R, Dana T, Bougatsos C, . Screening for hepatitis B virus infection in adolescents and adults: a systematic review to update the U.S. Preventive Services Task Force recommendation. Ann Intern Med. 2014;161(1):31–45. doi: 10.7326/m13-2837. PMID: 24861032.24861032
4 Chou R, Dana T, Bougatsos C, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Screening for Hepatitis B Virus Infection in Nonpregnant Adolescents and Adults: Systematic Review to Update the 2004 U.S. Preventive Services Task Force Recommendation. Evidence Synthesis No. 110. AHRQ Publication No. 12-05172-EF-1 Rockville (MD): Agency for Healthcare Research and Quality (US); 2014.
5 Lin KW, Kirchner JT. Hepatitis B. Am Fam Physician. 2004;69(1):75–82. PMID: 14727820.14727820
6 Mast EE, Weinbaum CM, Fiore AE, . A comprehensive immunization strategy to eliminate transmission of hepatitis B virus infection in the United States: recommendations of the Advisory Committee on Immunization Practices (ACIP) Part II: immunization of adults. MMWR Recomm Rep. 2006;55(RR-16):1–33; quiz CE1-4. PMID: 17159833.17159833
7 Centers for Disease Control and Prevention. Interpretation of Hepatitis B Serologic Test Results. 2005. www.cdc.gov/hepatitis/hbv/pdfs/serologicchartv8.pdf. Accessed August 21, 2019.
8 Terrault NA, Lok ASF, McMahon BJ, . Update on prevention, diagnosis, and treatment of chronic hepatitis B: AASLD 2018 hepatitis B guidance. Hepatology. 2018;67(4):1560–99. doi: 10.1002/hep.29800. PMID: 29405329.29405329
9 Dusheiko G, Antonakopoulos N. Current treatment of hepatitis B. Gut. 2008;57(1):105–24. PMID: 17502343.17502343
10 Mast EE, Margolis HS, Fiore AE, . A comprehensive immunization strategy to eliminate transmission of hepatitis B virus infection in the United States: recommendations of the Advisory Committee on Immunization Practices (ACIP) part 1: immunization of infants, children, and adolescents. MMWR Recomm Rep. 2005;54(RR-16):1–31. PMID: 16371945.16371945
11 Hoofnagle JH. Reactivation of hepatitis B. Hepatology. 2009;49:(5 Suppl):S156–65. doi: 10.1002/hep.22945. PMID: 19399803.19399803
12 Centers for Disease Control and Prevention. Viral Hepatitis Surveillance – United States, 2017. Version published November 14, 2019. 2019. https://www.cdc.gov/hepatitis/statistics/2017surveillance/index.htm. Accessed January 22, 2020.
13 Iqbal K, Klevens RM, Kainer MA, . Epidemiology of acute hepatitis B in the United States from population-based surveillance, 2006-2011. Clin Infect Dis. 2015;61(4):584–92. doi: 10.1093/cid/civ332. PMID: 25904365.25904365
14 Kim BH, Kim WR. Epidemiology of hepatitis B virus infection in the United States. Clin Liver Dis. 2018;12(1):1–4. doi: 10.1002/cld.732. PMID: 30988901.30988901
15 Kushner T, Chen Z, Tressler S, . Trends in hepatitis B infection and immunity among women of childbearing age in the United States. Clin Infect Dis. 2020;71(3):586–92. doi: 10.1093/cid/ciz841. PMID: 31504302.31504302
16 Roberts H, Kruszon-Moran D, Ly KN, . Prevalence of chronic hepatitis B virus (HBV) infection in U.S. households: national health and nutrition examination survey (NHANES), 1988-2012. Hepatology. 2016;63(2):388–97. doi: 10.1002/hep.28109. PMID: 26251317.26251317
17 Mitchell T, Armstrong G, Hu D, . The increasing burden of imported chronic hepatitis B—United States, 1974–2008. PLoS One. 2011;6(12):e27717. PMID: 22163270.22163270
18 Kowdley KV, Wang CC, Welch S, . Prevalence of chronic hepatitis B among foreign-born persons living in the United States by country of origin. Hepatology. 2012;56(2):422–33. doi: 10.1002/hep.24804. PMID: 22105832.22105832
19 U.S. Department of Commerce. QuickFacts United States. 2018. www.census.gov/quickfacts/fact/table/US/PST045217. Accessed August 21, 2019.
20 Centers for Disease Control and Prevention. Hepatitis B General Fact Sheet. 2010. www.cdc.gov/hepatitis/hbv/pdfs/hepbgeneralfactsheet.pdf. Accessed August 21, 2019.
21 United States Preventive Services Task Force. Screening for hepatitis B virus infection in pregnancy. Ann Intern Med. 2009;150:869–73. PMID: 19528565.19528565
22 Weinbaum CM, Williams I, Mast EE, . Recommendations for identification and public health management of persons with chronic hepatitis B virus infection. MMWR Recomm Rep. 2008;57(RR-8):1–20. PMID: 18802412.18802412
23 Kim GA, Lim YS, Han S, . High risk of hepatocellular carcinoma and death in patients with immune-tolerant-phase chronic hepatitis B. Gut. 2018;67(5):945–52.29055908
24 Fattovich G, Bortolotti F, Donato F. Natural history of chronic hepatitis B: Special emphasis on disease progression and prognostic factors. J Hepatol. 2008;48(2):335–52. doi: 10.1016/j.jhep.2007.11.011. PMID: 18096267.18096267
25 Chen CJ, Yang HI, Su J, . Risk of hepatocellular carcinoma across a biological gradient of serum hepatitis B virus DNA level. JAMA. 2006;295(1):65–73. doi: 10.1001/jama.295.1.65. PMID: 16391218.16391218
26 Iloeje UH, Yang HI, Su J, . Predicting cirrhosis risk based on the level of circulating hepatitis B viral load. Gastroenterology. 2006;130(3):678–86. doi: 10.1053/j.gastro.2005.11.016. PMID: 16530509.16530509
27 Bersoff-Matcha SJ, Cao K, Jason M, . Hepatitis B virus reactivation associated with direct-acting antiviral therapy for chronic hepatitis C virus: a review of cases reported to the U.S. Food and Drug Administration adverse event reporting system. Ann Intern Med. 2017;166(11):792–8. doi: 10.7326/m17-0377. PMID: 28437794.28437794
28 Loomba R, Liang TJ. Hepatitis B reactivation associated with immune suppressive and biological modifier therapies: current concepts, management strategies, and future directions. Gastroenterology. 2017;152(6):1297–309. doi: 10.1053/j.gastro.2017.02.009. PMID: 28219691.28219691
29 Mucke MM, Backus LI, Mucke VT, . Hepatitis B virus reactivation during direct-acting antiviral therapy for hepatitis C: a systematic review and meta-analysis. Lancet Gastroenterol Hepatol. 2018;3(3):172–80. doi: 10.1016/S2468-1253(18)30002-5. PMID: 29371017.29371017
30 Sorrell MF, Belongia EA, Costa J, . National Institutes of Health consensus development conference statement: management of hepatitis B. Ann Intern Med. 2009;150:104–10. PMID: 19124811.19124811
31 World Health Organization. Global Hepatitis Report. 2017. http://apps.who.int/iris/bitstream/handle/10665/255016/9789241565455-eng.pdf;jsessionid=23CD86753C0FA6AE96C26AC476ABACBB?sequence=1. Accessed August 21, 2019.
32 Quaglio G, Lugoboni F, Mezzelani P, . Hepatitis vaccination among drug users. Vaccine. 2006;24(15):2702–9. PMID: 16436307.16436307
33 Wasley A, Grytdal S, Gallagher K. Surveillance for acute viral hepatitis--United States, 2006. MMWR Surveill Summ. 2008;57(2):1–24. PMID: 18354374.18354374
34 Harris AM, Iqbal K, Schillie S, . Increases in acute hepatitis B virus infections - Kentucky, Tennessee, and West Virginia, 2006-2013. MMWR Morb Mortal Wkly Rep. 2016;65(3):47–50. doi: 10.15585/mmwr.mm6503a2. PMID: 26821369.26821369
35 Tyson GL, Kramer JR, Duan Z, . Prevalence and predictors of hepatitis B virus coinfection in a United States cohort of hepatitis C virus-infected patients. Hepatology. 2013;58(2):538–45. doi: 10.1002/hep.26400. PMID: 23505059.23505059
36 Bini EJ, Perumalswami PV. Hepatitis B virus infection among American patients with chronic hepatitis C virus infection: prevalence, racial/ethnic differences, and viral interactions. Hepatology. 2010;51(3):759–66. doi: 10.1002/hep.23461. PMID: 20140950.20140950
37 Siddiqui F, Mutchnick M, Kinzie J, . Prevalence of hepatitis A virus and hepatitis B virus immunity in patients with polymerase chain reaction-confirmed hepatitis C: implications for vaccination strategy. Am J Gastroenterol. 2001;96(3):858–63. doi: 10.1111/j.1572-0241.2001.03633.x. PMID: 11280565.11280565
38 Global prevalence, treatment, and prevention of hepatitis B virus infection in 2016: a modelling study. Lancet Gastroenterol Hepatol. 2018;3(6):383–403. doi: 10.1016/s2468-1253(18)30056-6. PMID: 29599078.29599078
39 Quang YN, Vu J, Yuk J, . Prevalence of hepatitis B surface antigen in US-born and foreign-born Asian/Pacific Islander college students. J Am Coll Health. 2010;59(1):37–41. doi: 10.1080/07448481.2010.486811. PMID: 20670927.20670927
40 Lin SY, Chang ET, So SK. Why we should routinely screen Asian American adults for hepatitis B: a cross-sectional study of Asians in California. Hepatology. 2007;46(4):1034–40. PMID: 17654490.17654490
41 Schillie S, Vellozzi C, Reingold A, . Prevention of hepatitis B virus infection in the United States: recommendations of the advisory committee on immunization practices. MMWR Recomm Rep. 2018;67(1):1–31. doi: 10.15585/mmwr.rr6701a1. PMID: 29939980.29939980
42 World Health Organization. Immunization Coverage. 2018. http://www.who.int/en/news-room/fact-sheets/detail/immunization-coverage. Accessed August 21, 2019.
43 Zanetti AR, Van Damme P, Shouval D. The global impact of vaccination against hepatitis B: a historical overview. Vaccine. 2008;26(49):6266–73. doi: 10.1016/j.vaccine.2008.09.056. PMID: 18848855.18848855
44 Dynavax. Dynavax Announces FDA Approval of HEPLISAV-B(TM) for Prevention of Hepatitis B in Adults. 2017. http://investors.dynavax.com/news-releases/news-release-details/dynavax-announces-fda-approval-heplisav-btm-prevention-hepatitis. Accessed August 21, 2019.
45 Major M. Summary Basis for Regulatory Action. 2017. https://www.fda.gov/downloads/BiologicsBloodVaccines/Vaccines/ApprovedProducts/UCM590190.pdf Accessed August 21, 2019.
46 Centers for Disease Control and Prevention. Prevention of Hepatitis B Virus Infection in the United States: Recommendations of the Advisory Committee on Immunization Practices. 2018. https://www.cdc.gov/mmwr/volumes/67/rr/rr6701a1.htm. Accessed August 21, 2019.
47 Hoofnagle JH, Doo E, Liang TJ, . Management of hepatitis B: summary of a clinical research workshop. Hepatology. 2007;45(4):1056–75. doi: 10.1002/hep.21627. PMID: 17393513.17393513
48 Martin P, Lau DT, Nguyen MH, . A treatment algorithm for the management of chronic hepatitis B virus infection in the United States: 2015 update. Clin Gastroenterol Hepatol. 2015;13(12):2071–87.e16. doi: 10.1016/j.cgh.2015.07.007. PMID: 26188135.26188135
49 U.S. Department of Health and Human Services. Hepatitis B and C Treatments. 2018. www.fda.gov/forpatients/illness/hepatitisbc/ucm408658.htm. Accessed August 21, 2019.
50 Gilead. U.S. Food and Drug Administration approved Gilead’s Vemlidy(R) (Tenofovir Alafenamide) for the treatment of chronic hepatitis B virus infection. 2018. https://www.gilead.com/news/press-releases/2016/11/us-food-and-drug-administration-approves-gileads-vemlidy-tenofovir-alafenamide-for-the-treatment-of-chronic-hepatitis-b-virus-infection. Accessed August 21, 2018.
51 Tang LSY, Covert E, Wilson E, . Chronic hepatitis B infection: a review. JAMA. 2018;319(17):1802–13. doi: 10.1001/jama.2018.3795. PMID: 29715359.29715359
52 Soriano V, Barreiro P, Benitez L, . New antivirals for the treatment of chronic hepatitis B. Expert Opin Investig Drugs. 2017;26(7):843–51. doi: 10.1080/13543784.2017.1333105. PMID: 28521532.28521532
53 Fransen van de Putte D, Blom R, van Soest H, . Impact of Fibroscan on management of chronic viral hepatitis in clinical practice. Ann Hepatol. 2011;10(4):469–76. PMID: 21911887.21911887
54 Poynard T, Vergniol J, Ngo Y, . Staging chronic hepatitis B into seven categories, defining inactive carriers and assessing treatment impact using a fibrosis biomarker (FibroTest(R)) and elastography (FibroScan(R)). J Hepatol. 2014;61(5):994–1003. doi: 10.1016/j.jhep.2014.06.027. PMID: 25016224.25016224
55 Houot M, Ngo Y, Munteanu M, . Systematic review with meta-analysis: direct comparisons of biomarkers for the diagnosis of fibrosis in chronic hepatitis C and B. Aliment Pharmacol Ther. 2016;43(1):16–29. doi: 10.1111/apt.13446. PMID: 26516104.26516104
56 Parikh P, Ryan JD, Tsochatzis EA. Fibrosis assessment in patients with chronic hepatitis B virus (HBV) infection. Ann Transl Med. 2017;5(3):40. doi: 10.21037/atm.2017.01.28. PMID: 28251119.28251119
57 Kansagara D, Papak J, Pasha AS, . Screening for hepatocellular carcinoma in chronic liver disease: a systematic review. Ann Intern Med. 2014;161(4):261–9. doi: 10.7326/m14-0558. PMID: 24934699.24934699
58 Zhou K, Fitzpatrick T, Walsh N, . Interventions to optimise the care continuum for chronic viral hepatitis: a systematic review and meta-analyses. Lancet Infect Dis. 2016;16(12):1409–22. doi: 10.1016/S1473-3099(16)30208-0. PMID: 27615026.27615026
59 Abara WE, Qaseem A, Schillie S, . Hepatitis B vaccination, screening, and linkage to care: best practice advice from the American College of Physicians and the Centers for Disease Control and Prevention. Ann Intern Med. 2017;167(11):794–804. doi: 10.7326/M17-1106. PMID: 29159414.29159414
60 Liu C, Chen T, Lin J, . Evaluation of the performance of four methods for detection of hepatitis B surface antigen and their application for testing 116,455 specimens. J Virol Methods. 2014;196:174–8. doi: 10.1016/j.jviromet.2013.10.039. PMID: 24239632.24239632
61 Gish RG, Gutierrez JA, Navarro-Cazarez N, . A simple and inexpensive point-of-care test for hepatitis B surface antigen detection: serological and molecular evaluation. J Viral Hepat. 2014;21(12):905–8. doi: 10.1111/jvh.12257. PMID: 24779356.24779356
62 Chevaliez S, Challine D, Naija H, . Performance of a new rapid test for the detection of hepatitis B surface antigen in various patient populations. J Clin Virol. 2014;59(2):89–93. doi: 10.1016/j.jcv.2013.11.010. PMID: 24355522.24355522
63 Amini A, Varsaneux O, Kelly H, . Diagnostic accuracy of tests to detect hepatitis B surface antigen: a systematic review of the literature and meta-analysis. BMC Infect Dis. 2017;17:(Suppl 1):698. doi: 10.1186/s12879-017-2772-3. PMID: 29143619.29143619
64 Spradling PR, Rupp L, Moorman AC, . Hepatitis B and C virus infection among 1.2 million persons with access to care: factors associated with testing and infection prevalence. Clin Infect Dis. 2012;55(8):1047–55. PMID: 22875876.22875876
65 Burman BE, Mukhtar NA, Toy BC, . Hepatitis B management in vulnerable populations: gaps in disease monitoring and opportunities for improved care. Dig Dis Sci. 2014;59(1):46–56. doi: 10.1007/s10620-013-2870-z. PMID: 24052195.24052195
66 Mukhtar NA, Toy BC, Burman BE, . Assessment of HBV preventive services in a medically underserved Asian and Pacific Islander population using provider and patient data. J Gen Intern Med. 2015;30(1):68–74. doi: 10.1007/s11606-014-3057-9. PMID: 25324148.25324148
67 Vijayadeva V, Spradling PR, Moorman AC, . Hepatitis B virus infection testing and prevalence among Asian and Pacific Islanders. Am J Manag Care. 2014;20(4):e98–e104. PMID: 24884958.24884958
68 National Academies of Sciences Engineering and Medicine. A national strategy for the elimination of hepatitis B and C. Washington, DC: The National Academies Press. 2017.
69 World Health Organization. Guidelines on hepatitis B and C testing. http://www.who.int/hepatitis/publications/guidelines-hepatitis-c-b-testing/en/ Accessed August 23, 2018. 2017.
70 National Institute for Health and Care Excellence. Hepatitis B and C testing: people at risk of infection. 2013. https://www.nice.org.uk/guidance/ph43. Accessed August 21, 2019.
71 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force procedure manual. Rockville, MD; 2016. http://www.uspreventiveservicestaskforce.org/Home/GetFile/6/7/procedure-manual_2016/pdf. Accessed August 21, 2019.
72 Chou R, Dana T, Bougatsos C, . Screening for Hepatitis B Virus Infection in Nonpregnant Adolescents and Adults: Systematic Review to Update the 2004 U.S. Preventive Services Task Force Recommendation. Evidence Synthesis No. 110. AHRQ Publication No. 12-05172-EF-1 Rockville (MD): Agency for Healthcare Research and Quality (US); 2014. PMID: 2492111224921112.
73 Sterne JA, Sutton AJ, Ioannidis JP, . Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. doi: 10.1136/bmj.d4002. PMID: 21784880.21784880
74 Bozkaya H, Yurdaydin C, Idilman R, . Lamivudine treatment in HBeAg-negative chronic hepatitis B patients with low level viraemia. Antivir Ther. 2005;10(2):319–25. PMID: 15865226.15865226
75 Chan HL-Y, Wang H, Niu J, . Two-year lamivudine treatment for hepatitis B e antigen-negative chronic hepatitis B: a double-blind, placebo-controlled trial. Antivir Ther. 2007;12(3):345–53. PMID: 17591024.17591024
76 Dienstag JL, Schiff ER, Wright TL, . Lamivudine as initial treatment for chronic hepatitis B in the United States. N Engl J Med. 1999;341(17):1256–63. doi: 10.1056/nejm199910213411702. PMID: 10528035.10528035
77 Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, . Adefovir dipivoxil for the treatment of hepatitis B e antigen-negative chronic hepatitis B. N Engl J Med. 2003;348(9):800–7. doi: 10.1056/NEJMoa021812. PMID: 12606734.12606734
78 Lai CL, Chien RN, Leung NW, . A one-year trial of lamivudine for chronic hepatitis B. Asia hepatitis lamivudine study group. N Engl J Med. 1998;339(2):61–8. doi: 10.1056/nejm199807093390201. PMID: 9654535.9654535
79 Lai CL, Ching CK, Tung AK, . Lamivudine is effective in suppressing hepatitis B virus DNA in Chinese hepatitis B surface antigen carriers: a placebo-controlled trial. Hepatology. 1997;25(1):241–4. PMID: 8985298.8985298
80 Lampertico P, Del Ninno E, Manzin A, . A randomized, controlled trial of a 24-month course of interferon alfa 2b in patients with chronic hepatitis B who had hepatitis B virus DNA without hepatitis B e antigen in serum. Hepatology. 1997;26(6):1621–5. PMID: 9398007.9398007
81 Lin SM, Sheen IS, Chien RN, . Long-term beneficial effect of interferon therapy in patients with chronic hepatitis B virus infection. Hepatology. 1999;29(3):971–5. PMID: 10051505.10051505
82 Marcellin P, Chang TT, Lim SG, . Adefovir dipivoxil for the treatment of hepatitis B e antigen-positive chronic hepatitis B. N Engl J Med. 2003;348(9):808–16. doi: 10.1056/NEJMoa020681. PMID: 12606735.12606735
83 Mazzella G, Saracco G, Festi D, . Long-term results with interferon therapy in chronic type B hepatitis: a prospective randomized trial. Am J Gastroenterol. 1999;94(8):2246–50. PMID: 10445557.10445557
84 Muller R, Baumgarten R, Markus R, . Treatment of chronic hepatitis B with interferon alfa-2b. J Hepatol. 1990;11:(Suppl 1):S137–40. doi: 10.1016/0168-8278(90)90181-p. PMID: 2079572.2079572
85 Tassopoulos NC, Volpes R, Pastore G, . Efficacy of lamivudine in patients with hepatitis B e antigen-negative/hepatitis B virus DNA-positive (precore mutant) chronic hepatitis B. Lamivudine Precore Mutant Study Group. Hepatology. 1999;29(3):889–96. doi: 10.1002/hep.510290321. PMID: 10051494.10051494
86 Yalcin K, Degertekin H, Kokoglu OF, . A three-month course of lamivudine therapy in HBeAg-positive hepatitis B patients with normal aminotransferase levels. Turk J Gastroenterol. 2004;15(1):14–20. PMID: 15264116.15264116
87 Yao G, Wang B, Cui Z, . A randomized double-blind placebo-controlled study of lamivudine in the treatment of patients with chronic hepatitis B virus infection. Chin Med J. 1999;112(5):387–91. PMID: 11593504.11593504
88 Realdi G, Fattovich G, Pastore G, . Problems in the management of chronic hepatitis B with interferon: experience in a randomized, multicentre study. J Hepatol. 1990;11: Suppl 1:S129–32. PMID: 2079570.2079570
89 Thomas HC, Lok AS, Carreno V, . Comparative study of three doses of interferon-alpha 2a in chronic active hepatitis B. The International Hepatitis Trial Group. J Viral Hepat. 1994;1(2):139–48. PMID: 8790569.8790569
90 Tseng KC, Chen CY, Tsai HW, . Efficacy of entecavir in chronic hepatitis B patients with persistently normal alanine aminotransferase: randomized, double-blind, placebo-controlled study. Antivir Ther. 2014;19(8):755–64. doi: 10.3851/IMP2754. PMID: 24583931.24583931
91 Wen Z, Zhang H, Zhang M, . Effect of hepatitis B virus genotypes on the efficacy of adefovir dipivoxil antiviral therapy. Hepatology. 2014;14(8):e10813. doi: 10.5812/hepatmon.10813. PMID: 25237370.25237370
92 Chang TT, Gish RG, de Man R, . A comparison of entecavir and lamivudine for HBeAg-positive chronic hepatitis B. N Engl J Med. 2006;354(10):1001–10. doi: 10.1056/NEJMoa051285. PMID: 16525137.16525137
93 Lai CL, Shouval D, Lok AS, . Entecavir versus lamivudine for patients with HBeAg-negative chronic hepatitis B. N Engl J Med. 2006;354(10):1011–20. doi: 10.1056/NEJMoa051287. PMID: 16525138.16525138
94 Lai C-L, Rosmawati M, Lao J, . Entecavir is superior to lamivudine in reducing hepatitis B virus DNA in patients with chronic hepatitis B infection. Gastroenterology. 2002;123(6):1831–8. PMID: 12454840.12454840
95 Lau GK, Piratvisuth T, Luo KX, . Peginterferon Alfa-2a, lamivudine, and the combination for HBeAg-positive chronic hepatitis B. N Engl J Med. 2005;352(26):2682–95. doi: 10.1056/NEJMoa043470. PMID: 15987917.15987917
96 Marcellin P, Heathcote EJ, Buti M, . Tenofovir disoproxil fumarate versus adefovir dipivoxil for chronic hepatitis B. N Engl J Med. 2008;359(23):2442–55. doi: 10.1056/NEJMoa0802878. PMID: 19052126.19052126
97 Ren F-Y, Piao D-M, Piao X-X. A one-year trial of entecavir treatment in patients with HBeAg-positive chronic hepatitis B. World J Gastroenterol. 2007;13(31):4264–7. PMID: 17696259.17696259
98 Hou JL, Gao ZL, Xie Q, . Tenofovir disoproxil fumarate vs adefovir dipivoxil in Chinese patients with chronic hepatitis B after 48 weeks: a randomized controlled trial. J Viral Hepat. 2015;22(2):85–93. doi: 10.1111/jvh.12313. PMID: 25243325.25243325
99 Lee KS, Kweon YO, Um SH, . Efficacy and safety of entecavir versus lamivudine over 5 years of treatment: a randomized controlled trial in Korean patients with hepatitis B e antigen-negative chronic hepatitis B. Clin Mol Hepatol. 2017;23(4):331–9. doi: 10.3350/cmh.2016.0040. PMID: 28946736.28946736
100 Suh DJ, Um SH, Herrmann E, . Early viral kinetics of telbivudine and entecavir: results of a 12-week randomized exploratory study with patients with HBeAg-positive chronic hepatitis B. Antimicrob Agents Chemother. 2010;54(3):1242–7. doi: 10.1128/aac.01163-09. PMID: 20028815.20028815
101 Yao G, Chen C, Lu W, . Efficacy and safety of entecavir compared to lamivudine in nucleoside-naive patients with chronic hepatitis B: a randomized double-blind trial in China. Hepatol Int. 2007;1(3):365–72. doi: 10.1007/s12072-007-9009-2. PMID: 19669331.19669331
102 Zheng MH, Shi KQ, Dai ZJ, . A 24-week, parallel-group, open-label, randomized clinical trial comparing the early antiviral efficacy of telbivudine and entecavir in the treatment of hepatitis B e antigen-positive chronic hepatitis B virus infection in adult Chinese patients. Clin Ther. 2010;32(4):649–58. doi: 10.1016/j.clinthera.2010.04.001. PMID: 20435234.20435234
103 Gordon SC, Lamerato LE, Rupp LB, . Antiviral therapy for chronic hepatitis B virus infection and development of hepatocellular carcinoma in a US population. Clin Gastroenterol Hepatol. 2014;12(5):885–93. doi: 10.1016/j.cgh.2013.09.062. PMID: 24107395.24107395
104 Hoang JK, Yang HI, Le A, . Lower liver cancer risk with antiviral therapy in chronic hepatitis B patients with normal to minimally elevated ALT and no cirrhosis. Medicine. 2016;95(31):e4433. doi: 10.1097/MD.0000000000004433. PMID: 27495067.27495067
105 Hosaka T, Suzuki F, Kobayashi M, . Long-term entecavir treatment reduces hepatocellular carcinoma incidence in patients with hepatitis B virus infection. Hepatology. 2013;58(1):98–107. doi: 10.1002/hep.26180. PMID: 23213040.23213040
106 Lee TY, Hsu YC, Yu SH, . Effect of nucleos(t)ide analogue therapy on risk of intrahepatic cholangiocarcinoma in patients with chronic hepatitis B. Clin Gastroenterol Hepatol. 2018;16(6):947–54.e4. doi: 10.1016/j.cgh.2017.09.031. PMID: 28951229.28951229
107 Matsumoto A, Tanaka E, Rokuhara A, . Efficacy of lamivudine for preventing hepatocellular carcinoma in chronic hepatitis B: a multicenter retrospective study of 2795 patients. Hepatol Res. 2005;32(3):173–84. doi: 10.1016/j.hepres.2005.02.006. PMID: 16024289.16024289
108 Wang JP, Kao FY, Wu CY, . Nucleos(t)ide analogues associated with a reduced risk of hepatocellular carcinoma in hepatitis B patients: a population-based cohort study. Cancer. 2015;121(9):1446–55. doi: 10.1002/cncr.29159. PMID: 25537961.25537961
109 Wu CY, Lin JT, Ho HJ, . Association of nucleos(t)ide analogue therapy with reduced risk of hepatocellular carcinoma in patients with chronic hepatitis B: a nationwide cohort study. Gastroenterology. 2014;147(1):143–51.e5. doi: 10.1053/j.gastro.2014.03.048. PMID: 24704525.24704525
110 Wei MT, Le AK, Chang MS, . Antiviral therapy and the development of osteopenia/osteoporosis among Asians with chronic hepatitis B. J Med Virol. 2019;91(7):1288–94. doi: 10.1002/jmv.25433. PMID: 30776311.30776311
111 Baltayiannis G, Katsanos K, Karayiannis P, . Interferon-α therapy in HBeAg-negative chronic hepatitis B: a long-term prospective study from north-western Greece. Aliment Pharmacol Ther. 2006;24(3):525–33. doi: 10.1111/j.1365-2036.2006.03008.x. PMID: 16886919.16886919
112 Hui CK, Leung N, Shek WH, . Changes in liver histology as a “surrogate” end point of antiviral therapy for chronic HBV can predict progression to liver complications. J Clin Gastroenterol. 2008;42(5):533–8. doi: 10.1097/MCG.0b013e31804bbdff. PMID: 18344885.18344885
113 Lau DT, Everhart J, Kleiner DE, . Long-term follow-up of patients with chronic hepatitis B treated with interferon alfa. Gastroenterology. 1997;113(5):1660–7. PMID: 9352870.9352870
114 Niederau C, Heintges T, Lange S, . Long-term follow-up of HBeAg-positive patients treated with interferon alfa for chronic hepatitis B. N Engl J Med. 1996;334(22):1422–7. PMID: 8618580.8618580
115 Papatheodoridis GV, Manesis E, Hadziyannis SJ. The long-term outcome of interferon-alpha treated and untreated patients with HBeAg-negative chronic hepatitis B. J Hepatol. 2001;34(2):306–13. PMID: 11281561.11281561
116 Papatheodoridis GV, Manolakopoulos S, Touloumi G, . Virological suppression does not prevent the development of hepatocellular carcinoma in HBeAg-negative chronic hepatitis B patients with cirrhosis receiving oral antiviral(s) starting with lamivudine monotherapy: results of the nationwide HEPNET. Greece cohort study. Gut. 2011;60(8):1109–16. doi: 10.1136/gut.2010.221846. PMID: 21270118.21270118
117 Arends P, Sonneveld MJ, Zoutendijk R, . Entecavir treatment does not eliminate the risk of hepatocellular carcinoma in chronic hepatitis B: limited role for risk scores in caucasians. Gut. 2015;64(8):1289–95. doi: 10.1136/gutjnl-2014-307023. PMID: 25011935.25011935
118 Lin SM, Yu ML, Lee CM, . Interferon therapy in HBeAg positive chronic hepatitis reduces progression to cirrhosis and hepatocellular carcinoma. J Hepatol. 2007;46(1):45–52. doi: 10.1016/j.jhep.2006.08.021. PMID: 17107734.17107734
119 Wong G-H, Chan H-Y, Chan HY, . Accuracy of risk scores for patients with chronic hepatitis B receiving entecavir treatment. Gastroenterology. 2013;144(5):933–44. PMID: 23405803.23415803
120 Spenatto N, Boulinguez S, Mularczyk M, . Hepatitis B screening: who to target? A French sexually transmitted infection clinic experience. J Hepatol. 2013;58(4):690–7. doi: 10.1016/j.jhep.2012.11.044. PMID: 23220369.23220369
121 Bottero J, Boyd A, Lemoine M, . Current state of and needs for hepatitis B screening: results of a large screening study in a low-prevalent, metropolitan region. PLoS One. 2014;9(3):e92266. doi: 10.1371/journal.pone.0092266. PMID: 24663387.24663387
122 Wolffram I, Petroff D, Batz O, . Prevalence of elevated ALT values, HBsAg, and anti-HCV in the primary care setting and evaluation of guideline defined hepatitis risk scenarios. J Hepatol. 2015;62(6):1256–64. doi: 10.1016/j.jhep.2015.01.011. PMID: 25617500.25617500
123 Cornberg M, Protzer U, Petersen J, . [Prophylaxis, diagnosis and therapy of hepatitis B virus infection - the German guideline]. Z Gastroenterol. 2011;49(7):871–930. doi: 10.1055/s-0031-1273462. PMID: 21748700.21748700
124 Sarrazin C, Berg T, Ross RS, . [Prophylaxis, diagnosis and therapy of hepatitis C virus (HCV) infection: the German guidelines on the management of HCV infection]. Z Gastroenterol. 2010;48(2):289–351. doi: 10.1055/s-0028-1110008. PMID: 20119896.20119896
125 Hadziyannis S, Bramou T, Makris A, . Interferon alfa-2b treatment of HBeAg negative/serum HBV DNA positive chronic active hepatitis type B. J Hepatol. 1990;11: Suppl 1:S133–6. PMID: 2079571.2079571
126 Perez V, Tanno H, Villamil F, . Recombinant interferon alfa-2b following prednisone withdrawal in the treatment of chronic type B hepatitis. J Hepatol. 1990;11: Suppl 1:S113–7. PMID: 2079567.2079567
127 Perrillo RP, Schiff ER, Davis GL, . A randomized, controlled trial of interferon alfa-2b alone and after prednisone withdrawal for the treatment of chronic hepatitis B. The Hepatitis Interventional Therapy Group. N Engl J Med. 1990;323(5):295–301. PMID: 2195346.2195346
128 Sarin SK, Guptan RC, Thakur V, . Efficacy of low-dose alpha interferon therapy in HBV-related chronic liver disease in Asian Indians: a randomized controlled trial. J Hepatol. 1996;24(4):391–6. PMID: 8738724.8738724
129 Waked I, Amin M, Abd el Fattah S, . Experience with interferon in chronic hepatitis B in Egypt. J Chemother. 1990;2(5):310–8. PMID: 2090770.2090770
130 Jonas MM, Kelly D, Pollack H, . Safety, efficacy, and pharmacokinetics of adefovir dipivoxil in children and adolescents (age 2 to <18 years) with chronic hepatitis B. Hepatology. 2008;47(6):1863–71. PMID: 18433023.18433023
131 Murray KF, Szenborn L, Wysocki J, . Randomized, placebo-controlled trial of tenofovir disoproxil fumarate in adolescents with chronic hepatitis B. Hepatology. 2012;56(6):2018–26. PMID: 22544804.22544804
132 Zeng M, Mao Y, Yao G, . A double-blind randomized trial of adefovir dipivoxil in Chinese subjects with HBeAg-positive chronic hepatitis B. Hepatology. 2006;44(1):108–16. doi: 10.1002/hep.21225. PMID: 16799983.16799983
133 Ali HY. Trial of lamivudine in hepatitis B surface antigen carriers with persistent hepatitis B core IgM antibody. Saudi Med J. 2003;24(9):996–9. PMID: 19746176.12973486
134 Bayraktar Y, Uzunalimoglu B, Arslan S, . Effects of recombinant alpha interferon on chronic active hepatitis B: preliminary results. Gut. 1993;34:(2 Suppl):S101. PMID: 8314468.8314468
135 Lai C, Lim SG, Brown NA, . A dose-finding study of once-daily oral telbivudine in HBeAg-positive patients with chronic hepatitis B virus infection. Hepatology. 2004;40(3):719–26. PMID: 15349912.15349912
136 Chang TT, Chao YC, Gorbakov VV, . Results of up to 2 years of entecavir vs lamivudine therapy in nucleoside-naive HBeAg-positive patients with chronic hepatitis B. J Viral Hepat. 2009;16(11):784–9. doi: 10.1111/j.1365-2893.2009.01142.x. PMID: 19457141.19457141
137 Marcellin P, Lau GK, Bonino F, . Peginterferon alfa-2a alone, lamivudine alone, and the two in combination in patients with HBeAg-negative chronic hepatitis B. N Engl J Med. 2004;351(12):1206–17. doi: 10.1056/NEJMoa040431. PMID: 15371578.15371578
138 Andreone P, Gramenzi A, Cursaro C, . High risk of hepatocellular carcinoma in anti-HBe positive liver cirrhosis patients developing lamivudine resistance. J Viral Hepat. 2004;11(5):439–42. PMID: 15357649.15357649
139 Di Marco V, Marzano A, Lampertico P, . Clinical outcome of HBeAg-negative chronic hepatitis B in relation to virological response to lamivudine. Hepatology. 2004;40(4):883–91. PMID: 15382125.15382125
140 Fattovich G, Giustina G, Realdi G, . Long-term outcome of hepatitis B e antigen-positive patients with compensated cirrhosis treated with interferon alfa. European Concerted Action on Viral Hepatitis (EUROHEP). Hepatology. 1997;26(5):1338–42. PMID: 9362381.9362381
141 Lampertico P, Del Ninno E, Vigano M, . Long-term suppression of hepatitis B e antigen-negative chronic hepatitis B by 24-month interferon therapy. Hepatology. 2003;37(4):756–63. doi: 10.1053/jhep.2003.50148. PMID: 12668967.12668967
142 Liaw YF, Sung JJ, Chow WC, . Lamivudine for patients with chronic hepatitis B and advanced liver disease. N Engl J Med. 2004;351(15):1521–31. doi: 10.1056/NEJMoa033364. PMID: 15470215.15470215
143 Eckman MH, Kaiser TE, Sherman KE. The cost-effectiveness of screening for chronic hepatitis B infection in the United States. Clin Infect Dis. 2011;52(11):1294–306. doi: 10.1093/cid/cir199. PMID: 21540206.21540206
144 Chahal HS, Peters MG, Harris AM, . Cost-effectiveness of hepatitis B virus infection screening and treatment or vaccination in 6 high-risk populations in the United States. Open Forum Infect Dis. 2019;6(1)doi: 10.1093/ofid/ofy353. PMID: 30931346.30931346
145 Terrault NA, Bzowej NH, Chang KM, . AASLD guidelines for treatment of chronic hepatitis B. Hepatology. 2016;63(1):261–83. doi: 10.1002/hep.28156. PMID: 26566064.26566064
146 Centers for Disease Control and Prevention. Hepatitis Risk Assessment Tool. https://www.cdc.gov/hepatitis/riskassessment/pdfs/HepatitisRiskAssessment.pdf. Accessed August 21, 2019.
147 Centers for Disease Control and Prevention. Hepatitis Risk Assessment. Viral Hepatitis. Are you at risk? 2018. https://www.cdc.gov/hepatitis/riskassessment/index.htm. Accessed May 17, 2019.
148 Reddy KR, Beavers KL, Hammond SP, . American gastroenterological association institute guideline on the prevention and treatment of hepatitis B virus reactivation during immunosuppressive drug therapy. Gastroenterology. 2015;148(1):215–9; quiz e16-7. doi: 10.1053/j.gastro.2014.10.039. PMID: 25447850.25447850
149 Perrillo RP, Gish R, Falck-Ytter YT. American gastroenterological association institute technical review on prevention and treatment of hepatitis B virus reactivation during immunosuppressive drug therapy. Gastroenterology. 2015;148(1):221–44.e3. doi: 10.1053/j.gastro.2014.10.038. PMID: 25447852.25447852
150 Hartwell D, Shepherd J. Pegylated and non-pegylated interferon-alfa and ribavirin for the treatment of mild chronic hepatitis C: a systematic review and meta-analysis. Int J Technol Assess Health Care. 2009;25(1):56–62. doi: 10.1017/s0266462309090084. PMID: 19126252.19126252
151 Venter WDF, Fabian J, Feldman C. An overview of tenofovir and renal disease for the HIV-treating clinician. South Afr J HIV Med. 2018;19(1):817-. doi: 10.4102/sajhivmed.v19i1.817. PMID: 30167339.30167339
152 Childs-Kean LM, Egelund EF, Jourjy J. Tenofovir alafenamide for the treatment of chronic hepatitis B monoinfection. Pharmacotherapy. 2018;38(10):1051–7. doi: 10.1002/phar.2174. PMID: 30120841.30120841
153 Wolff TA, Krist AH, LeFevre M, . Update on the methods of the U.S. Preventive Services Task Force: linking intermediate outcomes and health outcomes in prevention. Am J Prev Med. 2018;54(1s1):S4–s10. doi: 10.1016/j.amepre.2017.08.032. PMID: 29254525.29254525
154 Zhang BH, Yang BH, Tang ZY. Randomized controlled trial of screening for hepatocellular carcinoma. J Cancer Res Clin Oncol. 2004;130(7):417–22. PMID: 15042359.15042359
155 Chen JG, Parkin DM, Chen QG, . Screening for liver cancer: results of a randomised controlled trial in Qidong, China. J Med Screen. 2003;10(4):204–9. PMID: 14738659.14738659
156 Centers for Disease Control and Prevention. Surveillance for acute viral hepatitis - United States, 2007. MMWR Surveill Summ. 2009;58(SS-3).
157 Wasley A, Kruszon-Moran D, Kuhnert W, . The prevalence of hepatitis B virus infection in the United States in the era of vaccination. J Infect Dis. 2010;202(2):192–201. doi: 10.1086/653622. PMID: 20533878.20533878
158 Kwon H, Lok AS. Hepatitis B therapy. Nat Rev Gastroenterol Hepatol. 2011;8(5):275–84. doi: 10.1038/nrgastro.2011.33. PMID: 21423260.21423260
159 Serigado JM, Izzy M, Kalia H. Novel therapies and potential therapeutic targets in the management of chronic hepatitis B. Eur J Gastroenterol Hepatol. 2017;29(9):987–93. doi: 10.1097/MEG.0000000000000911. PMID: 28538269.28538269
160 Testoni B, Durantel D, Zoulim F. Novel targets for hepatitis B virus therapy. Liver Int. 2017;37: Suppl 1:33–9. doi: 10.1111/liv.13307. PMID: 28052622.28052622
161 Turker K, Oksuzoglu B, Balci E, . Awareness of hepatitis B virus reactivation among physicians authorized to prescribe chemotherapy. Eur J Intern Med. 2013;24(8):e90–2. doi: 10.1016/j.ejim.2013.07.008. PMID: 23953849.23953849
162 Hwang JP, Fisch MJ, Zhang H, . Low rates of hepatitis B virus screening at the onset of chemotherapy. J Oncol Pract. 2012;8(4):e32–9. doi: 10.1200/jop.2011.000450. PMID: 23180996.23180996
163 Lee ACK, Vedio A, Liu EZH, . Determinants of uptake of hepatitis B testing and healthcare access by migrant Chinese in the England: a qualitative study. BMC Public Health. 2017;17(1):747. doi: 10.1186/s12889-017-4796-4. PMID: 28950835.28950835
164 Djoufack R, Cheon SSY, Mohamed A, . Hepatitis B virus outreach to immigrant population in greater Boston area: key to improving hepatitis B knowledge. World J Gastroenterol. 2017;23(42):7626–34. doi: 10.3748/wjg.v23.i42.7626. PMID: 29204062.29204062
165 Cohen MS, Chen YQ, McCauley M, . Antiretroviral therapy for the prevention of HIV-1 transmission. N Engl J Med. 2016;375(9):830–9. doi: 10.1056/NEJMoa1600693. PMID: 27424812.27424812
166 Mizushima D, Takano M, Uemura H, . Prevention in idu and linkage with hepatitis vaccination: Prophylactic effect of PrEP against HBV infection among MSM. Conference on Retroviruses and Opportunistic Infections. 2020.
167 Chang JJ, Mohtashemi N, Bhattacharya D. Significance and management of isolated hepatitis B core antibody (Anti-HBc) in HIV and HCV: strategies in the DAA era. Curr HIV/AIDS Rep. 2018;15(2):172–81. doi: 10.1007/s11904-018-0379-y. PMID: 29572624.29572624
168 Liaw YF, Lin SM, Chen TJ, . Beneficial effect of prednisolone withdrawal followed by human lymphoblastoid interferon on the treatment of chronic type B hepatitis in Asians: a randomized controlled trial. J Hepatol. 1994;20(2):175–80. PMID: 8006397.8006397
169 Yao GB. Management of hepatitis B in China. J Med Virol. 2000;61(3):392–7. PMID: 10861652.10861652
170 Yao GB, Zhu M, Cui ZY, . A 7-year study of lamivudine therapy for hepatitis B virus e antigen-positive chronic hepatitis B patients in China. J Dig Dis. 2009;10(2):131–7. PMID: 19426396.19426396
171 Gish RG, Lok AS, Chang TT, . Entecavir therapy for up to 96 weeks in patients with HBeAg-positive chronic hepatitis B. Gastroenterology. 2007;133(5):1437–44. doi: 10.1053/j.gastro.2007.08.025. PMID: 17983800.17983800