# Acknowledgments

The authors thank AHRQ Medical Officers Kathleen Irwin, MD, MPH, Tracy Wolff, MD, MPH, and Iris Mabry-Hernandez, MD, MPH; as well as the U.S. Preventive Services Task Force.