# Chapter 4 Discussion

## Summary of Review Findings

As in the 2014 USPSTF review,^72^ we found no direct evidence on effects of screening for HBV infection versus no screening on clinical outcomes. The evidence reviewed in this update is summarized in Table 7. This report differs from the USPSTF review by focusing on evidence from populations more relevant for screening, by restricting to trials in which few (<20%) or no patients had cirrhosis at baseline and excluding trials of treatment-experienced patients. In addition, in accordance with USPSTF procedures,^71^ poor-quality trials included in the prior USPSTF review were excluded. Despite these differences, the main findings of this review are consistent with the prior USPSTF review.

Table 7 Summary of Evidence

Key Question | Studies; Observations (N); Study designs | Summary of Findings | Consistency and Precision | Other Limitations | EPC Assessment of Strength of evidence | Applicability
1. What are the benefits of screening for HBV infection in asymptomatic, nonpregnant adolescents and adults on morbidity, mortality, and disease transmission? | No studies | No evidence | N/A | No studies | No evidence | N/A
2. What are the harms of screening for HBV infection in asymptomatic, nonpregnant adolescents and adults (e.g., labeling or anxiety)? | No studies | No evidence | N/A | No studies | No evidence | N/A
3. What is the yield (number of new diagnoses per tests performed) and sensitivity of alternative HBV screening strategies (e.g., universal vs. targeted screening or screening strategies based on alternative risk factors)? | [underlined: Prior report]: 1 retrospective study^120^ (N=6,194); [underlined: Update]: 2 retrospective studies^121,122^ (N=24,846) | Three European studies found that screening strategies that targeted persons with a variety of risk factors (immigration from high prevalence risk factors, other demographic risk factors, and behavioral risk factors) would identify nearly all cases of HBV infection while screening about two-thirds of the population; numbers needed to screen to identify one HBV infection ranged from 32 to 148. Screening only immigrants from high prevalence (≥2%) countries was more efficient (number needed to screen 19 to 71) and identified 85% to 99% of patients with HBV infection in higher prevalence clinical settings, but missed about two-thirds of HBV infections in a study conducted in primary care practices. | Consistent; Precise | Studies applied screening strategies retrospectively | Moderate | Some studies included patients in high-prevalence settings; all studies were conducted in Europe
4. How effective is antiviral treatment in improving intermediate outcomes among nonpregnant adolescents and adults with chronic HBV infection, including virologic or histologic improvement, clearance of HBeAg (as indicated by loss of HBeAg or acquisition of the anti-HBe), or clearance of HBsAg (as indicated by loss of HBsAg or acquisition of anti-HBs)? | Treatment vs. placebo/no treatment; [underlined: Prior report]: 14 trials^74–87^ (N=2,148); [underlined: Update]: 4 trials^88–91^ (N=824); Preferred vs. nonpreferred; [underlined: Prior report]: 7 trials^92–97^ (N=2,793); U[underlined: pdate]: 5 trials^98–102^ (N=1,334) | Antiviral treatment vs. placebo or no treatment:; - HBeAg loss: 6 trials, N=1,121, RR 1.91, 95% CI 1.46 to 2.81, I^2^=15%); - HBeAg seroconversion: 4 trials, N=1,104, RR 2.11, 95% CI 1.30 to 3.55, I^2^=0%); - HBsAg loss: 3 trials, N=714, RR 4.63, 95% CI 1.10 to 19.55, I^2^=70%); - Virological suppression: 13 trials, N=2,522, RR 4.39, 95% CI 2.61 to 7.39, I^2^=86%); - ALT normalization: 11 trials, N=2,044, RR 2.62, 95% CI 2.22 to 3.10, I^2^=0%; - Histological improvement: 6 trials, N =1,057, RR 2.00, 95% CI 1.63 to 2.41, I^2^=0%; Entecavir was associated with increased likelihood of achieving intermediate outcomes vs. lamivudine (6 trials) and pegylated interferon associated with increased likelihood of intermediate outcomes vs. lamivudine (1 trial); TDF was associated with increased likelihood of virological suppression vs. adefovir (3 trials) | Consistency was high for antiviral therapies and for entecavir vs. lamivudine and TDF vs. adefovir; it could not be assessed for pegylated interferon vs. lamivudine (1 trial); Precision was high for antiviral therapy vs. placebo and entecavir vs. lamivudine; some imprecision for TDF vs. adefovir and pegylated interferon vs. lamivudine | Study duration and patient characteristics varied widely; few good quality studies; almost all placebo-controlled trials evaluated nonpreferred antiviral therapies; no trials of tenofovir alafenamide | Moderate for antiviral therapy vs. placebo, entecavir vs. lamivudine, and pegylated interferon vs. adefovir; low for TDF vs. adefovir | About half the studies conducted outside of the U.S. or other low prevalence settings; about one-third enrolled HBeAg-negative patients; no trial enrolled adolescents; inclusion restricted to studies in which <20% of patients had cirrhosis at baseline or were treatment-experienced
5. How effective is antiviral treatment in improving health outcomes among nonpregnant adolescents and adults with chronic HBV infection? | Treatment vs. placebo/no treatment; [underlined: Prior report]: 6 trials^75,76,78,80,81,83^ (N=866); [underlined: Update]: 1 RCT^89^ (N=176) and 7 cohort studies^103–109^ (N=~50,912; 3 studies likely examined overlapping populations); Preferred vs. nonpreferred; [underlined: Prior report]: 6 trials^92,93,95–97^ (N=2,608); [underlined: Update]: 3 trials^98,99,101^ (N=1,159) | Antiviral therapy vs. placebo or no treatment:; Incident cirrhosis: 2 trials; RR, 0.72; 95% CI, 0.29 to 1.77; I^2^=0%; Hepatocellular carcinoma: 4 trials; RR, 0.60; 95% CI, 0.16 to 2.33; I^2^=20%; Mortality: 3 trials; RR, 0.15; 95% CI, 0.03 to 0.69; I^2^=0%); Seven cohort studies with longer-term (2.7 to 8.9 years) followup found antiviral therapy consistently associated with decreased risk of hepatocellular carcinoma vs. no antiviral therapy (adjusted HRs ranged from 0.24 to 0.64); Data from head-to-head trials of preferred vs. nonpreferred antiviral therapy were insufficient to evaluate effects on clinical outcomes | Consistent; Some imprecision (RCTs) | RCTs were not designed to assess clinical outcomes and reported few events; most studies rated fair-quality, heterogeneity in patient populations and settings; observational studies for long-term clinical outcomes susceptible to residual confounding | Low | About half the studies conducted outside of the U.S. or other low-prevalence settings; about one-third of studies enrolled HBeAg-negative patients; inclusion restricted to studies in which <20% of patients had cirrhosis at baseline or were treatment-experienced; most studies evaluated nonpreferred outcomes
6. What are the harms associated with antiviral treatment in nonpregnant adolescents and adults with chronic HBV infection? | Treatment vs. placebo/no treatment; [underlined: Prior report]: 10 trials^75–80,82,85–87^ (N=1,851); [underlined: Update]: 2 RCTs^88,89^ (N=255) and 1 cohort study^110^ (N=1,224); Preferred vs. nonpreferred; [underlined: Prior report]: 7 trials^92–97^ (N=2,774); [underlined: Update]: 5 trials^98–102^ (N=1,334) | Antiviral therapy vs. placebo or no therapy:; - Serious adverse events: 4 trials, N=802, RR 0.92, 95% CI 0.45 to 1.85, I^2^=0%^75,77,78,85^; - Withdrawal due to adverse events: 3 trials, N=496, RR 4.44, 95% CI 0.95 to 20.77, I^2^=0%^80,82,85^; - Any adverse event: 5 trials, N=1,290, RR 1.01, 95% CI 0.90 to 1.11, I^2^=0%; - Nausea: 3 trials, RR 0.80, 95% CI 0.48 to 2.10, I^2^=0%; - Diarrhea: 4 trials, RR 1.50, 95% CI 0.87 to 2.46, I^2^=0%; - Kidney adverse events: 3 trials, RR 1.27, 95% CI 0.31 to 3.55, I^2^=0%^75,76,78^; One cohort study found no association between TDF or entecavir versus no antiviral therapy and risk of osteopenia or osteoporosis; In head-to-head trials, pegylated interferon was associated with increased risk of any adverse event (1 trial, N=543, RR 1.58, 95% CI 1.41 to 1.78) vs. lamivudine and is probably associated with increased risk of withdrawal due to adverse events (1 trial, N=543, RR 4.01, 95% CI 0.86 to 18.73).^95^ TDF was associated with increased risk of nausea vs. adefovir (RR 3.36, 95% CI 1.45 to 7.81). | Consistency was high.; Some imprecision present | See Key Question 4. In addition, no study evaluated tenofovir alafenamide, which may be associated with fewer kidney adverse effects | Moderate | See Key Question 4.
7. What is the association between improvements in intermediate outcomes as a result of antiviral treatment of chronic HBV infection and reduction in risk of HBV-related adverse health outcomes? | [underlined: Prior report]: 6 observational studies^111–116^ (N=1,385); [underlined: Update]: 3 observational studies^117–119^ (N=2,508) | Nine cohort studies found consistent associations between achieving or not achieving various intermediate outcomes (virological remission, biochemical remission, histological improvement, HBeAg loss, or a composite intermediate outcome) and decreased adverse health outcomes (death, hepatocellular carcinoma, cirrhosis, or a composite clinical outcome). However, variability in patient populations, the intermediate and clinical outcomes evaluated, and presence of methodological limitations make it difficult to draw strong conclusions. In some studies, estimates were imprecise and associations were not statistically significant. | Consistency was high.; Some imprecision in individual study estimates | High variability in patient characteristics and outcomes evaluated; all studies were rated fair-quality; all studies were observational studies and susceptible to residual confounding | Moderate | Inclusion restricted to studies that adjusted for baseline fibrosis stage and fewer than 30% of patients had cirrhosis at baseline; most studies conducted in Asia (though U.S. studies reported consistent findings); few studies focused on use of current preferred antiviral therapies

Abbreviations: ALT = alanine aminotransferase; anti-HBe = antibody to HBeAg; anti-HBs = hepatitis B surface antibody; CI = confidence interval; HBeAg = hepatitis B e antigen; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; HR = hazard ratio; N/A = not applicable; RCT = randomized controlled trial; RR = relative risk; TDF = tenofovir disoproxil fumarate; U.S. = United States.

The USPSTF previously determined that HBV screening tests (based on interpretation of serologic markers) are accurate (sensitivity and specificity greater than 98%).^21^ Evidence on the sensitivity and yield of different HBV screening strategies is available from three studies.^120–122^ These studies found that screening strategies that focused on patients with risk factors (immigration from high prevalence country, other demographic risk factors, and/or behavioral risk factors) would identify nearly all cases of HBV infection while screening about two-thirds of the population. The number needed to screen to identify one HBV infection ranged from 32 to 148, depending in part on the prevalence of HBV infection in the population studied. A more focused strategy of only screening immigrants from high prevalence countries would be more efficient (number needed to screen 16 to 71), but missed about two-thirds of infected persons in one study conducted in primary care practices.^122^ A limitation of these studies is that the screening strategies were retrospectively applied. In addition, the studies were conducted in Europe and some evaluated high HBV prevalence populations, which might limit applicability to primary care settings in the United States.

As in the previous USPSTF review, randomized trials found antiviral therapy to be more effective than placebo or no treatment for achieving various intermediate outcomes, including HBeAg loss (RR 1.91, 95% CI 1.46 to 2.81), HBeAg seroconversion (RR 2.11, 95% CI 1.30 to 3.55), HBsAg loss (RR 4.63, 95% CI 1.10 to 19.55), ALT normalization (RR 2.62, 95% CI 2.22 to 3.10), HBV DNA suppression (RR 4.39, 95% CI 2.61 to 7.39), histological improvement (RR 2.00, 95% CI 1.63 to 2.41), and composite intermediate outcomes (HBeAg loss/seroconversion plus DNA suppression: RR 2.36, 95% CI 1.44 to 4.28, I^2^=0% and DNA suppression plus ALT normalization: RR 6.30, 95% CI 3.06 to 13.11, I^2^=0%). The numbers needed to treat to achieve one intermediate outcome ranged from 2.6 for HBV DNA suppression to 17 for HBeAg seroconversion. Results were generally consistent when analyses were stratified by individual drug, though some estimates were imprecise and not statistically significant. Although this update focused on FDA-approved antiviral therapies, almost all of the trials evaluated therapies classified as nonpreferred in current guidelines (lamivudine, adefovir, nonpegylated interferon).^8^ There were no placebo-controlled trials of pegylated interferon, though some extrapolation from trials of nonpegylated interferon may be justified: pegylation increases the half-life of interferon and for HCV infection, pegylated interferon has been shown to be more effective than nonpegylated interferon.^150^ The effectiveness of preferred antiviral therapies is also supported by head-to-head trials, which found entecavir, TDF, and pegylated interferon associated with greater or similar likelihood of achieving various intermediate outcomes versus nonpreferred therapies. One trial found pegylated interferon associated with increased likelihood of achieving intermediate outcomes versus lamivudine 6 months following the completion of 48 weeks of therapy, a consideration for patients who may wish to avoid indefinite antiviral therapy.^95^ Effects of antiviral therapies were generally consistent when trials were stratified according to HBeAg status or whether some patients with cirrhosis were included. The trials focused on treatment of patients with immune active HBV infection, with very little data on effectiveness of antiviral therapy in the immune tolerant phase. There was insufficient evidence to determine how effects of antiviral therapies varied according to demographic and other clinical factors: the trials did not evaluate these factors and some factors (injection drug use status, HBV genotype, presence of nonalcoholic steatohepatitis, presence of hepatitis D virus) were not reported.

As in the prior USPSTF review, antiviral therapy was not associated with an increased risk of serious adverse events or experiencing any adverse event versus placebo. Antiviral therapy was associated with an increased risk of withdrawal due to adverse events (RR 4.44, 95% CI 0.95 to 20.77, I^2^=0%)^80,82,85^; the risk of withdrawal due to adverse events was greatest with interferon. In head-to-head comparisons, pegylated interferon alfa-2a was associated with increased risk of serious adverse events and withdrawal due to adverse events versus lamivudine, consistent with the known high prevalence of adverse events with interferon-based therapies. Data on risks of kidney and bone adverse events, were limited but did not indicate increased risk. TDF has been associated with bone and kidney toxicities in some conditions (e.g., HIV infection),^151^ but limited evidence in patients with HBV infection found few cases and no increase in risk. In general, adverse events associated with antiviral therapy, including interferon-based therapies, are self-limited and resolve following discontinuation of the drug.

Data from randomized trials on effects of antiviral therapy versus placebo or no therapy on clinical outcomes remains sparse. The trials were not designed to assess these outcomes, due to small sample sizes and insufficient duration of followup. Although antiviral therapy was associated with decreased risk of mortality, the estimate was based on three trials of nonpegylated interferon with a total of eight deaths. Antiviral therapy might be associated with decreased risk of cirrhosis and hepatocellular carcinoma, but estimates were imprecise and not statistically significant. To further inform conclusions regarding effects of antiviral therapy on clinical outcomes, this update included longer-term cohort studies of antiviral therapy versus no antiviral therapy that controlled for potential confounders. There was a consistent association between receipt of antiviral therapy and decreased risk of hepatocellular carcinoma; evidence on effects on risk of cirrhosis and mortality was sparse but also indicated decreased risk. Most of the cohort studies were conducted in Asia, which might limit applicability to U.S. primary care settings. However, studies conducted in the United States reported findings consistent with the Asian studies. Head-to-head trials of preferred versus nonpreferred antiviral therapy were not designed to assess clinical outcomes and were underpowered, with imprecise estimates. No trial evaluated effects of antiviral therapy on quality of life, risk of HBV transmission, or extrahepatic manifestations of HBV infection.

Understanding the degree to which improvements in intermediate outcomes are associated with mortality, hepatocellular carcinoma, or cirrhosis could be helpful for interpreting the effects of antiviral therapies on clinical outcomes through an indirect pathway. As in the prior USPSTF review, observational studies generally found an association between achieving an intermediate outcome (HBeAg loss or seroconversion, ALT normalization, HBV DNA suppression, or a composite intermediate outcome) and reduced risk of mortality, hepatocellular carcinoma, cirrhosis, or a composite clinical outcome. However, results were not statistically significant in all studies. In addition, differences across studies in the intermediate and clinical outcomes evaluated, variability in patient populations (e.g., with regard to HBeAg status, ALT levels, or HBV DNA levels) and methodological limitations preclude strong conclusions.

## Limitations

This review has several limitations. We excluded non-English language studies. We did not search for studies published only as abstracts and could not formally assess for publication bias with graphical or statistical methods due to small numbers of studies for each comparison and outcome.^73^ Evidence from placebo-controlled trials of preferred antiviral therapy was limited; therefore, we also included head-to-head trials of preferred versus nonpreferred antiviral therapy. No trial evaluated the preferred antiviral TAF, which was FDA-approved for treatment of chronic HBV infection in 2016 and may have fewer kidney and bone toxicities compared with TDF.^152^ There were no trials of telbivudine, which is FDA-approved but a non-preferred antiviral. However, this drug is no longer manufactured in the United States, though it is available in other countries. We excluded studies included in the prior USPSTF review in which greater than 20 percent of patients had cirrhosis, greater than 20 percent of patients were treatment-experienced, or that were rated poor-quality, reducing the evidence base available for this update. However, these exclusions strengthened the quality and applicability of the reviewed evidence to populations identified by screening, and overall conclusions were similar to the prior USPSTF review.

We included observational studies to evaluate the association between antiviral therapy versus no antiviral therapy and long-term clinical outcomes because randomized trials were not designed to assess these outcomes. We also included observational studies on the association between achieving an intermediate outcome after antiviral therapy and clinical outcomes, because it is not possible to randomize patients’ response to therapy.^153^ We focused on studies that controlled for potential confounders, in order to reduce potential effects from confounding.

Another limitation is that we included studies conducted in countries where the prevalence, characteristics (e.g., likelihood of HBeAg-negative chronic HBV infection), and natural history of HBV infection may differ from in the United States. Including such evidence might reduce the applicability of the reviewed evidence to screening in the United States. However, findings were similar when trials were stratified according to whether they were conducted in low or high HBV prevalence settings, and for studies conducted in Asia and the United States.

This update did not address effectiveness of vaccinations or the effectiveness of education or behavior change counseling. The prior USPSTF review found HBV vaccination in high risk persons with evidence of HBV immunity associated with decreased risk of HBV acquisition based on serologic and biochemical markers, but no evidence on clinical outcomes.^72^ It also identified no trials on the effectiveness of education or behavior change counseling in patients with chronic HBV infection for reducing transmission or improving health outcomes. A literature scan during the work plan development phase of this report and input from expert Key Informants identified no new evidence to address these areas. We also did not include evidence on the effectiveness of surveillance for hepatocellular carcinoma in patients with HBV infection, which reported mixed results.^154,155^ Hepatocellular carcinoma surveillance was considered to be outside the scope of screening.

## Emerging Issues/Next Steps

Trends in the epidemiology of HBV infection are likely to inform future assessments of screening. Symptomatic acute HBV infections in the United States declined approximately 85 percent from the early 1990s to 2009 following the adoption of universal infant vaccination and catch-up vaccinations for children and adolescents,^156,157^ with substantial reductions in prevalence among U.S. children and adolescents. Further declines in HBV prevalence in the United States have been offset by immigration from places where HBV infection remains endemic, such as Asia and Africa.^16^ Foreign-born persons are estimated to account for approximately 95 percent of newly reported HBV infections in the United States, a factor potentially informing future screening strategies.

Among currently approved drugs for treatment of HBV infection, entecavir and tenofovir (TDF or TAF) have potent antiviral activity, appear to have low rates of drug resistance, and are better tolerated than pegylated interferon alfa-2a, but data on their effects on clinical outcomes remain extremely limited. TAF, which was FDA-approved in 2016, may be associated with fewer kidney adverse effects than TDF, but data on effects on intermediate and clinical outcomes are lacking. Although a number of combination antiviral therapies have been evaluated for management of HBV infection, none has been proven to be superior to monotherapy for achieving intermediate or clinical outcomes and avoiding drug resistance.^158^ However, research on combination therapies and new investigational agents, including drugs with novel viral targets,^159,160^ is ongoing.

HBV reactivation has become increasingly recognized as a clinical issue in persons previously exposed to HBV.^28^ Screening could identify patients with evidence of past HBV infection but without current active disease who could benefit from interventions to prevent reactivation. To date, evidence on the prevalence and prevention of HBV reactivation has focused on patients with cancer or autoimmune conditions undergoing immunosuppressant therapy, or patients with HCV infection receiving antiviral therapy. The USPSTF generally considers management of such chronic conditions (including testing for HBV infection) to be outside the scope of screening. However, some evidence indicates that HBV testing rates are low in persons with cancer undergoing chemotherapy, highlighting a potential practice gap.^161,162^ Of greater relevance to evaluating benefits of screening would be data on the prevalence and severity of HBV reactivation in primary care settings in persons treated for acute conditions; such data are currently not available.

## Relevance for Priority Populations

HBV infection is more prevalent in the United States among persons originating from countries with higher prevalence. WHO regions with prevalence greater than 2 percent are the African Region (6.1%), Eastern Mediterranean (3.3%), South-East Asia (2.0%), and Western Pacific (6.2%).^31^ About half of prevalent U.S. cases of chronic infection are in non-Hispanic Asians, a group representing 5 to 6 percent of the U.S. population.^19^ Challenges in screening immigrant populations include language barriers, lack of access to healthcare, stigma associated with HBV infection, and lack of knowledge.^163,164^

Data indicate that the prevalence of HBV infection has declined in adolescents, due to implementation of universal HBV vaccination. However, there has been little change in prevalence among adults age 50 years or older. No randomized trial that met inclusion criteria evaluated antiviral therapy in adolescents. Nonpegylated interferon was the first antiviral therapy approved for treatment of chronic HBV infection in children. Pegylated interferon alfa-2a is approved for use in children ages 3 years and older, entecavir is approved in children ages 2 years and older, and TDF is approved in adolescents ages 12 years and older. Lamivudine and adefovir are now rarely used in adolescents, due to limited efficacy and high rates of viral resistance. Trials did not evaluate how effects of antiviral therapies varied according to age, race, or sex.

## Future Research

Research gaps limit full understanding of the benefits and harms of screening for HBV infection. Studies that compare clinical outcomes in patients screened and not screened for HBV infection would provide the most direct evidence but would require large sample sizes and long duration of followup. Studies would not necessarily need to be randomized trials; well-conducted observational studies (prospective or retrospective) that control for potential confounders could also be informative. Studies that compare different screening strategies would be helpful for understanding the feasibility and outcomes of alternative screening approaches (e.g., strategies that focus on persons originating from high-prevalence countries versus more generalized screening strategies).

Research is also needed on long-term clinical outcomes associated with use of preferred antiviral therapies for chronic HBV infection. Studies are needed to evaluate the most recently approved antiviral drug, TAF, and to determine whether it carries advantages with regard to adverse kidney and bone effects versus TDF or other antivirals. Studies that evaluate whether receipt of antiviral therapy is associated with decreased risk of HBV transmission (as has been shown for HIV infection)^165^ would be useful for identifying additional public health benefits of screening and subsequent treatment; studies are also needed on the effects of antiviral therapies on quality of life and extrahepatic manifestations of HBV infection. Almost all trials have focused on treatment of patients with immune active HBV infection; studies are needed on the effects of treatment during the immune tolerant phase, including risk of hepatocellular carcinoma.^23^ Evidence from observational studies on the association between achieving intermediate outcomes and clinical outcomes would be strengthened by improved standardization of the intermediate and clinical outcomes evaluated. Such studies should be designed and analyzed to account for important confounders. Pre-exposure prophylaxis with antiviral therapy to prevent HBV infection is a preventive strategy beyond the scope of this report, but may warrant additional research.^166^

## Conclusions

There was no direct evidence for the clinical benefits and harms of HBV screening versus no screening. Antiviral therapy for chronic HBV infection was associated with improved intermediate outcomes and may improve clinical outcomes. Research is needed to clarify effects of screening and subsequent interventions on clinical outcomes and to identify optimal screening strategies.