# Chapter 3 Results

A total of 6,272 new references from electronic database searches and manual searches of recently published studies were reviewed, and 506 full-text papers were evaluated for inclusion. Across all KQs, 30 RCTs^74–102^ (N=7,099), 17 cohort studies^103–119^ (N=56,029), and three retrospective studies addressing the yield of alternative strategies (N=31,040)^120–122^ were included. Twenty-two studies^88–91,98–110,117–119,121,122^ were new for this update, and 28 studies^74–87,92–97,111–116,120^ were carried forward from the previous review. Included studies and quality ratings are described in Appendix B.

## Key Question 1 What Are the Benefits of Screening for HBV Infection in Asymptomatic, Nonpregnant Adolescents and Adults on Morbidity, Mortality, and Disease Transmission?

As in the prior USPSTF review, no study compared clinical outcomes between individuals screened and not screened for HBV infection.

## Key Question 2 What Are the Harms of Screening for HBV Infection in Asymptomatic, Nonpregnant Adolescents and Adults (e.g., Labeling or Anxiety)?

As in the prior USPSTF review, no study compared harms between individuals screened and not screened for HBV infection.

## Key Question 3 What Is the Yield (Number of New Diagnoses per Tests Performed) and Sensitivity of Alternative HBV Screening Strategies (e.g., Universal vs. Targeted Screening or Screening Strategies Based on Alternative Risk Factors)?

### Summary

Three European studies (N=30,040) found that screening strategies that targeted persons with a variety of risk factors (ever having immigrated from high prevalence countries, other demographic risk factors, and behavioral risk factors) would identify nearly all cases of HBV infection while screening about two-thirds of the population; numbers needed to screen to identify one HBV infection ranged from 32 to 148. Screening only immigrants from high prevalence (≥2%) countries was more efficient (number needed to screen 19 to 71) and identified 85 to 99 percent of patients with HBV infection in higher prevalence clinical settings, but missed about two-thirds of HBV infections in a study conducted in primary care practices.

### Evidence

The prior USPSTF review included one fair-quality (n=6,194) retrospective study that found that a strategy of screening persons in France at a sexually transmitted infection clinic born in countries with higher (≥2%) chronic HBV prevalence, men, and unemployed persons would identify 98 percent (48/49) of HBV infections while testing about two-thirds of the population, for a number needed to screen to identify one case of HBV infection of 82 (Appendix B Tables 1–3).^120^ Strategies that involved screening persons born in higher prevalence countries and replaced male sex or employment status with behavioral risk factors would have resulted in higher proportions of patients, no increase in sensitivity, and numbers needed to screen similar to screening the whole population (~126). Screening only patients born in higher prevalence (≥2%) countries would have resulted in testing of 12 percent of patients, a sensitivity of 85 percent, and a number needed to screen to identify one case of HBV infection of 19.

Two new, fair-quality studies on the yield of alternative screening strategies were identified for this update (Appendix B Tables 1–3).^121,122^ Both studies were conducted in Europe and applied screening strategies retrospectively.

A French study (n=3,929) performed HBV screening in 10 centers, including settings with higher HBV prevalence (clinics focusing on sexually transmitted infection testing, immigrants, persons with low socioeconomic status, or incarcerated individuals). It found that 2.2 percent of participants had active HBV infection (based on a positive test for HBsAg), 13 percent had resolved HBV infection, 3.3 percent had isolated anti-HBc, 44 percent had been vaccinated, and 38 percent were non-immunized. In this population, 44 percent of patients were born in a country with HBV prevalence ≥2 percent, 46 percent had more than one sexual partner in the past 12 months, 23 percent had no healthcare or healthcare assistance, 11 percent were MSM, and 0.6 percent were intravenous drug users. A strategy of HBV screening based on the physicians’ judgment that testing was needed would identify 87 percent (74/85) of HBV infections while testing about two-thirds of the population, for a number needed to screen to identify one case of HBV infection of 35. A strategy of HBV screening based on the 2008 CDC HBV screening recommendations^22^ would have identified all infections and was slightly more efficient; in this strategy; about 7 percent of the population would be screened, resulting in a number needed to screen of 32. Screening only persons from countries with HBV prevalence ≥2% was the most efficient strategy: it would have identified almost all infections (99%, or 84/85) while screening 44 percent of the population, resulting in a number needed to screen of 20.

A German study (n=20,917) evaluated a series of screening strategies based on a 16-item questionnaire adapted from the German HBV^123^ and HCV^124^ guidelines. The sample consisted of patients in private primary care practices with an HBsAg prevalence of 0.52 percent.^122^ Screening all persons in the cohort would have resulted in a number needed to screen to detect one HBsAg positive unaware of their status of 224. A strategy of screening persons with a positive response to at least one of the HBV-related items in the questionnaire would have identified 67 percent (62/93) cases while testing 44 percent of the population, for a number needed to screen of 148. A strategy of screening only persons with an immigration background or hepatitis positive household member would have identified 37 percent (34 of 93) cases while screening 12 percent of the population, for a number needed to screen of 77. Screening only persons with an immigration background would have slightly lower sensitivity (30%), but would also be slightly more efficient (number needed to screen 71).

## Key Question 4 How Effective Is Antiviral Treatment in Improving Intermediate Outcomes Among Nonpregnant Adolescents and Adults With Chronic HBV Infection, Including Virologic or Histologic Improvement, Clearance of HBeAg (as Indicated by Loss of HBeAg or Acquisition of Anti-HBe), or Clearance of HBsAg (as Indicated by Loss of HBsAg or Acquisition of Anti-HBs)?

### Summary

As in the prior USPSTF review, antiviral therapy was associated with increased likelihood of achieving intermediate outcomes versus placebo:

- HBeAg loss: 6 trials, N=1,121, relative risk (RR) 1.91, 95% confidence interval (CI) 1.46 to 2.81, I^2^=15%; absolute risk difference (ARD) 14%, 95% CI 5.8% to 23%
- HBeAg seroconversion: 4 trials, N=1,104, RR 2.11, 95% CI 1.30 to 3.55, I^2^=0%; ARD 6.2%, 95% CI 2.4% to 10.5%
- HBsAg loss: 3 trials, N=714, RR 4.63, 95% CI 1.10 to 19.55, I^2^=70%; ARD 8.2%, 95% CI −2.6% to 18.9%
- Virological suppression: 13 trials, N=2,522, RR 4.39, 95% CI 2.61 to 7.39, I^2^=86%; ARD 39%, 95% CI 24% to 53%
- ALT normalization: 11 trials, N=2,044, RR 2.62, 95% CI 2.22 to 3.10, I^2^=0%; ARD 32%, 95% CI 27% to 37%
- Histological improvement: 6 trials, N =1,057, RR 2.00, 95% CI 1.63 to 2.41, I^2^=0%; ARD 28%, 95% CI 22% to 34%
- Composite of virological suppression plus ALT normalization: 3 trials, N=286, RR 6.30, 95% CI 3.06 to 13.11, I^2^=0%; ARD 48%, 95% CI 29% to 61%
- Composite of HBeAg loss/seroconversion plus virological suppression: 2 trials of lamivudine, N=391, RR 3.18, 95% CI 1.11 to 9.11, I^2^=0%; ARD 9.2%, 95% CI −0.2% to 16%; and 2 trials of interferon, N=232, RR 2.18, 95% CI 1.10 to 4.78; ARD 23%, 95% CI 8% to 37%

As in the prior USPSTF review, preferred antiviral therapies (entecavir, TDF, pegylated interferon) were associated with greater likelihood of achieving some intermediate outcomes versus nonpreferred therapies in head-to-head comparisons. Analyses were limited by small numbers of trials, with imprecise estimates for some outcomes. Evidence was most robust for effects of entecavir versus lamivudine on virological suppression (6 trials, N=2,115, RR 1.70, 95% CI 1.38 to 2.13, I^2^=81%; ARD 30%, 95% CI 17% to 43%) and ALT normalization (6 trials, N=2,079, RR 1.13, 95% CI 1.08 to 1.27, I^2^=0%; ARD 12%, 95% CI 4.2% to 22%). One trial found pegylated interferon alfa-2a associated with increased likelihood of achieving virological, biochemical, and histological outcomes versus lamivudine 24 weeks following the completion of 48 weeks of therapy. Three trials found TDF probably associated with increased likelihood of virological suppression versus adefovir (N=1,150, RR 2.32, 95% CI 0.96 to 6.10, I^2^=97%); estimates for other intermediate outcomes were imprecise or indicated no differences.

### Evidence

#### Antiviral Therapy vs. Placebo or No Treatment

The prior USPSTF review found antiviral therapy more effective than placebo or no treatment in achieving HBeAg loss or seroconversion (10 trials; RR, 2.1; 95% CI, 1.6 to 2.9; I^2^=4%), HBsAg loss or seroconversion (12 trials; RR, 2.4; 95% CI, 1.2 to 4.9; I^2^=0%), ALT normalization (12 trials; RR, 2.5; 95% CI, 2.1 to 3.0; I^2^=27%), reduction in HBV DNA (nine trials; RR, 7.2; 95% CI, 3.2 to 16; I^2^=58%), and histological improvement (seven trials; RR, 2.1; 95% CI, 1.8 to 2.6; I^2^=0%). The prior USPSTF review included trials in which more than 20 percent of patients had cirrhosis at baseline,^125–129^ patients had previously received antiviral therapy,^130–132^ or that were rated poor-quality;^133–135^ these trials were excluded for this update.

Eighteen trials (N=2,972) comparing antiviral therapy to placebo or no treatment were included in this update (Appendix B Tables 4–5).^74–91^ Fourteen trials were included in the prior USPSTF review and four trials^88–91^ were added for this update. One trial evaluated entecavir,^90^ six trials non-pegylated interferon,^80,81,83,84,88,89^ three trials adefovir,^77,82,91^ and eight trials lamivudine;^74–76,78,79,85–87^ no placebo-controlled trials of pegylated interferon, tenofovir (TDF or TAF), or telbivudine met inclusion criteria. The number of participants in the 18 trials ranged from 42 to 526. All trials included only adults, with mean ages ranging from 24 to 46 years. Most participants were male (54% to 100%). Of 11 studies reporting baseline HBeAg status, in eight trials more than 95 percent of patients were HBeAg-positive,^78,79,82–84,86–88^ in two studies 6 percent or less of patients were HBeAg-positive,^75,85^ and one study included 38 percent HBeAg-positive patients.^90^ One trial excluded patients with cirrhosis;^83^ in the other 17 trials, the proportion with cirrhosis was ≤20 percent. Eleven trials excluded patients with decompensated liver disease.^75,78,80,81,84–87,89–91^ Although the trials did not classify patients as having “immune active” or “immune tolerant” HBV infection, two trials appeared to focus on immune tolerant patients, based on high HBV DNA level, normal or minimally elevated AST, and minimal histological activity.^86,90^ In the other trials, patients had characteristics consistent with immune active disease.

The duration of followup ranged from 1.8 to 86 months. Six studies were conducted in the United States, Canada, Europe, Australia, or New Zealand,^76,80,83–85,88^ seven were conducted in Asia,^75,78,79,81,87,90,91^ and five were multinational or conducted in other countries.^74,77,82,86,89^

All trials were rated fair-quality (Appendix B Table 6). Frequent methodological limitations were unclear reporting of randomization, allocation concealment, and blinding methods.

##### HBeAg Loss or Seroconversion

In patients with HBeAg-positive HBV infection, antiviral therapy was associated with increased likelihood of HBeAg loss versus placebo or no antiviral therapy (6 trials, N=1,121, RR 1.91, 95% CI 1.46 to 2.81, I^2^=15%; ARD 14%, 95% CI 5.8% to 23%)^76,82,83,87–89^ (Figure 2). Effects favored antiviral therapy for each individual drug. Lamivudine was evaluated in two trials (N=515, RR 2.06, 95% CI 0.94 to 4.93, I^2^=0%),^76,87^ adefovir in one trial (N=332, RR 2.27, 95% CI 1.35 to 3.83),^82^ nonpegylated interferon alfa-2a in two trials (N=210, RR 2.61, 95% CI 1.15 to 5.47, I^2^=0%),^88,89^ and nonpegylated interferon alfa-2b in one trial (N=64, RR 1.48, 95% CI 1.10 to 2.00).^83^ There were no interactions between geographic region, prior antiviral treatment status, or followup duration and effects on HBeAg loss (Table 4). All trials were rated fair-quality.

Figure 2 Antiviral Treatment vs. Placebo or No Treatment – HBeAg Loss

Figure 2 is a forest plot examining HBeAg loss risk comparing antiviral treatment versus placebo or no treatment in 4 treatment subgroups. The risk ratio for the adefovir dipivoxil subgroup with 1 study is 2.27 (95% CI 1.35 to 3.83). The risk ratio for the interferon alpha-2a subgroup with 2 studies is 2.61 (95% CI 1.15 to 5.47) with an I-squared value of 0.0%. The risk ratio for the interferon alpha-2b subgroup with 1 study is 1.48 (95% CI 1.10 to 2.00). The risk ratio for the lamivudine subgroup with 2 studies is 2.06 (95% CI 0.94 to 4.93) with an I-squared value of 0.0%. The overall risk ratio is 1.91 (95% CI 1.46 to 2.81) with an I-squared value of 15.0%.

Table 4 Antiviral Treatment vs. Placebo or No Treatment on Intermediate Outcomes - Subgroup Analyses

Intermediate outcome; Subgroup analysis | Number of trials^*^ | Relative risk (95% CI) | I^2^ | P_Interaction_
HBeAg loss
Geographic region:; - Low-prevalence (US, Canada, Europe, Australia, etc.) | 3 | 1.59 (1.20 to 2.10) | 0% | 0.16
- High-prevalence (Asia) | 1 | 1.52 (0.60 to 3.89) | -- | --
- Mixed prevalence/other | 2 | 2.46 (1.61 to 3.78) | 0% | --
Treatment status:; - Naive | 2 | 2.94 (1.07 to 8.09) | 0% | 0.28
- Naïve and non-naive/NR | 5 | 1.74 (1.38 to 2.20) | 0% | --
Followup duration:; - <52 weeks | 2 | 2.07 (1.31 to 3.26) | 0% | 1.00
- ≥52 weeks | 5 | 1.71 (1.32 to 2.22) | 0% | --
Drug:; - Adefovir dipivoxil | 1 | 2.27 (1.35 to 3.83) | 0% | 0.44
- Interferon alpha-2a | 2 | 2.61 (1.15 to 5.47) | 0% | --
- Interferon alpha-2b | 1 | 1.48 (1.10 to 2.00) | 0% | --
- Lamivudine | 2 | 2.06 (0.94 to 4.93) | 0% | --
DNA loss
Geographic region:; - Low-prevalence (US, Canada, Europe, Australia, etc.) | 4 | 2.32 (1.39 to 4.10) | 62% | 0.000
- High-prevalence (Asia) | 5 | 7.06 (3.42 TO 15.93) | 72% | --
- Mixed prevalence/other | 4 | 2.09 (0.22 TO 164.21) | 0% | --
HBeAg; - Negative | 1 | 63.50 (4.00 to 1009.28) | NA | 0.001
- Positive, mixed, or not reported | 12 | 4.01 (2.43 to 7.19) | 84% | --
Treatment status:; - Naive | 2 | 2.78 (1.08 to 6.92) | 0% | 1.00
- Naïve and non-naive/NR | 11 | 4.77 (2.66 to 10.34) | 88% | --
Followup duration:; - <52 weeks | 4 | 5.65 (3.14 to 48.75) | 36% | 0.000
- ≥52 weeks | 9 | 3.50 (1.88 to 6.94) | 85% | --
Immune tolerant:; - Yes | 2 | 8.81 (0.75 to 103.94) | 39% | 0.13
- No | 11 | 4.17 (2.46 to 7.97) | 88% | --
Drug:; - Adefovir dipivoxil | 3 | 19.22 (10.98 to 33.67) | 0% | 0.000
- Entecavir | 1 | 31.50 (2.02 to 492.36) | 0% | --
- Interferon alpha-2a | 2 | 1.88 (1.25 to 2.82) | 0% | --
- Interferon alpha-2b | 1 | 1.36 (0.96 to 1.92) | 0% | --
- Lamivudine | 6 | 3.98 (3.07 to 5.17) | 12.5% | --
ALT normalization
Geographic region:; - Low-prevalence (US, Canada, Europe, Australia, etc.) | 3 | 2.76 (1.44 to 5.27) | 52% | 1.00
- High-prevalence (Asia) | 5 | 2.60 (2.07 to 3.26) | 15% | --
- Mixed prevalence/other | 3 | 2.73 (2.08 to 3.58) | 0% | --
HBeAg; - Negative | 1 | 2.51 (1.66 to 3.81) | 0% | 0.88
- Positive, mixed, or not reported | 10 | 2.64 (2.22 to 3.14) | 7% | --
Treatment status:; - Naive | 2 | 3.53 (1.37 to 9.12) | 50% | 0.32
- Naïve and non-naive/NR | 9 | 2.58 (2.20 to 3.02) | 0% | --
Followup duration:; - <52 weeks | 3 | 2.61 (2.05 to 3.33) | 0% | 1.00
- ≥52 weeks | 8 | 2.64 (2.10 to 3.31) | 18% | --
Drug:; - Adefovir dipivoxil | 3 | 3.04 (2.32 to 3.96) | 0% | 0.38
- Interferon alpha-2a | 2 | 2.44 (1.29 to 4.62) | 0% | --
- Interferon alpha-2b | 1 | 1.88 (1.10 to 3.20) | 0% | --
- Lamivudine | 5 | 2.43 (1.90 to 3.39) | % | --

* Trials with poolable data.

Abbreviations: ALT = alanine aminotransferase; CI = confidence interval; DNA = deoxyribonucleic acid; HbeAg = antibody to hepatitis B e-antigen; NR = not reported.

Antiviral therapy was also associated with increased likelihood of HBeAg seroconversion, though fewer trials (four) evaluated this outcome (N=1,104, RR 2.11, 95% CI 1.30 to 3.55, I^2^=0%; ARD 6.2%, 95% CI 2.4% to 10%) (Figure 3).^76,82,86,87^ Lamivudine was evaluated in three trials (N=607, RR 1.98, 95% CI 0.99 to 4.65, I^2^=0%)^76,86,87^ and adefovir in one trial (N=497, RR 2.29, 95% CI 1.14 to 4.58).^82^

Figure 3 Antiviral Treatment vs. Placebo or No Treatment – HBeAg Seroconversion

Figure 3 is a forest plot examining HBeAg seroconversion comparing antiviral treatment versus placebo or no treatment in 2 treatment subgroups. The risk ratio for the adefovir dipivoxil subgroup with 1 study is 2.29 (95% CI 1.14 to 4.58). The risk ratio for the lamivudine subgroup with 3 studies is 1.98 (95% CI 0.99 to 4.65) with an I-squared value of 0.0%. The overall risk ratio is 2.11 (95% CI 1.30 to 3.55) with an I-squared value of 0.0%.

##### HBsAg Loss or Seroconversion

Antiviral therapy was associated with increased likelihood of HBsAg loss versus placebo or no antiviral therapy (three trials, N=714, RR 4.63, 95% CI 1.10 to 19.55, I^2^=70%; ARD 8.2%, 95% CI −2.6% to 19%) (Figure 4).^83,85,91^ Adefovir was evaluated in one trial (RR 12.58, 95% CI 5.93 to 26.71)^91^ and nonpegylated interferon-alfa in one trial (RR 3.76, 95% CI 1.17 to 12.06);^83^ the third trial evaluated lamivudine but only reported one case of HBsAg loss (RR 0.36, 95% CI 0.01 to 8.55).^85^

Figure 4 Antiviral Treatment vs. Placebo or No Treatment – HBsAg Loss

Figure 4 is a forest plot examining HBsAg loss comparing antiviral treatment versus placebo or no treatment. The overall risk ratio for the 3 studies is 4.63 (95% CI 1.10 to 19.55) with an I-squared value of 70.0%.

Effects of antiviral therapy versus placebo or no antiviral therapy on likelihood of HBsAg seroconversion was only reported in one trial, which reported no cases.^85^

##### Virological Suppression

Antiviral therapy was associated with increased likelihood of HBV DNA suppression versus placebo (13 trials, N=2,522, RR 4.39, 95% CI 2.61 to 7.39, I^2^=86%; ARD 39%, 95% CI 24% to 53%) (Figure 5).^75–78,82,83,85–91^ HBV DNA suppression was defined as less than 500 IU/mL (one trial), less than 400 copies/mL (two trials), less than 100 copies/mL (1 trial), or less than 1 to less than 2.5 pg/mL (five trials); four trials^83,88–90^ did not report criteria for HBV DNA suppression. Statistical heterogeneity was present in the overall analysis, but not in analyses of the individual drugs, each of which favored antiviral therapy. Lamivudine was evaluated in six trials (N=1.159, RR 3.98, 95% CI 3.07 to 5.17, I^2^=12%),^75,76,78,85–87^ adefovir in three trials (N=1,048, RR 19.22, 95% CI 10.98 to 33.67, I^2^=0%),^77,82,91^ entecavir in one trial (N=41, RR 31.50, 95% CI 2.02 to 492.36),^90^ nonpegylated interferon alfa-2a in two trials (N=210, RR 1.88, 95% CI 1.25 to 2.82, I^2^=0%),^88,89^ and nonpegylated interferon alfa-2b in one trial (N=64, RR 1.36, 95% CI 0.96 to 1.92).^83^ Results also consistently favored antiviral therapy in stratified analyses based on geographic region, HBeAg status, prior antiviral treatment status, and duration of followup, though some statistically significant interactions were observed (Table 4). Effects on HBV DNA suppression were stronger in trials conducted in Asia (five trials, RR 7.06, 95% CI 3.43 to 15.93, I^2^=72%)^75,78,87,90,91^ than in trials conducted in the United States, Canada, Europe, Australia, or New Zealand (4 trials, RR 2.32, 95% CI 1.39 to 4.10, I^2^=62%; p for interaction <0.005).^76,77,82,83^ Effects were also stronger in trials with followup less than 52 weeks (four trials, RR 5.65, 95% CI 3.14 to 48.74, I^2^=36%)^77,82,87,91^ than in trials greater than or equal to 52 weeks (nine trials, RR 3.50, 95% CI 1.88 to 6.94, I^2^=85%, p for interaction<0.005).^75,76,78,83,85,86,88–90^ Although there was an interaction between HBeAg status and greater effects on HBV DNA suppression, only one trial excluded HBeAg-positive patients (Table 4). Effects were similar in trials that were restricted to treatment-naïve patients and trials that included some treatment-experienced patients or that did not report prior treatment status. Antiviral therapy was associated with increased likelihood of HBV DNA suppression in trials of immune tolerant patients (two trials, RR 8.81, 95% CI 0.75 to 103.94, I^2^=39%)^86,90^ and trials of immune active patients (11 trials, RR 4.17, 95% CI 2.46 to 7.97, I^2^=88%; p for interaction=0.13), though the estimate for immune tolerant patients was very imprecise and not statistically significant. All of the trials were rated fair-quality.

Figure 5 Antiviral Treatment vs. Placebo or No Treatment – HBV DNA Loss/Virological Suppression

Figure 5 is a forest plot examining HBV DNA loss/viral suppression comparing antiviral treatment versus placebo or no treatment in 5 treatment subgroups. The risk ratio for the adefovir dipivoxil subgroup with 3 studies is 19.22 (95% CI 10.98 to 33.67) with an I-squared value of 0.0%. The risk ratio for the entecavir subgroup with 1 study is 31.50 (95% CI 2.02 to 492.36). The risk ratio for the interferon alpha-2a subgroup with 2 studies is 1.88 (95% CI 1.25 to 2.82) with an I-squared value of 0.0%. The risk ratio for the interferon alpha-2b subgroup with 1 study is 1.36 (95% CI (0.96 to 1.92). The risk ratio for the lamivudine subgroup with 6 studies is 3.98 (95% CI 3.07 to 5.17) with an I-squared value of 12.5%. The overall risk ratio is 4.39 (95% CI 2.61 to7.39) with an I-squared value of 85.6%.

Abbreviation: NR = not reported.

##### ALT Normalization

Antiviral therapy was associated with increased likelihood of ALT normalization (11 trials, N=2,044, RR 2.62, 95% CI 2.22 to 3.10, I^2^=0%; ARD 24%, 95% CI 7.8% to 39%) (Figure 6).^74–78,81–83,87,88,91^ Effects favored antiviral therapy for each individual drug. Lamivudine was evaluated in five trials (N=752, RR 1.88, 95% CI 1.10 to 3.20, I^2^=0%),^74–76,78,87^ adefovir in three trials (N=1,033, RR 3.04, 95% CI 2.32 to 3.96, I^2^=0%),^77,82,91^ and nonpegylated interferon alfa-2a in two trials (N=195, RR 2.44, 95% CI 1.29 to 4.62, I^2^=0%),^81,88^ and nonpegylated interferon alfa-2b in one trial (N=64, RR 1.88, 95% CI 1.10 to 3.20).^83^ There were no interactions between geographic region, restriction to treatment-naïve patients, or followup duration and effects of antiviral treatment on likelihood of ALT normalization (Table 4). One trial^77^ excluded HBeAg-positive patients; effects on likelihood of ALT normalization (RR 2.51, 95% CI 1.66 to 3.81) were very similar to the overall estimate.

Figure 6 Antiviral Treatment vs. Placebo or No Treatment – ALT Normalization

Figure 6 is a forest plot examining ALT normalization comparing antiviral treatment versus placebo or no treatment in 4 treatment subgroups. The risk ratio for the adefovir dipivoxil group with 3 studies is 3.04 (95% CI 2.32 to 3.96) with an I-squared value of 0.0%. The risk ratio for the interferon alpha-2a subgroup with 2 studies is 2.44 (95% CI 1.29 to 4.62) with an I-squared value of 0.0%. The risk ratio for the interferon alpha-2b subgroup with 1 study is 1.88 (95% CI 1.10 to 3.20). The risk ratio for the lamivudine subgroup with 5 studies is 2.43 (95% CI 1.90 to 3.39) with an I-squared value of 0.0%. The overall risk ratio is 2.62 (95% CI 2.22 to 3.10) with an I-squared value of 0.0%.

##### Histological Improvement

Antiviral therapy was associated with increased likelihood of histological improvement versus placebo or no therapy (six trials, N=1,057, RR 2.00, 95% CI 1.63 to 2.41, I^2^=0%; ARD 28%, 95% CI 22% to 34%) (Figure 7).^75–78,82,90^ In all trials, histological improvement was defined as ≥2 point improvement in the Knodell score (scale 0 to 22). Effects favored antiviral therapy for lamivudine (three trials, N=511, RR 2.29, 95% CI 1.66 to 3.26, I^2^=0%)^75,76,78^ and adefovir (two trials, N=507, RR 2.02, 95% CI 1.51 to 2.65, I^2^=0%);^77,82^ the estimate for entecavir was imprecise (one trial, N=39, RR 0.86, 95% CI 0.40 to 1.82).^90^

Figure 7 Antiviral Treatment vs. Placebo or No Treatment – Histologic Improvement

Figure 7 is a forest plot examining histologic improvement comparing antiviral treatment versus placebo or no treatment in 3 treatment subgroups. The risk ratio for the adefovir dipivoxil subgroup with 2 studies is 2.02 (95% CI 1.51 to 2.65) with an I-squared value of 0.0%. The risk ratio for the entecavir subgroup with 1 study is 0.86 (95% CI 0.40 to 1.82). The risk ratio for the lamivudine subgroup with 3 studies is 2.29 (95% CI 1.66 to 3.26) with an I-squared value of 0%. The overall risk ratio is 2.00 (95% CI 1.63 to 2.41) with an I-squared value of 0.0%.

Abbreviation: HAI = histology activity index.

##### Composite Intermediate Outcomes

Antiviral therapy was associated with increased likelihood of the composite outcome of HBV DNA suppression plus ALT normalization versus placebo or no therapy (three trials, N=286, RR 6.30, 95% CI 3.06 to 13.11, I^2^=0%; ARD 48%, 95% CI 29% to 61%)^75,80,85^ (Figure 8). Two trials evaluated lamivudine (N=244, RR 6.98, 95% CI 2.85 to 20.01, I^2^=0%)^75,85^ and one trial evaluated nonpegylated interferon alfa-2b (RR 4.00, 95% CI 0.96 to 16.66).^80^

Figure 8 Antiviral Treatment vs. Placebo or No Treatment – HBV DNA Loss + ALT Normalization

Figure 8 is a forest plot examining HBV DNA loss + ALT normalization comparing antiviral treatment versus placebo or no treatment in 2 treatment subgroups. The risk ratio for the interferon subgroup with 1 study is 4.00 (95% CI 0.96 to 16.66). The risk ratio for the lamivudine subgroup with 2 studies is 6.98 (95% CI 2.85 to 20.01) with an I-squared value of 0.0%. The overall risk ratio is 6.30 (95% CI 3.06 to 13.11) with an I-squared value of 0.0%.

Abbreviation: IM = intramuscular.

Antiviral therapy was also associated with increased likelihood of the composite outcome of HBeAg loss or seroconversion plus HBV DNA suppression versus placebo or no therapy (four trials, N=623, RR 2.36, 95% CI 1.44 to 4.28, I^2^=0%; ARD 12%, 95% CI 4.8% to 24%) (Figure 9).^78,81,86,89^ Two trials evaluated nonpegylated interferon alfa-2a (N=232, RR 2.18, 95% CI 1.10 to 4.78, I^2^=0%)^81,89^ and two trials evaluated lamivudine (N=391, RR 3.18, 95% CI 1.11 to 9.11, I2=0%).^78,86^

Figure 9 Antiviral Treatment vs. Placebo or No Treatment – HBV DNA Loss + HBeAg Loss

Figure 9 is a forest plot examining HBV DNA loss + HBeAg loss comparing antiviral treatment versus placebo or no treatment in 2 treatment subgroups. The risk ratio for the interferon-alpha-2a group with 2 studies is 2.18 (95% CI 1.10 to 4.78) with an I-squared value of 0%. The risk ratio for the lamivudine group with 2 studies is 3.18 (95% CI 1.11 to 9.11) with an I-squared value of 0%. The overall risk ratio is 2.36 (95% CI 1.44 to 4.28) with an I-squared value of 0.0%.

##### Subgroups

Effects of HBeAg status and inclusion of some patients with cirrhosis at baseline were evaluated in stratified analyses across trials, as described above. Two trials enrolled only patients with normal ALT values, and results were consistent with those of other trials.^86,90^ There was insufficient evidence to evaluate how effects of antiviral therapies varied within studies according to demographic (age, sex, race) and other clinical factors (HBV DNA level, injection drug use status, HBV genotype, ALT level, presence of nonalcoholic steatohepatitis, or hepatitis D virus status). Few trials reported how effects of antiviral therapies varied according to these factors, with one trial reporting no effect of HBV genotype^91^ and two that did not report statistical analyses for subgroup differences.^78,89^ Some factors (e.g., injection drug use status and presence of nonalcoholic steatohepatitis) were not reported by the trials.

#### Preferred vs. Nonpreferred Regimens

The prior USPSTF review found the preferred antiviral therapies entecavir (four trials) and pegylated interferon alfa-2a (two trials) associated with greater likelihood of achieving some intermediate outcomes (virological improvement, histological improvement) versus the nonpreferred antiviral therapy lamivudine, though comparisons were limited by small numbers of trials. Estimates for effects of TDF versus adefovir on intermediate outcomes were imprecise, based on two trials.

Twelve head-to-head trials (reported in 11 publications; N=4,127) of preferred (entecavir, TDF, or pegylated interferon alfa-2a) versus nonpreferred (lamivudine, telbivudine, or adefovir) antiviral regimens for HBV infection were included in this update (Appendix B Tables 7–8).^92–102^ Seven trials were included in the prior USPSTF review and five trials were added for this update. Sample sizes ranged from 44 to 715. All trials only enrolled adults. Between 55 and 83 percent of patients were men. In six trials, all or most of patients were HBeAg-positive,^92,95–97,100,102^ and in two trials, few to no patients were HBeAg-positive;^93,96^ one trial did not report HBeAg status.^99^ Of five studies reporting cirrhosis at baseline, prevalence ranged from 7 to 20 percent.

Six trials compared entecavir versus lamivudine,^92–94,97,99,101^ two trials entecavir versus telbivudine,^100,102^ three trials (reported in two publications) TDF versus adefovir,^96,98^ and one trial pegylated interferon alfa-2a versus lamivudine.^95^ No trial evaluated TAF (FDA-approved in 2016). Duration of followup ranged from 3.7 to 22 months. Two multinational trials were conducted in the United States, Europe, and other areas with low HBV prevalence,^96^ six trials were conducted in Asia,^97–102^ and four multinational trials were conducted in high and low HBV prevalence settings (e.g., Asia and the United States or Europe).^92–95^ Five trials were rated good-quality^92,93,95,98,101^ and the others were rated fair-quality. Methodological limitations in the fair-quality trials included unclear or no blinding of outcome assessors, care providers, and patients in most studies; attrition did not differ between groups for all studies (Appendix B Table 6).

##### HBeAg Loss or Seroconversion

Three trials compared effects of preferred versus nonpreferred antiviral therapies on likelihood of HBeAg loss.^94,95,98^ Each evaluated a different drug comparison; though results favored preferred antiviral drugs, estimates were imprecise. One trial (n=202) compared TDF versus adefovir (18% vs. 10%, RR 1.73, 95% CI 0.84 to 3.56)^98^ and one trial (n=543) pegylated interferon alfa-2a versus lamivudine (27% vs. 20%, RR 1.38 95% CI 1.04 to 1.84 at end of treatment at 48 weeks and 32% vs. 19%, RR 1.64, 95% CI 1.23 to 2.18 at 24 weeks following the end of treatment).^95^ A third, smaller (n=69) trial evaluated entecavir versus lamivudine, but there were only 2 cases of HBeAg loss (both in the lamivudine arm).^94^

Seven trials evaluated effects of preferred versus nonpreferred antiviral therapies on likelihood of HBeAg seroconversion (Figure 10).^94–97,101,102,136^ One trial found pegylated interferon alfa-2a associated with increased likelihood of HBeAg seroconversion versus lamivudine at the end of treatment at 48 weeks (N=543, 27% vs. 20%, RR 1.31, 95% CI 0.97 to 1.79)^95^ and at 24 weeks following the end of treatment (32% vs. 19%, RR 1.68, 95% CI 1.24 to 2.27). Although estimates favored entecavir over lamivudine at 22 to 96 weeks (five trials, N=1,266, RR 1.19, 95% CI 0.87 to 1.49, I^2^=0%)^94,97,101,136^ and TDF over adefovir at 48 weeks (one trial, N=233, RR 1.20, 95% CI 0.68 to 2.11)^96^ differences were not statistically significant. In one trial, entecavir was associated with decreased likelihood of HBeAg seroconversion versus telbivudine at 24 weeks, but the estimate was imprecise and not statistically significant (one trial, N=131, RR 0.55, 95% CI 0.26 to 1.16).^102^

Figure 10 Preferred vs. Nonpreferred Treatment – HBeAg Seroconversion

Figure 10 is a forest plot examining HBeAg seroconversion comparing preferred versus nonpreferred treatments in 4 treatment subgroups. The risk ratio for the entecavir versus lamivudine subgroup with 4 studies is 1.19 (95% CI 0.87 to 1.49) with an I-squared value of 0.0. The risk ratio for the entecavir versus telbivudine subgroup with 1 study is 0.55 (95% CI 0.26 to 1.16). The risk ratio for the interferon versus lamivudine subgroup with 1 study is 1.68 (95% CI 1.24 to 2.27). The risk ratio for the tenofovir versus adefovir subgroup with 1 study is 1.20 (95% CI 0.68 to 2.11).

##### HBsAg Loss or Seroconversion

Three trials evaluated effects of preferred versus nonpreferred antiviral therapies on likelihood of HBsAg loss or seroconversion.^92,95,96^ Each evaluated a different antiviral therapy comparison. Although results favored the preferred antiviral therapies, estimates were imprecise. One trial (n=709) compared entecavir versus lamivudine (RR 1.8, 95% CI 0.9 to 3.9 for HBsAg loss),^92^ one trial (n=240) TDF versus adefovir (RR 5.74, 95% CI 0.32 to 102.59 for HBsAg loss),^96^ and one trial (n=543) pegylated interferon alfa-2a versus lamivudine (RR 17, 95% CI 1.0 to 294 for HBsAg seroconversion at 72 weeks, 24 weeks following the completion of therapy).^95^ Two other trials (N=481) reported no cases of HBsAg loss with either TDF or adefovir.^96,98^

##### Virological Suppression

Nine trials compared effects of preferred versus nonpreferred antiviral therapy on likelihood of HBV DNA suppression.^93–99,136^ Virological suppression was defined as less than 300 copies/mL in three trials and less than 400 copies/mL in three trials; two trials did not define criteria for virological suppression.

Entecavir was associated with increased likelihood of HBV DNA suppression versus lamivudine at 22 to 96 weeks (six trials, N=2,115, RR 1.70, 95% CI 1.38 to 2.13, I^2^=81%; ARD 30%, 95% CI 17% to 43%) (Figure 11).^93,94,97,99,101,136^ Although statistical heterogeneity was present, estimates favored entecavir in all trials (RRs ranged from 1.25 to 2.08). There was no interaction between HBeAg status and likelihood of virological suppression (HBeAg-negative: 1 trial, RR 1.95, 95% CI 1.51 to 2.54 versus HBeAg-positive/mixed: five trials, RR 1.66, 95% CI 1.28 to 2.16 I^2^=0%; p for interaction=0.60), though stratification by HBeAg status eliminated statistical heterogeneity. There was also no interaction between duration of followup and likelihood of virological suppression (Table 5).

Figure 11 Preferred vs. Nonpreferred Treatment – HBV DNA Loss/Suppression

Figure 11 is a forest plot examining HBV DNA loss/suppression comparing preferred versus nonpreferred treatments in 4 treatment subgroups. The risk ratio for the entecavir versus lamivudine subgroup with 6 studies is 1.70 (95% CI 1.38 to 2.13) with an I-squared value of 80.6%. The risk ratio for the entecavir versus telbivudine subgroup with 2 studies is 0.89 (95% CI 0.59 to 3.44) with an I-squared value of 0.0%. The risk ratio for the interferon versus lamivudine subgroup with 1 study is 2.80 (95% CI 1.55 to 5.03). The risk ratio for the tenofovir versus adefovir subgroup with 3 studies is 2.32 (95% 0.96 to 6.10) with an I-squared value of 97.1%.

Abbreviation: NR = not reported.

Table 5 Entecavir vs. Lamivudine on Intermediate Outcomes – Subgroup Analyses

Intermediate outcome; Subgroup analysis | Number of trials^*^ | Relative risk (95% CI) | I^2^ | P_Interaction_
ALT normalization
HBeAg:; - Excluded | 1 | 1.70 (1.31 to 2.19) | -- | 0.035
- Not excluded | 5 | 1.12 (1.07 to 1.17) | 0% | --
Followup duration:; - <52 weeks | 3 | 1.15 (1.04 to 1.27) | 0% | 0.72
- ≥52 weeks | 3 | 1.12 (0.90 to 1.77) | 0% | --
DNA loss
HBeAg:; - Excluded | 1 | 1.95 (1.51 to 2.54) | -- | 0.60
- Not excluded | 5 | 1.66 (1.28 to 2.16) | 0% | --
Followup duration:; - <52 weeks | 3 | 1.77 (1.42 to 2.18) | 0% | 0.92
- ≥52 weeks | 3 | 1.69 (1.17 to 2.50) | 91% | --

* Trials with poolable data.

Note: RR>1.00 favored entecavir.

Abbreviations: ALT = alanine aminotransferase; CI = confidence interval; DNA = deoxyribonucleic acid; HBeAg = antibody to hepatitis B e-antigen.

Results favored TDF over adefovir for likelihood of HBV DNA suppression at 48 weeks, though the difference was not statistically significant (three trials, N=1,150, RR 2.32, 95% CI 0.96 to 6.10, I^2^=92%) (Figure 11).^96,98^ Statistical heterogeneity was also present in this analysis, but estimates favored tenofovir in all trials (RR ranged from 1.47 to 5.71).

One trial found pegylated interferon alfa-2a associated with decreased likelihood of HBV DNA suppression versus lamivudine at the end of treatment at 48 weeks (N=543, 25% vs. 40%, RR 0.63, 95% CI 0.49 to 0.81), but increased likelihood 24 weeks following the end of treatment (14% vs. 5%, RR 2.80, 95% CI 1.55 to 5.03). There was no difference between entecavir versus telbivudine in likelihood of HBV DNA suppression (two trials, N=175, RR 0.89, 95% CI 0.59 to 3.44, I2=0%).^100,102^

Across preferred versus nonpreferred antiviral therapy comparisons, there were no interactions between HBeAg status or duration of followup and likelihood of virological suppression (Table 5).

##### ALT Normalization

Entecavir was associated with increased likelihood of ALT normalization versus lamivudine at 22 to 96 weeks (six trials, N=2,079, RR 1.13, 95% CI 1.08 to 1.27, I^2^=0%; ARD 12%, 95% CI 4.2% to 22%) (Figure 12).^85,93,94,99,136^ There was no statistical heterogeneity and estimates favored entecavir in all trials (RR ranged from 1.10 to 1.70). There was an interaction between HBeAg status and likelihood of ALT normalization (HBeAg-negative: one trial, RR 1.70, 95% CI 1.31 to 2.19 versus HBeAg-positive/mixed: five trials, RR 1.12, 95% CI 1.07 to 1.17, I^2^=0%; p for interaction=0.035). There was no interaction between duration of followup and likelihood of ALT normalization (Table 5).

Figure 12 Preferred vs. Nonpreferred Treatment – ALT Normalization

Figure 12 is a forest plot examining ALT normalization comparing preferred versus nonpreferred treatments in 4 treatment subgroups. The risk ratio for the entecavir versus lamivudine subgroup with 6 studies is 1.13 (95% CI 1.08 to 1.27) with an I-squared value of 0.0%. The risk ratio for the entecavir versus telbivudine subgroup with 1 study is 0.95 (95% CI 0.78 to 1.15). The risk ratio for the interferon versus lamivudine subgroup with 1 study is 1.47 (95% CI 1.15 to 1.86). The risk ratio for the tenofovir versus adefovir subgroup with 3 studies is 1.03 (95% CI 0.96 to 1.18) with an I-squared value of 0.0%.

There was no difference between tenofovir versus adefovir in likelihood of ALT normalization at 48 weeks (three trials, N=1,122, RR 1.03, 95% CI 0.96 to 1.18, I^2^=0%).^96,98^ One trial found pegylated interferon alfa-2a associated with decreased likelihood of ALT normalization versus lamivudine at the end of treatment at 48 weeks (N=543, 39% vs. 62%, RR 0.63, 95% CI 0.53 to 0.75)^95^ but greater likelihood 24 weeks following the end of treatment (41% vs. 28%, RR 1.47, 95% CI 1.15 to 1.86). One trial found no difference between entecavir versus telbivudine in likelihood of ALT normalization at 48 weeks (N=131, RR 0.95, 95% CI 0.78 to 1.15).^102^

##### Histological Improvement

Entecavir was associated with increased likelihood of histological improvement versus lamivudine at 52 or 96 weeks (two trials, N=1211, RR 1.16, 95% CI 1.06 to 1.27, I^2^=0%; ARD 9.8%, 95% CI 3.7% to 16%) (Figure 13).^93,136^

Figure 13 Entecavir vs. Lamivudine – Histologic Improvement

Figure 13 is a forest plot examining histologic improvement comparing entecavir versus lamivudine. The overall risk ratio for the 2 studies is 1.16 (95% CI 1.06 to 1.27) with an I-squared value of 0.0%.

One trial (n=512) found no difference between tenofovir versus adefovir in likelihood of histological improvement at 48 weeks (RR 1.02, 95% CI 0.79 to 1.31)^98^ and one trial (n=543) found no difference between pegylated interferon alfa-2a versus lamivudine in likelihood of histologic improvement at 72 weeks (24 weeks after the end of treatment; RR 1.10, 95% CI 0.88 to 1.38).^95^

## Key Question 5 How Effective Is Antiviral Treatment in Improving Health Outcomes Among Nonpregnant Adolescents and Adults With Chronic HBV Infection?

### Summary

As in the prior USPSTF review, evidence from randomized trials on effects of antiviral therapy versus placebo or no treatment on clinical outcomes was limited due to small numbers of trials, few events, and insufficient duration of followup. Antiviral therapy was associated with decreased risk of mortality, based on three trials of interferon with a total of 8 deaths (N=349, RR 0.15, 95% CI 0.03 to 0.69, I^2^=0%; ARD −0.3%, 95% CI −1.7% to 0.8%). Estimates for incident cirrhosis (two trials, N=165, RR 0.72, 95% CI 0.29 to 1.77, I^2^=0%)^81,83^ and hepatocellular carcinoma (four trials, N=343, RR 0.60, 95% CI 0.16 to 2.33, I^2^=20%)^75,80,81,83^ favored antiviral therapy over placebo or no therapy, but differences were not statistically significant. In seven cohort studies with longer-term (2.7 to 8.9 years) followup, antiviral therapy was consistently associated with decreased risk of hepatocellular carcinoma versus no antiviral therapy (adjusted hazard ratios [HRs] ranged from 0.24 to 0.64). One cohort study found antiviral therapy associated with decreased risk of mortality after 8.25 years (adjusted HR 0.58, 95% CI 0.43 to 0.79).^108^ Data from head-to-head trials of preferred versus nonpreferred antiviral therapy were insufficient to evaluate effects on clinical outcomes.

### Evidence

#### Antiviral Therapy vs. Placebo or No Treatment

The prior USPSTF report found antiviral therapy might be associated with reduced risk of incident cirrhosis (three trials; RR, 0.70; 95% CI, 0.33 to 1.46; I^2^=0%), hepatocellular carcinoma (five trials; RR, 0.57; 95% CI, 0.32 to 1.04; I^2^=2%), and mortality (five trials; RR, 0.55; 95% CI, 0.18 to 1.71; I^2^=43%) versus placebo or no therapy. However, none of the differences was statistically significant, estimates were imprecise, and some trials had relatively short duration of followup. The prior USPSTF review included trials in which more than 20 percent of patients had cirrhosis had baseline,^125–129,137–142^ trials of treatment-experienced patients,^130–132^ and poor-quality trials;^133–135^ these trials were excluded for this update.

Seven randomized trials (N=1,042) of antiviral therapy versus placebo or no treatment (see Key Question 4 for more detailed description of trials) that reported effects on clinical outcomes were included in this update (Appendix B Tables 4–5).^75,76,78,80,81,83,89^ All but one^89^ of these trials were included in the prior USPSTF report. None of the trials reported effects on quality of life, risk of HBV disease transmission, or extrahepatic outcomes. Four trials evaluated nonpegylated interferon,^80,81,83,89^ and three trials lamivudine;^75,76,78^ all of the trials evaluated adults. The trials were generally not designed to evaluated effects on clinical outcomes and generally reported small numbers of events. There were a total of 23 cases of incident cirrhosis in two trials,^81,83^ 13 cases of hepatocellular carcinoma in four trials,^75,80,81,83^ and eight deaths in three trials^81,83,89^ (two other trials that reported mortality recorded no deaths).^76,78^ The duration of followup ranged from 11 to 86 months. All of the trials were rated fair-quality (Appendix B Table 6).

Antiviral therapy was associated with decreased risk of mortality versus placebo or no therapy (three trials, N=349, RR 0.15, 95% CI 0.03 to 0.69, I^2^=0%; ARD −0.3%, 95% CI −1.7% to 0.8%) (Figure 14); all of the trials reporting mortality evaluated nonpegylated interferon.^81,83,89^ Pooled estimates for incident cirrhosis (two trials, N=165, RR 0.72, 95% CI 0.29 to 1.77, I^2^=0%)^81,83^ (Figure 15) and hepatocellular carcinoma (four trials, N=343, RR 0.60, 95% CI 0.16 to 2.33, I^2^=20%) (Figure 16)^75,80,81,83^ favored antiviral therapy over placebo or no therapy, but differences were not statistically significant.

Figure 14 Antiviral Treatment vs. Placebo or No Treatment – Mortality

Figure 14 is a forest plot examining mortality comparing antiviral treatment versus placebo or no treatment. The overall risk ratio for the 3 studies is 0.15 (95% CI 0.03 to 0.69) with an I-squared value of 0.0%.

Figure 15 Antiviral Treatment vs. Placebo or No Treatment – Incident Cirrhosis

Figure 15 is a forest plot examining incident cirrhosis comparing antiviral treatment versus placebo or no treatment. The overall risk ratio for the 2 studies is 0.72 (95% CI 0.29 to 1.77) with an I-squared value of 0.0%.

Figure 16 Antiviral Treatment vs. Placebo or No Treatment – Hepatocellular Carcinoma

Figure 16 is a forest plot examining hepatocellular carcinoma comparing antiviral treatment versus placebo or no treatment. The overall risk ratio for the 4 studies is 0.60 (95% CI 0.16 to 2.33) with an I-squared value of 20.5%.

Abbreviation: IM = intramuscular.

Seven cohort studies (N=~50,912) evaluated effects of antiviral therapy versus no therapy on mortality or hepatocellular carcinoma after controlling for potential confounders (Appendix B Tables 9–11).^103–109^ Cohort studies on effects of antiviral therapy on clinical outcomes were not included in the prior USPSTF review. Sample sizes ranged from 632 to 43,190 and the duration of followup ranged from 2.7 to 8.9 years. The proportion of patients with cirrhosis at baseline ranged from 13 to 29 percent. All studies were conducted in Asia except for two^103,104^ which evaluated U.S. cohorts. Three of the Asian studies appeared to examine overlapping populations from Taiwan’s National Health Insurance Research Database.^106,108,109^ One study focused on patients who received entecavir,^105^ a preferred antiviral and one study focused on lamivudine,^107^ a nonpreferred antiviral; in the other studies, the antiviral drugs varied. All of the studies were rated fair-quality. Methodological limitations included unclear blinding of data analysts, unclear percentages of those with missing data or lost to followup, and failure to adjust for key confounders. Studies typically adjusted for age, sex, fibrosis stage; some studies also adjusted for HBV DNA level, ALT level, or medical comorbidities.

Antiviral therapy was consistently associated with decreased risk of hepatocellular carcinoma. Two studies of U.S. cohorts found antiviral therapy associated with decreased risk of hepatocellular carcinoma after a median 5.2 years (adjusted HR 0.39, 95% CI 0.27 to 0.56)^103^ or after a median of 8.9 years (adjusted HR 0.24, 95% CI 0.15 to 0.39). U.S. patients found receipt of various antivirals associated with decreased risk of hepatocellular carcinoma after a median of 8.9 years (adjusted HR 0.24, 95% CI to 0.10 to 0.58).^104^ Results were similar in five studies conducted in Asian populations (adjusted HRs ranged from 0.37 to 0.64 at 2.7 to 5.3 years followup).^105–109^ A study conducted on Taiwan’s National Health Insurance Research Database found antiviral therapy associated with decreased risk of mortality (adjusted HR 0.58, 95% CI 0.43 to 0.79).^108^

#### Preferred vs. Nonpreferred Regimens

The prior USPSTF report found too few clinical events in head-to-head trials of entecavir or pegylated interferon alfa-2a versus lamivudine to determine effects on clinical outcomes. For this update, nine trials (reported in eight publications; N=3,767) evaluated effects of preferred versus nonpreferred antiviral therapy (see Key Question 4 for description of trials) on clinical outcomes (mortality, cirrhosis, hepatocellular carcinoma);^92,93,95–97,99,101^ six trials were carried forward from the prior report^92,93,95–97^ and three were new^98,99,101^ (Appendix B Tables 7–8). Five trials compared entecavir versus lamivudine,^92,93,97,99,101^ three trials TDF versus adefovir,^96,98^ and one trial pegylated interferon alfa-2a versus lamivudine.^95^ The duration of followup ranged from 11 to 22 months. Five trials were rated good-quality^92,93,95,98,101^ and the remainder fair-quality (Appendix B Table 6).

The trials were not designed to evaluate clinical outcomes, with small numbers of events reported. For entecavir versus lamivudine, there were a total of nine deaths in four trials^92,93,97,99^ and two cases of hepatocellular carcinoma in 3 trials;^92,93,97^ cirrhosis was not reported. For comparisons of pegylated interferon versus lamivudine^95^ and tenofovir versus adefovir,^98^ there was one death each; cirrhosis and hepatocellular carcinoma were not reported. In a pooled analysis, there was no difference between entecavir versus lamivudine in risk of mortality, but the estimate was very imprecise (three trials, N=1,467, RR 1.19, 95% CI 0.28 to 5.12, I^2^=10%) (Figure 17).^93,99,136^

Figure 17 Preferred vs. Nonpreferred Treatment – Mortality

Figure 17 is a forest plot examining mortality comparing preferred versus nonpreferred treatments in 3 treatment subgroups. The risk ratio for the entecavir versus lamivudine subgroup with 3 studies is 1.19 (95% CI 0.28 to 5.12) with an I-squared value of 10.3%. The risk ratio for the interferon versus lamivudine subgroup with 1 study is 0.33 (95% CI 0.01 to 8.18). The risk ratio for the tenofovir versus adefovir subgroup with 1 study is 2.94 (95% CI 0.12 to 71.88).

## Key Question 6 What Are the Harms Associated With Antiviral Treatment in Nonpregnant Adolescents and Adults With Chronic HBV Infection?

### Summary

As in the prior USPSTF review, antiviral therapy was associated with no differences versus placebo in risk of serious adverse events or any adverse event. Antiviral therapy was associated with increased risk of study withdrawal due to adverse events (three trials, N=496, RR 4.44, 95% CI 0.95 to 20.77, I^2^=0%),^80,82,85^ with the risk highest in a trial of nonpegylated interferon. Estimates for gastrointestinal and kidney adverse events were imprecise.

In head-to-head trials, pegylated interferon was associated with increased risk of any adverse event (one trial, N=543, RR 1.58, 95% CI 1.41 to 1.78) versus lamivudine and is probably associated with increased risk of withdrawal due to adverse events, though the difference was not statistically significant (one trial, N=543, RR 4.01, 95% CI 0.86 to 18.73).^95^ TDF was associated with increased risk of nausea versus adefovir (RR 3.36, 95% CI 1.45 to 7.81). For other head-to-head comparisons and harms, there were no differences or imprecise estimates.

One cohort study found no association between TDF or entecavir versus no antiviral therapy and risk of osteopenia or osteoporosis; it was not designed to evaluated risk of fracture.

### Evidence

#### Antiviral Therapy vs. Placebo or No Treatment

The prior USPSTF review found no differences between antiviral therapy versus placebo or no therapy in risk of serious adverse events or any adverse events. Antiviral therapy was associated with more withdrawals due to adverse events than placebo or no treatment (nine trials; RR, 3.97; 95% CI, 1.4 to 11; I^2^=0%).

Twelve trials of antiviral therapy versus placebo or no treatment (see Key Question 4 for study details) that reported harms were included in this update (Appendix B Tables 4–5).^75–80,82,85–89^ All trials but two^88,89^ were included in the prior USPSTF report. Three trials evaluated pegylated interferon,^80,88,89^ two trials evaluated adefovir,^77,82^ and the other trials evaluated lamivudine. Followup ranged from 1.8 to 30 months. All of the trials were rated fair-quality (Appendix B Table 6).

One new cohort study (n=1,224) evaluated risk of incident osteopenia or osteoporosis in patients with chronic HBV infection on TDF, entecavir, or no therapy. The study was rated fair-quality, due in part to differences between groups in duration of followup (Appendix B Tables 9–11).

##### Serious Adverse Events

There was no difference between antiviral therapy versus placebo or no antiviral therapy in risk of serious adverse events (four trials, N=802, RR 0.92, 95% CI 0.45 to 1.85, I^2^=0%) (Figure 18).^75,77,78,85^ Rates of serious adverse events on antiviral therapy ranged from 1.8 to 14.6 percent. Lamivudine was evaluated in three trials and adefovir in one trial.

Figure 18 Antiviral Treatment vs. Placebo or No Treatment – Serious Adverse Effects

Figure 18 is a forest plot examining serious adverse effects comparing antiviral treatment versus placebo or no treatment in 2 treatment subgroups. The risk ratio for the adefovir dipivoxil subgroup with 1 study is 0.50 (95% CI 0.13 to 1.92). The risk ratio for the lamivudine group with 3 studies is 1.11 (95% CI 0.49 to 2.67). The overall risk ratio is 0.92 (95% CI 0.45 to 1.85) with an I-squared value of 0.0%.

##### Withdrawal Due to Adverse Events

Antiviral therapy was associated with increased risk of withdrawal due to adverse events versus placebo or no antiviral therapy, but the estimate was very imprecise and the difference was not statistically significant (three trials, N=505, RR 4.44, 95% CI 0.95 to 20.77, I^2^=0%) (Figure 19).^80,82,85^ Rates of withdrawal due to adverse events on antiviral therapy were 24 percent in one trial of interferon alfa-2b and less than 2 percent in one trial each of adefovir or lamivudine. The risk of withdrawal due to adverse events was higher in the trial of interferon alfa-2b (RR 11.00, 95% CI 0.65 to 187.17)^80^ than in the trial of adefovir (RR 2.93, 95% 0.31 to 27.88)^82^ or lamivudine (RR 3.25, 95% CI 0.13 to 78.18).^85^ One trial of interferon reported no withdrawals due to adverse events in either group.^88^

Figure 19 Antiviral Treatment vs. Placebo or No Treatment – Withdrawals Due to Adverse Effects

Figure 19 is a forest plot examining withdrawals due to adverse effects comparing antiviral treatment versus placebo or no treatment. The overall risk ratio for the 3 studies is 4.44 (95% CI 0.95 to 20.77) with an I-squared value of 0.0%.

Abbreviation: IM = intramuscular.

##### Any Adverse Event

There was no difference between antiviral therapy versus placebo or no therapy in risk of any adverse event (five trials, N=1,290, RR 1.01, 95% CI 0.90 to 1.11, I^2^=0%) (Figure 20).^77,78,85,87,89^ Rates of any adverse event ranged from 42 to 97 percent. The risk of any adverse event was substantially higher in one trial of interferon alfa-2a (RR 107.14, 95% CI 6.78 to 1,694.36)^89^ than in trials of lamivudine (three trials, RR 0.99, 95% CI 0.80 to 1.12, I^2^=0%)^78,85,87^ or adefovir (one trial, RR 1.04, 95% CI 0.87 to 1.24).^77^

Figure 20 Antiviral Treatment vs. Placebo or No Treatment – Any Adverse Effects

Figure 20 is a forest plot examining any adverse effects comparing antiviral treatment versus placebo or no treatment in 3 treatment subgroups. The risk ratio for the adefovir dipivoxil subgroup with 1 study is 1.04 (95% CI 0.87 to 1.24). The risk ratio for the interferon alpha-2a subgroup with 1 study is 107.14 (95% CI 6.78 to 1,694.36). The risk ratio for the lamivudine subgroup with 3 studies is 0.99 (95% CI 0.80 to 1.12) with an I-squared value of 0.0%. The overall risk ratio is 1.01 (95% CI 0.90 to 1.11) with an I-squared value of 0.0%.

##### Gastrointestinal Adverse Events

There was no difference between antiviral therapy versus placebo or no antiviral therapy in risk of nausea (three trials, RR 0.80, 95% CI 0.48 to 2.10, I^2^=0%) (Figure 21).^82,85,87^ Two trials evaluated lamivudine and one trial evaluated adefovir.

Figure 21 Antiviral Treatment vs. Placebo or No Treatment – Nausea

Figure 21 is a forest plot examining nausea comparing antiviral treatment versus placebo or no treatment. The overall risk ratio for the 3 studies is 0.80 (95% CI 0.48 to 2.10) with an I-squared value of 0.0%.

Antiviral therapy might be associated with increased risk of diarrhea versus placebo or no antiviral therapy, but the estimate was imprecise and the difference was not statistically significant (four trials, RR 1.50, 95% CI 0.87 to 2.46, I^2^=0%) (Figure 22).^76,82,85,87^ Three trials reporting diarrhea evaluated lamivudine and one trial evaluated adefovir.

Figure 22 Antiviral Treatment vs. Placebo or No Treatment – Diarrhea

Figure 22 is a forest plot examining diarrhea comparing antiviral treatment versus placebo or no treatment. The overall risk ratio for the 4 studies is 1.50 (95% CI 0.87 to 2.46) with an I-squared value of 0.0%.

##### Kidney Adverse Events

There was no statistically significant difference between antiviral therapy versus placebo or no antiviral therapy in risk of creatinine elevation versus placebo or no antiviral therapy, though the estimate favored placebo (three trials, RR 1.27, 95% CI 0.31 to 3.55, I^2^=0%) (Figure 23).^75,76,78^ All of the trials evaluated lamivudine.

Figure 23 Antiviral Treatment vs. Placebo or No Treatment – Elevated Creatinine

Figure 23 is a forest plot examining elevated creatinine comparing antiviral treatment versus placebo or no treatment. The overall risk ratio for the 3 studies is 1.27 (95% CI 0.31 to 3.55) with an I-squared value of 0.0%

Abbreviation: NR = not reported.

##### Bone Adverse Events

A cohort study (n=1,224) compared risk of incident osteopenia or osteoporosis in patients with chronic HBV infection on TDF (median followup 48 months), entecavir (median 67 months), or no therapy (median 24 months).^110^ The study was conducted in the United States in Asian patients. Neither TDF nor entecavir was associated with increased risk of osteopenia or osteoporosis compared with no therapy, though estimates were imprecise (adjusted HR 0.74, 95% CI 0.34 to 1.59 and 0.98, 95% CI 0.51 to 1.90, respectively). The study was not designed to assess risk of fractures.

#### Preferred vs. Nonpreferred Regimens

The prior USPSTF review found pegylated interferon alfa-2a was associated with greater risk of serious adverse events (RR, 2.1; 95% CI, 1.0 to 4.5; I^2^=0%), withdrawals due to adverse events (RR, 7.6; 95% CI, 1.1 to 52; I^2^=38%), and any adverse event (RR, 1.7; 95% CI, 1.5 to 2.0; I^2^=55%) versus lamivudine. There were no differences between entecavir and lamivudine (three trials) or between tenofovir and adefovir (two trials).

Twelve head-to-head trials (reported in 11 publications) of preferred versus nonpreferred therapies that reported harms were included in this update (see Key Question 4 for study details) (Appendix B Tables 7–8).^92–102^ Seven trials were included in the prior USPSTF review, and five trials were added for this update.^98–102^ Six trials compared entecavir versus lamivudine,^92–94,97,99,101^ two compared entecavir to telbivudine,^100,102^ three trials compared TDF versus adefovir,^96,98^ and one trial compared pegylated interferon versus lamivudine.^95^ The duration of followup ranged from 3.7 to 22 months. Five trials were rated good-quality^92,93,95,98,101^ and the others fair-quality (Appendix B Table 6).

##### Serious Adverse Events

Entecavir might be associated with decreased risk of serious adverse events versus lamivudine, but the difference was not statistically significant (four trials, N=1,986, RR 0.78, 95% CI 0.54 to 1.07, I^2^=0%) (Figure 24).^93,99,101,136^ Results were similar for tenofovir versus adefovir (two trials, N=1,150, RR 0.84, 95% CI 0.22 to 1.81, I^2^=0%).^96,98^

Figure 24 Preferred vs. Nonpreferred Treatment – Serious Adverse Effects

Figure 24 is a forest plot examining serious adverse effects comparing preferred versus nonpreferred treatments in 3 treatment subgroups. The risk ratio for the entecavir versus lamivudine subgroup with 4 studies is 0.78 (95% CI 0.54 to 1.07) with an I-squared value of 0.0%. The risk ratio for the interferon versus lamivudine group with 1 study is 2.41 (95% CI 0.86 to 6.74). The risk ratio for the tenofovir versus adefovir subgroup with 2 studies is 0.84 (95% CI 0.22 to 1.81) with an I-squared value of 0.0%.

One trial (n=543) found that pegylated interferon alfa-2a might be associated with increased risk of serious adverse events versus lamivudine, but the difference was not statistically significant (RR 2.41, 95% CI 0.86 to 6.74).^95^

##### Withdrawal Due to Adverse Events

There was no difference between entecavir versus lamivudine in likelihood of withdrawal from study due to adverse events, but the estimate was imprecise (five trials, N=2,073, RR 0.50, 95% CI 0.18 to 1.15, I^2^=0%) (Figure 25).^93,94,99,101,136^ There was no difference between tenofovir versus adefovir in likelihood of withdrawal due to adverse events, though the estimate was imprecise (two trials, N=1,150, RR 1.03, 95% CI 0.28 to 3.79, I^2^=0%).^96,98^

Figure 25 Preferred vs. Nonpreferred Treatment – Withdrawals Due to Adverse Effects

Figure 25 is a forest plot examining withdrawals due to adverse effects comparing preferred versus nonpreferred treatments in 3 treatment subgroups. The risk ratio for the entecavir versus lamivudine subgroup with 5 studies is 0.50 (95% CI 0.18 to 1.15) with an I-squared value of 0.0%. The risk ratio for the interferon versus lamivudine subgroup with 1 study is 4.01 (95% CI 0.86 to 18.73). The risk ratio for the tenofovir versus adefovir subgroup with 2 studies is 1.03 (95% CI 0.28 to 3.79) with an I-squared value of 0.0%.

One trial (n=543) found pegylated interferon alfa-2a associated with substantially increased likelihood of withdrawal due to adverse events versus lamivudine, though the difference was not statistically significant (RR 4.01, 95% CI 0.86 to 18.73).^95^

##### Any Adverse Event

There were no differences between entecavir versus lamivudine (five trials, N=2,073, RR 1.02, 95% CI 0.96 to 1.08, I^2^=0%;^93,94,99,101,136^ or tenofovir versus adefovir (two trials, N=1,150, RR 1.03, 95% CI 0.92 to 1.23, I^2^=0%; Figure 26)^96,98^ in risk of any adverse event. In one trial (n=543), pegylated interferon alfa-2a was associated with increased risk of any adverse event versus lamivudine (RR 1.58, 95% CI 1.41 to 1.78)^95^ and in one small trial (n=44) entecavir was associated with increased risk of any adverse event versus telbivudine, but the difference was not statistically significant (RR 1.58, 95% CI 0.86 to 2.91).^100^

Figure 26 Preferred vs. Nonpreferred Treatment – Any Adverse Effects

Figure 26 is a forest plot examining any adverse effects comparing preferred versus nonpreferred treatments in 4 treatment subgroups. The risk ratio for the entecavir versus lamivudine subgroup with 5 studies is 1.02 (95% CI 0.96 to 1.08) with an I-squared value of 0.0%. The risk ratio for the entecavir versus telbivudine subgroup with 1 study is 1.58 (95% CI 0.86 to 2.91). The risk ratio for the interferon versus lamivudine subgroup with 1 study is 1.58 (95% CI 1.41 to 1.78). The risk ratio for the tenofovir versus adefovir subgroup with 2 studies is 1.03 (95% CI 0.92 to 1.23) with an I-squared value of 0.0%.

##### Other Adverse Events

Harms were combined from two trials of TDF versus adefovir reported in the same publication; the trials differed primarily in enrollment of HBeAg-positive or -negative patients.^96^ At 48 weeks, only one case of serum creatinine increase ≥0.5 mg/dL was reported (0% vs. 0.5%, RR 0.17, 95% CI 0.007 to 4.12), with no cases of creatinine clearance less than 50 mL/min. TDF was associated with increased risk of nausea (9.4% vs. 2.8%, RR 3.36, 95% CI 1.45 to 7.81) and might be associated with increased risk of diarrhea (6.6% vs. 5.1%, RR 1.28, 95% CI 0.65 to 2.53), though the difference was not statistically significant, and a small trial (n=42) found no difference in diarrhea between entecavir and lamivudine (28.6% vs. 33.3%).^97^ One trial reported no difference between entecavir versus lamivudine in likelihood of creatinine increase, with few events recorded (3.6% vs. 0%).^99^

## Key Question 7 What Is the Association Between Improvements in Intermediate Outcomes as a Result of Antiviral Treatment of Chronic HBV Infection and Reduction in Risk of HBV-Related Adverse Health Outcomes?

### Summary

As in the prior USPSTF review, there were consistent associations between various intermediate outcomes (virological remission, biochemical remission, histological improvement, HBeAg loss, or a composite intermediate outcome) and clinical outcomes (death, hepatocellular carcinoma, cirrhosis, or a composite clinical outcome), based on nine observational studies. However, variability in patient populations (e.g., HBeAg status, viral load, or AST levels), the intermediate and clinical outcomes evaluated, and presence of some methodological limitations make it difficult to draw strong conclusions. In some studies, estimates were imprecise and associations were not statistically significant.

### Evidence

The prior USPSTF review included 10 studies that found an association between various intermediate outcomes (virological remission, biochemical remission, histological improvement, HBeAg loss, or a composite intermediate outcome) and clinical outcomes (death, hepatocellular carcinoma, or a composite clinical outcome). However, results were not statistically significant in all studies and variability in patient populations (e.g., HBeAg status and prevalence of cirrhosis at baseline, intermediate and clinical outcomes evaluated, and methodological limitations (including failure to control for key potential confounders: age, sex, fibrosis stage, HBV DNA level, and HBeAg status) made it difficult to draw strong conclusions. The prior USPSTF review included studies on the association between intermediate and clinical outcomes in which more than 30 percent of patients had cirrhosis at baseline;^138–141^ these studies were excluded for this update.

Nine studies (N=3,893) on the association between improvement in intermediate outcomes following antiviral therapy for chronic HBV infection and clinical outcomes were included for this update (Table 6 and Appendix B Tables 12–13). Six studies^111–116^ were included in the prior USPSTF report and three studies^117–119^ were added for this update. Sample sizes ranged from 63 to 1,531 patients, and duration of followup from 3.2 to 9.9 years. The studies varied in the intermediate outcomes that were evaluated. Four studies evaluated virological response (loss of HBV DNA or sustainability of HBV DNA loss),^111,116,117,119^ one study evaluated biochemical remission (normalization of serum transaminase levels),^115^ one study evaluated HBeAg clearance,^114^ one study evaluated HBeAg seroconversion,^118^ one study evaluated histological response (improvement in biopsy findings),^112^ and one study evaluated a composite intermediate outcome (virological response plus HBeAg clearance).^113^ The clinical outcomes also varied. One study evaluated death,^113^ four studies hepatocellular carcinoma,^116–119^ one study cirrhosis,^118^ and the remainder various composite clinical outcomes (2 or more of the following: death, liver transplantation, cirrhosis, or complications of cirrhosis).^111–115,117^ Four studies focused on HBeAg-positive patients, three studies focused on HBeAg-negative patients and the remainder included mixed populations of HBeAg-positive and negative. The antiviral treatment was lamivudine in one study, interferon in six studies, and entecavir in 2 studies. One study excluded patients with cirrhosis, and in the other studies, the proportion of patients with cirrhosis ranged from 8 to 27 percent.

Six studies were conducted in the United States or Europe and three studies were conducted in Asia. All studies were rated fair-quality (Appendix B Table 14). Methodological shortcomings included unclear blinding status of outcome assessors and failure to report loss to followup; some studies did not control for five key confounders (age, sex, fibrosis stage, HBV DNA level, HBeAg status) or it was unclear whether the adjustments were made for these specific analyses.^112,113,115,117–119^

As in the prior USPSTF review, the variability in patient populations (e.g., HBeAg status and prevalence of cirrhosis at baseline), intermediate and clinical outcomes evaluated, and methodological limitations makes it difficult to draw strong conclusions regarding the association between achieving intermediate outcomes after antiviral treatment and improvement in clinical outcomes (Table 6). However, across intermediate and clinical outcome comparisons, estimates of risk consistently favored achieving the intermediate outcomes, although results were not always statistically significant.

Table 6 Associations Between Intermediate Outcomes and Health Outcomes

Intermediate Outcomes | Health Outcomes
Intermediate Outcomes | Cirrhosis | Death | HCC | Composite Outcome
ALT normalization | - | - | - | 1 study; Death or liver transplantation aHR, 0.48 (95% CI, 0.23 to 1.0)^*^,^115^; Severe clinical complications (death, liver decompensation [ascites, variceal bleeding, hepatic encephalopathy], and HCC) aHR 0.53 (95% CI, 0.29 to 0.91)^*^,^115^
Composite intermediate outcome (Sustained loss of HBV DNA and clearance of HBeAg within 1 year of starting treatment)^113^ | - | 1 study; aHR, 0.59 (95% CI, 0.20 to 1.67)^113^ | - | 1 study; Death or liver-related complication (variceal hemorrhage, ascites, encephalopathy): aHR, 0.07 (95% CI, 0.02 to 0.33)^113^
HBeAg loss | - | - | - | 1 study; Liver complications (death; need for liver transplantation; development of ascites, jaundice, or hepatic encephalopathy; occurrence of or bleeding from esophageal varices): aHR, 0.06 (95% CI, 0.01 to 0.61)^114^
HBeAg seroconversion | 1 study; aHR 0.41 (95% CI, 0.32 to 0.88)^118^ | - | 1 study; aHR 0.13 (95% CI, 0.08 to 0.57)^118^ | -
Histological response | - | - | - | 1 study; Liver complications (HBV-related decompensated liver cirrhosis or HCC): aHR, 0.62 (95% CI, 0.06 to 6.9)^112^
Virological response | - | - | 3 studies; aHR, 0.77 (95% CI, 0.35 to 1.69)^*^,^116^; aHR 0.87 (95% CI, 0.17 to 4.58)^117^; aHR 0.3 (95% CI 0.1, to 0.6)^119^ | 2 studies; Death or disease complication (not defined): aHR, 0.24 (95% CI, 0.06 to 0.96)^*^,^111^; Clinical event (composite endpoint of development of HCC, liver decompensation, or death): aHR 0.70 (95% CI, 0.28 to 1.77)^117^

- = No studies examined the association.

* Study performed in HBeAg-negative patients.

Note: Studies examined association of achieving intermediate outcomes and decreased risk of health outcomes.

Abbreviations: aHR = adjusted hazard ratio; ALT = alanine aminotransferase; CI = confidence interval; DNA = deoxyribonucleic acid; HBeAg = hepatitis B e antigen; HBV = hepatitis B virus; HCC = hepatocellular carcinoma.

#### Mortality

One study (n=103) of HBeAg-positive patients with elevated AST and/or ALT found achieving a composite intermediate outcome (sustained HBV DNA loss and HBeAg clearance) with antiviral therapy associated with decreased risk of death (adjusted HR, 0.59; 95% CI, 0.20 to 1.67).^113^ The mean duration of followup was 6.2 years.

#### Hepatocellular Carcinoma

Four studies evaluated the association between achieving intermediate outcomes following antiviral therapy and risk of hepatocellular carcinoma.^116–119^ In three studies, the intermediate outcome was virological remission and in the fourth it was HBeAg seroconversion.

Studies suggest that achieving virological remission might reduce risk of hepatocellular carcinoma, but estimates varied and were not statistically significant in two of the three studies. One study (n=233) of HBeAg-positive patients found HBeAg seroconversion associated with decreased risk of hepatocellular carcinoma at a median duration of followup of 6.8 years (adjusted HR, 0.13, 95% CI 0.08 to 0.57).^118^ A study (n=744) of patients with chronic HBV infection (HBeAg status not reported) found a virological response (HBV DNA <80 IU/mL) associated with a slightly decreased risk of hepatocellular carcinoma that was not statistically significant (adjusted HR 0.87, 95% CI 0.17 to 4.58).^117^ The third study (n=818) of HBeAg-negative patients with elevated ALT or HBV DNA greater than 2000 IU/mL found virological remission (HBV DNA <200 IU/mL) associated with a reduction in risk of hepatocellular carcinoma that was not statistically significant at mean followup of 4.7 years (adjusted HR 0.77, 95% CI 0.35 to 1.69).^116^

One study (n=1,531) of patients with HBV infection (30% HBeAg-positive) found sustained (≥24 months) virological remission associated with decreased risk of hepatocellular carcinoma versus remission sustained for less than 24 months (adjusted HR 0.3, 95% CI 0.1 to 0.6).^119^ In this study, 31 percent of patients had received prior antiviral therapy; results were similar in the subgroup of treatment-naïve patients (adjusted HR 0.4, 95% CI 0.2 to 0.7).

#### Cirrhosis

One study (n=233) of HBeAg-positive patients found HBeAg seroconversion associated with decreased risk of cirrhosis (adjusted HR 0.41, 95% CI 0.32 to 0.88).^118^ The median duration of followup was 6.8 years.

#### Composite Clinical Outcomes

Six studies evaluated the association between various intermediate outcomes (virological response, ALT normalization, HBeAg loss, histological response, or a composite intermediate outcomes) and effects on composite clinical outcomes.^111–115,117^ Despite heterogeneity in patient populations and the intermediate and composite clinical outcomes evaluated, there was a consistent association between achieving the intermediate outcomes and decreased risk of the composite outcome, though some differences were not statistically significant.

Two studies evaluated the association between achieving a virological response and risk of a composite clinical outcome.^111,117^ One study (n=744) of patients with chronic HBV infection (HBeAg status not reported) found a virological response (HBV DNA <80 IU/mL) associated with decreased risk of a clinical event (hepatocellular carcinoma, liver decompensation, or death) that was not statistically significant at median followup of 3.2 years (adjusted HR 0.70, 95% CI 0.28 to 1.77).^117^ A small study (n=63) of HBeAg-negative patients with HBV infection found a virological response (HBV DNA <10,000 copies/mL) associated with decreased risk of a disease complication (not defined) at 6 years (adjusted HR 0.24, 95% CI 0.06 to 0.96).^111^

The other studies each looked at a different intermediate outcome. One study (n=89) of HBeAg-positive patients with HBV infection found a histological response (improvement of 2 points or more on the Histological Activity Index) following antiviral therapy associated with decreased risk of liver complications that was not statistically significant at median followup of 9.9 years (adjusted HR 0.62, 95% CI 0.06 to 6.9).^112^ A study (n=103) of HBeAg-positive patients with elevated AST and/or ALT found achieving a composite intermediate outcome (sustained HBV DNA loss and HBeAg clearance) associated with decreased risk of death or a liver-related complication (variceal hemorrhage, ascites, or encephalopathy) at median followup of 6.2 years (adjusted HR, 0.07; 95% CI, 0.02 to 0.33).^113^ A study (n=103) of HBeAg-positive patients with elevated ALT found HBeAg loss associated with decreased risk of liver complications (death, liver transplantation, decompensated cirrhosis, or esophageal varices) at mean followup of 4.2 years (adjusted HR 0.06, 95% CI 0.01 to 0.61).^114^ The fourth study (n=209) evaluated HBeAg-negative patients with elevated ALT; it found normalization of ALT associated with decreased risk of the composite outcomes of death or liver transplantation (adjusted HR 0.48, 95% CI 0.23 to 1.0) or severe clinical complications, defined as death, liver transplantation, liver decompensation, or hepatocellular carcinoma at mean followup of 6 years (adjusted HR 0.53, 95% CI 0.29 to 0.91).^115^

## Contextual Question 1 What Are the Effects of Different Risk- or Prevalence-Based Methods for Screening for HBV Infection in Modeling Studies?

Two studies modeled the incremental cost-effectiveness of alternative HBV screening strategies in U.S. settings.^143,144^ One study focused on screening in six higher-risk populations: foreign-born Asian/Pacific Islanders (based case HBV prevalence 7.9%), Africa-born black persons (9.7%), incarcerated persons (1.4%), refugees (6.3%), PWID (11.8%), and MSM (2.3%).^144^ In each population, three strategies were compared to no screening: 1) screen for HBV infection and treat infected persons (“treatment only”); 2) screen for HBV susceptibility and vaccinate susceptible (“vaccinate only”); and 3) screen for HBV infection and susceptibility and treat or vaccinate as appropriate (“inclusive”). The screening strategies were evaluated using a lifetime Markov model and assumed treatment with tenofovir (not specified if TDF or TAF, though both are preferred antivirals in HBV treatment guidelines).^145^ Across populations, the vaccinate-only strategy was associated with incremental cost-effectiveness ratios (ICERs) of less than $14,000 per quality-adjusted life year (QALY) gained or was dominant (less expensive and more effective), compared with no screening. The treatment only strategy was associated with ICERs of $17,000 to $26,000 per QALY gained, compared with the vaccinate only strategy. The inclusive strategy dominated (resulted in cost savings and health gains) the treatment only strategy in most populations. The exception was Asian/Pacific Islanders, in which the inclusive strategy was associated with an ICER of $18,378/QALY compared with treatment only. The inclusive strategy was also directly compared to no screening, with ICERs that ranged from $3,000 to $18,000 per QALY gained. In one-way sensitivity analyses, factors with the greatest impact on ICER estimates were age, discount rate, tenofovir cost, health state utilities, and rate of disease progression. However, in all populations, the ICER of the inclusive strategy remained less than $50,000 per QALY gained across all uncertainty ranges. In multivariate analyses, at a willingness-to-pay threshold of $50,000 per QALY gained, the inclusive strategy was cost-effective in 61 to 97 percent of simulations across all populations, and was usually the preferred strategy.

Another study modeled the cost-effectiveness of screening in a setting with an HBV infection prevalence of 2 percent.^143^ Screening strategies were compared with no screening in a Markov model, with differences in strategies according to the antiviral therapy used followed screening: 1) pegylated interferon alfa-2a, 2) low-cost nucleoside or nucleotide agent with a higher rate of developing viral resistance for 48 weeks, 3) prolonged treatment with low-cost, high-resistance nucleoside or nucleotide, or 4) prolonged treatment with a high-cost, low-resistance nucleoside or nucleotide. The strategy involving prolonged treatment with a low-cost, high-resistance nucleoside or nucleotide assumed use of salvage therapy with a high-cost, low-resistance nucleoside or nucleotide in persons who developed resistance. Versus no screening, this strategy was associated with an ICER of $29,232 per QALY gained; this strategy was associated with a lower ICER (versus no screening) than screening followed by treatment with the same regimen for 48 weeks and dominated strategies involving treatment with pegylated interferon or a high-cost, low-resistance nucleoside or nucleotide (the ICER for this strategy was $43,500/QALY versus no screening). In probabilistic sensitivity analysis, the low-cost, high-resistance nucleoside or nucleotide strategy was preferred 80 percent of the time and the high-cost, low-resistance nucleoside or nucleotide strategy was preferred 20 percent of the time. In deterministic sensitivity analysis, the ICER of the low-cost, high-resistance nucleoside or nucleotide strategy remained less than $50,000/QALY when the prevalence of HBV infection was as low as 0.3 percent (similar to the prevalence of HBV infection in the general U.S. population).

## Contextual Question 2 What Is the Accuracy of Tools for Identifying Persons With Chronic HBV Infection?

No study evaluated the accuracy of tools for identifying persons with chronic HBV infection. Although the CDC has developed a “Hepatitis Risk Assessment Tool,” it has not undergone formal validation. The tool was designed as a self-administered tool to help individuals determine whether they should be vaccinated or tested for viral hepatitis, according to CDC criteria (Appendix C Table 1).^146,147^

## Contextual Question 3 In Persons With Serologic Evidence of HBV Infection (HBsAg-Positive/Anti-HBc-Positive or HBsAg-Negative/Anti-HBc-Positive), What Is the Likelihood of Reactivation Following Exposure to Immunosuppressant Therapy, and What Is the Effectiveness of Interventions to Improve Clinical Outcomes Associated With Reactivation?

Screening could identify persons with serologic evidence of HBV infection (HBsAg-positive/anti-HBc-positive or HBsAg-negative/anti-HBc-positive) who might benefit from interventions to prevent or treat HBV reactivation when receiving immunosuppressant drugs. HBV reactivation has primarily been described in persons with chronic conditions such as cancer or an autoimmune disorder. Management of such conditions, including assessment of HBV status,^8,148^ is generally considered outside the scope of the USPSTF. Of more relevance to screening is the prevalence of reactivation among persons without conditions warranting HBV screening who receive immunosuppressant therapy for acute conditions (e.g., gout, asthma) in primary care settings. We identified no study on the likelihood of HBV reactivation in anti-HBc-positive patients exposed to immunosuppressant therapy in primary care settings or among patients exposed to immunosuppressant therapy for treatment of an acute medical condition.

In persons with chronic conditions, the major factors affecting risk of reactivation are the patient’s HBsAg status and the type of immunosuppressant drugs used. A systematic review commissioned by the American Gastroenterological Association summarized the evidence on risk of reactivation for different immunosuppressant drugs in anti-HBc-positive patients (Appendix C Table 2).^149^ Risk was classified as high (>10%), moderate (1% to 10%), and low (<1%). High risk scenarios were HBsAg-positive or -negative persons who received B cell-depleting agents (e.g., rituximab and ofatumumab) and HBsAg-positive patients who received anthracycline derivatives (e.g., doxorubicin and epirubicin) or moderate/high dose corticosteroid therapy for ≥4 weeks. Moderate risk scenarios were HBsAg-positive or -negative persons who received tumor necrosis factor-alpha inhibitors (e.g., etanercept, adalumumab, certolizumab, or infliximab), other cytokine inhibitors and integrin inhibitors (e.g., abatacept, ustekinumab, natalizumab, or vedolizumab), or tyrosine kinase inhibitors (e.g., imatinib, nilotinib); other moderate risk scenarios were low-dose corticosteroid therapy for ≥4 weeks in HBsAg-positive persons or moderate/dose corticosteroid therapy for ≥4 weeks in HBsAg-negative persons. Low risk scenarios were use of traditional immunosuppressive agents (e.g., azathioprine, 6-mercaptupurine, or methotrexate), intra-articular corticosteroids, corticosteroid therapy for ≤1 week, or low-dose corticosteroid therapy for ≥4 weeks in HBsAg-negative persons.

In persons at higher risk for reactivation due to receipt of immunosuppressant therapy, prophylactic antiviral therapy appears to be effective for reducing risk. The systematic review found antiviral treatment in anti-HBc-positive patients associated with decreased of HBV reactivation (five trials, RR 0.13, 95% CI 0.06 to 0.30, I^2^=0%) and HBV hepatitis flare (five trials, RR 0.16, 95% CI 0.06 to 0.42, I^2^=0%) versus no prophylaxis.^149^ Four trials in the meta-analysis evaluated lamivudine and one trial evaluated entecavir.

HBV reactivation also occurs in persons with HCV co-infection treated with direct acting antiviral (DAA) therapy, with risk varying according to HBsAg status. A recent systematic review of 17 studies found the proportion who experienced HBV reactivation with DAA therapy was 24 percent (95% CI 19 to 30%) among HBsAg-positive/anti-HBc-positive patients and 1.4 percent (95% CI 0.8 to 2.4%) among HBsAg-negative/anti-HBc-positive patients.^29^ Rates of HBV reactivation related hepatitis were 9 percent (95% CI 5% to 16%) and 0.5 percent (95% CI 0.0% to 1.2%), respectively.