# Chapter 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^71^ the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for this review. Investigators created an analytic framework with the key questions and the patient populations, interventions, and outcomes reviewed (Figure 1).

Figure 1 Analytic Framework and Key Questions

The analytic framework depicts the relationship between the populations, interventions, outcomes, and harms of screening for HBV infection. The far left of the framework describes the target population as asymptomatic, non-pregnant adolescents and adults. To the right of the population is an arrow that represents HBV screening. This arrow represents the yield and sensitivity of alternative HBV screening strategies (key question 3) and a subsequent arrow indicates assessment of harms of screening (key question 2). The screening arrow also leads to populations that fall into one of the four following categories: chronic HBV infection, evidence of HBV immunity, isolated anti-HBc positive, or never exposed to HBV, and footnotes define these categories in more detail. An arrow to the right of the chronic HBV infection population leads to the provision of education or behavior change counseling, and another arrow leads to provision of antiviral medications. To the right of antiviral medications, one arrow leads to intermediate outcomes of virologic improvement, histologic improvement, clearance of HBeAg (acquisition of anti-HBe), and clearance of HBsAg clearance (acquisition of anti-HBs) (key question 4), and a second arrow leads to clinical health outcomes, including mortality, cirrhosis, extrahepatic manifestations of HBV, hepatocellular cancer, quality of life, and disease transmission (key question 5). A third arrow to the right of antiviral medications indicates assessment of harms associated with antiviral treatment for HBV infection (key question 6). A dotted line represents the examination of the association between improvements in intermediate outcomes as a result of antiviral treatment for chronic HBV infection and reduction in risk of HBV-related adverse health outcomes (key question 7). To the right of the population with evidence of HBV immunity, an arrow leads to education or behavior change counseling interventions. To the right of the isolated anti-HBc positive population, arrows lead to education or behavior change counseling and vaccination interventions. To the right of the never exposed to HBV population, an arrow leads to vaccination intervention. To the right of the education or behavior change counseling and vaccination interventions, an arrow leads to clinical health outcomes. An overarching arrow that extends from the screened population of asymptomatic, non-pregnant adults and adolescents to the clinical health outcomes symbolizes key question 1 about the direct benefits of screening on clinical health outcomes.

Analytic Framework

Note: “Screening” is defined as testing for anti-HBs and HBsAg, with or without testing for anti-HBc.

* “Chronic HBV infection” is defined by a positive HBsAg test result. Chronic HBV infection should be staged by assessment for hepatitis fibrosis/inflammation, HBV viral load, HBeAg status, anti-HBe status, and liver function tests. Appropriate interventions depend on disease stage.

^†^ “Evidence of HBV immunity” is defined as positive anti-HBs, negative HBsAg, and positive (cleared infection) or negative (seroprotection due to vaccination) anti-HBc test results. Patients who have positive anti-HBc test results may benefit from education regarding risk of reactivation.

^‡^ “Isolated anti-HBc positive” is defined as positive anti-HBc test results but negative anti-HBs and HBsAg test results and indicates prior HBV exposure or false positive test. Patients who have positive isolated anti-HBc test results may benefit from education regarding risk of reactivation and if immunocompromised, HBV DNA testing. HBV vaccination is recommended for patients with positive isolated anti-HBc test results who are from countries with low prevalence of HBV infection (such as the United States) or who are immunocompromised.

^§^ “Never exposed to HBV” is defined as negative anti-HBs, anti-HBc, and HBsAg test results.

Abbreviations: anti-HBc = antibody to the hepatitis B core antigen; anti-HBe = antibody to the hepatitis B e antigen; anti-HBs = hepatitis B surface antibody; HBeAg = hepatitis B e-antigen; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; KQ = key question.

Key Questions

1. What are the benefits of screening for hepatitis B virus (HBV) infection in asymptomatic, nonpregnant adolescents and adults on morbidity, mortality, and disease transmission?
2. What are the harms of screening for HBV infection in asymptomatic, nonpregnant adolescents and adults (e.g., labeling or anxiety)?
3. What is the yield (number of new diagnoses per tests performed) and sensitivity of alternative HBV screening strategies (e.g., universal vs. targeted screening or screening strategies based on alternative risk factors)?
4. How effective is antiviral treatment in improving intermediate outcomes among nonpregnant adolescents and adults with chronic HBV infection, including virologic or histologic improvement, clearance of hepatitis B e-antigen (HBeAg) (as indicated by loss of HBeAg or acquisition of the antibody to HBeAg [anti-HBe]), or clearance of hepatitis B surface antigen (HBsAg) (as indicated by loss of HBsAg or acquisition of hepatitis B surface antibody [anti-HBs])?^*^
  * Subpopulations of interest for key questions 4, 5, and 6 include those defined by age, race/ethnicity, sex, injection drug use status, HBV genotype, HBeAg status, fibrosis stage, alanine transaminase level, presence of nonalcoholic steatohepatitis, HBV deoxyribonucleic acid (DNA) level, and hepatitis D virus status.
5. How effective is antiviral treatment in improving health outcomes among nonpregnant adolescents and adults with chronic HBV infection?^*^
6. What are the harms associated with antiviral treatment in nonpregnant adolescents and adults with chronic HBV infection?^*^
7. What is the association between improvements in intermediate outcomes as a result of antiviral treatment of chronic HBV infection and reduction in risk of HBV-related adverse health outcomes?

### Key Questions

1. What are the benefits of screening for HBV infection in asymptomatic, nonpregnant adolescents and adults on morbidity, mortality, and disease transmission?
2. What are the harms of screening for HBV infection in asymptomatic, nonpregnant adolescents and adults (e.g., labeling or anxiety)?
3. What is the yield (number of new diagnoses per tests performed) and sensitivity of alternative HBV screening strategies (e.g., universal vs. targeted screening or screening strategies based on alternative risk factors)?
4. How effective is antiviral treatment in improving intermediate outcomes among nonpregnant adolescents and adults with chronic HBV infection, including virologic or histologic improvement, clearance of HBeAg (as indicated by loss of HBeAg or acquisition of anti-HBe), or clearance of HBsAg (as indicated by loss of HBsAg or acquisition of anti-HBs)?^*^
5. How effective is antiviral treatment in improving health outcomes among nonpregnant adolescents and adults with chronic HBV infection?^*^
6. What are the harms associated with antiviral treatment in nonpregnant adolescents and adults with chronic HBV infection?^*^
7. What is the association between improvements in intermediate outcomes as a result of antiviral treatment of chronic HBV infection and reduction in risk of HBV-related adverse health outcomes?

* Subpopulations of interest for key questions 4, 5, and 6 include those defined by age, race/ethnicity, sex, injection drug use status, HBV genotype, HBeAg status, fibrosis stage, alanine transaminase level, presence of nonalcoholic steatohepatitis, HBV DNA level, and hepatitis D virus status.

### Contextual Questions

Contextual Question were also requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology:

1. What are the effects of different risk- or prevalence-based methods for screening for HBV infection in modeling studies?
2. What is the accuracy of tools for identifying persons with chronic HBV infection?
3. In persons with serologic evidence of HBV infection (positive test results for anti-HBc or for HBsAg), what is the likelihood of reactivation following exposure to immunosuppressant therapy, and what is the effectiveness of interventions to improve clinical outcomes associated with reactivation?

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews and Ovid MEDLINE (2014 to August 2019), and clinicaltrials.gov for relevant studies and systematic reviews. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles; studies from the prior USPSTF review^3,72^ meeting inclusion criteria were carried forward. Ongoing surveillance was conducted to identify major studies published since August 2019 that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on July 24, 2020 and identified no studies affecting review conclusions.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies on the basis of prespecified inclusion and exclusion criteria developed for each key question (Appendix A2). For Key Questions on screening, randomized trials and cohort studies on benefits or harms of screening versus no screening or on the yield (sensitivity and number needed to screen to identify one HBV-infected person) were included. We also included cross-sectional studies on the yield of screening. For Key Questions related to treatment, randomized trials of patients that compared monotherapy with an FDA-approved medication versus placebo or no treatment and reported clinical outcomes (including mortality, cirrhosis, hepatocellular cancer, quality of life, HBV transmission, extrahepatic outcomes, or harms) or intermediate outcomes (virologic improvement, histologic improvement, biochemical improvement [improvement in alanine aminotransferase levels], HBeAg clearance [loss of HBeAg or acquisition of anti-HBe], or HBsAg clearance [loss of HBsAg or acquisition of anti-HBs]) were included. FDA-approved antiviral therapies classified as either preferred/first-line or nonpreferred in recent HBV guidelines were included (Table 3).^8,49^ Preferred antiviral therapies are entecavir, TDF, TAF, pegylated interferon (adults), and nonpegylated interferon (children); nonpreferred therapies are adefovir, lamivudine, and telbivudine. Because few placebo controlled trials evaluated preferred antiviral therapies, we also included randomized trials of preferred versus nonpreferred therapies. Studies of treatment were excluded if they evaluated non–FDA-approved or combination therapies. In adults, nonpegylated interferon has been supplanted by pegylated interferon and is no longer available in the United States; however, we included trials of nonpegylated interferon because evidence from placebo-controlled and head-to-head trials of pegylated interferon was sparse. Long-term (≥1 year), large (n>1,000) cohort studies of antiviral treatment versus no treatment that reported clinical outcomes and controlled for potential confounders were also included. We also included cohort studies that reported adjusted risk estimates for the association between achieving an intermediate outcome following antiviral treatment (e.g., clearance of HBeAg or HBV DNA from serum, normalization of serum transaminases, histological improvement, or a composite intermediate outcome) and long-term clinical outcomes (mortality, hepatocellular carcinoma, or cirrhosis). In order to increase the applicability of the evidence to populations likely to be identified by screening, we excluded trials of antiviral therapy in which greater than 20 percent of the population was treatment experienced (nonresponders to prior antiviral therapy or patients with virological relapse) or had cirrhosis at baseline. For cohort studies, we permitted studies in which up to 30 percent of patients had cirrhosis, if fibrosis stage was controlled for in the analysis. We excluded studies of patients with HIV or HCV coinfection, patients on hemodialysis, and transplant patients; management of these conditions is considered outside the scope of screening by the USPSTF.

Table 3 HBV Treatment Recommendations From the AASLD

Category | Drug | Dose in Adults^*^ | Use in Children^*^
Preferred | Peg-IFN-α-2a (adult); IFN-a-2b (children) | 180 mcg weekly | ≥1 year dose: 6 million IU/m^2^ 3 times weekly^†^
Preferred | Entecavir | 0.5 mg daily | ≥2 years dose: weight-based to 10 to 30 kg; above 30 kg: 0.5 mg daily^‡^
Preferred | Tenofovir dipovoxil fumarate | 300 mg daily | ≥12 years
Preferred | Tenofovir alafenamide | 25 mg daily | -
Nonpreferred | Lamivudine | 100 mg daily | ≥2 years dose: 3 mg/kg daily to max 100 mg
Nonpreferred | Adefovir | 10 mg daily | ≥12 years
Nonpreferred | Telbivudine | 600 mg daily | -

Source: American Association for the Study of Liver Diseases.^8^

* Dose adjustments are needed in patients with renal dysfunction.

† Peg-IFN-α-2a is not approved for children with chronic HBV, but is approved for treatment of chronic hepatitis C. Providers may consider using this drug for children with chronic HBV. The duration of treatment indicated in adults is 48 weeks.

‡ Entecavir dose is 1 mg daily if the patient is lamivudine experienced or if they have decompensated cirrhosis.

Abbreviations: AASLD = American Association for the Study of Liver Diseases; HBV = hepatitis B virus; IFN = interferon.

For Key Questions related to screening, inclusion was restricted to the United States and other low prevalence settings in which the epidemiology and management of HBV infection are similar to those in the United States. For treatment, studies from any country were eligible for inclusion.

The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists the included studies, and Appendix A5 lists the excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

For studies meeting inclusion criteria, we created data abstraction forms to summarize characteristics of study populations, interventions, comparators, outcomes study designs, settings, and methods. One investigator conducted data abstraction, which was reviewed for completeness and accuracy by another team member. Predefined criteria were used to assess the quality of individual controlled trials and observational studies by using criteria developed by the USPSTF; studies were rated as “good,” “fair,” or “poor” per USPSTF criteria, depending on the seriousness of the methodological shortcomings (Appendix A6).^71^ For each study, quality assessment was performed by two team members. Disagreements were resolved by consensus.

## Data Synthesis

To summarize evidence on effects of antiviral therapy versus placebo and preferred versus nonpreferred antiviral therapies, meta-analysis was conducted on intermediate outcomes (HBeAg loss, HBeAg seroconversion, HBsAg loss, HBsAg seroconversion, HBV DNA loss [virological suppression], ALT normalization, histological improvement, and composite outcomes [HBeAg loss plus HBV DNA loss, or HBV DNA loss plus ALT normalization]), clinical outcomes (mortality, cirrhosis, hepatocellular carcinoma), and harms (serious adverse events, withdrawal due to adverse events, any adverse events, gastrointestinal adverse events, and kidney adverse events) using a random effects (profile likelihood) model in Stata/IC 14.2 (StataCorp LP, College Station, TX). When the profile likelihood model did not converge, the Dersimonian-Laird model was used instead. For placebo-controlled trials, data from all antiviral drugs were pooled, though analyses were stratified by individual drug. For head-to-head comparisons, each drug-drug comparison was pooled separately. Stratified analyses were conducted based on study quality, geographic setting (low prevalence, high prevalence, or mixed/other), duration of followup (<52 weeks versus ≥52 weeks), HBeAg status, immune tolerant (based on high HBV DNA level, normal or minimally elevated AST level, and minimal or no histological activity) or immune active status, and cirrhosis (excluded or included some [up to 20% of sample] with baseline cirrhosis) when there were at least five trials, and a test for subgroup differences (interaction) performed. Statistical heterogeneity was assessed using the I^2^ statistic. Graphical and statistical tests for small sample effects were not conducted due to fewer than 10 trials for most analyses and clinical heterogeneity (due to differences in the drugs evaluated and populations [e.g., HBeAg status]) in analyses with more than 10 trials.^73^

For all Key Questions, the overall quality of evidence was determined using the approach described in the USPSTF Procedure Manual.^71^ Evidence was rated “good”, “fair”, or “poor” based on study quality, consistency of results between studies, precision of estimates, risk of reporting bias, applicability, and other study limitations.^71^ A summary of evidence table was developed to assess the overall quality of evidence for each Key Question using the approach described in the USPSTF Procedure Manual.^71^

## Expert Review and Public Comment

The draft Research Plan was posted for comment on the USPSTF Web site from November 29, 2018 through January 2, 2019. In response to public comments, the USPSTF revised the Research Plan by adding extrahepatic manifestations as a health outcome, removing harms of liver biopsies as a key question, and adding cohort studies of treatment versus no treatment for long-term clinical outcomes.

A draft version of this report was reviewed by content experts (Appendix A7), representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report. Reviewers suggested edits for clarity; some publications were suggested but did not meet inclusion criteria. The draft report was also posted for public comment from 5/5/20 to 6/1/20 and one person responded. In response, to the Recommendations of Other Groups section, we revised the text to include details about the 2008 CDC hepatitis B screening recommendations. No other changes were necessary.