# Chapter 1 Introduction and Background

## Purpose

This systematic review update will be used by the United States Preventive Services Task Force (USPSTF) to update its recommendation from 2014^1,2^ on screening for hepatitis B virus (HBV) infection in nonpregnant adolescents and adults.^3,4^ In 2014, the USPSTF recommended screening for HBV infection in persons at high risk for infection (B recommendation). The USPSTF recommendation noted an HBV prevalence of two percent or greater as a reasonable threshold for deciding to screen; this includes persons born in countries and regions with a prevalence of HBV infection of two percent or greater, U.S.-born persons not vaccinated as infants whose parents were born in regions with a HBV prevalence of eight percent or greater, HIV-positive persons, persons who inject drugs, men who have sex with men, and household contacts or sexual partners of persons with HBV infection.

## Condition Background

### Condition Definition

HBV is a double-stranded deoxyribonucleic acid (DNA) virus enclosed in a nucleocapsid protein (hepatitis B core antigen [HBcAg]) surrounded by an envelope protein (hepatitis B surface antigen [HBsAg]).^5^ Serologic markers are usually the initial tests used to determine HBV infection status (Table 1); subsequent tests in persons with markers indicating active infection are performed to determine the presence and level of circulating HBV DNA (viral load). Acute HBV infection (within 6 months after infection) is typically characterized by the initial appearance of HBsAg with HBV e antigen (HBeAg) and HBV DNA; immunoglobulin M (IgM) antibody to the HBV core antigen (anti-HBc) appears soon after infection, evolving to anti-HBc immunoglobulin G (IgG).^6,7^ Chronic infection is characterized by the persistent presence of HBsAg for longer than 6 months.^6–8^ The presence of HBeAg is usually associated with high levels of HBV DNA in serum and high infectivity.^9,10^ Resolution of HBV infection and disease inactivity are typically characterized by the disappearance of HBsAg and appearance of antibody to HBV surface antigen (anti-HBs). Inactive chronic HBV infection, characterized by the disappearance of HBeAg and appearance of antibody to HBeAg (anti-HBe), eventually occurs in most patients with chronic HBV infection, usually correlating with low levels of HBV DNA in serum and remission of liver inflammatory activity. Reactivation of HBV, or a flare in HBV activity in persons, can occur in persons with serological evidence of inactive or resolved (positive for anti-HBc, but negative for HBsAg) HBV infection.^11^

Table 1 Interpretation of Screening Tests for HBV Infection

Screening Test Results | | | Interpretation | Management | Vaccinate?
HBsAg | Anti-HBc | Anti-HBs | Interpretation | Management | Vaccinate?
+ | + | - | Chronic HBV infection | Additional testing and management needed | No
- | + | + | Past HBV infection, resolved | No further management unless immunocompromised or undergoing chemotherapy or immunosuppressive therapy | No
- | + | - | Past HBV infection, resolved or false-positive (“isolated anti-HBc”^*^) | HBV DNA testing if immunocompromised patient | Yes, if not from area of intermediate or high endemicity
- | - | + | Immune due to HBV vaccination | No further testing | No
- | - | - | Uninfected and not immune | No further testing | Yes

Source: American Association for the Study of Liver Diseases 2018.^8^

* May be seen in persons with HIV infection coinfected with hepatitis C virus infection.^167^

Abbreviations: anti-HBc = antibody to hepatitis B core antigen; anti-HBs = antibody to HBsAg; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus.

### Prevalence and Burden of Disease/Illness

The incidence of acute symptomatic HBV infections in the United States reported to the Centers for Disease Control and Prevention (CDC)^12^ fell from over 20,000 cases annually in the mid-1980s to 2,791 cases in 2014, with an increase to 3,409 in 2017.^12^ Due to underreporting, the actual number of cases is estimated to be 6.5 times higher than the number of reported cases.^12^ From 2001 to 2010, the incidence of acute HBV infection declined among all age groups.^12^ The highest incidence of acute HBV infections is among persons 40 to 49 years of age (2.5 cases/100,000 population in 2017), followed by persons 30 to 39 years of age; the rate of acute HBV infection is higher in men than women.^12^ Since 2010, a rise in acute and chronic HBV infection related to drug use has been reported in several states.^13–15^

As of 2012, the overall prevalence of chronic HBV infection in the United States is about 0.3 percent.^16^ In 2011 and 2012, an estimated 847,000 people in the United States were chronically infected with HBV.^12,16^ Universal infant vaccination, instituted in 1991, has reduced the incidence and prevalence of chronic HBV infection. The number of persons with serological evidence of vaccine protection from HBV rose from 57.8 million in 1999 to 68.5 million in 2011 to 2012.^16^ The prevalence of HBV infection in persons 6 to 19 years of age was 0.03 percent, compared with 0.4 percent among persons 20 to 49 years of age and 0.3 percent among persons ≥50 years of age. Effects of vaccination on the overall prevalence of chronic HBV infection have been offset by immigration from places where chronic HBV is endemic, such as Asia and Africa.^16^ Foreign-born persons are estimated to account for approximately 95 percent of newly reported chronic HBV infections in the United States and have an estimated HBV prevalence of approximately 3.5 percent.^17,18^ About half of prevalent U.S. cases of chronic infection are in non-Hispanic persons of Asian descent, a group representing 5 to 6 percent of the U.S. population.^19^ In the National Health and Nutrition Examination Survey, the prevalence of chronic HBV infection in non-Hispanic persons of Asian descent was 3.1 percent in 2011 to 2012, or 10 times higher than in the general population.^16^ The prevalence was 0.1 percent in non-Hispanic white persons, 0.6 percent in non-Hispanic black persons, and 0.06 percent in Mexican American persons. In 2017, there were an estimated 1,727 deaths associated with HBV infection (0.46 per 100,000 persons); death rates were higher in persons age 75 years and older compared to other age groups, persons of Asian/Pacific Islander race compared to other races/ethnicities, and males compared to females.^12^

### Etiology and Natural History

HBV is spread through percutaneous or mucous membrane exposure to blood or blood-containing body fluids (serum, semen, or saliva), including sexual contact and injection drug use; horizontal transmission of HBV also occurs among close household contacts.^6,10,20^ HBV infection can be transmitted from mother to infant during birth (perinatal transmission); the USPSTF addresses perinatal HBV screening in a separate review.^21^ The liver is the primary site of HBV replication. Acutely infected individuals may be asymptomatic or present with symptoms of acute infection, such as nausea, anorexia, fatigue, low-grade fever, and abdominal pain.^5^ Jaundice may also be present, and elevated liver enzymes (e.g., alanine aminotransferase [ALT] and aspartate aminotransferase [AST]) can be seen on standard assays.

If symptoms of acute disease occur, they can take from 6 weeks to 6 months to appear.^22^ Acute infection generally self-resolves in 2 to 4 months, although mortality in this phase is about 1 percent. The risk of progression from acute to chronic infection varies according to age at the time of exposure. Risk of chronic infection is more than 90 percent in infants, 30 percent in children age 1 to 5 years, and less than 5 percent in those older than age 5 years.^10,22^ Chronic infection spontaneously resolves in 1 percent of individuals annually.^8^ Some chronically infected individuals are asymptomatic, although others experience a range of symptoms, including nonspecific symptoms of fatigue or other symptoms related to hepatitis, cirrhosis, or hepatocellular carcinoma.^22^ Extrahepatic manifestations of HBV infection include polyarteritis nodosa, membranous nephropathy, and membranoproliferative glomerulonephritis. Chronic HBV infection is characterized by several phases: 1) immune tolerant, characterized by the presence of HBeAg and very high levels of HBV DNA but normal ALT and minimal hepatic inflammation and fibrosis; 2) immune active, characterized by high levels of HBV DNA, ALT elevation, and moderate to severe hepatic inflammation; HBeAg can be present or absent (positive anti-HBe); and 3) inactive, characterized by the absence of HBeAg and presence of anti-HBe, low or undetectable levels of HBV viremia, normal ALT, and minimal hepatic inflammation.^8^ The immune tolerant phase has been considered a period of minimal or no disease progression, though recent studies indicate that histological activity and increased risk of hepatocellular carcinoma may occur.^23^ Fibrosis progression primarily occurs during the immune active phase; however, the presence and severity of fibrosis in the immune active and inactive phases is variable, as patients can transition between these phases. Although the course of chronic HBV infection varies widely, potential long-term sequelae include cirrhosis, hepatic decompensation, and hepatocellular carcinoma.^24^ Death from cirrhosis or hepatocellular carcinoma is thought to occur in 15 to 25 percent of those chronically infected with HBV. Increased viral load is associated with greater risk of cirrhosis, hepatocellular carcinoma, and liver-related mortality.^25,26^ Reactivation of HBV, or the abrupt increase in HBV activity in persons with inactive or resolved HBV, can also occur.^11^ Reactivation may be spontaneous, but is more commonly associated with use of immunosuppressive agents; reactivation can also occur in patients receiving direct-acting antiviral therapy for hepatitis C virus (HCV) infection.^27–29^ Clinically, the severity of reactivation ranges from mild to severe, fulminant or even fatal hepatitis. Chronically infected persons are a reservoir for person-to-person transmission of HBV infection. Presence of hepatitis D virus coinfection can impact the clinical course of HBV infection and inform treatment choices.^8^

### Risk Factors

People born in countries with an HBV prevalence of 2 percent or greater account for 47 to 95 percent of the chronically infected population in the United States, although marked decreases in prevalence have been seen among younger persons born in these countries due to universal immunization programs.^17,18,30,31^ In 2015, the prevalence of HBV infection was highest in Africa (6.1%) and in the Western Pacific region (6.2% in countries including China, the Philippines, and Vietnam), and lowest in Europe (1.6%) and the Americas (0.7%).^31^ Persons at higher risk for acute HBV infection in the United States include men, those age 30 to 49 years, and in recent years, non-Hispanic white persons.^12^ Risk factors for HBV infection include working in healthcare, having household contacts or sex partners with HBV infection (prevalence of chronic infection, 3% to 20%), HCV-positive status (1.3% to 5.8%), male sexual activity with other males (1.1% to 2.3%), injection drug use (2.7% to 11%), and HIV-positive status (6% to 15%).^10,12,22,32–37^ Settings with high proportions of persons at risk for HBV infection include sexually transmitted infection clinics, HIV testing and treatment centers, health care settings that target services toward persons who inject drugs (PWID) and men who have sex with men (MSM), correctional facilities, hemodialysis facilities, and institutions and nonresidential daycare centers for developmentally disabled persons.^6^

### Rationale for Screening/Screening Strategies

Identification of asymptomatic persons with chronic HBV infection through screening may identify those who would benefit from earlier evaluation and management of their disease. In 2016, an estimated 90 percent of HBsAg-positive individuals globally remained undiagnosed.^38^ In the United States, estimates of the proportion of persons with HBV infection unaware of their infection status range from one-third to two-thirds.^22^ Identification of asymptomatic chronic HBV infection could also lead to reductions in behaviors associated with more rapid progression of liver disease or interventions to decrease transmission of HBV, and identify close contacts who might also benefit from testing.^38–40^ Screening could also identify persons with evidence of HBV exposure (positive anti-HBc) who could benefit from education regarding risk of reactivation, and those who could benefit from HBV vaccination (e.g., those never exposed to HBV or those who are isolated anti-HBc positive and immunocompromised).

### Interventions/Treatment

#### Vaccination

Screening could identify persons without prior evidence of HBV exposure (anti-HBs and anti-HBc negative), who could benefit from vaccination to protect against future infection. In persons with isolated anti-HBc positivity, vaccination is recommended in persons from low endemicity areas or those who are immunocompromised.^8^ In the United States, current policies are for universal vaccination of all infants at birth, catch-up vaccination of adolescents, and vaccination of high-risk adults.^41^ In persons not at increased risk of HBV infection, HBV serologic testing prior to vaccination is not required. HBV vaccines in the United States contain between 10 to 40 micrograms of HBsAg protein/mL for adolescents and adults, and before 2017 involved at least three intramuscular doses administered at 0, 1, and 6 months.^6,10^ Vaccination with the three dose vaccine results in greater than 90 percent protective antibody response after the third dose in adults and greater than 95 percent in adolescents, although protective anti-HBs titers may be attained in some persons after one or two doses.^6,10^ By the end of 2017, 187 countries had introduced nationwide HBV vaccine for infants, with 105 countries targeting vaccination of all newborns.^42^ In 2015, global coverage with the third infant dose of HBV vaccine reached 84 percent, and prevalence of chronic infection in children under 5 years of age dropped to 1.3 percent, compared with about 4.7 percent before vaccination programs began.^31,43^ In November 2017, the U.S. Food and Drug Administration (FDA) approved a two-dose HBV vaccine^44^ for use in adults based on three trials showing comparable serologic outcomes to three-dose vaccines through up to 28 weeks.^45^ Studies of the two-dose vaccine were not designed to assess effects on risk of HBV acquisition, though vaccine-induced seroprotection is considered a surrogate of clinical protection.^46^

#### Treatment

Drugs for HBV infection are broadly categorized as interferons or nucleoside/nucleotide analogs.^8,30,47,48^ The interferons affect viral replication as well as immune modulation.^8,9^ Nucleoside/nucleotide analogues (lamivudine, adefovir, entecavir, and others) compete with binding sites on the HBV reverse transcriptase. As of October 2017, seven antiviral drugs had been approved by the FDA for treatment of chronic HBV infection: interferon alfa-2b, pegylated interferon alfa-2a, lamivudine, adefovir, entecavir, telbivudine, tenofovir disoproxil fumarate (TDF); and the most recently approved medication (in 2016), tenofovir alafenamide (TAF).^49,50^ TAF is a prodrug of tenofovir with improved kidney and bone safety parameters compared with TDF. The American Association for the Study of Liver Diseases (AASLD) recommends pegylated interferon, entecavir, and TDF as preferred initial therapy for immune-active chronic HBV;^8^ TAF was recently added to the preferred list.^8^ Telbivudine is no longer manufactured in the United States, though it is available in other countries.

Cure rates with current antiviral therapies are low,^51^ and other therapies have been studied, but remain investigational.^52^ A number of combination therapies have also been evaluated but are not FDA approved and not recommended as first-line treatment due to unclear advantages over monotherapy in most patients, particularly in those at low risk for developing drug resistance.^8^ The choice of antiviral medication varies according to patient characteristics and disease activity. Factors that affect the decision to treat include the HBV DNA level, serum transaminase levels, and HBeAg status.^8^ Biopsy may be performed in some patients to establish the degree of liver inflammation and fibrosis, which also affect treatment, surveillance and hepatocellular carcinoma screening decision-making.^8^ Noninvasive alternatives to biopsy for assessing degree of hepatic fibrosis include imaging with transient elastography and various blood tests.^53–56^ The goal of treatment is to achieve sustained suppression of HBV replication and remission of liver disease in order to prevent cirrhosis, hepatic failure, and hepatocellular carcinoma.^30,47^ The recommended duration of treatment varies depending on the HBeAg status, presence of cirrhosis, duration of HBV DNA suppression, and choice of medication.^8,22^ Many patients remain on antiviral treatment indefinitely, with the exception of interferon-based therapy, which is usually recommended for a defined duration of treatment, in part due to limited tolerability and immunomodulatory effects of interferons which may result in a sustained response.^8^ Other treatments in patients with chronic HBV infection could include counseling or education to potentially reduce behaviors associated with accelerated progression of liver disease (such as alcohol use) or transmission, or surveillance with imaging tests to identify hepatocellular carcinoma,^8^ though the effectiveness of such surveillance on improving clinical outcomes is uncertain.^57^ Low rates of linkage and retention in treatment and use of antiviral therapy are barriers to optimal care of persons with HBV infection.^58^

### Current Clinical Practice/Recommendations of Other Groups

Screening for HBV infection is usually performed by testing for HBsAg and anti-HBs.^8^ Testing for anti-HBc is not routinely recommended by AASLD^8^ but is recommended by the American College of Physicians (ACP)/CDC;^59^ it indicates prior HBV exposure status (anti-HBc does not develop after vaccination) and can help determine a patient’s risk for reactivation (e.g., in persons being considered for HCV therapy or immunosuppressive treatment). New rapid tests for HBsAg have recently been developed, but no rapid test has been approved by the FDA.^60–63^ The CDC recommends that FDA-approved tests be used to screen for HBsAg and a confirmatory test performed for initially reactive results.^22^ In persons with serologic findings suggesting chronic infection, followup includes quantitative testing for HBV viremia, presence of HBeAg, and liver transaminase levels. Current U.S. screening practices for HBV and rates of HBV testing are largely unreported. One study of over one million Americans with access to private health care found that about 20 percent were tested for HBV over a median of more than 7 years and 1.4 percent tested positive for HBV infection.^64^ Based on national HBV prevalence data, it was estimated that 20 to 50 percent of expected HBV infections were not identified in this cohort. Guidelines generally recommend that screening be targeted to populations and persons at increased risk for chronic HBV infection, including persons born in high-prevalence countries.^8,59^ However, some studies indicate that target populations are not being provided with screening and/or vaccination despite having contact with their clinician.^65–67^ HBV screening best practice advice from the ACP/CDC^59^ and recommendations from AASLD^8^ are shown in Table 2.

Table 2 HBV Screening Recommendations From the CDC and AASLD

Risk factor | Chronic HBV prevalence | AASLD, 2018^8^ | ACP/CDC, 2017^59^
Persons born in region with ≥2% HBV prevalence | 4.5% to 10.3% | ✓ | ✓
Men who have sex with men | 1.1% to 2.3% (7% for persons with HIV) | ✓ | ✓
U.S. born persons, not vaccinated as infant, parent born in region with ≥8% HBV prevalence | Not available | ✓ | -
Persons who inject drugs | 3% to 20% | ✓ | ✓
Persons with HIV | 6% to 14% | ✓ | ✓
Household contact or sexual partner of person with HBV infection | 3% to 20% | ✓ | ✓
Inmates of correctional facilities | 1% to 3.7% | ✓ | ✓
Persons with hepatitis C virus infection | 1.4% | ✓ | ✓
Multiple sexual partners or seeking evaluation or treatment for sexually transmitted infections | Not available | ✓ | -
Unvaccinated persons with diabetes, ages 19 to 59 years | <1% | ✓ | -
Persons with end-stage renal disease | 2.8% | ✓ | ✓

Abbreviations: AASLD = American Association for the Study of Liver Diseases; ACP = American College of Physicians; CDC = Centers for Disease Control and Prevention; HBV = hepatitis B virus.

Both the ACP/CDC best practice advice and AASLD guideline also recommend screening of persons who engage in behaviors associated with increased risk for HBV, including men who have sex with men, persons who inject drugs, HIV-positive persons, and household contacts or sexual partners of persons with HBV infection, inmates of correctional facilities, persons with HCV infection, and persons with end-stage kidney disease.^59^ AASLD also recommends screening of persons with multiple sex partners or those seeking evaluation or treatment for a sexually transmitted infection, residents and staff of facilities for the developmentally disabled, and travelers to HBV endemic countries.^8^ Both AASLD and earlier (2008) CDC guidelines recommend screening of U.S. born persons not vaccinated as infants whose parents were born in regions with an eight percent or greater prevalence; the CDC guideline also recommends screening needle-sharing contacts of injection drug users.^8,22^ The National Academies of Science, Engineering, and Medicine National Strategy cites the USPSTF recommendation on screening as an essential component of its National Strategy for Elimination of Hepatitis B and C.^68^

Internationally, the World Health Organization (WHO) recommends HBV testing in the general population when the prevalence is 2 percent or greater and in higher-risk populations.^69^ The United Kingdom’s National Institute for Clinical Excellence recommends HBV testing in higher-risk populations and is generally consistent with the USPSTF recommendation.^70^