# Appendix C Supplementary Tables

Appendix C Table 1 CDC Hepatitis Risk Assessment Tool

Questions | Recommendations and Explanation
1. Have you ever been diagnosed with a clotting factor disorder? | If yes, talk to your doctor about getting vaccinated for Hepatitis A.
2. Have you ever been diagnosed with a chronic liver disease? | If yes, talk to your doctor about getting vaccinated for Hepatitis A and B.
3. Were you or at least one parent born outside of the United States? | If yes, talk to a doctor about getting a blood test for Hepatitis B. Many parts of the world have high rates of Hepatitis B, including the Amazon Basin, parts of Asia, Sub-Saharan Africa and the Pacific Islands.
4. Do you currently live with someone who is diagnosed with Hepatitis B? | If yes, talk to a doctor about getting a blood test for Hepatitis B.
5. Have you previously lived with someone who has been diagnosed with hepatitis B? | If yes, talk to a doctor about getting a blood test for Hepatitis B.
6. Have you recently been diagnosed with a STD? | If yes, talk to a doctor about getting vaccinated for Hepatitis B.
7. Have you been diagnosed with diabetes? | If yes, talk to a doctor about getting vaccinated for Hepatitis B.
8. Have you been diagnosed with HIV/AIDS? | If yes, talk to a doctor about getting vaccinated for Hepatitis B and getting a blood test for Hepatitis B and Hepatitis C.
9. If you are a man, do you have sexual encounters with other men? | If yes, talk to a doctor about getting vaccinated for Hepatitis A and B, and getting a blood test for Hepatitis B.
10. Do you currently inject drugs? | If yes, talk to a doctor about getting vaccinated for Hepatitis A and B, and getting a blood test for Hepatitis B and C.
11. Were you born from 1945 to 1965? | If yes, talk to a doctor about getting a blood test for Hepatitis C.
12. Have you ever received a blood transfusion or organ transplant before July 1992? | If yes, talk to a doctor about getting a blood test for Hepatitis C.
13. Have you ever received a clotting factor concentrate before 1987? | If yes, talk to a doctor about getting a blood test for Hepatitis C.
14. Have you ever injected drugs, even if just once? | If yes, talk to a doctor about getting a blood test for Hepatitis C.
15. Do you plan on traveling outside of the United States within the next year? | If yes, talk to a doctor about what vaccines may be needed for travel outside the United States.

Source: Centers for Disease Control and Prevention, available at: https://www.cdc.gov/hepatitis/riskassessment/pdfs/HepatitisRiskAssessment.pdf

Abbreviations: CDC = Centers for Disease Control and Prevention, STD = sexually transmitted disease.

Appendix C Table 2 AGA Risk Groups for HBV Reactivation

Risk group | HBVr drug risk estimates (HBsAg positive or anti-HBc positive)
High-risk group (>10%) | B cell–depleting agents such as rituximab and ofatumumab; - HBsAg positive/anti-HBc positive: 30% to 60% (A); - HBsAg negative/anti-HBc positive: >10% (A); Anthracycline derivatives such as doxorubicin and epirubicin; - HBsAg positive/anti-HBc positive: 15% to 30% (A); Corticosteroid therapy for ≥4 weeks; - HBsAg positive/anti-HBc positive: >10% (B) (moderate/high dose^a^)
Moderate-risk group (1%–10%) | TNF-a inhibitors: etanercept, adalimumab, certolizumab, infliximab; - HBsAg positive/anti-HBc positive: 1% to 10% (B); - HBsAg negative/anti-HBc positive: 1% (C); Other cytokine inhibitors and integrin inhibitors: abatacept, ustekinumab, natalizumab, vedolizumab; - HBsAg positive/anti-HBc positive: 1% to 10% (C); - HBsAg negative/anti-HBc positive: 1% (C); Tyrosine kinase inhibitors: imatinib, nilotinib; - HBsAg positive/anti-HBc positive: 1% to 10% (B); - HBsAg negative/anti-HBc positive: 1% (C); Corticosteroid therapy for ≥4 weeks; - HBsAg positive/anti-HBc positive: 1 to 10% (C) (low dose^a^); - HBsAg negative/anti-HBc positive: 1 to 10% (C) (moderate/high dose^a^); Anthracycline derivatives: doxorubicin and epirubicin; - HBsAg negative/anti-HBc positive: 1% to 10% (C)
Low-risk group (<1%) | Traditional immunosuppressive agents: azathioprine, 6-mercaptopurine, methotrexate; - HBsAg positive/anti-HBc positive: <1% (A); - HBsAg negative/anti-HBc positive: <1% (A); Intra-articular corticosteroids; - HBsAg positive/anti-HBc positive: <1% (A); - HBsAg negative/anti-HBc positive: <1% (A); Corticosteroid therapy for ≤1 week; - HBsAg positive/anti-HBc positive: <1% (B); - HBsAg negative/anti-HBc positive: <1% (A); Corticosteroid therapy for ≥4 weeks; - HBsAg negative/anti-HBc positive: <1% (B) (low dose^a^)

Source: Perillo 2015 for the American Gastroenterological Association^149^

NOTE. Confidence in evidence was graded as follows:

(A), high confidence that the estimate lies within group risk boundaries;

(B), moderate confidence that the estimate lies within group risk boundaries;

(C), little or no confidence that the estimate lies within group risk boundaries.

a Glucocorticoids: prednisone (or equivalent): low dose, <10 mg; moderate dose, 10 to 20 mg; high dose, >20 mg.

Abbreviations: AGA = American Gastroenterological Association; anti-HBc = antibody to hepatitis B core antigen; HBV = hepatitis B virus; HBVr = hepatitis B virus reactivation; HBsAg = hepatitis B surface antigen; anti-HBc = antibody to hepatitis B core antigen; TNF = tumor necrosis factor.