# Appendix B Data Abstraction and Quality Assessment Tables

Appendix B Table 1 HBV Screening Strategies – Study Characteristics

Author, year; Study name; From prior report or update | Study design | Setting; Country; Study period | N | Baseline characteristics | Screening strategies | Funding source | Quality
Bottero 2014^121^; OPTISCREEN-B; From update | Cross-sectional, substudy | 10 healthcare centers; Paris, France; September 2010 to August 2011 | Screened for eligibility: 5,393; Included in study: 3,997; Included in primary analysis: 3,929 | Age, median: 33 years; Male: 55.9%; HBV prevalence of birth country: 56.2% low (<2.0%), 20.5% intermediate (2.0 to 8.0%), high 23.3% (>8.0%); Intravenous drug use: 0.6%; Men who have sex with men: 10.6% | A. Previous HBV-testing; B. Physician’s decision to screen; C. 2008 CDC HBV screening recommendations^22^ (Testing recommended for pregnant women, infants born to HBsAg-positive mothers, household contacts and sex partners of HBV-infected persons, populations with and persons born in countries with HBsAg prevalence of ≥2%, persons who are the source of blood or body fluid exposures that might warrant postexposure prophylaxis, persons infected with HIV, men who have sex with mean, and persons who inject drugs); D. Persons from countries with high prevalence (≥2%) of HBV | Agence Nationale de Recherchesur le Sida et les Hepatites virales, Gilead Sciences and Roche | Fair
Spenatto 2013^120^; From prior report | Cross-sectional | 1 sexually transmitted disease clinic; France; January 2009 to June 2009 | Screened=6,194; 183 patients (1 HBV case) did not have information on country of birth | Age: 62% 20 to 29 years; Male: 44%; High endemic area (prevalence >8%) country of birth: 7.2%; Self-reported injection drug use: 0.7% | A. Screen all; B. Screening those born in moderate or high prevalence (>2%) country; C. Same as B, plus men and unemployed; D. Screen those born in moderate or high prevalence country, transfusion history or blood contacts, tattoos, body piercing, more than two sexual partners during the last year, hepatitis among sexual partners or household members, or intravenous or intranasal drug use; no screening for patients who reported prior HBV vaccination; E. Same as D, except prior vaccination history not considered | NR | Fair
Wolffram 2015^122^; From update | Cross-sectional; Screening strategies were hypothetically applied after the data was collected, so these are proposed strategies | 51 private primary care practices; Germany; January 2012 to June 2013 | Screened=21,008 | Non-HBV/HCV vs. HBsAg positive; Age: 57.5 vs. 52.3 years; Male: 43.9% vs. 54.5%; Intravenous drug use: 0.1% vs. 0.9%; Blood transfusion before 1992: 5.8% vs. 4.1%; Immigration: 10.0% vs. 35.6%; Infection in household: 4.0% vs. 11.0%; Elevated ALT: 13.2% vs. 21.8% | [underlined: Screening strategies for HBsAg positive patients, based on identified risk factors]; A. Male, immigrant, and someone with hepatitis in the household; B. Male, with either immigration background or someone with hepatitis in the household; C. Male, with immigration background; D. Elevated ALT values; E. German HBV guidelines; HBV questionnaire^*^ added to Check-Up 35+^†^ and the following 3 risk factors were associated with HBsAg positivity via stepwise logistic regression:; Immigration: OR 4.4 (95% CI, 2.9 to 6.7); Infection in household: OR 2.5 (95% CI, 1.2 to 4.5); Male: OR 1.6 (95% CI, 1.1 to 2.4) | Gilead, Janssen | Fair
Wolffram 2015^122^; From update | See Wolfram 2015 | See Wolfram 2015 | Screened=20,864 | See Wolfram 2015 | [underlined: Screening strategies for previously unknown HBsAg positive patients according to German guideline adapted questions][underlined: ^123^]; A. Total cohort; B. Positive answer to at least either one of the HBV related questions; C. Positive answer to at least either one of the HBV related questions or elevated serum ALT; D. Positive answer to at least either one of the HBV related questions excluding the question for elevated ALT values; E. Positive answer to at least either one of the HBV related questions excluding the question for ALT values or elevated serum ALT; F. Presence of elevated serum ALT levels; G. Immigration background or hepatitis positive household member; H. Immigration background or hepatitis positive house member or elevated serum ALT; I. Immigration background | See Wolfram 2015 | See Wolfram 2015

* Questionnaire covered 12 yes/no questions with risk scenarios for HBV or HCV adapted for the German guidelines which should prompt a screening if positively answered; with the addition of 4 questions on piercings, tattoos, previous surgery, or travel to countries with high HBV and HCV prevalence.

† Standard preventive medical examination for patients at least 35 years of age.

Abbreviations: ALT = alanine aminotransferase; CDC = Centers for Disease Control and Prevention; CI = confidence interval; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; HCV = hepatitis C virus; NR= not reported; OPTISCREEN-B = study name is a not an acronym; OR = odds ratio.

Appendix B Table 2 HBV Screening Strategies – Results

Author, year; Study name; From prior report or update | Screening strategies | HBV prevalence, HBsAg positive | Proportion screened | Sensitivity | Specificity | AUROC | NNS to identify 1 case of HBV infection
Bottero 2014^121^; OPTISCREEN-B; From update | A. Previous HBV-testing; B. Physician’s decision to screen; C. 2008 CDC HBV screening recommendations^22^; D. Persons from countries with high prevalence (≥2%) of HBV | 2.2% (85/3,929); Resolved HBV infection: 13.4% (528/3,929); anti-HBcAb: 3.3% (131/3,929) | A. 30.5% (1,199/3,929); B. 66.6% (2,615/3,929); C. 69.6% (2,735/3,929); D. 43.8% (1,721/3,929) | A. 36.5% (95% CI, 26.3% to 47.6%); B. 87.1% (95% CI, 78.0% to 93.4%); C. 100% (95% CI, 95.8% to 100%) p<0.0001; D. 99% (84/85) | A. 69.6; B. 33.9; C. 31.1% (95% CI, 29.6% to 32.6%); D. 47% (2207/3844) | A. 0.53 (95% CI, 0.48 to 0.58); B. 0.61 (95% CI, 0.57 to 0.64); C. 0.66 (95% CI, 0.65 to 0.66) | - 20
Spenatto 2013^120^; From prior report | A. Screen all; B. Screening those born in moderate or high prevalence (>2%) country; C. Same as B, plus men and unemployed; D. Screen those born in moderate or high prevalence country, transfusion history or blood contacts, tattoos, body piercing, more than two sexual partners during the last year, hepatitis among sexual partners or household members, or intravenous or intranasal drug use; no screening for patients who reported prior HBV vaccination; E. Same as D, except prior vaccination history not considered | 0.8% (49/6,194); anti-HBc positive: 4.4% (275/6,194) | - A: 100% (6,194/6,194); - B: 12% (761/6,011); - C: 64% (3,949/6,194); - D: 73% (4,504/6,194); - E: 84% (5,205/6,194) | - A: 100% (49/49); - B: 85% (41/48); - C: 98% (48/49); - D: 84% (41/49); - E: 94% (46/49) | - A: 0% (0/6,145); - B: 88% (5,243/5,963); - C: 37% (2,244/6,145); - D: 27% (1,682/6,145); - E: 16% (986/6,145) | - 0.92 | - A: 126; - B: 19; - C: 82; - D: 110; - E: 113
Wolffram 2015^122^; From update | [underlined: Screening strategies for HBsAg positive patients, based on identified risk factors]; A. Male, immigrant, and someone with hepatitis in the household; B. Male, with either immigration background or someone with hepatitis in the household; C. Male, with immigration background; D. Elevated ALT values; E. German HBV guidelines; HBV questionnaire^*^ added to Check-Up 35+^†^ and the following 3 risk factors were associated with HBsAg positivity via stepwise logistic regression:; Immigration: OR 4.4 (95% CI, 2.9 to 6.7); Infection in household: OR 2.5 (95% CI, 1.2 to 4.5); Male: OR 1.6 (95% CI, 1.1 to 2.4) | Total: 0.52% (110/21,008); A. Unclear; B. 2.0% (23/1,169), identified 21% of all HBsAg positive patients; C. 2.1% (20/948),identified 18% of all HBsAg positive patients; D. 0.8% (24/2,835), 22% of all HBsAg positive patients; E. 0.45% (93/20,864), 84.5% of all HBsAg positive patients | A. 0.30% (62/21,008); B. 5.56% (1,169/21,008); C. 4.51% (948/21,008); D. 13.5% (2,835/21,008); E. 99.3% (20,864/21,008) | NR | NR | NR | NR
Wolffram 2015^122^; From update | [underlined: Screening strategies for previously unknown HBsAg positive patients according to German guideline adapted questions][underlined: ^123^]; A. Total cohort; B. Positive answer to at least either one of the HBV related questions; C. Positive answer to at least either one of the HBV related questions or elevated serum ALT; D. Positive answer to at least either one of the HBV related questions excluding the question for elevated ALT values; E. Positive answer to at least either one of the HBV related questions excluding the question for ALT values or elevated serum ALT; F. Presence of elevated serum ALT levels; G. Immigration background or hepatitis positive household member; H. Immigration background or hepatitis positive house member or elevated serum ALT; I. Immigration background | Total:; A. 0.45% (93/20,864); B. 0.67%; C. 0.66%; D. 0.69%; E. 0.65%; F. 0.71%; G. 1.3%; H. 0.91%; I. 1.4% | A. 100% (20,864/20,864); B. 44.1% (9,198/20,864); C. 50.2% (10,467/20,864); D. 39.1% (8,147/20,864); E. 46.6% (9,719/20,864); F. 13.4% (2,799/20,864); G. 12.5% (2,603/20,864); H. 23.8% (4,970/20,864); I. 9.5% (1,976/20,864) | NR | NR | NR | A. 224; B. 148; C. 152; D. 145; E. 154; F. 140; G. 77; H. 116; I. 71

* Questionnaire covered 12 yes/no questions with risk scenarios for HBV or HCV adapted for the German guidelines which should prompt a screening if positively answered; with the addition of 4 questions on piercings, tattoos, previous surgery, r travel to countries with high HBV and HCV prevalence.

† Standard preventive medical examination for patients at least 35 years of age.

Abbreviations: ALT = alanine aminotransferase; anti-HBc = antibody to hepatitis B core antigen; anti-HBcAb = antibodies to hepatitis B surface and core antigens; AUROC = area under the receiver operating characteristics; CDC = Centers for Disease Control and Prevention; CI = confidence interval; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; NNS = number needed to screen; NPV = negative predictive value; NR = not reported; OPTISCREEN-B = study name is a not an acronym; OR = odds ratio; PPV = positive predictive value.

Appendix B Table 3 HBV Screening Strategies – Quality Assessment

Study, Year; From prior report or update | Did the Study Attempt to Enroll All (or a Random Sample of) Patients Meeting Inclusion Criteria, or a Random Sample (Inception Cohort)? | Did the Study Evaluate a Representative Spectrum? | Did the Study Report the Proportion of Eligible Patients Who Met Inclusion Criteria Who Underwent Screening? | Was There a High Rate of Nonscreening Among Eligible Patients? | Did the Study Describe Methods for Ascertaining Risk Factors? | Did the Study Prospectively Compare Different Predefined Screening Strategies? | Quality
Bottero 2014^121^; From update | Yes | Yes | No | Unclear | Yes | Yes | Fair
Spenatto 2013^120^; From prior report | Yes | Yes | Yes | No (19%) | Yes | No | Fair
Wolffram 2015^122^; From update | Yes | Yes | No | Unclear | Yes | No | Fair

Appendix B Table 4 Trials of HBV Antiviral Treatment vs. Placebo or No Treatment – Study Characteristics

Author, year Quality; From prior report or update | Study design | Number of sites; Country | Study duration; Mean followup | Interventions | Baseline characteristics | Eligibility criteria | Exclusion criteria | Number screened, eligible, enrolled, analyzed | Withdrawals (number, %); Loss to followup (number, %) | Funding source
Bozkaya 2005^74^; Fair; From prior report | Non-RCT | 1 site; Turkey | 1 year treatment; 6 months post-treatment followup (for those in treatment group); Mean followup: NR | - A: Lamivudine 100 mg daily (n=18); - B: Untreated group with raised ALT (n=19); - C: Untreated group with normal ALT (n=18) | A vs. B vs. C; Age, mean: 32 vs. 39 vs. 38 years; Male: 94% vs. 68% vs. 17%; Race: NR; Serology:; HBV DNA, median (range): 1.2 × 10^3^ (1 × 10^2^ to 9.7 × 10^4^) vs. 4.2 × 10^3^ (1 × 10^2^ to 3.6 × 10^5^) vs. 2.5 × 10^3^ (1 × 10^2^ to 5.2 × 10^5^) copies/mL; ALT, median (range): 64 (38 to 186) vs. 48 (35 to 168) vs. 17 (11 to 30) IU/L; Histopathology:; HAI (Knodell score) median (range): 4.5 (1.0 to 16.0) vs. 4.0 (1.0 to 8.0) vs. 2.0 (1.0 to 4.0); Fibrosis (Knodell fibrosis score ≥1) : 33% vs. 24% vs. 0%; Cirrhosis: NR; Prior HBV treatment: No patients | ALT >1 × ULN (groups A and B); undetectable HBV DNA by hybrid capture assay during monthly/bi-monthly assessments during year prior to entry into study; alcohol intake absent or <20 g per week; body mass index <30 kg/m^2^ | Presence of non-alcoholic steatohepatitis and significant liver steatosis; high body mass index; high alcohol intake; drug-related toxicity | Screened: 390; Eligible: 55; Enrolled: 55; Analyzed: 55 | NR | NR
Chan 2007^75^; Fair; From prior report | RCT | 8 sites; China | 24 months of treatment; 6 months followup; Mean followup: NR | A. Lamivudine 100 mg daily (n=89); B. Placebo (n=47) | A vs. B; Age, mean: 39 vs. 39 years; Male: 84% vs. 83%; Race: NR; Serology:; HBV DNA, mean: 5.7 vs. 5.6 log copies/mL; HBeAg positive: 6% vs. 6%; Anti-HBe positive: 94% vs. 96%; ALT, mean: 2.1 vs. 2.6 × ULN; Histopathology (reported for n=52 vs. 28 patients):; Necroinflammatory score, median (Knodell 0 to 18): 5 vs. 5; Fibrosis score, median (Ishak 0 to 6): 2 vs. 2; Cirrhosis: 16% overall (histology not reported for 42%); Prior HBV treatment: NR, but allowed (see eligibility criteria) | Age >18 years; positive HBsAg for >6 months prior to screening; detectable HBV DNA by non-PCR based assay; significantly increased ALT levels (ALT 1.5 to 10 times ULN on >2 occasions in the previous 6 months or ALT above ULN with >1 flare-up of ALT >200 IU/L in past 12 months); liver biopsy in past 12 months showing evidence of active hepatitis; once PCR-based HBV DNA assay was available, inclusion modified to HBV DNA >100,000 copies/mL | Hepatocellular carcinoma; ALT >10 times ULN at screening; decompensated liver disease; complications of liver cirrhosis; coinfection with HCV, HDV, or HIV; serious medical or psychiatric illness; use of immunosuppressive or immunomodulatory therapy within the previous 6 months; treatment with antiviral agent within the previous 6 months; history of hypersensitivity to nucleoside analogues; serum creatinine >1.5 times ULN; anti-nuclear antibody titer >1:160; serum amylase or lipase level >2 times ULN, hemoglobin <11 g/dL; white cell count <3x10^9^/L; platelet count <100x10^9^/L; pregnant or lactating women | Screened: 443; Eligible: 139; Enrolled: 139; Analyzed: 136 | Withdrawals during treatment: 18% (25/136); Withdrawals post-treatment: 18% (19/105); Post-randomization exclusions: 2.2% (3/139); Missing data: 6.6% (9/136) | Glaxo-SmithKline
Dienstag 1999^76^; Fair; From prior report | RCT | 34 sites; United States | Study duration: 68 weeks; Treatment duration: 52 weeks; Post-treatment followup: 16 weeks | A. Lamivudine 100 mg daily (n=66); B. Placebo (n=71) | A vs. B; Age, median: 40 vs. 38 years; Male: 86% vs. 80%; Race: 59% vs. 56% white, 24% vs. 17%; Asian, 15% vs. 18% black; Serology: HBV DNA, median serum : 102.2 vs. 56.5 pg/mL; ALT, median serum: 125 vs. 135 IU/L; Bilirubin, median serum: 0.7 vs. 07 mg/dL; Albumin, median serum: 3.9 vs. 3.8 g/dL; Histopathology:; Median HAI (Knodell score): 10 vs. 11; Cirrhosis: 6% vs. 14%; Prior HBV treatment: None | Age ≥18 years; detectable serum HBsAg for at least 6 months, serum HBeAg for at least 1 month, and ALT levels 1.3 to 10 times ULN for at least 3 months; evidence of chronic hepatitis on liver biopsy; and detectable levels of HBV DNA | Previous antiviral therapy for HBV; any treatment with antiviral drugs, immunomodulatory drugs, or corticosteroids within the previous 6 months; bilirubin level >2.5 mg/dL; prothrombin time more than 3 seconds longer than normal; albumin level of less than 3.5 g/dL; history of ascites, variceal hemorrhage, or hepatic encephalopathy; co-infection with HCV, HDV, or HIV; a nuclear antibody titer of more than 1:160; a creatine level of more than 1.5 mg/dL; a hemoglobin level of less than 11 g/dL; a white-cell count of less than 3,000 cells/mm^3^; a neutrophil count of less than 1500 cells/mm^3^; a platelet count of less than 100,000 cells/mm^3^; presence of a confounding illness or other type of liver disease; pregnant or breastfeeding | Screened: 217; Eligible: NR; Enrolled: 143; Analyzed: 137; 143 enrolled but 6 excluded at the baseline visit because they did not have 6 months of serum HBsAg | Withdrawals: 6 (2 patients withdrew before receiving treatment, 4 others excluded because they did not meet inclusion criteria) | Glaxo Wellcome; Hepatitis Research Fund of Massachusetts General Hospital; National Institutes of Health Clinical Research Center
Hadziyannis 2003^77^; Fair; From prior report | RCT | 32 sites;; Canada, Greece, Israel, France, Italy, Australia, Taiwan, Singapore | 48 weeks duration and followup; safety analysis included all events that occurred within 30 days of drug discontinuation | A. Adefovir 10 mg daily (n=123); B. Placebo (n=62) | A vs. B; Age, mean: 46 vs. 45 years; Male: 83% vs. 82%; Race: 67% vs. 66% white; 4% vs. 2% black; 29% vs. 33%; Asian Serology:; HBV DNA, mean: 6.9 vs. 6.9 log copies/mL; ALT × ULN, mean: 3.5 vs. 3.6; Histopathology:; Knodell necroinflammatory activity score, mean: 7.7 vs. 7.1; Knodell fibrosis score, mean: 1.9 vs. 1.8; Cirrhosis: 11% vs. 10%; Prior HBV treatment:; Prior interferon alfa treatment: 39% vs. 46%; Prior lamivudine treatment: 8% vs. 7%; Prior famciclovir treatment: 6% vs. 11%; Note: some patients had received more than one medication | Age 16 to 65 years of age with HBeAg negative chronic HBV and compensated liver disease. Chronic HBV defined as HBsAg for at least 6 months, undetectable HBeAg, detectable anti-HBe, HBV DNA of at least 10^5^ copies/mL, ALT between 1.5 and 15x ULN. Total bilirubin no more than 2.5 mg/dL; prothrombin time no more than 1 second above normal range; albumin at least 3 g/dL; creatinine no more than 1.5 mg/dL; adequate blood count. | Coexisting serious medical or psychiatric illness, immune globulin, interferon, or other immune or cytokine based therapies with possible activity against HBV disease within 6 months before screening; organ or bone marrow transplantation; recent treatment with systemic corticosteroids, immunosuppressants, or chemotherapeutic agents; serum AFP of at least 50 ng/mL, evidence of a hepatic mass, liver disease not due to HBV, prior therapy for more than 12 weeks with a nucleoside or nucleotide analogue with activity against HBV, seropositivity for HIV, HCV, or HDV | Screened: 391; Eligible: 235; Enrolled: 185; Analyzed: 178 for histologic outcomes; Note: one patient in group B never received treatment and was excluded, baseline n=123 in group A, 61 in group B | Withdrawals: 2.4% (3/123) vs. 1.6% (1/61); Loss to followup: 0.8% (1/123) vs. 0% (0/61) | Gilead Sciences
Lai 1997^79^; Fair; From prior report | RCT | Single site; Hong Kong | Treatment duration: 4 weeks; Post-treatment followup: 4 weeks | A. Lamivudine 25 mg daily (n=12); B. Lamivudine 100 mg daily (n=12); C. Lamivudine 300 mg daily (n=12); D. Placebo (n=6) | A vs. B vs. C vs. D; Age, mean: 33 vs. 33 vs. 34 vs. 26 years; Male: 58% vs. 58% vs. 75% vs. 67%; Race: 100% Asian; Serology:; Mean HBV DNA: 91.3 vs. 94.5 vs. 103.0 vs. 67.1 pg/mL; HBsAg positive: 100% vs. 100% vs. 100% vs. 100%; HBeAg positive: 100% vs. 100% vs. 100% vs. 100%; ALT, median: 37.5 vs. 29.5 vs. 38.0 vs. 28.5 IU/L; Histopathology: NR; Prior HBV treatment: NR | Chronic HBsAg carriers; HBV DNA levels >10 pg/mL for at least 3 months; stable serum ALT and AST levels of less than 2 times ULN range for at least 3 months; no antiviral, investigational, or biological modifier drugs in the past 6 months; no evidence of liver decompensation, renal impairment, or pancytopenia; tested negative for antibodies against HCV, HDV, and HIV | NR | Screened: NR; Eligible: NR; Enrolled: 42; Analyzed: 42 | None | NR
Lai 1998^78^; Fair; From prior report | RCT | Multiple sites (number NR); Hong Kong, Taiwan, Singapore | Study duration: 52 weeks; Median followup: 365 days, range 2 to 409 days | A. Lamivudine 25 mg daily (n=142); B. Lamivudine 100 mg daily (n=143); C. Placebo (n=73) | A vs. B vs. C; Age, median: 33 vs. 31 vs. 29 years; Male: 73% vs. 74% vs. 72%; Race: 100% Asian; Serology:; HBV DNA, median serum: 70.7 vs. 74.2 vs. 99.4 pg/mL (A vs. C, p=0.04, B vs. C, p=0.08); HBsAg positive: 100% vs. 100% vs. 100%; HBeAg positive: 100% vs. 100% vs. 99%; Anti-HBeAg positive: 0% vs. 4% vs. 3%; ALT, median: 1.4 vs. 1.5 vs. 1.5 × ULN; Histopathology:; Knodell (histologic activity) score, mean: 9 vs. 8 vs. 8; Cirrhosis: 5% overall (individual groups NR) | Aged 16 to 70 years; detectable serum HBsAg and HBeAg for at least the previous 6 months; serum HBV DNA levels of at least 5 pg/mL; ALT levels <10 times the ULN for at least the previous 3 months | HCV, HDV, or HIV infection; decompensated liver disease; evidence of autoimmune hepatitis; received an investigational drug in the previous 30 days; received any antiviral, immunomodulator, cytotoxic agents, or corticosteroids in the previous 6 months; or received lamivudine in the previous 3 months | Screened: NR; Eligible: NR; Enrolled: 358; Analyzed: 357; Note: 1 patient in placebo group excluded due to no evidence of HBsAg for 6 months prior to enrollment | A vs. B vs. C; Withdrawals: 6% (8/142) vs. 3% (4/143) vs. 4% (3/73) | Glaxo Wellcome Research and Development
Lampertico 1997^80^; Fair; From prior report | Open label RCT | Single site; Italy | Study duration: 3 years (2 years treatment + 1 year followup); Mean duration of followup: 22 months | A. Interferon alfa 2b 6 MU intramuscular injection 3x/week (n=21); B. No treatment (n=21) | A vs. B; Age, mean: 44 vs. 47 years; Male: 80% vs. 90%; Race: NR; Serology: HBV DNA positive: 67% vs. 67%; HBcAg, tissue: 82% vs. 81%; IgM anti-HBc: 95% vs. 100%; ALT, mean: 140 vs. 173 U/L; Histopathology:; HAI, median: 10 vs. 10; Cirrhosis: 19% vs. 14% | Age 18 to 65 years; chronic active HBV, with or without cirrhosis; HBsAg and anti-HBe in serum for ≥1 year; serum ALT >2x ULN; detectable serum HBV DNA in year preceding study | HCV, HDV or HIV positive; pregnant or lactating; drug abuse; alcoholism; antiviral or immunosuppressive therapy in 12 months preceding study; platelet counts <100,000/mL; white blood cell counts <3,000/mL; serum markers of autoimmunity; renal failure; history of hepatic decompensation; other serious medical illness | Screened: NR; Eligible: NR; Enrolled: 42; Analyzed: unclear | Withdrawals: 6/42 (14%); Loss to followup: 3/42 (7%) | Istituto Superiore di Sanità (Italian National Health Service)
Lin 1999^81^; Fair; From prior report; Additional publication: Liaw 1994 ^168^ | RCT | Single site; China | 18 weeks treatment + mean 7 years followup (range 1 to 11 years) | A. Interferon alfa 2a 4 to 5 MU/m^2^ (n=67); B. Placebo (n=34) | A vs. B; Age, mean: 32 vs. 32 years; Male: 100% (both groups); Race: 100% Chinese (both groups); Serology:; HBV DNA, pg/mL: ≤200: 18% vs. 18%; 201 to 500: 22% vs. 12%; 501 to 1,000: 7% vs. 18%; >1,000: 52% vs. 53%; ALT, mean: 227 vs. 256 U/L; AFP, mean: 9 vs. 11 ng/mL; Histopathology:; Cirrhosis: 10% vs. 15% | Age 16 to 65 years; heterosexual male; HBsAg and HBeAg positive; elevated ALT (<40 U/L); liver biopsy within 3 months of study entry showing chronic active hepatitis or chronic lobular hepatitis; presence of serum HBV DNA | Immunosuppressive or antiviral therapy use; HDV infection; intravenous drug abuse; decompensated liver disease; other serious medical illness; AFP >100 ng/mL | Screened: NR; Eligible: NR; Enrolled: 120; Analyzed: 101 | NR | The Prosperous Foundation (Taipei, Taiwan)
Marcellin 2003^82^; Fair; From prior report | RCT | 78 sites; North America, Europe, Australia, and Southeast Asia | 48 weeks duration and followup; safety analysis included all events that occurred within 30 days of drug discontinuation | A. Adefovir 10 mg daily (n=172); B. Placebo (n=170); Excluding adefovir 30 mg daily (n=173); FDA-approved dose is 10 mg | A vs. B; Age, mean: 34 vs. 37 years; Male: 76% vs. 71.3%; Race: 35.1% vs. 35.9%; white, 4.7% vs. 1.8%; black, 59.6% vs. 60.5%; Asian, 0.6% vs. 1.8%; other; Serology:; HBV DNA, mean: 8.25 vs. 8.12 log copies/mL; HBeAg positive: 100%; ALT, mean: 3.4 vs. 3.4 times ULN; Histopathology:; Total Knodell score, mean: 9.01 vs. 9.65; Knodell necroinflammatory score, mean: 7.37 vs. 7.83; Knodell fibrosis score, mean: 1.64 vs. 1.83; Prior interferon alfa treatment (all groups): 24.9% (123/494) | Age 16 to 65 years with HBeAg positive chronic HBV and compensated liver disease. Chronic HBV defined as presence of serum HBsAg for at least 6 months, serum HBV DNA of at least 1 million copies per mL, and serum ALT 1.2 to 10 × ULN. Prothrombin time no more than 1 second above normal range, serum albumin greater than 3 g/dL, total bilirubin level no more than 2.5 mg/dL, serum creatinine level of no more than 1.5 mg/dL, adequate blood count. Negative pregnancy test and contraception use for women. | Coexisting serious medical or psychiatric illness; immune globulin, interferon, or other immune or cytokine based therapies with possible activity against HBV disease within 6 months before screening, organ or bone marrow transplantation, recent treatment with systemic corticosteroids, immunosuppressants, or chemotherapeutic agents; serum AFP level of at least 50 ng/mL, evidence of hepatic mass, liver disease not due to HBV, prior therapy for more than 12 weeks with a nucleoside or nucleotide analogue with activity against HBV, seropositivity for HIV or HCV or HDV. | Screened: NR; Eligible: NR; Enrolled: 342; Analyzed: 329 for histologic outcomes; Note: 4 patients (1 in group A, 3 in group B) took no study medications and were excluded after randomization, baseline n=171 in group A, 167 in group B | A vs. B; Withdrawals: 7.0% (12/171) vs. 7.8% (13/167); Loss to followup for baseline biopsies: 1.8% (3/171) vs. 3.6% (6/167); Loss to followup for total group: Unclear | Gilead Sciences
Mazzella 1999^83^; Fair; From prior report | RCT | Number of sites NR; Italy | 6 months treatment; 7.2 years mean followup | A. Interferon alfa, 5 MU/m^2^ 3 times weekly for 6 months, mean total dose 648 MU (n=33); B. No treatment (n=31) | A vs. B; Age, mean: 36.3 vs. 40.6 years; Male: 75.8 vs. 80.6%; Race: NR; Serology: HBsAg and HBeAg: 100% positive; ALT, mean: 106 vs. 144 U/L; Histopathology:; Cirrhosis: 0% (both groups); Prior HBV treatment: NR | HBsAg, HBeAg and HBV DNA positive; elevated ALT; histologic evidence of chronic active or persistent hepatitis | Age <18 or >65 years; pregnancy; histologically proven cirrhosis; HDV or HIV antibodies; history of drug abuse | Screened: NR; Eligible: NR; Enrolled: 64; Analyzed: 64 | NR | NR
Muller 1990^84^; Fair; From prior report | RCT | Unclear (likely single site); Germany | Study duration: 4 months; Duration of followup: range 10 to 28 months (including treatment period) | A. Interferon alfa 2b 3 MU subcutaneous 3x/week (n=30); B. No treatment (n=28) | A vs. B; Age: mean NR, range 18 to 65 years; Male: 79.3%; Race: NR; Serology:; HBsAg positive: 100%; HBeAg positive: 96.4% vs. 96.3% of completers (n=55); ALT: NR; Histopathology:; Cirrhosis: 5.2%; Prior HBV treatment: NR | Age 18 to 65 years; HBsAg and HBV DNA positive for ≥6 months | HDV or HIV positive; decompensated cirrhosis; chronic renal insufficiency; use of hemodialysis or immunosuppressive agents; previous organ transplantation; poor physical condition | Screened: NR; Eligible: NR; Enrolled: 58; Analyzed: 55 | Withdrawals: 5.2% (3/58); Loss to followup: none reported | NR
Realdi 1990^88^; Fair; From update | RCT | Multicenter (number of sites NR); Italy | 4 month treatment with 16 months followup | A. Interferon alfa-2a 4.5 MU thrice weekly (n=39); B. No treatment (n=40) | Age, mean: 33 vs. 31 years; Male: 64% vs. 74%; Race: NR (set in Italy); Serology:; HBV DNA 1+: 36% vs. 28%; HBV DNA 2+: 18% vs. 38%; HBV DNA 3+: 26% vs. 28%; HBV DNA 4+: 21% vs. 8%; HBeAg positive: 100% vs. 100%; HBsAg positive: 100% vs. 100%; ALT, mean × ULN: 4.8 vs. 4.0; Active cirrhosis: 18% vs. 15%; Fibrosis: 1.5 vs. 1.5 | Male and female, HBsAg, HBeAg, HBV DNA positive for at least 12 months, abnormal ALT; chronic hepatitis on biopsy within 6 months of entry | HDV or HIV coinfection | Screened: NR; Eligible: NR; Enrolled (randomized): 82; Analyzed: 79 | Withdrawals: 3, 3.7%; Loss to followup: 0 | NR
Tassopoulos 1999^85^; Fair; From prior report | RCT | Unclear (authors from North America and Europe) | A vs. B; Followed for up to 52 weeks (unblinding at week 26 and further participation based on week 24 sera results); Median exposure (range): 366 (55 to 425) vs.189 (11 to 257) days | A. Lamivudine 100 mg daily (n=60); B. Placebo (n=64); Note: Comparison data only available up to week 26 | A vs. B; Age, median: 42 vs. 44 years; Male: 83.3% vs. 76.6%; Race: NR; Serology: HBV DNA positive: 91.7% vs. 85.9%; HBV DNA, median: 255.0 vs. 95.5 pg/mL; HBsAg positive: 100% vs. 100%; HBeAg negative: 98.3% vs. 98.4%; Anti-HBeAg positive: 98.3% vs. 100%; Abnormal ALT: 96.7% vs. 95.3%; ALT × ULN, median: 3.2 vs. 3.3; Histopathology:; Knodell necro-inflammatory score, median: 5 vs. 7; Cirrhosis: 13.3% vs. 15.6% (calculated from n’s reported in table; reported %’s are 14% and 18%); Prior HBV treatment: NR, but allowed (see eligibility criteria) | Men and women 16 to 70 years of age with detectable HBsAg, detectable anti-HBeAg, and undetectable HBeAg at screening and for 6 months prior to screening; serum HBV DNA >2.5 pg/mL at screening, presence of HBV DNA in serum for 3 months before screening; ALT 1.5 to 10 times ULN at screening and at least once >3 months before screening with no value falling in reference range during intervening period | HCV, HDV, HIV positive; presence of decompensated liver disease; evidence of autoimmune hepatitis; interferon treatment within previous 6 months | Screened: 260; Eligible: 125; Enrolled: 125; Analyzed: 124 | A vs. B; Withdrawals: 11.7% (7/60) vs. 6.3% (4/64) | Glaxo Wellcome Research and Develop-ment
Thomas 1994^89^; Fair; From update | RCT | 6 countries (United Kingdom, Hong Kong, Spain, Australia, Argentina, Switzerland based on author locations) | 24 weeks duration and 12 month followup post-treatment | A. Interferon-α2a 2.5 MIU thrice weekly (n=45); B. Interferon-α2a 5 MIU thrice weekly (n=47); C. Interferon-α2a 10 MIU thrice weekly (n=44); D. No treatment (n=40) | Age: NR; Male: 89% vs. 83% vs. 98% vs. 88%; Europid: 58% vs. 57% vs. 68% vs. 72%; Chinese: 36% vs. 37% vs. 27% vs. 25%; Black: 6% vs. 6% vs. 5% vs. 3%; With cirrhosis: 9% vs. 15% vs. 34% vs. 25%; HIV positive: 9% vs. 2% vs. 9% vs. 7%; ALT ratio to ULN ≤1: 18% vs. 20% vs. 14% vs. 30%; ALT ratio to ULN >1 to 3: 47% vs. 50% vs. 43% vs. 42%; ALT ratio to ULN >3 to 5: 22% vs. 11% vs. 18% vs. 15%; ALT ratio to ULN >5: 13% vs. 19% vs. 25% vs. 13% | Male and female 18 to 65 with histological diagnosis of chronic active hepatitis, with or without cirrhosis | Minimal hepatitis, chronic persistent hepatitis, decompensated cirrhosis, HCC, previously received interferon-α, pregnant | Screened: NR; Eligible: 191; Enrolled (randomized): NR; Analyzed: 176 | Withdrawals: NR; Loss to followup: NR | NR
Tseng 2014^90^; Fair; From update | RCT | 5 sites; Taiwan | 52 weeks duration and followup | A. Entecavir 0.5 mg daily (n=22); B. Placebo (n=20) | Age, mean: 45 vs. 42 years; Male: 59% vs. 55%; Race: NR (set in Taiwan); Serology: HBV DNA, mean, log_10_ copies/mL: 6.0 vs. 6.3; HBeAg positive: 32% vs. 45%; Anti-HBe positive: 64% vs. 45%; ALT, mean × ULN: 0.6 vs. 0.6; Histopathology:; Knodell score, mean total: 5.1 vs. 6.7; Knodell score, mean necroinflammatory: 3.1 vs. 4.6; Knodell score, mean fibrosis: 1.1 vs. 2.0; Prior HBV treatment: None | Male and female 18 to 65 with chronic HBV; detectable HBsAg for ≥24 weeks, or for <24 weeks and negative for IgM anti-HBc and chronic HBV confirmed by biopsy; at least 2 ALT <ULN within 1 year that were ≥3 months apart; normal ALT at screening; HBV DNA ≥10^4^ copies/mL by PCR; Knodell score ≥4 within a year of randomization; and negative pregnancy test for women with childbearing potential | Coinfection with HIV, HCV, HDV or other liver disease including alcoholic, autoimmune, or biliary; decompensated liver disease; therapy with agents active against HBV within 24 weeks of randomization; more than 12 weeks of therapy with nucleoside or nucleotide agents active against HBV; prior entecavir; allergy to nucleoside analogs; hemoglobin, platelets, or neutrophils below specific thresholds; creatinine or anti-nuclear antibody titer above specified thresholds | Screened: 380; Eligible: 95; Enrolled (randomized): 43; Analyzed: 39 | Withdrawals: 9% (4/43); Loss to followup: NR | Bristol Myers Squibb and the Department of Health, Taiwan
Wen 2014^91^; Fair; From update | RCT | 1 site; China | 48 weeks duration and 1 year followup | A. Adefovir dipivoxil 10 mg daily (n=252); B. Placebo (n=274) | Age, mean: 38 vs, 37; Male: 73% vs. 70%; Race: NR (set in China); HBV DNA level of 10^4^ to 10^7^ IU/mL; ALT: 80 to 400 U/mL | Male and female 18 to 65 with HBsAg positive for at least 6 months | Coinfection with HIV, HCV, HDV, positive results for autoantibody, decompensated hepatosis, hyperthyroidism, psychosis, pregnancy | Screened: NR; Eligible: NR; Enrolled (randomized): 526; Analyzed: NR | Withdrawals: NR; Loss to followup: NR | Non-profit
Yalcin 2004^86^; Fair; From prior report | RCT | One site; Turkey | Duration: 12 months; Active treatment: 12 weeks | A. Lamivudine 100 mg daily (n=13); B. Control (n=33) | A vs. B; Age, mean: 23.3 vs. 24.8 years; Male: 53.8% vs. 54.5%; Race: NR; Serology:; HBV DNA, median: 4,116 vs. 4,094 pg/mL; HBsAg positive: 100% in both groups; HBeAg positive: 100% in both groups; ALT, median: 27 vs. 30 IU/L; Histopathology:; Knodell inflammation score, median: 1.0 vs. 2.0; Knodell fibrosis score, median: 0 in both groups; Prior HBV treatment: 0% vs. 0% (ineligible) | Adult patients with no previous antiretroviral treatment; HBsAg positive for >6 months; positive HBeAg; serum HBV DNA >1 pg/mL; persistently normal ALT values on at least 3 occasions in the previous 6 months; histological evidence of absent or minimal changes in liver biopsy; negative urine or serum pregnancy test for women of childbearing age; all men with partners of childbearing age and premenopausal women required to use reliable contraception during study and 6 months after treatment completion | Previously treated with interferon or antiviral or immunosuppressive medications; positive for antibody to HDV, HCV, HIV and pregnancy; with decompensated liver disease; with medical condition associated with chronic liver disease other than viral hepatitis; alcohol and/or drug abuse within 1 year of study entry | Screened: 53; Eligible: 46; Enrolled: 46; Analyzed: 46 | Withdrawals: 2.2% (1/46), NR by group; Loss to followup NR | NR
Yao 1999^87^; Fair; From prior report; Additional publications: Yao 2000^169^ and Yao 2009 ^170^ | RCT | Multiple sites (number NR); China | Blinded treatment duration: 12 weeks; Open-label treatment: 9 months | A. Lamivudine 100 mg daily (n=329); B. Placebo (n=110); N=429 for efficacy, 439 for harms | A vs. B; Age: 32.2 vs. 30.8 years (unclear if this is mean or median); Male: 74.2% vs. 69.2%; Race: NR, conducted in China; Serology:; HBV DNA, median: 66.4 vs. 60.4 pg/mL; HBsAg positive: 100%; HBeAg positive: 100%; ALT, median: 1.0 (range 0.3 to 6.7) vs. 1.0 (range 0.2 to 17.3) × ULN; Histopathology: NR; Prior HBV treatment: NR | Aged 16 to 65 years; HBeAg and HBsAg positive in the 6 months prior to screening; detectable HBV DNA at screening; ALT levels <10 × ULN at screening | HCV, HDV, or HIV infection; decompensated liver disease; evidence of autoimmune or hereditary liver disease; bone marrow depression; serious concurrent illness; alcoholism; drug abuse; elevated creatinine concentration >1.5 × ULN; had received antiviral or cytotoxic agents, corticosteroids, or immunomodulators in the previous 6 months; history of hypersensitivity to nucleoside analogs; pregnancy or lactation; females of childbearing age not using contraceptives | Screened: 440; Eligible: 429; Enrolled: 429; Analyzed: 429 | A vs. B; Withdrawals: 2.8% (9/322) vs. 1.9% (2/107) | NR

Abbreviations: AFP = alpha-fetoprotein; ALT = alanine aminotransferase; AST = aspartate aminotransferase; anti-HBc = antibody to hepatitis B core antigen; anti-HBe = antibody to hepatitis B e-antigen; anti-HBeAg = antibody to hepatitis B e antigen; DNA = deoxyribonucleic acid; FDA = U.S. Food and Drug Administration; HAI = histology activity index; HBcAg = hepatitis B core antigen; HBeAg = hepatitis B e-antigen; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; HCV = hepatitis C virus; HDV = hepatitis D virus; IgM = immunoglobulin M; NR = not reported; PCR = polymerase chain reaction; RCT = randomized controlled trial; U = units; ULN = upper limit of normal.

Appendix B Table 5 Trials of HBV Antiviral Treatment vs. Placebo or No Treatment – Results

Author, year; From prior report or update | Interventions | Number screened, eligible, enrolled, analyzed | Adjusted variables for statistical analysis | Intermediate outcomes | Clinical health outcomes | Adverse events
Bozkaya 2005^74^; From prior report | - A: Lamivudine 100 mg daily (n=18); - B: Untreated group with raised ALT (n=19); - C: Untreated group with normal ALT (n=18) | Screened: 390; Eligible: 55; Enrolled: 55; Analyzed: 55 | N/A | A vs. B vs. C; Month 12; ALT normalization A vs. B (group C had normal ALT at baseline): 44% (8/18) vs. 21% (4/19); RR 2.1 (95% CI, 0.7 to 5.8) | NR | NR
Chan 2007^75^; From prior report | A. Lamivudine 100 mg daily (n=89); B. Placebo (n=47) | Screened: 443; Eligible: 139; Enrolled: 139; Analyzed: 136 | OR adjusted for baseline HBV DNA and ALT levels | A vs. B; Month 24; Complete response: 56% (50/89) vs. 11% (5/47); adjusted OR 10.8 (95% CI, 3.8 to 30.2) HBV <10,000 copies/mL: 58% (52/89) vs. 19% (9/47); RR 3.1 (95% CI, 1.7 to 5.6); HBV undetectable: 26% (23/89) vs. 6% (3/47); RR 4.1 (95% CI, 1.3 to 12.8); HBsAg loss: 0 vs. 0; ALT normalization: 74% (66/89) vs. 36% (17/47); RR 2.1 (95% CI, 1.4 to 3.1); Month 30; Complete response: 26% (23/89) vs. 19% (9/47); RR 1.4 (95% CI, 0.7 to 2.7); HBV <10,000 copies/mL: 33% (29/89) vs. 26% (12/47); RR 1.3 (95% CI, 0.7 to 2.3); HBV undetectable: 10% (9/89) vs. 2% (1/47); RR 4.8 (95% CI, 0.6 to 36.4); HBsAg loss: 1% (1/89) vs. 0% (0/47); RR 1.6 (95% CI, 0.07 to 38.5); ALT normalization: 60% (53/89) vs. 38% (18/47); RR 1.6 (95% CI, 1.0 to 2.3); Necroinflammatory improvement (Knodell ≥2 points): 78% (14/18) vs. 25% (2/8); RR 3.1 (95% CI, 0.9 to 10.6); Fibrosis improvement (Ishak ≥2 points): 33% (6/18) vs. 0% (0/8); RR 6.2 (95% CI, 0.4 to 97.7); Complete response =HBV DNA <10,000 copies/mL + ALT normalization;; HBV by PCR, detection limit <100 copies/mL | A vs. B; Mortality: NR; HCC: 3.4% (3/89) vs. 2.1% (1/47); RR 1.6 (95% CI, 0.2 to 14.8); Note: Study not powered to detect effect of lamivudine on prevention of HCC | A vs. B; Serious adverse events 15% (13/89) vs. 13% (6/47) RR 1.1 (95% CI, 0.5 to 2.8)
Dienstag 1999^76^; From prior report | A. Lamivudine 100 mg daily (n=66); B. Placebo (n=71) | Screened: 217; Eligible: NR; Enrolled: 143; Analyzed: 137; 143 enrolled but 6 excluded at the baseline visit because they did not have 6 months of serum HBsAg | Adjustments for ORs: ALT, HBV DNA, HAI (Knodell score), race, age, sex, weight, and the presence of cirrhosis | A vs. B; 1 year results (end of treatment):; HBV DNA loss: 44% (28/63) vs. 16% (11/69); RR 2.79 (95% CI, 1.52 to 5.12); HBeAg seroconversion: 17% (11/63) vs. 6% (4/69); RR 3.01 (95% CI, 1.01 to 8.98); HBeAg loss: 32% (21/66) vs. 11% (8/71); RR 2.82 (95% CI, 1.34 to 5.93); ALT normalization: 41% (27/66) vs. 7% (5/68); RR 5.56 (95% CI, 2.28 to 13.58); Histologic improvement (≥2 points on HAI): 52% (34/66) vs. 23% (16/71); RR 2.29 (95% CI, 1.40 to 3.73); 16 month results (4 months post-treatment): HBsAg loss: 2% (1/66) vs. 0% (0/71); RR 3.22 (95% CI, 0.13 to 77.78); HBeAg seroconversion: 17% (11/63) vs. 9% (6/69); RR 2.01 (95% CI, 0.79 to 5.11); HBeAg loss: 29% (19/66) vs. 15% (11/71); RR 1.86 (95% CI, 0.96 to 3.60); Time point NR:; Likelihood of histologic response: adjusted OR 7.5, (95% CI, 2.7 to 20.9); Likelihood of HBeAg seroconversion: adjusted OR 9.7 (95% CI, 1.7 to 56.1); Seroconversion =HBV DNA loss + HBeAg loss + anti-HBe development; HBV DNA by hybridization, detection limit 1.6 pg/mL | Mortality: None | A vs. B; Serious adverse events 0% (0/66) vs. 0% (0/71) RR 1.1 (95% CI, 0.0 to 53); (inferred)
Hadziyannis 2003^77^; From prior report | A. Adefovir 10 mg daily (n=123); B. Placebo (n=62) | Screened: 391; Eligible: 235; Enrolled: 185; Analyzed: 178 for histologic outcomes; Note: 1 patient in group B never received treatment and was excluded, baseline n=123 in group A, 61 in group B | N/A | A vs. B; Histologic improvement: 64% (77/121) vs. 33% (19/57); RR 1.9 (95% CI, 1.3 to 2.8); HBV DNA undetectable: 51% (63/123) vs. 0% (0/61); RR 64 (95% CI, 4.0 to 1,009); ALT normalization: 72% (84/116) vs. 29% (17/59); RR 2.5 (95% CI, 1.7 to 3.8); Histologic improvement =≥2 point reduction in Knodell necro-inflammatory score with no increase in Knodell fibrosis score; HBV DNA by PCR, detection limit 400 copies/mL | NR | A vs. B; Serious adverse events 3% (4/123) vs. 7% (4/61) RR 0.5 (95% CI, 0.1 to 1.9); Withdrawal due to adverse events : 0% (0/123) vs. 0% (0/61) RR 0.5 (95% CI, 0.0 to 25); Any adverse events: 76% (94/123) vs. 74% (45/61) RR 1.0 (95% CI, 0.9 to 1.2); Note: any adverse event refers to those reported by at least 5% of patients in group A
Lai 1997^79^; From prior report | A. Lamivudine 25 mg daily (n=12); B. Lamivudine 100 mg daily (n=12); C. Lamivudine 300 mg daily (n=12); D. Placebo (n=6) | Screened: NR; Eligible: NR; Enrolled: 42; Analyzed: 42 | N/A | (A+ B + C) vs. D; HBV DNA: >90% decrease vs. no significant change; HBeAg loss: 0/36 vs. 0/6; ALT: no change with treatment; HBV DNA: Abbott assay, method and detection limit NR | NR | A vs. B; Serious adverse events: 0% (0/36) vs. 0% (0/6) RR 0.2 (95% CI, 0.0 to 8.8)
Lai 1998^78^; From prior report | A. Lamivudine 25 mg daily (n=142); B. Lamivudine 100 mg daily (n=143); C. Placebo (n=73) | Screened: NR; Eligible: NR; Enrolled: 358; Analyzed: 357; Note: 1 patient in placebo group excluded due to no evidence of HBsAg for 6 months prior to enrollment | N/A | A vs. B vs. C; HBeAg seroconversion and HBV DNA undetectable: 13% (17/135) vs. 16% (22/140) vs. 4% (3/70); RR of A vs. C: 2.94 (95% CI, 0.89 to 9.69); RR of B vs. C: 3.67 (95% CI, 1.14 to 11.83); Sustained ALT response: 65% (64/98) vs. 72% (68/95) vs. 24% (12/50); RR of A vs. C: 2.72 (95% CI, 1.63 to 4.55); RR of B vs. C: 2.98 (95% CI, 1.79 to 4.96); Histologic improvement: 49% (70/142) vs. 56% (80/143) vs. 25% (18/73); RR of A vs. C: 2.00 (95% CI, 1.29 to 3.09); RR of B vs. C: 2.27 (95% CI, 1.48 to 3.48); Treated vs. untreated; HBeAg seroconversion and HBV DNA undetectable: 14.2% (39/275) vs. 4% (3/70); RR 3.31 (95% CI, 1.05 to 10.40); Sustained ALT response: 68.4% (132/193) vs. 24% (12/50); RR 2.85 (95% CI, 1.72 to 4.71); Histologic improvement: 52.6% (150/285) vs. 25% (18/73); RR 2.13 (95% CI, 1.41 to 3.24); HBV DNA by hybridization, detection limit 1.6 pg/mL; seroconversion =loss of antigen and development of antibody; sustained ALT response =2 consecutive normal values with no 2 consecutive abnormal values, or 1 normal value at 52 weeks; histologic improvement =≥2 point decrease in Knodell necroinflammatory score | Mortality: None | A + B vs. C; Serious adverse events 1.8% (5/285) vs. 0% (0/73) RR 2.9 (95% CI, 0.2 to 51); Any adverse event 78.6% (224/285) vs. 77% (56/73) RR 1.0 (95% CI, 0.9 to 1.2); (combined treatment arms)
Lampertico 1997^80^; From prior report | A. Interferon alfa 2b 6 MU intramuscular injection 3x/week (n=21); B. No treatment (n=21) | Screened: NR; Eligible: NR; Enrolled: 42; Analyzed: unclear | N/A | A vs. B; 2-year outcomes (end of treatment); HBsAg loss: 0/21 vs. 0/21; Loss of HBV DNA + ALT normalization: 38% (8/21) vs. 10% (2/21); RR 4.0 (95% CI, 0.96 to 17); HAI (Knodell score) improvement (paired biopsy data available for 13 treated and 13 untreated patients): 33% (7/21) vs. 10% (2/21); RR 3.5 (95% CI 0.82 to 15);; 3-year outcomes (post treatment); Loss of HBsAg: 10% (2/21) vs. 0% (0/21); RR 5 (95% CI, 0.25 to 98); Loss of HBV DNA + ALT normalization: 29% (6/21) vs. 0% (0/21); RR 13 (95% CI, 0.78 to 217); Loss of HBsAg and/or HBV DNA: 33% (7/21) vs. 0% (0/21); RR 15 (95% CI, 0.91 to 247); HBV DNA by hybridization, detection limit 1 pg/mL | A vs. B; HCC: 4.8% (1/21) vs. 0% (0/21); RR 3 (95% CI, 0.13 to 70) | A vs. B; Withdrawals due to adverse events : 4% (5/21) vs. 0% (0/21) RR 11 (95% CI, 0.65 to 187)
Lin 1999^81^; From prior report; Additional publication: Liaw 1994 ^168^ | A. Interferon alfa 2a 4 to 5 MU/m^2^ (n=67); B. Placebo (n=34) | Screened: NR; Eligible: NR; Enrolled: 120; Analyzed: 101 | Age, baseline; ALT, baseline; HBV DNA, preexisting cirrhosis, AFP level, duration of HBV, treatment regimen | A vs. B.; ALT normalization: 48.7% (37/76) vs. 20% (8/40), RR 2.43 (95% CI, 1.26 to 4.72); Composite outcome (HBeAg + HBV DNA loss): 13.2% (10/76) vs. 0% (0/40), RR 11.18 (95% CI, 0.67 to 186); HbeAg seroconversion: 42% (28/67) vs. 24% (8/34); Seroclearance: 62% (41/67) vs. 67% (23/34); HbsAg loss: 0% (0/67) vs. 0% (0/34) | A vs. B; Mortality: 1.5% (1/67) vs. 12% (4/34); RR 0.13 (95% CI, 0.01 to 1.09); HCC: 1.5% (1/67) vs. 12% (4/34); RR 0.13 (95% CI, 0.01 to 1.09); Incident cirrhosis: 12% (8/67) vs. 15% (5/34); RR 0.81 (95% CI, 0.29 to 2.29) | NR
Marcellin 2003^82^; From prior report | A. Adefovir 10 mg daily (n=172); B. Placebo (n=170); Excluding adefovir 30 mg daily (n=173); FDA-approved dose is 10 mg | Screened: NR; Eligible: NR; Enrolled: 342; Analyzed: 329 for histologic outcomes; Note: 4 patients (1 in group A, 3 in group B) took no study medications and were excluded after randomization, baseline n=171 in group A, 167 in group B | Adjustments made for 7 geographic regions | A vs. B; HBV DNA undetectable: 21.1% (36/171) vs. 0% (0/167); RR 71.30 (95% CI, 4.41 to 1,152.4); HBeAg loss: 24.0% (41/171) vs. 10.6% (17/161); RR 2.27 (95% CI, 1.35 to 3.83);; HBeAg seroconversion: 11.7% (20/171) vs. 5.6% (9/161); RR 2.09 (95% CI, 0.98 to 4.46); ALT normalization: 48.2% (81/168) vs. 15.9% (26/164); RR 3.04 (95% CI, 2.07 to 4.47); Histologic improvement (unassessable data: 1 to 2%, missing data: 9 to 10%): 53.0% (89/168) vs. 25.5% (41/161); adjusted RR 2.08 (95% CI, 1.54 to 2.81); HBV DNA by PCR, detection limit 400 copies/mL; seroconversion =loss of antigen and development of antibody; histologic improvement =≥2 point decrease in Knodell necroinflammatory score without increase in Knodell fibrosis score | NR | A vs. B; Overall adverse events: NR; Serious adverse events: NR (severe only); Withdrawal due to adverse events: 1.83% (3/171) vs. 0.6% (1/167); Diarrhea: 13.5% (23/171) vs. 7.8% (13/167); Nausea: 9.9% (17/171) vs. 13.8% (23/167); Note: n values calculated from proportions provided by study, based on the number of participants at baseline; Combined treatment arms
Mazzella 1999^83^; From prior report | A. Interferon alfa, 5 MU/m^2^ 3 times weekly for 6 months, mean total dose 648 MU (n=33); B. No treatment (n=31) | Screened: NR; Eligible: NR; Enrolled: 64; Analyzed: 64 | N/A | A vs. B; HBV DNA loss: 78.8% (26/33) vs. 58.1% (18/31); RR 1.36 (95% CI, 0.96 to 1.92); HBsAg loss: 36.4% (12/33) vs. 9.7% (3/31); RR 3.76 (95% CI, 1.17 to 12.06); HBeAg loss: 90.9% (30/33) vs. 61.3% (19/31); RR 1.48 (95% CI, 1.10 to 2.00); ALT normalization: 66.7% (22/33) vs. 35.5% (11/31); RR 1.88 (95% CI, 1.10 to 3.20); Definition of HBV DNA loss unclear; detection limit reported for PCR, but data in Table 2 from hybridization assay | A vs. B; Mortality: 0% (0/33) vs. 6.5% 2/31; RR 0.19 (95% CI, 0.01 to 3.77); HCC: 3.0% (1/33) vs. 6.5% (2/31); RR 0.47 (95% CI, 0.04 to 4.92); Incident cirrhosis: 12.1% (4/33) vs. 19.4% (6/31); RR 0.63 (95% CI, 0.2 to 2.01) | NR
Muller 1990^84^; From prior report | A. Interferon alfa 2b 3 MU subcutaneous 3x/week (n=30); B. No treatment (n=28) | Screened: NR; Eligible: NR; Enrolled: 58; Analyzed: 55 | N/A | A vs. B; Complete response: 3.6% (1/28) vs. 0% (0/27); RR 2.90 (95% CI, 0.12 to 68.15); Partial response: 28.6% (8/28) vs. 0% (0/27); RR 16.41 (95% CI, 0.99 to 271.15); HBV DNA by hybridization, detection limit NR; complete response =elimination of HBsAg, HBeAg, and HBV DNA and normalization of ALT; partial response =elimination of HBeAg and HBV DNA and normalization of ALT while HBsAg persisted | NR | Interferon alfa 2b (no results presented for untreated group); Withdrawals due to adverse events: 3.3% (1/30)
Realdi 1990^88^; From update | A. Interferon alfa-2a 4.5 MU thrice weekly (n=39); B. No treatment (n=40) | Screened: NR; Eligible: NR; Enrolled (randomized): 82; Analyzed: 79 | N/A | A vs. B; End of treatment:; HBV DNA negative: 13/39 (33%) vs. 5/40 (12.5%); HBeAg negative: 8/39 (20.5%) vs. 4/40 (10%); ALT normal: 12/39 (31%) vs. 5/40 (12.5%); End of followup:; HBV DNA negative: 16/39 (41%) vs. 10/40 (25%); HBeAg negative: 13/39 (33%) vs. 6/40 (15%); ALT normal: 23/39 (59%) vs. 14/40 (35%); Liver biopsy fibrosis score: 1.3 vs. 1.1 | NR | Side effects of interferon mild (41%) or moderate (51%); no mention of harms in nontreated group; no specific harms mentioned; Withdrawals due to adverse events: 0% (0/39) vs. 0% (0/40)
Tassopoulos 1999^85^; From prior report | A. Lamivudine 100 mg daily (n=60); B. Placebo (n=64) Note: Comparison data only available up to week 26 | Screened: 260; Eligible: 125; Enrolled: 125; Analyzed: 124 | N/A | A vs. B; Week 24; Complete response: 63.0% (34/54) vs. 5.6% (3/54); RR 11.33 (95% CI, 3.70 to 34.69); Partial response: 27.8% (15/54) vs. 20.4% (11/54); RR 1.36 (95% CI, 0.69 to 2.69); HBsAg loss: 0% (0/60) vs. 1.6% (1/64); RR 0.36 (95% CI, 0.015 to 8.55); HBsAg seroconversion: 0 vs. 0; DNA by hybridization, detection limit 2.5 pg/mL; complete response =HBV DNA loss + ALT normalization; partial response =HBV DNA loss without ALT normalization | NR | A vs. B; Any adverse events 46.7% (28/60) vs. 61.5% (40/65); RR 0.76 (95% CI, 0.54 to 1.06); Serious adverse events 5.0% (3/60) vs. 6.2% (4/65); RR 0.81 (95% CI, 0.19 to 3.48); Withdrawal due to adverse events 1.7% (1/60) vs. 0% (0/65); RR 3.25 (95% CI, 0.13 to 78.18); Diarrhea 5.0% (3/60) vs. 3.1% (2/65); RR 1.63 (95% CI, 0.28 to 9.39); Nausea and vomiting (5/60) vs. (1/65); RR 5.42 (95% CI, 0.65 to 45.05)
Thomas 1994^89^; From update | A. Interferon-α2a 2.5 MIU thrice weekly; B. Interferon-α2a 5 MIU thrice weekly; C. Interferon α2a 10 MIU thrice weekly; D. No treatment | Screened: NR; Eligible: 191; Enrolled (randomized): NR; Analyzed: 176 | N/A | A vs. B vs. C vs. D; HBV DNA clearance: 67% (30/45) vs. 60% (28/47) vs. 61% (27/44) vs. 35% (14/40); HBeAg clearance: 33% (15/45) vs. 38% (18/47) vs. 50% (22/44) vs. 15% (6/40); Response:; 33% vs. 34% vs. 43% vs. 13%; Response =complete response + partial response; complete response =suppression of all signs of viral replication and seroconversion from HBeAg and HBsAg and significant improvement of necroinflammatory lesions on followup biopsy; partial response =suppression of signs of viral replication and seroconversion from HBe to anti-HBe with persistence of HBsAG and some signs of improvement in necroinflammatory lesions | NR | Only provided for interferon groups
Tseng 2014^90^; From update | A. Entecavir 0.5 mg daily (n=22); B. Placebo (n=21) | Screened: 380; Eligible: 95; Enrolled (randomized): 43; Analyzed: 42 (39 for biopsy) | N/A | A vs. B; HBV DNA loss: 73% (16/21) vs. 0% (0/18); RR 28.5 (95% CI, 1.8 to 444); HBeAg loss (of those HBeAg positive at baseline): 29% (2/7) vs. 0% (0/8); RR 5.6 (95% CI, 0.31 to 101); HBeAg seroconversion (of those HBeAg positive at baseline): 29% (2/7) vs. 0% (0/8); RR 5.6 (95% CI, 0.31 to 101); HbsAg loss: 0 vs. 0; HbsAg seroconversion: 0 vs. 0; ALT, mean × ULN: 0.5 (SD 0.2) vs. 0.6 (SD 0.2), p=0.009; Histologic improvement: 38% (8/21) vs. 44% (8/18); RR 0.86 (95% CI, 0.40 to 1.8); HBV DNA by PCR, detection limit 60 IU/mL; seroconversion not defined | NR | NR
Wen 2014^91^; From update | A. Adefovir dipivoxil 10 mg daily (n=252); B. Placebo (n=274) | Screened: NR; Eligible: NR; Enrolled (randomized): 526; Analyzed: NR | N/A but analyzed results for genotypes B and C separately | A vs. B (see figure 2 for all values; estimated); HBV DNA <500IU/mL at 3, 6, 12 months favors A, p≤0.05; HBV DNA decline rate (>3Ig IU/mL) at 3, 6, 12 months favor A, p≤0.05; ALT normalization rate at 3, 6, 12 months favors A, p≤0.05; HBeAg seroclearance rate at 3, 6, 12 months favors A, p≤0.05; HBeAg seroconversion rate at 3, 6, 12 months favors A, p≤0.05; HBV DNA level at 3, 6 months no difference between groups, p>0.05; HBV DNA level at 12 months favors A in genotype B only, p≤0.05 | NR | NR
Yalcin 2004^86^; From prior report | A. Lamivudine 100 mg daily (n=13); B. Control (n=33) | Screened: 53; Eligible: 46; Enrolled: 46; Analyzed: 46 | N/A | A vs. B; Month 3 (on treatment); Transient loss of HBV DNA: 100% (13/13) vs. 0% (0/33); RR 65.57 (95% CI, 4.18 to 1029.05); Month 12 (treatment plus post-treatment followup); Loss of HBV DNA: 7.7% (1/13) vs. 3.0% (1/33); RR 2.54 (95% CI, 0.17 to 37.64); Loss of HBsAg: 0/13 vs. 0/33; RR 2.43 (95% CI, 0.051 to 116.46); HBeAg seroconversion: 7.7% (1/13) vs. 3.0% (1/33); RR 2.54 (95% CI, 0.17 to 37.64); HBeAg seroconversion + HBV DNA loss (At 12 months, or SVR): 7.7% (1/13) vs. 3.0% (1/33); RR 2.54 (95% CI, 0.17 to 37.64); HBV DNA by hybridization, detection limit 1 pg/mL; seroconversion =loss of antigen and development of antibody | NR | A vs. B; Serious adverse events: 0% (0/13) vs. 0% (0/33) RR 2.43 (95% CI, 0.051 to 116.46); Any adverse events, withdrawals due to adverse events, specific adverse events: NR
Yao 1999^87^; From prior report; Additional publications: Yao 2000^169^ and Yao 2009 ^170^ | A. Lamivudine 100 mg daily (n=322); B. Placebo (n=107); N=429 for efficacy, 439 for harms | Screened: 440; Eligible: 429; Enrolled: 429; Analyzed: 429 | N/A | A vs. B; Cumulative undetectable HBV DNA at week 12: 92.2% (270/293) vs. 14.1% (14/99); RR 6.52 (95% CI, 4.01 to 10.56); Sustained undetectable HBV DNA at week 12: 78.2% (229/293) vs. 11.1% (11/99); RR 7.03 (95% CI, 4.02 to 12.32); HBeAg loss: 8.1% (23/284) vs. 5.3% (5/94); RR 1.52 (95% CI, 0.60 to 3.89); Anti-HBe development: 10.2% (29/284) vs. 6.4% (6/94); RR 1.60 (95% CI, 0.69 to 3.73); HBeAg seroconversion: 5.3% (15/284) vs. 4.3% (4/94); RR 1.24 (95% CI, 0.42 to 3.65); Sustained ALT response : 60.3% (91/151) vs. 27.5% (14/51); RR 2.20 (95% CI, 1.38 to 3.49); HBV DNA by hybridization, detection limit 1.6 pg/mL; seroconversion not defined; sustained ALT response =value at or below ULN with no subsequent increases above ULN | NR | A vs. B; Any adverse events : 41.9% (138/329) vs. 40.9% (45/110) RR 1.03 (95% CI, 0.79 to 1.33); Serious adverse events: NR; Withdrawal due to adverse events: 0% (0/329) vs. 0% (0/110) RR 0.34 (95% CI, 0.007 to 16.85); Diarrhea: 4.0% (13/329) vs. 2.7% (3/110) RR 1.45 (95% CI, 0.42 to 4.99); Nausea, vomiting: 4.0% (13/329) vs. 5.5% (6/110); RR 0.72 (95% CI, 0.28 to 1.86)

Abbreviations: AFP = alpha-fetoprotein; ALT = alanine aminotransferase; anti-HBe = antibody to hepatitis B e-antigen; CI = confidence interval; DNA = deoxyribonucleic acid; FDA = U.S. Food and Drug Administration; HAI = histology activity index; HBeAg = hepatitis B e-antigen; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; HCC = hepatocellular carcinoma; N/A = not applicable; NR = not reported; OR = odds ratio; PCR = polymerase chain reaction; RR = relative risk; SD = standard deviation; SVR = sustained virologic response; ULN = upper limit of normal.

Appendix B Table 6 Trials of HBV Antiviral Treatment – Quality Assessment

Author, year; From prior report or update | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Eligibility criteria specified? | Outcome assessors masked? | Care provider masked? | Patient masked? | Attrition and with-drawals reported? | Loss to followup: differential/high? | Analyze people in the groups in which they were randomized? | Quality
Bozkaya 2005^74^; From prior report | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Unclear | No/No | Yes | Fair
Chan 2007^75^; From prior report | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes/No | Yes | Fair
Chang 2006^92^; Gish 2007^171^; Chang 2009^136^; From prior report | Yes | Unclear | Yes | Yes | Yes | Unclear | Yes | Yes | No/No | Yes | Good
Dienstag 1999^76^; From prior report | Unclear | Unclear | Yes | Yes | Yes | Unclear | Unclear | Yes | No | Yes | Fair
Hadziyannis 2003^77^; From prior report | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | No/No | Yes | Fair
Hou 2015^98^; From update | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | No/No | Yes | Good
Lai 1997^79^; From prior report | Yes | Yes | Yes | Yes | Unclear | No | Yes | Yes | No | Yes | Fair
Lai 1998^78^; From prior report | Unclear | Unclear | Yes | Yes | Yes | Unclear | Unclear | Yes | No | Yes | Fair
Lai 2002^94^; From prior report | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | No/No | Yes | Fair
Lai 2006^93^; From prior report | Yes | Unclear | Yes | Yes | Yes | Unclear | Yes | Yes | No/No | Yes | Good
Lampertico 1997^80^; From prior report | Yes | Yes | Yes | Yes | No | No | No | Yes | Unclear | Yes | Fair
Lau 2005^95^; From prior report | Yes | Unclear | Yes | Yes | Yes | Unclear | Yes | Yes | No/No | Yes | Good
Lee 2017^99^; From update | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Yes | Yes | No/Yes | Yes | Fair
Lin 1999^81^, Liaw 1994^168^; From prior report | Yes | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | No | Yes | Fair
Marcellin 2003^82^; From prior report | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | No/No | Unclear | Fair
Marcellin 2008^96^ (2 studies in article); From prior report | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | No/No | Yes | Fair
Mazzella 1999^83^; From prior report | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | No | Yes | Fair
Muller 1990^84^; From prior report | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | No | Yes | Fair
Realdi 1990^88^; From update | Unclear | Unclear | No | Yes | Unclear | Unclear | Unclear | Yes | No/No | Yes | Fair
Ren 2007^97^; From prior report | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | No/No | Yes | Fair
Suh 2010^100^; From update | Unclear | Unclear | No | Yes | Unclear | No | No | Yes | No/No | Yes | Fair
Tassopoulos 1999^85^; From prior report | Yes | Unclear | No | Yes | Yes | Yes | Yes | Yes | No | Yes | Fair
Thomas 1994^89^; From update | Unclear | Unclear | Unclear | Yes | Unclear | No | No | Yes | Unclear/No | Yes | Fair
Tseng 2014^90^; From update | Unclear | Unclear | No | Yes | Yes | Unclear | Unclear | Yes | No/No | Yes | Fair
Wen 2014^91^; From update | Yes | Unclear | Yes | Yes | Unclear | Unclear | Unclear | No | Unclear | Unclear | Fair
Yalcin 2004^86^; From prior report | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | No | Yes | Fair
Yao 1999^87^, Yao 2000^169^, Yao 2009^170^; From prior report | Unclear | Unclear | Yes | Yes | Unclear | Unclear | Yes | Yes | No | Yes | Fair
Yao, 2007^101^; From update | Unclear | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | No/No | Yes | Good
Zheng, 2010^102^; From update | Yes | Unclear | Unclear | Yes | Yes | No | No | Yes | No/No | Yes | Fair

Appendix B Table 7 Trials of HBV Preferred vs. Non-Preferred Treatments – Study Characteristics

Author, year; Quality; From prior report or update | Study design | Number of sites; Country | Study duration; Mean followup | Interventions | Baseline characteristics | Eligibility criteria | Exclusion criteria | Number screened, eligible, enrolled, analyzed | Withdrawals (number, %); Loss to followup (number, %) | Funding source
Chang 2006^92^; Gish 2007^171^; Chang 2009^136^; Good; From prior report | RCT | 137 centers; North America, Asia, Australia, South America | 96 weeks (52 weeks treatment + additional 44 weeks for partial responders; results for responders, partial responders and non-responders included in results) | A. Entecavir 0.5 mg daily (n=354); B. Lamivudine 100 mg daily (n=355) | A vs. B; Age, mean: 35 vs. 35 years; Male: 77% vs. 74%; Race:; Asian: 58% vs. 57%; White: 40% vs. 40%; Black: 2% vs. 2%; Other: <1% vs. 1%; Serology:; HBV DNA: 2.56 vs. 2.61 MEq/mL, 9.62 vs. 9.69 log copies/mL; HBeAg positive: 98% vs. 99%; Anti-HBe negative: 97% vs. 97%; ALT, mean: 140.5 vs. 146.3 IU/L; Histopathology:; Knodell necroinflammatory score, mean (for n=659 with biopsy specimens): 7.8 vs. 7.7; Ishak fibrosis score, mean (n=659): 2.3 vs. 2.3; Cirrhosis: 8% vs. 8%; Prior interferon treatment: 13% vs. 13%; Prior lamivudine treatment: 3% vs. 3% | Age ≥16 years, HBeAg positive, compensated liver function, serum HBsAg present for at least 24 weeks prior to screening, evidence of chronic HBV per liver biopsy, evidence of HBV DNA at least 4 weeks prior to screening, ALT 1.3 to 10x ULN | HCV, HDV or HIV coinfection, other liver disease, use of antiviral agents within 24 weeks of randomization, prior lamivudine use lasting >12 weeks, AFP >100 mg/mL, history of ascites requiring diuretics or paracentesis, previous entecavir treatment | Screened: 1,056; Eligible: NR; Enrolled: 715; Analyzed: 709 | Withdrawals: unclear; 10/715 (1%) withdrew due to adverse events; Loss to follow up: 54/715 (8%) | Bristol Myers Squibb
Hou 2015^98^; Good; From update | RCT | 22 sites; China | 48 weeks duration with open label after week 48 to week 240 | A. Tenofovir disoproxil fumarate 300 mg daily (n=257); B. Adefovir dipivoxil 10 mg daily (n=252) | Age, mean: 36 vs. 36; Male: 83% vs. 83%; Race:; Asian-East Asian Heritage: 100% vs. 100%; HBV DNA log_10_ copies/mL: 7.6 vs. 7.7; HBeAg-positive: 40% vs. 39%; HBV genotype B: 47% vs. 47%; HBV genotype C: 51% vs. 51%; ALT: 159.7 vs. 142.6 | Male and female aged 18 to 69 with HBV DNA ≥10^5^ copies/mL and elevated ALT, HBsAg-positive for >6 months | HCC, decompensated liver disease, liver transplantation, autoimmune hepatitis or other hepatitis, HIV | Screened: 969; Eligible: NR; Enrolled (randomized): 512; Analyzed: 509 | Withdrawals: 12; Loss to followup: 2 | Industry
Lai 2002^94^; Fair; From prior report | RCT | 39 centers; Australia, Belgium, Canada, France, Germany, Hong Kong, Israel, Italy, Malaysia, the Netherlands, the Philippines, Poland, Russia, Singapore, Thailand | 22 weeks (22 weeks treatment + 2 weeks post-treatment) | A. Entecavir 0.5 mg daily (n=46); B. Lamivudine 100 mg daily (n=41); Dose ranging study; results for 0.01 and 0.1 mg not abstracted | A vs. B; Age, median: 31 vs. 29 years; Male: 65% vs. 85%; Race:; Asian/Pacific Islander: 50% vs. 56%; White: 35% vs. 39%; Other: 15% vs. 5%; Serology:; HBV DNA, mean: 8.1 vs. 8.0 log_10_ copies/mL; HBsAg positive: 100%; HBeAg positive: 78% vs. 80%; ALT, median serum: 80.0 vs. 65.0 IU/L; Histopathology: NR; Prior interferon treatment: 24% vs. 20%; Prior lamivudine treatment: 0% vs. 2.4% | Age ≥16 years, HBsAg positive, HBeAg positive or HBeAg negative and anti-HBe positive, HBV DNA >40 MEq/mL, ALT <10x ULN, compensated liver disease | Pregnancy, previous use of immunosuppre-ssive therapy or antiviral therapy within 24 weeks of randomization, HIV, HCV or HDV infection, serious medical illness, pancytopenia, alcohol or drug abuse | Screened: 431; Eligible: NR; Enrolled: 185; Analyzed: 169 (87 A vs. B) | Withdrawals: 8/185 (4%); Loss to followup: None reported | NR
Lai 2006^93^; Good; From prior report | RCT | 146 centers; Europe, Middle East, Asia, Australia, North America, South America | 52 weeks (time on treatment; responders followed for 24 weeks post-treatment, partial responders given an additional 44 weeks of treatment); mean followup 56 weeks | A. Entecavir 0.5 mg daily (n=325); B. Lamivudine 100 mg daily (n=313) | A vs. B; Age, mean: 44 vs. 44 years; Male: 76% vs. 75%; Race:; White: 59% vs. 56%; Asian: 38% vs. 41%; Black: 2% vs. 2%; Other: <1% vs. <1%; Serology: HBV DNA, mean: 1.2 vs. 1.2 MEq/mL, 7.6 vs. 7.6 log_10_ copies/mL; HBeAg positive: 1% vs. 1%; Anti-HBe positive: 99% vs. 100%; ALT, mean: 141 vs. 143 IU/L; Histopathology:; Knodell necroinflammatory score, mean (for n=596 patients with biopsy specimens): 8.0 vs. 7.7; Ishak fibrosis score, mean (n=596): 2.4 vs. 2.5; Cirrhosis: 5% vs. 10%; Prior HBV treatment: 15% vs. 14% | Age ≥16 years, HBeAg negative, compensated liver function, serum HBsAg present for at least 24 weeks prior to screening, evidence of chronic HBV per liver biopsy, evidence of HBV DNA at least 4 weeks prior to screening, ALT 1.3 to 10 × ULN | HCV, HDV or HIV coinfection, other liver disease, use of antiviral agents within 24 weeks of randomization, prior lamivudine use lasting >12 weeks, AFP >100 ng/mL, history of ascites requiring diuretics or paracentesis, previous entecavir treatment | Screened: 1,468; Eligible: 694; Enrolled: 648; Analyzed: 638 | Withdrawals: 31/638 (5%); Loss to followup: None reported | Bristol Myers Squibb
Lau 2005^95^; Good; From prior report | RCT | 67 centers; 16 countries in Asia, Australasia, Europe, North America, South America | 72 weeks (48 weeks treatment + 24 weeks followup) | A. Pegylated interferon alfa 2a 180 μg per week + placebo (n=271); B. Lamivudine (100 mg) (n=272); n=543 (excluding 271 patients randomized to peg interferon + lamivudine combination therapy) | Age, mean: 32.5 vs. 31.6 years; Male: 79% vs. 79%; Race:; Asian: 87% vs. 85%; White: 9% vs. 12%; Black: 1% vs. 1%; Other: 2% vs. 2%; Serology:; HBV DNA, mean: 9.9 vs. 10.1 log_10_ copies/mL; HBsAg positive: 100%; HBeAg positive: 100% ALT, mean: 114.6 vs. 102.3 IU/L; Histopathology:; Bridging fibrosis or cirrhosis: 18% vs. 17%; Prior interferon treatment: 11% vs. 12%; Prior lamivudine treatment: 11% vs. 15% | HBsAg positive for at least 6 months, anti-HBs negative, HBeAg positive, HBV DNA >500,000 copies/mL, ALT >1 and <10x ULN, chronic HBV confirmed by liver biopsy | Decompensated liver disease, coexisting serious medical or psychiatric illness, neutrophil count <1500/mL^3^, platelet count <90,000/mL^3^, creatinine >1.5x ULN, history of alcohol or drug abuse, HIV, HCV or HDV coinfection, HBV treatment within 6 months of study | Screened: NR; Eligible: NR; Enrolled: n=543 (excluding 271 patients randomized to peg interferon + lamivudine combination therapy); Analyzed: 543 | Withdrawals: 70/543 (13%); Loss to followup: NR | Roche Pharmac-euticals
Lee 2017^99^; Fair; From update | RCT | 16 sites; South Korea | 96 weeks duration with open label after week 96 to week 240 | A. Entecavir 0.5 mg once daily; B. Lamivudine 100 mg once daily | Age, mean: 46 vs. 49; Male: 84% vs. 75%; Race: NR (set in South Korea); HBV DNA log_10_ copies/mL: 6.1 vs. 5.8; ALT: 111 vs. 94; Prior interferon: 3.6% vs. 0% | Male and female 17 years and up who were HBeAg-negative, antiHBe-positive for ≥ 6 months; naïve to long-term nucleos(t)ide analogue treatment; compensated liver function, HBV DNA ≥ 10^5^ copies, international normalized ratio ≤ 1.5, albumin ≥ 3 g/dL, bilirubin ≤ 2.5 mg/dL | Interferon treatment within 24 weeks of randomization, HIV, HCV, HDV, HCC, pregnancy | Screened: 200; Eligible: 122; Enrolled (randomized): 122; Analyzed: 106 (double-blind treatment period); Analyzed: 61 (open-label extension | Double-blind period:; Withdrawals: 14; Loss to followup: 2; Open-label extension:; Withdrawals: 28; Loss to followup: 3; Did not participate: 14 | Industry
Marcellin 2008^96^; Fair; Study 102 (HBeAg negative at baseline); From prior report | RCT | 106 centers; 15 countries in Europe, North America, Australia and New Zealand | 48 weeks (time on treatment) | A. Tenofovir disoproxil fumarate 300 mg daily (n=250); B. Adefovir dipivoxil 10 mg daily (n=125) | Age, mean: 44 vs. 43 years; Male: 77.2% vs. 77.6%; Race:; White: 64.4% vs. 64.5%; Asian: 25.2% vs. 24.0%; Black: 3.2% vs. 3.2%; Other: 7.2% vs. 8.0%; Serology:; HBV DNA, mean: 6.86 vs. 6.98 log_10_ copies/mL; HBsAg positive: 100%; HBeAg positive: 0%; ALT, mean: 127.5 vs. 163.6 IU/mL; Histopathology:; Knodell necroinflammatory score, mean: 7.8 vs. 7.9; Knodell fibrosis score, mean: 2.3 vs. 2.4; Cirrhosis: 18.8% vs. 20.0%; Prior treatment with lamivudine or emtricitabine: 17.2% vs. 18.4%; Prior treatment with interferon: 16.8% vs. 18.4% | Age 18 to 69 years, compensated liver disease, Knodell necroinflammatory score ≥3 (scale 0 to 18, higher score=more severe hepatitis), HBsAg positive for at least 6 months before screening, ALT >1 to <10x ULN, HBV DNA >10^5^ copies/mL, <12 weeks treatment with any nucleoside or nucleotide or use of lamivudine or emtricitabine for at least 12 weeks | HIV, HCV or HDV infection, evidence of HCC, creatinine clearance <70 mL/minute, hemoglobin <8 g/dL, neutrophil count <1000/mL^3^, liver decompensation or failure | Screened: 846; Eligible: 382; Enrolled: 375; Analyzed: 375 | Withdrawals: 10/375 (2.7%); Loss to followup: 1/375 (0.3%) | Gilead Sciences
Marcellin 2008^96^; Fair; Study 103 (HBeAg positive at baseline); From prior report | RCT | 106 centers; 15 countries in Europe, North America, Australia and New Zealand | 48 weeks (time on treatment) | A. Tenofovir disoproxil fumarate 300 mg daily (n=176); B. Adefovir dipivoxil 10 mg daily (n=90) | Age, mean: 34 vs. 34 years; Male: 67.6% vs. 71.1%; White: 52.3% vs. 51.1%; Asian: 36.4% vs. 35.6%; Black: 7.4% vs. 5.6%; Other: 4.0% vs. 7.8%; Serology:; HBV DNA, mean: 8.64 vs. 8.88 log_10_ copies/mL; HBsAg positive: 100%; HBeAg positive: 100%; ALT, mean: 142 vs. 155 IU/mL; Histopathology:; Knodell necroinflammatory score, mean: 8.3 vs. 8.3; Knodell fibrosis score, mean: 2.3 vs. 2.4; Cirrhosis: 19.8% vs. 19.5%; Prior treatment with lamivudine or emtricitabine: 4.5% vs. 1.1%; Prior treatment with interferon: 17.0% vs. 14.4% | Age 18 to 69 years, compensated liver disease, Knodell necroinflammatory score ≥3 (scale 0 to 18, higher score=more severe hepatitis), HBsAg positive for at least 6 months before screening, ALT >2 to <10x ULN, HBV DNA >10^6^ copies/mL, <12 weeks treatment with any nucleoside or nucleotide | HIV, HCV or HDV infection, evidence of HCC, creatinine clearance <70 mL/minute, hemoglobin <8 g/dL, neutrophil count <1000/mL^3^, liver decompensation or failure | Screened: 603; Eligible: 272; Enrolled: 266; Analyzed: 266 | Withdrawals: 15/266 (5.6%); Loss to followup: noted but number NR | Gilead Sciences
Ren 2007^97^; Fair; From prior report | RCT | Single center; China | 48 weeks (time on treatment) | A. Entecavir 0.5 mg daily (n=21); B. Lamivudine 100 mg daily (n=21); n=42 (excluding 19 patients who previously failed lamivudine treatment and were switched to entecavir) | A vs. B; Age, mean: 33 vs. 31 years; Male: 57.1% vs. 52.4%; Race: NR, conducted in China; Serology: HBV DNA, mean: 8.52 vs. 8.49 log_10_ copies/mL; HBsAg positive: 100%; HBeAg positive: 100%; ALT, mean: 211 vs. 202 IU/L; Histopathology: NR; Prior HBV treatment: 100% | Age 19 to 68 years, HBeAg positive chronic HBV, compensated liver function, serum bilirubin ≤2.5 mg/dL, prothrombin time not more than 3 seconds longer than normal, serum albumin at least 3 g/dL, no history of variceal bleeding or hepatic encephalopathy, detectable HBsAg, HBV DNA positive, serum ALT 1.3 to 10 X ULN | HIV, HCV or HDV infection, other liver disease, use of interferon, thymosin or HBV antivirals within 24 weeks of randomization, prior lamivudine therapy lasting more than 12 weeks, AFP >100 ng/mL, history of ascites requiring diuretics or paracentesis, previous treatment with entecavir or adefovir | Screened: NR; Eligible: NR; Enrolled: 61; Analyzed: unclear of efficacy, 61 for harms | Withdrawals: 1.6% (1/61); Loss to followup: None reported | NR
Suh 2010^100^; Fair; From update | RCT | Multicenter, number NR; South Korea | 16 weeks (12 weeks’ treatment) | A. Entecavir 0.5 mg daily (n=21); B. Telbivudine 600 mg daily (n=23) | A vs. B; Age, mean: 33 vs. 36 years; Male: 57.1% vs. 78.3%; Race: 100% South Korean; Serology:; HBV DNA, mean: 9.72 vs. 10.29 log_10_ copies/mL; ALT, mean: 170.2 vs. 163.1 IU/L; Histopathology: NR; Prior HBV treatment: not reported | Age ≥18 years, HBeAg+ compensated chronic HBV. detectable HBsAg for ≥24 weeks, HBV DNA ≥7 log_10_ copies/ml, ALT 1.3 to 10.0x ULN, and evidence of chronic liver inflammation. | HCV, HDV, or HIV infection; interferon or other immunomodulatory agents within 12 months; any previous treatment with oral nucleoside or nucleotide analog agents; conditions requiring systemic corticosteroids or hepatotoxic or nephrotoxic medications | Screened: NR; Eligible: NR; Enrolled (randomized): 44; Analyzed: 44 | Withdrawals: 0% (0/44); Loss to followup: None reported | Novartis Pharma
Yao 2007^101^; Good; From update | RCT | 26 centers; China | Treatment 48 to 96 weeks based on response; mean treatment 51.1 vs. 50.5 weeks | A. Entecavir 0.5 mg daily (n=261); B. Lamivudine 100 mg daily (n=264) | A vs. B; Age, mean: 30 vs. 30 years; Male: 82% vs. 83%; HBV DNA, mean: 8.64 vs. 8.48 log_10_ copies/mL; HBeAg+: 87% vs. 85%; ALT, mean: 196 vs. 198 U/L; Prior interferon treatment: 14% vs. 16% | ≥16 years, compensated chronic HBV, HBV DNA ≥3.0 MEq/ml, ALT 1.3–10x ULN | HCV, HDV, or HIV infection; > 12 weeks’ therapy with a nucleoside or nucleotide analog active against HBV; therapy with any anti-HBV drug within 24 weeks | Screened: 962; Eligible: 525; Enrolled (randomized): 525; Analyzed: 519 | Withdrawals: 3.1% (16/519); Loss to followup: 0.8% (4/519) | NR
Zheng, 2010^102^; Fair; From update | RCT | Single center; China | 24 weeks | A. Entecavir 0.5 mg daily (n=66); B. Telbivudine 600 mg daily (n=65) | A vs. B; Age, mean: 33.5 vs. 31.6 years; Male: 63.6% vs. 75.4%; HBV DNA, mean: 7.51 vs. 7.45 log_10_ copies/mL; ALT, mean: 160.3 vs. 167.3 U/L | 18 to 65 years, HBeAg+ compensated chronic HBV, no prior treatment with nucleosides or nucleotides for HBV, HBV DNA ≥6 log_10_ copies/mL | HIV, HCV, or HDV; pregnancy, breastfeeding, alcohol abuse, impaired renal function, muscular disease, or serum creatinine phosphokinase >190 U/L | Screened: 286; Eligible: 131; Enrolled (randomized): 131; Analyzed: 131 | Withdrawals (non-compliance): 0.8% (1/131); Loss to followup: 2.3% (3/131) | Scientific Research Foundation, Zhejiang Province

Abbreviations: AFP = alpha-fetoprotein; ALT = alanine aminotransferase; anti-HBs = antibody to hepatitis B surface antigen; anti-HBe = antibody to hepatitis B e-antigen; DNA = deoxyribonucleic acid; HBeAg = hepatitis B e-antigen; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; HCC = hepatocellular carcinoma; HCV = hepatitis C virus; HDV = hepatitis D virus; MEq = mega equivalents; NR = not reported; RCT = randomized controlled trial; ULN = upper limit of normal.

Appendix B Table 8 Trials of HBV Preferred vs. Non-Preferred Treatments – Results

Author, year; From prior report or update | Interventions | Number screened, eligible, enrolled, analyzed | Adjusted variables for statistical analysis | Intermediate outcomes | Clinical health outcomes | Adverse events
Chang 2006^92^; Gish 2007^171^; Chang 2009^136^; From prior report | A. Entecavir 0.5 mg daily (n=354); B. Lamivudine 100 mg daily (n=355) | Screened: 1,056; Eligible: NR; Enrolled: 715; Analyzed: 709 | N/A | A vs. B; Blood tests (week 96, data from Chang 2009, Figure 2: HBV DNA loss: 80% (284/354) vs. 39% (137/355); RR 2.1 (95% CI, 1.8 to 2.4); HBsAg loss: 5% (18/354) vs. 3% (10/355); RR 1.8 (95% CI, 0.9 to 3.9); HBsAg seroconversion: 2% (6/354) vs. 2% (8/355); RR 0.75 (95% CI, 0.26 to 2.1); HBeAg seroconversion: 31% (110/354) vs. 25% (89/355); RR 1.2 (95% CI, 0.98 to 1.6); ALT normalization (≤1x ULN): 87% (307/354) vs. 79% (280/355); RR 1.1 (95% CI, 1.03 to 1.2); Histologic improvement (week 48): 72% (226/314) vs. 62% (195/314); RR 1.2 (95% CI, 1.03 to 1.3); HBV DNA by PCR, detection limit 300 copies/mL; seroconversion =antigen loss and antibody development; histologic improvement =Knodell necroinflammatory score improvement ≥2 points with no worsening of fibrosis score among patients with adequate biopsy specimen | A vs. B; HCC: 0.3% (1/354) vs. 0% (0/355); RR 3.0 (95% CI, 0.12 to 74); Mortality: 0.6% (2/354) vs. 1% (4/355); RR 0.5 (95% CI, 0.09 to 2.72) | A vs. B; Serious adverse events: 8% (27/354) vs. 8% (30/355); RR 0.9 (95% CI, 0.6 to 1.5); Withdrawals due to adverse events: 0.3% (1/354) vs. 3% (9/355); RR 0.1 (95% CI, 0.01 to 0.9); Any adverse event: 86% (306/354) vs. 84% (297/355); RR 1.0 (95% CI, 0.97 to 1.1)
Hou 2015^98^; From update | A. Tenofovir disoproxil fumarate 300 mg daily (n=257); B. Adefovir dipivoxil 10 mg daily (n=255) | Screened: 969; Eligible: NR; Enrolled (randomized): 512; Analyzed: 509 | N/A | A vs. B; HBV DNA <400 copies/mL: 88.7% vs. 50.4%; Mean log reduction in HBV DNA: −5.5 vs. −4.3; ALT normalization: 80.9% vs. 79.0%; Virologic breakthrough: 0% vs. 2.4%; HBsAg loss: 0% vs. 0%; HBeAg loss: 7.0% vs. 4.0%; Histological Improvement: 75.9% of 83 vs. 73.7% of 99 | A vs. B; Mortality: 0.39 (1/257) vs. 0% (0/252) | A vs. B; Withdrawals due to adverse events: 0.39% vs. 0%; Serious adverse events: 0.8% vs. 2.4%; Any adverse event: 32.2% (83/257) vs. 27.8% (70/252); Grade 3/4 abnormality: 16.0% vs. 9.5%; ALT: 8.9% vs. 7.1%; AST: 2.7% vs. 1.6%; Bilirubin: 0.4% vs. 0%; Platelets: 1.6% vs. 0.8%; Prothrombin time: 1.2% vs. 1.2%; Neutrophils: 1.2% vs. 0%
Lai 2002^94^; From prior report | A. Entecavir 0.5 mg daily (n=46); B. Lamivudine 100 mg daily (n=41); Dose ranging study; results for 0.01 and 0.1 mg not abstracted | Screened: 431; Eligible: NR; Enrolled: 185; Analyzed: 169 (87 A vs. B) | N/A | A vs. B; HBV DNA undetectable: 24% (11/46) vs. 17% (7/41); RR 1.4 (95% CI, 0.60 to 3.3); HBeAg loss (among HBeAg positive patients): 0% (0/36) vs. 6% (2/33); RR 0.2 (95% CI, 0.01 to 3.7); Anti-HBe seroconversion: 0% (0/36) vs. 3% (1/33); RR 0.3 (95% CI, 0.01 to 7.3); ALT normalization (among patients with elevated ALT at baseline): 69% (20/29) vs. 59% (13/22); RR 1.2 (95% CI, 0.8 to 1.8); HBV DNA loss + ALT normalization (and HBeAg loss if HBeAg positive at baseline): 16% (7/43) vs. 15% (6/40); RR 1.1 (95% CI, 0.4 to 3.3); HBV DNA by both PCR and hybridization, results reported for PCR, detection limit NR; seroconversion not defined (“seroconversion to anti-HBe”) | None reported | A vs. B; Serious adverse events: None reported; Withdrawals due to adverse events (excluded lamivudine patient with baseline ALT elevation): 0% (0/46) vs. 0% (0/41); RR 0.89 (95% CI, 0.02 to 44); Any adverse event: 65% (30/46) vs. 73% (30/41); RR 0.9 (95% CI, 0.7 to 1.2)
Lai 2006^93^; From prior report | A. Entecavir 0.5 mg daily (n=325); B. Lamivudine 100 mg daily (n=313) | Screened: 1,468; Eligible: 694; Enrolled: 648; Analyzed: 638 | N/A | A vs. B (week 48 of minimum 52 weeks of treatment); HBV DNA loss: 90% (293/325) vs. 72% (225/313); RR 1.3 (95% CI, 1.2 to 1.4); ALT normalization (<1 × ULN): 78% (253/325) vs. 71% (222/313); RR 1.1 (95% CI, 1.0 to 1.2); Histologic improvement: 70% (208/296) vs. 61% (174/287); RR 1.2 (95% CI, 1.02 to 1.3); HBV DNA by PCR, detection limit 300 copies/mL; histologic improvement =≥2 point decrease in Knodell necroinflammatory score with no worsening of fibrosis score, among patients with adequate baseline biopsy specimen | A vs. B; HCC: 0.3% (1/325) vs. 0% (0/313); RR 2.89 (95% CI, 0.12 to 71); Mortality: 0.6% (2/325) vs. 0% (0/313); RR 4.82 (95% CI, 0.23 to 100) | A vs. B; Serious adverse events: 6% (21/325) vs. 8% (24/313); RR 0.8 (95% CI, 0.5 to 1.5); Withdrawals due to adverse events: 2% (6/325) vs. 3% (9/313); RR 0.6 (95% CI, 0.2 to 1.8); Any adverse event: 76% (246/325) vs. 79% (248/313); RR 1.0 (95% CI, 0.9 to 1.04)
Lau 2005^95^; From prior report | A. Pegylated interferon alfa 2a 180 μg per week + placebo (n=271); B. Lamivudine (100 mg) (n=272) n=543 (excluding 271 patients randomized to peg interferon + lamivudine combination therapy) | Screened: NR; Eligible: NR; Enrolled: n=543; (excluding 271 patients randomized to peg interferon + lamivudine combination therapy); Analyzed: 543 | N/A | A vs. B; 48 weeks (end of treatment):; HBV DNA loss: 25% (68/271) vs. 40% (108/272), RR 0.6 (95% CI, 0.5 to 0.8);; HBeAg loss: 30% (81/271) vs. 22% (59/272), RR 1.4 (95% CI, 1.0 to 1.8); HBeAg seroconversion: 27% (72/271) vs. 20% (55/272), RR 1.3 (95% CI, 1.0 to 1.8); ALT normalization: 39% (105/271) vs. 62% (168/272), RR 0.6 (95% CI, 0.5 to 0.7); HBeAg seroconversion + ALT normalization + HBV DNA <100,000 copies/mL: 10% (27/271) vs. 18% (50/272), RR 0.5 (95% CI, 0.4 to 0.8); 72 weeks (end of followup):; HBV DNA loss: 14% (39/271) vs. 5% (14/272); RR 2.8 (95% CI, 1.6 to 5.0); HBsAg seroconversion: 3% (8/271) vs. 0% (0/272); RR 17 (95% CI, 1.0 to 294); HBeAg loss: 34% (91/271) vs. 21% (57/272), RR 1.6 (95% CI, 1.2 to 2.1); HBeAg seroconversion: 32% (87/271) vs. 19% (52/272), RR 1.7 (95% CI, 1.2 to 2.3); ALT normalization: 41% (111/271) vs. 28% (76/272); RR 1.5 (95% CI, 1.2 to 1.9); HBeAg seroconversion + ALT normalization + HBV DNA <100,000 copies/mL: 23% (62/271) vs. 10% (28/272); RR 2.2 (95% CI, 1.5 to 3.4); Histologic improvement : 38% (102/271) vs. 34% (93/272); RR 1.1 (95% CI, 0.9 to 1.4); HBV DNA assay unclear, detection limit 400 copies/mL for DNA loss reported above; seroconversion =antigen loss and antibody development; histologic improvement =reduction of at least 2 points in the modified Histology Activity Index (Ishak score) | A vs. B (72 weeks); Mortality: 0% (0/271) vs. 0.4% (1/272) | A vs. B (through week 56); Serious adverse events: 4% (12/271) vs. 2% (5/272); RR 2.4 (95% CI, 0.9 to 6.7); Withdrawals due to adverse events: 3% (8/271) vs. 1% (2/272); RR 4.0 (95% CI, 0.9 to 19); Any adverse event: 89% (240/271) vs. 56% (152/272); RR 1.6 (95 % CI, 1.4 to 1.8)
Lee 2017^99^; From update | A. Entecavir 0.5 mg daily (n=57); B. Lamivudine 100 mg daily (n=65) | Screened: 200; Eligible: 122; Enrolled (randomized): 122; Analyzed: 106 (double-blind treatment period); Analyzed: 61 (open-label extension | N/A | A vs. B (Double-blind treatment period); HBV DNA <300 copies/mL: 94.6% vs. 48.4%, p<0.0001; Mean log reduction in HBV DNA: see figure 3; ALT normalization: 87.5% vs. 51.3%, p<0.0001; Virologic breakthrough: 1.8% vs. 42.6%, p<0.001 | Mortality: 1.8% (1/56) vs. 0% (0/64) | A vs. B (through open-label extension); Withdrawals due to adverse events: 0% vs. 1.6%; Serious adverse events: 12.5% vs. 26.6%; A vs. B (though double-blind period); Grade 3/4 abnormalities:; ALT: 0% vs. 9.7%; AST: 0% vs. 4.8%; Creatinine: 3.6% vs. 0%; Bilirubin: 1.8% vs. 4.8%; Glucose (fasting): 9.4% vs. 5.6%; Lipase: 3.6% vs. 6.5%; Platelets: 1.8% vs. 1.6%; Prothrombin time: 1.8% vs. 0%; Neutrophils: 0% vs. 1.6%
Marcellin 2008^96^; Study 102 (HBeAg negative at baseline); From prior report | A. Tenofovir disoproxil fumarate 300 mg daily (n=250); B. Adefovir dipivoxil 10 mg daily (n=125) | Screened: 846; Eligible: 382; Enrolled: 375; Analyzed: 375 | Baseline ALT stratum | A vs. B; HBV DNA loss (<400 copies/mL): 93.2% (233/250) vs. 63.2% (79/125); ARD 30.3 (95% CI, 21.3 to 39.2); RR 1.47 (95% CI, 1.28 to 1.69); HBsAg loss: 0% (0/250) vs. 0% (0/125); RR 0.50 (95% CI, 0.01 to 25.15); ALT normalization (among patients with elevated ALT as baseline): 76.3% (180/236) vs. 77.1% (91/118); ARD −0.8 (95% CI, −10.2 to 8.5); RR 0.99 (95% CI, 0.88 to 1.12); Histologic improvement: 72.4% (181/250) vs. 68.8% (86/125); ARD 5.2 (95% CI, −4.5 to 14.9); RR 1.05 (95% CI, 0.91 to 1.21); HBV DNA loss + histologic improvement: 70.8% (177/250) vs. 48.8% (61/125); RR 1.45 (95% CI, 1.19 to 1.77); HBV DNA by PCR, detection limit 169 copies/mL but 400 copies/mL used to define DNA loss; seroconversion not defined (“seroconversion to anti-HBe”); histologic improvement =≥2 point reduction in Knodell necroinflammatory score with no worsening of fibrosis score | No deaths in either group; 3 cases of HCC but results NR according to study group | A (n=426) vs. B (n=215; results for studies 102 and 103 reported together); Any adverse event: 74.4% (317/426) vs. 73.5% (158/215); RR 1.01 (95% CI, 0.92 to 1.12); Serious adverse events overall: 6.3% (27/426) vs. 6.5% (14/215); RR 0.97 (95% CI, 0.52 to 1.82); Assumes serious adverse events listed as drug-related (N=24) are included in overall serious adverse events (N=41); Withdrawals due to adverse events: 1.2% (5/426) vs. 1.4% (3/215); RR 0.84 (95% CI, 0.20 to 3.49); Diarrhea: 6.6% (28/426) vs. 5.1% (11/215); RR 1.28 (95% CI, 0.65 to 2.53); Nausea: 9.4% (40/426) vs. 2.8% (6/215); RR 3.36 (95% CI, 1.45 to 7.81); Renal dysfunction (serum creatinine increase ≥0.5 mg/dL above baseline): 0% (0/426) vs. 0.5% (1/215); RR 0.17 (95% CI, 0.007 to 4.12); Renal dysfunction (creatinine clearance <50 mL/minute): 0% (0/426) vs. 0% (0/215); RR 0.51 (95% CI, 0.01 to 25.41); Vomiting, bone loss, fractures: NR
Marcellin 2008^96^; Study 103 (HBeAg positive at baseline); From prior report | A. Tenofovir disoproxil fumarate 300 mg daily (n=176); B. Adefovir dipivoxil 10 mg daily (n=90) | Screened: 603; Eligible: 272; Enrolled: 266; Analyzed: 266 | Baseline ALT stratum | A vs. B; HBV DNA loss: 76.1% (134/176) vs. 13.3% (12/90); ARD 63.1 (95% CI, 53.8 to 72.3); RR 5.71 (95% CI, 3.35 to 9.73); HBsAg loss: 3.2% (5/158) vs. 0% (0/82); ARD 10.9 (95% CI, 1.9 to 19.9); RR 5.74 (95% CI, 0.32 to 102.59); HBeAg seroconversion: 20.9% (32/153) vs. 17.5% (14/80); ARD 4.7 (95% CI, −5.5 to 14.9); RR 1.20 (95% CI, 0.68 to 2.11); ALT normalization: 68.0% (115/169) vs. 54.4% (49/90); ARD 13.6 (95% CI, 1.1 to 26.1); RR 1.25 (95% CI, 1.01 to 1.55); Histologic improvement: 74.4% (131/176) vs. 67.7% (61/90); ARD 5.8 (95% CI, −5.6 to 17.2); RR 1.10 (95% CI, 0.93 to 1.30); HBV DNA loss + histologic improvement: 66.5% (117/176) vs. 12.2% (11/90); ARD 54.1 (95% CI, 44.6 to 63.6); RR 5.44 (95% CI, 3.10 to 9.56); HBV DNA by PCR, detection limit 169 copies/mL but 400 copies/mL used to define DNA loss; seroconversion not defined (“seroconversion to anti-HBe”); histologic improvement =≥2 point reduction in Knodell necroinflammatory score with no worsening of fibrosis score | No deaths in either group | As above; results for studies 102 and 103 reported together
Ren 2007^97^; From prior report | A. Entecavir 0.5 mg daily (n=21); B. Lamivudine 100 mg daily (n=21) n=42 (excluding 19 patients who previously failed lamivudine treatment and were switched to entecavir) | Screened: NR; Eligible: NR; Enrolled: 61; Analyzed: unclear of efficacy, 61 for harms | N/A | A vs. B; HBV DNA undetectable: 71.4% (15/21) vs. 38.1% (8/21); RR 1.9 (95% CI, 1.0 to 3.5); HBeAg seroconversion: 14.3% (3/21) vs. 19.0% (4/21); RR 0.8 (95% CI, 0.2 to 3.0); ALT normalization: 85.7% (18/21) vs. 76.2% (16/21); RR 1.1 (95% CI, 0.8 to 1.5); HBV DNA by PCR, detection limit NR; seroconversion =antigen loss and antibody development | A vs. B; HCC: 0% (0/21) vs. 0% (0/21); RR not estimable; Mortality: 0% (0/21) vs. 0% (0/21); RR not estimable | Serious adverse events: NR; Withdrawals due to adverse events: NR; Any adverse event: NR; Diarrhea: 28.6% (6/21) vs. 33.3% (7/21); RR 0.86 (95% CI, 0.35 to 2.1)
Suh, 2010^100^; From update | A. Entecavir 0.5 mg daily (n=21); B. Telbivudine 600 mg daily (n=23) | Screened: NR; Eligible: NR; Enrolled (randomized): 44; Analyzed: 44 | N/A | A vs. B; HBV DNA undetectable by week 12: 28.6% (6/21) vs. 8.7% (2/23); RR 3.29 (95% CI 0.74 to 14.54); ALT, mean reduction baseline to week 12, IU/L (SD): 116.3 (162.81) vs. 108.0 (147.87); DNA limit of detection: 300 copies/mL | Not reported | Withdrawals due to adverse events: none; Serious adverse events: NR; Any adverse events: 61.9% (13/21) vs. 39.1% (9/23); RR 1.58 (95% CI 0.86 to 2.91); ALT increased: 4.8% (1/21) vs. 13.0% (3/23); RR 0.37 (95% CI 0.041 to 3.24); AST increased: 0% (0/21) vs. 4.3% (1/23); RR 0.37 (95% CI 0.016 to 8.47); Hypophosphatemia: 0% (0/21) vs. 4.3% (1/23); RR 0.37 (95% CI 0.016 to 8.47); Neutropenia: 0% (0/21) vs. 4.3% (1/23); RR 0.37 (95% CI 0.016 to 8.47); Thrombocytopenia: 0% (0/21) vs. 4.3% (1/23); RR 0.37 (95% CI 0.016 to 8.47)); Nausea: 9.5% (2/21) vs. 0% (0/23); RR 5.45 (95% CI 0.28 to 107.47)
Yao 2007^101^; From update | A. Entecavir 0.5 mg daily (n=261); B. Lamivudine 100 mg daily (n=264) | Screened: 962; Eligible: 525; Enrolled (randomized): 525; Analyzed: 519 | Baseline measurement, HBeAg status | A vs. B at 48 weeks; HBV DNA <0.7 MEq/ml and ALT <1.25x ULN (composite primary endpoint): 90% (231/258) vs. 67% (174/261), p<0.0001; HBV DNA loss: 76% (197/258) vs. 43% (112/261), p<0.0001; HBeAg loss: 18% (41/225) vs. 20% (44/221), p=not significant; HBeAg seroconversion: 15% (33/225) vs. 18% (39/221), p=not significant; ALT normalization: 90% (231/258) vs. 78% (203/261), p=0.0003; HBV DNA limit of detection 300 copies/ml | Mortality: 0% (0/258) vs. 0% (0/261); HCC: 0% (0/258) vs. 0% (0/261) | Withdrawls due to adverse events: 0.4% (1/258) vs. 1% (3/261); RR 0.34 (95% CI 0.035 to 3.22); Serious adverse events: 3% (9/258) vs. 5% (12/261); RR 0.76 (95% CI 0.33 to 1.77); Any adverse event: 60% (154/258) vs. 56% (145/261); RR 1.07 (95% CI 0.93 to 1.25); ALT increased: 7% (17/258) vs. 9% (23/261); RR 0.75 (95% CI 0.41 to 1.37); Diarrhea: 5% (13/258) vs. 2% (4/261); RR 3.29 (1.09 to 9.95)
Zheng, 2010^102^; From update | A. Entecavir 0.5 mg daily (n=66); B. Telbivudine 600 mg daily (n=65) | Screened: 286; Eligible: 131; Enrolled (randomized): 131; Analyzed: 131 | Baseline value of variable | A vs. B at 24 weeks; HBV DNA loss: 57.6% (38/66) vs. 67.7% (44/65), p=0.232; HBeAg loss: 28.8% (19/66) vs. 36.9% (24/65), p=0.321; HBeAg seroconversion: 13.6% (9/66) vs. 24.6% (16/65), p=0.110; ALT normalization: 74.2% (49/66) vs. 78.5% (51/65), p=0.570; HBV DNA detection level 500 copies/mL; HBeAg seroconversion = HBeAg loss with development of anti-HBe antibody | NR | Withdrawls due to adverse events: 0% (0/66) vs. 0% (0/65); Serious adverse events: 0% (0/66) vs. 0% (0/65); Any adverse event: NR; Diarrhea: 3.0% (2/66) vs. 1.5% (1/65), p > 0.999; Creatinine phosphokinase increased: 0% (0/66) vs. 12.3% (8/65), p=0.003

Abbreviations: ALT = alanine aminotransferase; anti-HBe = antibody to hepatitis B e-antigen; ARD = absolute risk difference between groups; AST = aspartate aminotransferase; CI = confidence interval; DNA = deoxyribonucleic acid; HBeAg = hepatitis B e-antigen; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; HCC = hepatocellular carcinoma; N/A = not applicable; NR = not reported; PCR = polymerase chain reaction; RR = relative risk; SD = standard deviation; ULN = upper limit of normal.

Appendix B Table 9 Cohort Studies of HBV Treatment – Study Characteristics

Author, year; Quality | Study design | Number of sites Country | Treatment duration Followup Study period | Interventions (n) | Baseline characteristics | Eligibility criteria | Number screened, eligible, enrolled, analyzed Withdrawals Loss to followup | Funding source
Gordon 2014^103^; CHeCS; Fair | Cohort, retrospective and real time | 4 sites; United States | Median treatment duration: 45 months (interquartile range 22 to 81 months); Followup: Median 5.2 years; Evaluated those diagnosed between the years of 1992 and 2011 | A. HBV treatment, including interferon alpha-2b, pegylated interferon alpha-2a or alpha 2b, lamivudine, entecavir, tenofovir, telbivudine, or adefovir (n=820) 94% received nucleos(t)ide analog therapy, alone or before or after interferon-based therapy, whereas 6% received only interferon or pegylated interferon-based therapy; B. No treatment (n=1,851) | A vs. B; Age: 18% vs. 32% <40, 26% vs. 23% 40 to 50, 30% vs. 23% 50 to 60, 26% vs. 22% >60 years; Male: 70% vs. 50%; Race/ethnicity: 48% vs. 57% Asian or Pacific Islander, 45% vs. 30% white, black, or Native American, 6% vs. 13% unknown; [underlined: Serology]:; HBV DNA: NR; HBeAg positive: NR; Anti-HBe negative: NR; ALT: 43% vs. 21% abnormal, 35% vs. 64% normal, 23% vs. 15% unknown; AST: median APRI score (n=1,463) 0.42; [underlined: Histopathology]:; Fibrosis stage: median FIB4 score (n=1,404) 1.25; Cirrhosis: NR; Major comorbidity (Charlson/Deyo index score of 2 or 3): 9%; HIV positive during followup: 6% | Patients had to fulfill at least 2 criteria, including: 2 positive laboratory tests consistent with current HBV infections (i.e., positive for HBV surface antigen, e-antigen, or DNA test, or a positive laboratory test and an ICD-9 code, or 2 ICD-9 codes) obtained at least 6 months apart; Exclusion: Coinfection with HCV, diagnosis of HCC more than 60 days before the diagnosis of HBV | Screened: 4,158; Eligible: NR; Enrolled: NR; Analyzed: 2,671 after propensity score adjustment; Withdrawals and loss to followup: NR | CDC Foundation, which receives grants from AbbVie, Genentech, Janssen Pharmaceutical Companies of Johnson & Johnson, and Vertex Pharmaceuticals.
Hoang 2016^104^; REVEAL-HBV; Taiwanese Cohort + United States clinics; Fair | Cohort, retrospective | Multisite; United States (Northern California) and Taiwan | Treatment duration: NR; Median followup: 8.9 years; United States study period 1991 to 2014; Taiwanese study period 1991 to 1992 | A. United States cohort, Treated. Any FDA-approved agent or combination: lamivudine, adefovir, entecavir telbivudine, tenofovir, or interferon (n=548); 82% received either entecavir or tenofovir monotherapy or in combination; remainder received adefovir, lamivudine, or pegylated interferon; B. United States cohort, Untreated (n= 754); C. Taiwan REVEAL cohort, Untreated (n=2,363) | A (treated) vs. B+C (untreated); Age, mean: 49.5 vs. 50.8 years; Male: 66.4% vs. 59.3%; Race/ethnicity: 98.2%; Asian overall; HBeAg positivity: 23.7% vs. 10.4%; ALT, median (IU/mL), ALT <2x ULN: 32 vs. 14; ALT, median (IU/mL), ALT ≥2x ULN: 87 vs. 68; HBV DNA, median (log_10_ copies/mL), ALT <2x ULN: 4.7 vs. 3.5; HBV DNA, median (log_10_ copies/mL), ALT ≥2x ULN: 6.0 vs. 4.6 | Patients ages 40 years and older with chronic HBV; Exclusion: Coinfection with HCV, HDV, or HIV, HCC at presentation or within 6 months, cirrhosis at presentation or within 2 years | Screened: NR; Eligible: NR; Enrolled: NR; Analyzed: 3,665; Withdrawals and loss to followup: NR | NR
Hosaka 2013^105^; Fair | Cohort, prospective treatment and retrospective control | Unclear; Japan | Treatment duration: NR; Followup: 1 year or until the last visit before December 2011; entecavir 3.3 years vs. control 7.6 years (p<0.001), but adjusted to 5 years for each group with propensity matching; Study periods: 2004 to 2019 for entecavir treated patients and 1973 to 1999 for untreated control group patients | A. Entecavir, 0.5 mg (n=472, reduced to 316); B. Non-treated control (n=1,143 reduced to 316) | A vs. B (propensity matched cohorts); Age, mean: 46 vs. 46 years; Male: 50.5% vs. 50.5%; Race/ethnicity: NR (Japan); HBeAg positive: 43% vs. 42%; HBV DNA: 6.3 vs. 6.6 log_10_ copies/mL; AST: 45 vs. 49 IU/L; AST: 1.4 vs. 1.5 × ULN; ALT: 61 vs. 60 IU/L; ALT: 1.7 vs. 1.6 × ULN; Preexisting cirrhosis: 25% vs. 29% | Chronically monoinfected with HBV and were confirmed as HBsAg positive for at least 6 months with followup at least 1 year; treatment naïve; Exclusion: Incomplete data or serum samples. For those in control group, excluded if had corticosteroid withdrawal therapy, interferon treatment or nucleos(t)ide analog treatment was initiated during followup, or positive for anti-HCV antibodies | Screened: 2,842; Eligible: NR; Enrolled: 1,615; Analyzed: 632 after propensity score matching; Withdrawals and loss to followup: NR | NR
Lee 2018^106^; Taiwan’s National Health Insurance Research Database; Fair | Cohort, retrospective | Multisite (national database); Taiwan | Treatment duration: nucleos(t)ide therapy mean 3.1 years, median 2.2 years; Followup: mean 5.6 years, median 5.8 years in each arm; Study period: October 1, 2003 to December 31, 2012 | A. Nucleos(t)ide analogue therapy (n=10,062); B. Untreated (n=10,062) | A vs. B (propensity matched cohorts); Age, mean: 45.5 vs. 45.5 years; Male: 80.1% vs. 80.1%; Race/ethnicity: NR (Taiwan); Hepatoprotectant: 0.8 vs. 1.0 years; Alcoholic liver disease: 7.0% vs. 7.0%; Cirrhosis: 26.0% vs. 26.0%; Liver decompensation: 11.5% vs. 11.5% | Chronic HBV infection diagnosed at least 3 times in outpatient clinics or 1 time in a hospitalization; treatment for at least 90 days; Exclusion: Patients with confounding disorders such as infection with HCV, HIV, or other hepatitis-associated viruses, liver flukes, biliary stone diseases, cholangitis, congenital biliary anomalies, biliary tract surgeries, or cancer; Excluded patients treated for less than 90 days | Screened: 185,843; Eligible: 51,707; Enrolled: NR; Analyzed: 20,124 after propensity score matching; Withdrawals and loss to followup: NR; 59% (5,934/10,062) vs. 59% (5,937/10,062) with data available for intrahepatic cholangiocarcinoma analysis at year 5 | National Health Research Institutes, Taichung Veterans General Hospital
Matsumoto 2005^107^; Inuyama Hepatitis Study Group; Fair | Cohort, retrospective | Multicenter (30 institutions); Japan | Treatment duration: median 18.9 months; Followup: lamivudine arm 2.7 years vs. control arm 5.3 years; Study period: 1980 to March 2002; analysis begins at time of liver biopsy | A. Lamivudine, 100 mg/day (n=657, reduced to 377); B. Untreated (n=2,138, reduced to 377) | A vs. B; Age, mean: 41.5 vs. 41.4 years; Male: 73.2% vs. 72.4%; Race/ethnicity: NR (Japan); Previous interferon therapy: 34.2% vs. 37.9%; Liver histology, grade of inflammation:; A0 1.6% vs. 4.8%,; A1 29.2% vs. 26.8%,; A2 41.6% vs. 49.3%,; A3 26.0% vs. 19.1%, unknown 1.6% vs. 0%, p=0.001; Stage of fibrosis:; F0 1.9% vs. 1.6%,; F1 27.3% vs. 31.0%,; F2 25.2% vs. 25.7%,; F3 28.4% vs. 23.9%,; F4 17.2% vs. 17.8%; HBeAg: positive 51.2% vs. 58.4%, negative 47.2% vs. 37.4%, unknown 1.6% vs. 4.2%, p=0.005; HBeAg: positive 33.4% vs. 32.1%, negative 65.0 vs. 62.9%, unknown 1.6% vs. 5.0%, p=0.030; Albumin: 4.00 vs. 4.00 g/dL; AST: 118.5 vs. 95.5 IU/L, p=0.031; ALT: 191.7 vs. 151.5 IU/L, p=0.009; Platelet count: 161.7 vs. 164.3 x1000/mm^3^ | Histologically diagnosed chronic HBV patients; underwent liver biopsy; for those on treatment, started lamivudine within 2 years of liver biopsy; sufficient data available; Exclusion: Excluded coinfection with HCV or HIV; liver biopsy >2 years after starting lamivudine therapy | Screened: 3,022; Eligible: NR; Enrolled: NR; Analyzed: 2,795 (reduced to 754 in propensity-score matching); Withdrawals and loss to followup: Details NR; 45% on lamivudine through end of followup period | Ministry of Health, Labor, and Welfare, Japan
Wang 2015^108^; Taiwan’s National Health Insurance Database; Fair | Cohort, retrospective | Multisite (national database); Taiwan | Treatment duration: mean 1.6 years, median 1.4 years; Followup: 5.3 vs. 5.2 years; Study period: October 1, 2003 to December 31, 2011 | A. Nucleos(t)ide analogue therapy (lamivudine, telbivudine, entecavir, or tenofovir) (n=1,544); B. Untreated (n=1,544) | A vs. B (propensity match cohorts); Age, mean: 42.2 vs. 42.7 years; Male: 72.7 vs. 74.7%; Cirrhosis: 23.4% vs. 24.3%; Ascites: 5.4% vs. 5.6%; Charlson comorbidity index, mean: 0.77 vs. 0.75 | Patients with a first-time diagnosis of HBV infection, who received nucleos(t)ide analogues for at least 90 days; Exclusion: Patients diagnosed with HIV, HCV, other viral hepatitis, alcohol-related disease, or malignant tumors; or if they received interferon or nucleos(t)ide analogue therapy before October 1, 2003, or if they used nucleos(t)ide analogues for <90 days during or before the observational period | Screened: 1,001,932; Eligible: 19,936; Enrolled: NR; Analyzed: 3,088 after propensity score matching; Withdrawals and loss to followup: NR; 30.2% (467/1,544) vs. 33.2% (513/1544) with data available for HCC analysis at year 7, after adjustments, etc. | Taipei Veterans General Hospital, National Science Council, the National Research Program for Biopharmaceutics of Taiwan
Wei 2019^110^; Fair | Cohort, retrospective | 4 sites; US | Treatment duration: NR; Followup: median 4-5 years; 8 year cumulative; Study period: 2008 to 2016 | A. Tenofovir disoproxol fumarate (n=276); B. Entecavir (n=335); C. Untreated (n=613) | A vs. B vs. C; Age, mean: 44.3 vs. 47.4 vs. 46.2, p=0.03; Male: 61.6% vs. 65.4% vs. 51.6%, p<0.001; Asian ethnicity: 100%; Baseline cirrhosis: 16.3% vs. 17.6% vs. 2.6%, p<0.001; APRI interquartile range: 0.35 vs. 0.40 vs. 0.27, p<0.008; FIB-4, interquartile range: 1.06 vs. 1.13 vs. 0.94, p=0.042; Deyo-Charlson Comorbidity Index, mean: 3.76 vs. 3.39 vs. 2.61, p=0.0025; HBeAg positive: 26.3% vs. 24.3% vs. 8.8%, p<0.001; Log10 HBV DNA, IU/mL: 3.96 vs. 4.07 vs. 3.20, p<0.001; AST, U/L, interquartile range: 28 vs. 33 vs. 24, p<0.001; ALT, U/L, interquartile range: 42 vs. 46 vs. 31, p<0.001; Albumin, g/dL: 4.06 vs. 3.95 vs. 4.16, p<0.001; Total bilirubin, mg/dL, interquartile range: 0.7 vs. 0.7 vs. 0.7 | Treatment-naïve, Asian, chronic HBV patients at least 18 years old without baseline osteopenia or osteoporosis; Excluded patients taking medications with increased risk for osteopenia or osteoporosis, and those with HIV or HCV coinfection | Screened: 1,982; Eligible: 1,224; Enrolled: 1,224; Analyzed (baseline): 1,224; Analyzed (outcomes): 1,160; Withdrawals and loss to followup: 5.2% (64/1,224) | Unclear; Five authors have served as either advisory members, speakers, or consultants, or received research support or has stock with from pharmaceutical companies
Wu 2014^109^; Taiwan’s National Health Insurance Research Database; Fair | Cohort, retrospective | Multisite (national database); Taiwan | Treatment duration: mean 1.44 years, median 1.42 years; Followup, mean: 3.46 vs. 5.24 years; Study period: January 1, 1997 to December 31, 2010 | A. Nucleos(t)ide analogue therapy (n=21,595); B. Untreated with nucleos(t)die therapy; used hepatoprotectants for at least 90 days (n=21,595) | A vs. B (propensity match cohorts); Age, mean: 43.5 vs. 43.5 years; Male: 75.5% vs. 76.9%; Hepatoprotective agents, mean: 0.78 vs. 1.24 years, p<0.001; Cirrhosis: 13.2% vs. 14.0%, p=0.018; Liver decompensation: 7.8% vs. 7.6%; Charlson comorbidity index, mean: 0.79 vs. 0.80 | Chronic HBV infection diagnosed at least 3 times in outpatient clinics or 1 time in a hospitalization; treatment for at least 90 days; Exclusion: Patients with HCV, HIV, other viral hepatitis, and malignant tumors; excluded patients with HCC diagnosis within first 90 days of start of therapy | Screened: 199,451; Eligible: 72,458; Enrolled: NR; Analyzed: 43,190 after propensity score matching; Withdrawals and loss to followup: NR; 18% (3,966/21,595) vs. 55% (11,780/21,595) with data available for HCC analysis at year 6, after adjustments, etc. | Taiwan’s National Health Research Institutes, Taipei Veterans General Hospital and Department of Health, Center of Excellence for Cancer Research at Taipei Veterans General Hospital and National Yang-Ming University

Abbreviations: ALT = alanine aminotransferase; anti-HBe = antibody to hepatitis B e-antigen; APRI = aspartate aminotransferase to platelet ratio index; AST = aspartate aminotransferase; CDC = Centers for Disease Control; CHeCS = Chronic Hepatitis Cohort Study; DNA = deoxyribonucleic acid; FDA = U.S. Food and Drug Administration; FIB4 = fibrosis-4 index; HBeAg = hepatitis B e-antigen; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; HCC = hepatocellular carcinoma; HCV = hepatitis C virus; HDV = hepatitis D virus; ICD = international classification of disease; NR = not reported; REVEAL = study name is not an acronym; ULN = upper limit of normal.

Appendix B Table 10 Cohort Studies of HBV Treatment – Results

Author, year | Followup | Interventions (n) | Adjusted variables for statistical analysis | Outcomes
Gordon 2014^103^; CHeCS | Median 5.2 years | A. HBV treatment, including interferon alpha-2b, pegylated interferon alpha-2a or alpha 2b, lamivudine, entecavir, tenofovir, telbivudine, or adefovir (n=820); 94% received nucleos(t)ide analog therapy, alone or before or after interferon-based therapy, whereas 6% received only interferon or pegylated interferon-based therapy; B. No treatment (n=1,851) | ALT; Serum markers of cirrhosis; Study site; Patient demographics; Comorbidity Index | A vs. B; HCC; Unadjusted rates: 2.4% (20/820) vs.2.5% (47/1,851) cases, crude incidence rate 4.2 cases per 1,000 person-years; Simple Cox regression, treatment vs. no treatment, aHR 0.50 (95% CI, 0.35 to 0.72), p<0.001; Propensity-adjusted Cox regression, after adjusting for abnormal ALT: lower risk for those who received treatment vs. no treatment, aHR 0.39 (95% CI, 0.27 to 0.56), p<0.001; Subgroup analysis (n=1,404), after adjusting for serum markers of cirrhosis: lower risk for those who received treatment vs. no treatment, aHR 0.24 (95% CI, 0.15 to 0.39), p<0.001; Subgroup analysis (n=1,986), of patients with data available on HBV DNA viral load:; For viral loads >20,000 IU/mL, lower risk for those who received treatment vs. no treatment, aHR 0.17 (95% CI, 0.06 to 0.52), p=0.002; For viral loads 2,000 to 20,000 IU/mL, treatment vs. no treatment: 0.45 (95% CI, 0.14 to 1.47), p=0.185; For viral loads <2,000 IU/mL, treatment vs. no treatment: 0.72 (95% CI, 0.43 to 1.20), p=0.206
Hoang 2016^104^; Taiwanese REVEAL-HBV Cohort + United States clinics | Median 8.9 years | A. United States cohort, Treated. Any FDA-approved agent or combination: lamivudine, adefovir, entecavir telbivudine, tenofovir, or interferon (n=548); 82% received either entecavir or tenofovir monotherapy or in combination; remainder received adefovir, lamivudine, or pegylated interferon; B. United States cohort, Untreated (n= 754); C. Taiwan REVEAL cohort, Untreated (n=2,363) | REACH-B predictive score (validated composite 17-point HCC risk-prediction score based on 5 clinical, laboratory, and virologic parameters, including gender, age, HBeAg status, ALT levels, and HBV DNA levels) | HCC; Number of cases, A vs. B vs. C: 7/548 vs. 15/754 vs.180/2363; Incidence rates per 100,000 person years, A vs. B vs. C: 208.90 vs. 438.52 vs. 488.39; Incidence rates, adjusted for REACH-B score: A vs. B (United States groups only, treatment vs. no treatment): aHR 0.24 (95% CI, 0.10 to 0.58), p=0.0017; A vs. C (United States treatment vs. Taiwan no treatment): aHR 0.32 (95% CI, 0.15 to 0.70), p=0.0042; A vs. B+C (United States treatment vs. both United States and Taiwan untreated groups): aHR 0.31 (95% CI, 0.14 to 0.67), p=0.0027
Hosaka 2013^105^ | Entecavir 3.3 years vs. control 7.6 years (p<0.001), but adjusted to 5 years for each group with propensity matching | A. Entecavir, 0.5 mg (n=472, reduced to 316); B. Non-treated control (n=1,143 reduced to 316 with propensity matching) | Age, sex, cirrhosis, HBeAg, HBV DNA, AST, ALT, gamma glutamyl transpeptidase, bilirubin, albumin, platelet counts | A vs. B; HCC; Cumulative incidence rate at 5 years: 3.7% vs. 13.7%, p<0.001; Cox proportional hazard regression analysis (adjusted for HCC risk factors): benefit to entecavir-treated group vs. no treatment, HR 0.37 (95% CI, 0.15 to 0.91), p=0.030
Lee 2018^106^; Taiwan’s National Health Insurance Research Database | Mean 5.6 years, median 5.8 years in each arm | A. Nucleos(t)ide analogue therapy (n=10,062); B. Untreated (n=10,062) | Age, sex, cirrhosis, liver decompensation, diabetes mellitus, and hyperlidemia | A vs. B; Intrahepatic cholangiocarcinoma; Cumulative incidence, year 3: 1.28% (95% CI, 0.56% to 2.01%) vs. 3.14% (95% CI, 2.02% to 4.27%); Cumulative incidence, year 5: 1.53% (95% CI, 0.73% to 2.33%) vs. 4.32% (95% CI, 2.96% to 5.69%); Multivariable regression analysis, year 5: 0.17% (17/10,062) vs. 0.39% (39/10,062), HR 0.44 (95% CI, 0.25 to 0.78), p=0.005; HCC; Cumulative incidence, year 5: 2.93% (95% CI, 2.57% to 3.28%) vs. 4.75% (95% CI, 4.31% to 5.20%), p<0.001
Matsumoto 2005^107^; Inuyama Hepatitis Study Group | Lamivudine arm 2.7 years vs. control arm 5.3 years | A. Lamivudine, 100 mg/day (n=657, reduced to 377); B. Untreated (n=2,138, reduced to 377) | Age, gender, family clustering of HBV, stage of hepatic fibrosis, serum albumin level, platelet count | HCC; Cox regression analysis: effect of lamivudine therapy vs. no treatment: HR 0.49 (95% CI, 0.31 to 0.77), p=0.002; Propensity-matched analysis; Annual incidence rate: 0.4% patients/year vs. 2.5% patients/year, p<0.001; Number of events: 1.1% (4/377) vs. 13.3% (50/377)
Wang 2015^108^; Taiwan’s National Health Insurance Database | 5.3 vs. 5.2 years | A. Nucleos(t)ide analogue therapy (lamivudine, telbivudine, entecavir, or tenofovir) (n=1,544); B. Untreated (n=1,544) | Sex, age, major coexisting comorbidities (such as diabetes, hypertension, etc.) | HCC; Occurrence, after adjustments, 8.25 year cumulative incidence: 6.0% (95% CI, 4.4% to 7.9%) vs. 8.5% (95% CI, 6.6% to 10.6%), p=0.0025; aHR: 0.64 (95% CI, 0.45 to 0.93), p=0.017; Dose response between nucleos(t)ide analogue use and HCC:; 90 to 365 daily dose: aHR 0.93 (95% CI, 0.58 to 1.48); 366 to 730 daily dose: aHR 0.67 (95% CI, 0.42 to 1.06); >730 daily dose: aHR 0.35 (95% CI, 0.17 to 0.70); Mortality; Occurrence, 8.25 year cumulative incidence: 6.9% (95% CI, 5.3% to 8.7%) vs. 9.4% (95% CI, 7.7% to 11.3%), p=0.0003; aHR: 0.58 (95% CI, 0.43 to 0.79), p<0.001
Wei 2019^110^ | Followup: median 4-5 years; 8 year cumulative | A. Tenofovir disoproxil fumarate (n=276); B. Entecavir (n=335); C. Untreated (n=613) | Age, sex, diabetes, vitamin D deficiency, treatment status, hepatitis B viral load, cirrhosis, PLT, ALT, Deyo Charlton Comorbodity Index | Harms; Osteopenia/osteoporosis; A vs. B vs. C; 8 year cumulative incidence: 13.2% (95% CI 6.95% to 24.21%) vs. 15.1% (95% CI 10.95% to 20.60%) vs. 10.2% (95% CI 6.72% to 15.24%), p=0.22; Multivariable Cox regression; Adjusted for various baseline demographic and clinical factors:; Tenofovir disoproxol fumarate vs. untreated: aHR 0.74 (95% CI 0.34 to 1.59), p=0.44; Entecavir vs. untreated: aHR 0.98 (95% CI 0.51 to 1.90), p=0.96; Additionally adjusted for Deyo Charlton Comorbidity Index:; Tenofovir disoproxol fumarate vs. untreated: aHR 0.69 (95% CI 0.32 to 1.50), p=0.35; Entecavir vs. untreated: aHR 0.89 (95% CI 0.45 to 1.75), p=0.73
Wu 2014^109^; Taiwan’s National Health Insurance Research Database | Mean: 3.46 vs. 5.24 years | A. Nucleos(t)ide analogue therapy (n=21,595); B. Untreated with nucleos(t)die therapy; used hepatoprotectants for at least 90 days (n=21,595) | Age, sex, cirrhosis, liver decompensation, comorbidities, use of statins, use of nonsteroidal anti-inflammatory drugs, use of metformin Conducted sensitivity analysis for differential followup periods between arms | HCC; Incidence: 4.6% (992/21,595) vs. 20.6% (4,454/21,595), p<0.01; 7 year cumulative incidence, adjusted for competing mortality: 7.32% (95% CI 6.77% to 7.7%) vs. 22.7% (95% CI, 22.1% vs. 23.3%), p<0.001; aHR 0.37 (95% CI, 0.34 to 0.39), p<0.001, favors treatment; Death; Death before HCC: 4.8% (1,036/21,595) vs. 11.8% (2,556/21,595), p<0.001; Overall death: 6.5% (1,406/21,595) vs. 22.1% (4,778/21,595), p<0.001

Abbreviations: aHR = adjusted hazard ratio; ALT = alanine aminotransferase; AST = aspartate aminotransferase; CHeCS = Chronic Hepatitis Cohort Study; CI = confidence interval; DNA = deoxyribonucleic acid; FDA = U.S. Food and Drug Administration; HBeAg = hepatitis B e-antigen; HBV = hepatitis B virus; HCC = hepatocellular carcinoma; HR = hazard ratio; REACH-B = risk estimation for hepatocellular carcinoma in chronic hepatitis B; REVEAL = study name is not an acronym.

Appendix B Table 11 Cohort Studies of HBV Treatment – Quality Assessment

Author, year | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria, or a random sample (inception cohort)? | Were the groups comparable at baseline on key prognostic factors (e.g., by restriction or matching)? | Did the study use accurate methods for ascertaining outcomes? | Were outcome assessors and/or data analysts blinded to treatment? | Did the article report the number of patients who met inclusion criteria excluded due to missing data or loss to followup? | Did the study perform appropriate statistical analyses on potential confounders, or appropriately account for them (should evaluate at least age, sex, fibrosis stage, HBV viral load, HBeAg status)? | Is there important (overall or differential) exclusion of patients due to missing data or loss to followup? | Were outcomes pre-specified and defined, and ascertained using accurate methods? | Quality
Gordon 2014^103^ | Yes | Yes | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Hoang 2016^104^ | Yes, there were 2 distinct cohorts from different countries merged together, but also analyzed separately | Unclear | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Hosaka 2013^105^ | Yes, but separately; there were 2 separate cohorts for the treatment and control groups | Yes, by propensity matching | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Lee 2018^106^ | Yes | Yes, by propensity matching | Yes | Unclear | No | Yes | Unclear, 59% remaining at year 5 after adjustments, etc. | Yes | Fair
Matsumoto 2005^107^ | Yes | Mostly, by propensity matching; however still some significant differences | Yes | Yes | No | Yes | Unclear, 45% on remaining on treatment by end of followup period after adjustments, etc. | Yes | Fair
Wang 2015^108^ | Yes | Yes, by propensity matching | Yes | Unclear | No | Yes | Unclear, 30% and 32% remaining at year 7 after adjustments, etc. | Yes | Fair
Wei 2019^110^ | Yes | No, but adjustments were made in analysis | Yes | Unclear | Yes | Yes | No | Yes | Fair
Wu 2014^109^ | Yes | Yes, by propensity matching | Yes | Unclear | No | Yes | Unclear, 18% and 55% remaining at year 6 after adjustments, etc. | Yes | Fair

Abbreviations: HBeAg = hepatitis B e-antigen; HBV = hepatitis B virus.

Appendix B Table 12 Association Studies of HBV Intermediate and Health Outcomes – Study Characteristics

Author, year; Country; From prior report or update | Study design | Comparison; Definition | Treatment; Duration of followup | Inclusion criteria | Number receiving antiviral treatment Lost to followup | Age; Sex; Race | Characteristics of HBV infection | Quality | Funding source
Arends 2015^117^; European network of excellence for VIRGIL Surveillance Study Group; 11 European referral centers; From update | Cohort, retrospective; Study period 2005 to May 2013 | Virological response vs. no virological response; Virological response=HBV DNA <80 IU/mL | Entecavir; Followup, median 3.2 years | All chronic HBV monoinfected patients treated with entecavir for at least 3 months; Excluded: HIV, HCV, or HDV, or if they had HCC at baseline | N=744; Lost to followup: NR | Age, mean: 44 years; Male: 77%; Race/ethnicity: 42% white, 29% Asian, 19% Asian, 10% unknown | HBeAg positive: 32%; HBV DNA, mean: 5.3_log_ IU/mL; Mean ALT: 1.4 xULN; Cirrhosis: 22%; Chinese University HCC risk score, mean: 8; Guide with Age, Gender, HBV DNA, Core Promoter Mutations and Cirrhosis HCC risk score, mean: 62; REACH-B risk score, mean: 9 | Fair | Foundation for Liver and Gastrointestinal Research Rotterdam, European Network of Excellence for Vigilance against Viral Resistance, Bristol Myers Squibb
Baltayiannis 2006^111^; Greece; From prior report | Cohort (unclear if prospective or retrospective) | Virological response at 6 months vs. no virological response; Virological response=HBV DNA <10,000 copies/mL at 6 months of treatment | Interferon alfa; 6 years | HBeAg-negative chronic HBV infection with elevated ALT and histologic evidence of chronic HBV; Excluded: HCC, HCV, HDV, HIV | n=63; Lost to followup: 1.6% (1/63) | Age, mean: 51 years; Male: 63%; Race: NR | HBV DNA, median serum: 1.2 × 10^6^ copies/mL; HBsAg clearance: NR; HBeAg positive: None; ALT, median: 178; AST, median: 130; Fibrosis stage, mean Desmet: 2.2; Cirrhosis: Excluded | Fair | NR
Hui 2008^112^; China (Hong Kong); From prior report | Cohort (unclear if prospective or retrospective) | Histological response in modified HAI score vs. no histological response; Histological response=improvement of 2 points or more on modified HAI score after end of treatment | Interferon alfa 2a or 2b; Median 9.9 years | HBeAg-positive chronic HBV infection; Excluded: HDV, HCV, HIV | n=89; Lost to followup: NR | Age, mean: 30 years; Male: 78%; Race: NR | HBV DNA, serum >10^5^ copies/mL: 100%; HBsAg clearance: NR; HBeAg positive: All; ALT, mean: 113; AST: NR; Fibrosis stage, mean Ishak: 2; Cirrhosis: 12% | Fair | Reports no funding received
Lau 1997^113^; United States; From prior report | Cohort (originally enrolled in RCTs) | Response vs. non-response; Response=Sustained loss of HBV DNA and clearance of HBeAg within 1 year of starting treatment | Interferon alfa; Mean 6.2 years | HBeAg-positive chronic HBV infection with elevated AST and/or ALT; Excluded: HDV, HIV after 1988 | n=103; Lost to followup: 7.8% (8/103); assumed to be alive and without liver-related complications | Age, mean: 41 years; Male: 83%; Race: 94% white, 6% black | Serum HBV DNA: 4843 MEq/mL; HBsAg clearance: 86% (responder) vs. 11% (nonresponder); HBeAg positive: All; ALT, median: 154; AST, median: 94; Fibrosis stage, mean HAI: 2.1; Cirrhosis: 17%; HCV infection: 6.8%; HIV infection: 14% | Fair | NR
Lin 2007^118^; Taiwan; From update | Cohort, matched with untreated controls; Study period 1986 to 1995 | HBeAg seroconversion vs. non-seroconversion (and treated vs. non-treated/control); Seroconverter=persistent loss of HBV–DNA with anti-HBe seropositivity ≥12 months until last followup | Interferon alpha; Median followup 6.8 years (range up to 15 years) | HBeAg seropositive patients with active HBV demonstrated by a biopsy within 3 months before starting therapy; Excluded those with HCV or HDV and alcohol-related etiology | N=466 total (233 received treatment vs. 233 control); Lost to followup: not applicable | Interferon vs. control:; Age, mean: 32 vs. 31 years; Male: 94% vs. 94%; Race/ethnicity: NR (conducted in Taiwan) | Interferon vs. control:; HBV DNA (pg/mL): 18% vs. 20% ≤200, 35% vs. 30% 201 to 500, 7% vs. 10% 501 to 1000, 40% vs. 40% >1000; ALT: 175 vs. 187 U/L; AFP: 7 vs. 8 ng/mL; Cirrhosis: 8.1% vs. 10.7%; HBV genotype: 61% vs. 57% B, 32% vs. 35% C, 7% vs. 8% other | Fair | Grants from the Department of Health and the Prosperous Foundation Taipei, Taiwan
Niederau 1996^114^; Europe; From prior report | Prospective cohort | Loss of HBeAg after therapy vs. no loss | Interferon alfa 2b; Mean 4.2 years | HBeAg-positive chronic HBV infection, ALT >2 times ULN and histologic evidence of active hepatitis; Excluded: HDV, HIV, advanced cirrhosis | n=103; Lost to followup: None | Age, mean: NR; Male: NR; Race: NR | HBV DNA: NR; HBsAg clearance: 9.7% HBeAg positive: All; ALT: NR; AST: NR; Fibrosis stage: NR; Cirrhosis: NR (Child-Pugh class B or C excluded) | Fair | Van Meeteren Foundation
Papatheodoridis 2001^115^; Greece; From prior report | Cohort (unclear if prospective or retrospective) | Sustained biochemical response vs. no sustained biochemical response; Sustained biochemical response=normalization of ALT at the end of interferon therapy and persistently normal ALT levels throughout the post-treatment followup period | Interferon alfa; Mean 6 years | HBeAg-negative chronic HBV infection with elevated ALT and histologic evidence of chronic HBV; Excluded: decompensated liver disease, HCC, HCV, HDV, HIV | n=209; Lost to followup: 9 (4.3%) | Age, mean: 47 years; Male: 83%; Race: NR | HBV DNA, median serum: 4.4 pg/mL; HBsAg clearance: 13% (27/209, mean 2.9 years after end of treatment); HBeAg positive: Excluded; ALT, median: 112; AST, median: 67; Fibrosis stage, mean Ishak: 3.3; Cirrhosis: 27% | Fair | NR
Papatheodoridis 2011^116^; Greece; From prior report | Retrospective cohort | Virological remission vs. no virological remission; Virological remission=HBV DNA <200 IU/mL throughout therapy | Lamivudine; Median 4.7 years | HBeAg-negative chronic HBV infection with at least 2 of the following: elevated ALT, HBV DNA >2000 IU/mL, or histologic evidence of chronic HBV; Excluded: HDV, HCV, HIV, HCC diagnosed before or within first 6 months of treatment | n=818; Lost to followup: 180 (22%) | Age, mean: 54 years; Male: 72%; Race: NR | HBV DNA, median serum: 400 x10^3^ IU/mL; HBsAg clearance: NR; HBeAg positive: Excluded; ALT (median): 98; AST (median): 68; Fibrosis stage: NR; Cirrhosis: 26% | Fair | Hellenic Center for Disease Control and Prevention
Wong 2013^119^; Hong Kong; From update | Cohort, retrospective and prospective; December 2005 to August 2012 (Patients treated prior to October 2009 were retrospectively identified) | Duration of virological remission ≥24 months vs. shorter duration; Virological remission=undetectable serum HBV DNA | Entecavir; Duration of followup: 3.5 years | Chronic HBV patients treated with entecavir 0.5 mg daily for at least 12 months, positive HBsAg for ≥6 months, life expectancy of >1 year at recruitment; Excluded: preexisting HCC or HCC diagnosed within the first year on entecavir, other chronic liver diseases, Child class C cirrhosis, autoimmune hepatitis, HCV or another concurrent illness (e.g. alcoholism, uncontrolled diabetes, or cancer) | 1531; Lost to followup: NR | Age: 51 years; Male: 72%; Race/ethnicity: NR (Hong Kong) | HBeAg positive: 30%; HBV DNA: 5.0 log_10_ IU/mL; HBV DNA [underlined: >2]000 IU/mL: 77%; HBsAg: 3.0 log_10_ IU/mL; HBsAg >1000 IU/mL: 61%; Cirrhosis: 22% | Fair | Direct Grant of the Chinese University of Hong Kong

Abbreviations: ALT = alanine aminotransferase; APRI = AST/platelet ratio index; AST = aspartate aminotransferase; DNA = deoxyribonucleic acid; FIB4 = fibrosis-4 index; HAI = histology activity index; HBeAg = hepatitis B e-antigen; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; HCC = hepatocellular carcinoma; HCV = hepatitis C virus; HDV = hepatitis D virus; MEq = mega equivalents; NR = not reported; RCT = randomized controlled trial; REACH-B = Risk Estimation for Hepatocellular Carcinoma in Chronic Hepatitis B; ULN = upper limit of normal; VIRGIL = Vigilance Against Viral Resistance.

Appendix B Table 13 Association Studies of HBV Intermediate and Health Outcomes – Results

Author, year; Country; From prior report or update | Comparison | Treatment; Duration of followup | Number receiving antiviral treatment | Proportion of patients with intermediate outcome | Confounders adjusted for in analysis | Results (by clinical outcome)
Arends 2015^117^; European network of excellence for VIRGIL Surveillance Study Group; 11 European referral centers; From update | Virological response vs. no virological response | Entecavir; Followup, median 3.2 years | 744 | Virological response: 88% (655/744); cumulative probability at 5 years, 99% | Unclear for this analysis, but age, sex, cirrhosis, albumin, bilirubin, HBV DNA, ALT, HBeAg status were examined for risk scores | HCC and virologic response (HBV DNA <80 IU/mL) as a time dependent factor: HR 0.87 (95% CI, 0.17 to 4.58), p=0.87; Clinical event (composite endpoint of development of HCC, liver decompensation, or death) and virologic response (HBV DNA <80 IU/mL) as a time dependent factor: HR 0.70 (95% CI, 0.28 to 1.77), p=0.46; Univariate analysis, association of HCC and HBV DNA: HR 0.82 (95% CI, 0.64 to 1.05), p=0.12; Overall clinical events and HBV DNA: HR 1.09 (95% CI, 0.94 to 1.27), p=0.26; HCC and HBeAg negative: HR 0.81 (95% CI, 0.25 to 2.57), p=0.72; Overall clinical events and HBeAg negative: HR 1.11 (95% CI, 0.55 to 2.34), p=0.78
Baltayiannis 2006^111^; Greece; From prior report | Virological response at 6 months vs. no virological response | Interferon alfa; 6 years | 63 | Virological response at 6 months: 35% (22/63) | Age; Gender; Alcohol use; HBV DNA >10,000 copies/mL at baseline; HBeAg: all patients negative; ALT >200 IU/L at baseline; Histologic grade >9; Histologic stage >2 | Death or disease complication (hepatic encephalopathy, ascites, variceal bleeding, HCC); Virological response at 6 months vs. no virological response: aHR 0.24 (95% CI, 0.06 to 0.96)
Hui 2008^112^; China (Hong Kong); From prior report | Histological response in HAI score vs. no histological response | Interferon alfa 2a or 2b; Median 9.9 years | 89 | Histological response in HAI score: 40% (36/89); Histological response in fibrosis stage: 18% (16/89) | HBV DNA level; HBeAg: all patients positive Fibrosis | Liver complications (HBV-related decompensated liver cirrhosis or HCC); Histological response on HAI score vs. no response: aHR 0.62 (95% CI, 0.06 to 6.9)
Lau 1997^113^; United States; From prior report | Response vs. non-response | Interferon alfa; Mean 6.2 years | 103 | Response: 30% (31/103) (Response=Sustained loss of HBV DNA and clearance of HBeAg within 1 year of starting treatment) | Age; Sex; HBeAg: all patients positive; ALT; AST; Cirrhosis | Death (results only adjusted for age and sex); Responder vs. non-responder: aHR 0.59 (95% CI, 0.20 to 1.67); Death or liver-related complication (variceal hemorrhage, ascites, encephalopathy); Responder vs. non-responder: aHR 0.07 (95% CI, 0.02 to 0.33)
Lin 2007^118^; Taiwan; From update | HBeAg seroconversion vs. non-seroconversion (and treated vs. non-treated/control) | Interferon alpha; Median followup 6.8 years (range up to 15 years) | 233 (466 in total sample) | At the end of 15 years of followup:; HBeAg seroconversion rates of 74.6% in interferon vs. 51.7% in control group, p=0.031; HBsAg seroclearance 3% vs. 0.4%, p=0.03 | Age; ALT; HBV-DNA; Platelet count; Preexisting cirrhosis; AFP; Known duration of hepatitis; HBV genotype and regimen; Corticosteroid priming; Duration of interferon treatment; HBeAg seroconversion | Multivariate analysis:; HBeAg seroconversion and cirrhosis: HR 0.41 (95% CI, 0.32 to 0.88), p=0.027; HBeAg seroconversion and HCC: HR 0.13 (95% CI, 0.08 to 0.57), p=0.022
Niederau 1996^114^; Europe; From prior report | Loss of HBeAg after therapy vs. no loss | Interferon alfa 2b; Mean 4.2 years | 103 | HBeAg loss: 51% (53/103) | Age; Sex; HBV DNA at baseline; HBeAg: all patients positive; ALT at baseline; Duration of hepatitis; Cirrhosis at baseline | Liver complications (death; need for liver transplantation; development of ascites, jaundice, or hepatic encephalopathy; occurrence of, or bleeding from, esophageal varices); HBeAg loss vs. no loss: aHR 0.06 (95% CI, 0.01 to 0.61)
Papatheodoridis 2001^115^; Greece; From prior report | Sustained biochemical response vs. no sustained biochemical response | Interferon alfa; Mean 6 years | 209 | Sustained biochemical response: 27% (57/209) (Sustained biochemical response=normalization of ALT at the end of interferon therapy and persistently normal ALT levels throughout the post-treatment followup period) | Age; HBeAg: all patients negative Cirrhosis | Death or liver transplantation; Sustained biochemical response vs. no sustained biochemical response: aHR 0.48 (95% CI, 0.23 to 1.0); Severe clinical complications (death, liver transplantation, liver decompensation [ascites, variceal bleeding, hepatic encephalopathy], and HCC); Sustained biochemical response vs. no sustained biochemical response: aHR 0.53 (95% CI, 0.29 to 0.91)
Papatheodoridis 2011^116^; Greece; From prior report | Virological remission vs. no virological remission | Lamivudine; Median 4.7 years | 818 | Virological remission: 28% (228/818); (Virological remission=HBV DNA <200 IU/mL throughout therapy) | Age; Sex; HBV DNA; HBeAg: all patients negative; ALT; AST; Bilirubin; Albumin; Hemoglobin; Platelet count; Liver disease severity; Interferon alfa in the past | HCC; Virological remission under therapy vs. no virological remission: aHR 0.77 (95% CI, 0.35 to 1.69)
Wong 2013^119^; Hong Kong; From update | Duration of virological remission ≥24 months vs. shorter duration | Entecavir; Duration of followup: 3.5 years | 1,531 | Maintained virologic response: 77% (1,174/1,531); Duration of virologic remission: 34 months | Unclear for this analysis, but adjustments reported | Duration of virologic remission ≥24 months and subsequent development of HCC:; Entire cohort: aHR 0.3 (95% CI, 0.1 to 0.6), p=0.007; Previously treatment-naïve patients: aHR 0.4 (95% CI, 0.2 to 0.7), p=0.009; Incidence of HCC: 3.1% (47/1,531); Association between HCC and achieving a maintained virologic response (response rates among those developing HCC vs. not): 64% (30/47) vs. 77% (1,144/1,484), p=0.03; with a shorter duration of virologic remission: 31 (HCC) vs. 35 months (no HCC), p<0.009

Abbreviations: AFP = alpha-fetoprotein; aHR = adjusted hazard ratio; ALT = alanine aminotransferase; APRI = AST/platelet ratio index; AST = aspartate aminotransferase; CI = confidence interval; DNA = deoxyribonucleic acid; FIB4 = fibrosis-4 index; HAI = histology activity index; HBV = hepatitis B virus; HBeAg = hepatitis B e-antigen; HCC = hepatocellular carcinoma; HR = hazard ratio; NR = not reported; VIRGIL = Vigilance Against Viral Resistance.

Appendix B Table 14 Association Studies of HBV Intermediate and Health Outcomes – Quality Assessment

Author, year; From prior report or update | Did the study attempt to enroll all (or a random sample of) patients meeting inclusion criteria, or a random sample (inception cohort)? | Were the groups comparable at baseline on key prognostic factors (e.g., by restriction or matching)? | Did the study use accurate methods for ascertaining intermediate outcomes? | Were outcome assessors and/or data analysts blinded to treatment? | Did the article report the number of patients who met inclusion criteria excluded due to missing data or loss to followup? | Did the study perform appropriate statistical analyses on potential confounders, or appropriately account for them (should evaluate at least age, sex, fibrosis stage, HBV viral load, HBeAg status)? | Is there important (overall or differential) exclusion of patients due to missing data or loss to followup? | Were outcomes pre-specified and defined, and ascertained using accurate methods? | Quality
Arends, 2015^117^; From update | Yes | Unclear | Yes | Unclear | No | Unclear | Unclear | Yes | Fair
Baltayiannis 2006^111^; From prior report | Yes | Unclear | Yes | Unclear | Yes | Yes | No | Yes | Fair
Hui 2008^112^; From prior report | Yes | Unclear | Yes | Yes | Yes | Unclear | No | Yes | Fair
Lau 1997^113^; From prior report | Yes | No | Yes | Unclear | Yes | No | No | Yes | Fair
Lin 2007^118^; From update | Yes | Yes | Yes | Unclear | No | Yes | Unclear | Yes | Fair
Niederau 1996^114^; From prior report | Yes | Unclear | Yes | Unclear | Yes | Yes | No | Yes | Fair
Papatheodoridis 2001^115^; From prior report | Yes | No | Unclear | Unclear | Yes | Unclear | No | Yes | Fair
Papatheodoridis 2011^116^; From prior report | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | Yes | Fair
Wong 2013^119^; From update | Yes | Unclear | Yes | Unclear | No | Unclear | Unclear | Yes | Fair

Abbreviations: HBeAg = hepatitis B e-antigen; HBV = hepatitis B virus.