# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Key Questions 1-2

#### Database: Ovid MEDLINE(R) and Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Daily and Versions(R)

1. exp Hepatitis B/
2. exp Hepatitis B Antigens/
3. Hepatitis B virus/
4. (“hepatitis b” or hbv).ti,ab,kf.
5. or/1-4
6. Mass Screening/
7. screen*.ti,ab,kf.
8. 6 or 7
9. 5 and 8
10. exp cohort studies/
11. cohort$.tw.
12. controlled clinical trial.pt.
13. epidemiologic methods/
14. limit 13 to yr=1966-1989
15. exp case-control studies/
16. (case$ and control$).tw.
17. or/10-12,14-16
18. randomized controlled trial.pt.
19. (random* or placebo* or control* or trial or blind*).ti,ab.
20. (animals not humans).sh.
21. (comment or editorial or meta-analysis or practice-guideline or review or letter).pt.
22. (18 or 19) not (20 or 21)
23. review.pt.
24. (medline or medlars or embase or pubmed or cochrane).tw,sh.
25. (scisearch or psychinfo or psycinfo).tw,sh.
26. (psychlit or psyclit).tw,sh.
27. cinahl.tw,sh.
28. ((hand adj2 search$) or (manual$ adj2 search$)).tw,sh.
29. (electronic database$ or bibliographic database$ or computeri?ed database$ or online database$).tw,sh.
30. (pooling or pooled or mantel haenszel).tw,sh.
31. (peto or dersimonian or der simonian or fixed effect).tw,sh.
32. or/24-31
33. 23 and 32
34. meta-analysis.pt.
35. meta-analysis.sh.
36. (meta-analys$ or meta analys$ or metaanalys$).tw,sh.
37. (systematic$ adj5 review$).tw,sh.
38. (systematic$ adj5 overview$).tw,sh.
39. (quantitativ$ adj5 review$).tw,sh.
40. (quantitativ$ adj5 overview$).tw,sh.
41. (quantitativ$ adj5 synthesis$).tw,sh.
42. (methodologic$ adj5 review$).tw,sh.
43. (methodologic$ adj5 overview$).tw,sh.
44. (integrative research review$ or research integration).tw.
45. or/34-44
46. 33 or 45
47. 17 or 22 or 46
48. 9 and 47
49. (2013 jul $ or 2013 aug $ or 2013 sep $ or 2013 oct $ or 2013 nov $ or 2013 dec $).dp.
50. (“2013 07 $” or “2013 08 $” or “2013 09 $” or 2013 10 $ or 2013 11 $ or 2013 12 $).dp.
51. 48 and (49 or 50)
52. limit 48 to yr="2014 - 2019"
53. 51 or 52
54. limit 53 to english language

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Hepatitis B/
2. exp Hepatitis B Antigens/
3. Hepatitis B virus/
4. (“hepatitis b” or hbv).ti,ab,kf.
5. or/1-4
6. Mass Screening/
7. screen*.ti,ab,kf.
8. 6 or 7
9. 5 and 8
10. limit 9 to yr="2013 - 2019"

### Key Question 3

#### Database: Ovid MEDLINE(R) and Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Daily and Versions(R)

1. exp Hepatitis B/
2. Hepatitis B virus/
3. (“hepatitis b” or hbv).ti,ab,kf.
4. mass screening/
5. screen*.ti,ab,kf.
6. exp “Sensitivity and Specificity”/
7. (accuracy or sensitivity or specificity).ti,ab,kf.
8. (screen* adj5 (strateg* or method* or algorithm* or risk)).ti,ab,kf.
9. (1 or 2 or 3) and (4 or 5) and (6 or 7 or 8)
10. (2013 jul $ or 2013 aug $ or 2013 sep $ or 2013 oct $ or 2013 nov $ or 2013 dec $).dp.
11. (“2013 07 $” or “2013 08 $” or “2013 09 $” or 2013 10 $ or 2013 11 $ or 2013 12 $).dp.
12. 9 and (10 or 11)
13. limit 9 to yr="2014 - 2019"
14. limit 13 to english language

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Hepatitis B/
2. Hepatitis B virus/
3. (“hepatitis b” or hbv).ti,ab,kf.
4. mass screening/
5. screen*.ti,ab,kf.
6. exp “Sensitivity and Specificity”/
7. (accuracy or sensitivity or specificity).ti,ab,kf.
8. (screen* adj5 (strateg* or method* or algorithm* or risk)).ti,ab,kf.
9. (1 or 2 or 3) and (4 or 5) and (6 or 7 or 8)
10. limit 9 to yr="2013 - 2019"

### Key Questions 4-6

#### Database: Ovid MEDLINE(R) and Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Daily and Versions(R)

1. exp Hepatitis B/dt, pc, th [Drug Therapy, Prevention & Control, Therapy]
2. Hepatitis B virus/de [Drug Effects]
3. (“hepatitis b” or hbv).ti,ab,kf.
4. (interferon or “alfa 2a” or “alfa 2b” or entecavir or tenofovir or lamivudine or adefovir or telbivudine).ti,ab,kf,hw.
5. 1 or 2
6. 4 and
7. 3 and 4
8. 6 or 7
9. Treatment Outcome/
10. limit 8 to “therapy (best balance of sensitivity and specificity)”
11. (8 and 9) or 10
12. exp cohort studies/
13. cohort$.tw.
14. controlled clinical trial.pt.
15. epidemiologic methods/
16. limit 15 to yr=1966-1989
17. exp case-control studies/
18. (case$ and control$).tw.
19. or/12-14,16-18
20. randomized controlled trial.pt.
21. (random* or placebo* or control* or trial or blind*).ti,ab.
22. (animals not humans).sh.
23. (comment or editorial or meta-analysis or practice-guideline or review or letter).pt.
24. (20 or 21) not (22 or 23)
25. review.pt.
26. (medline or medlars or embase or pubmed or cochrane).tw,sh.
27. (scisearch or psychinfo or psycinfo).tw,sh.
28. (psychlit or psyclit).tw,sh.
29. cinahl.tw,sh.
30. ((hand adj2 search$) or (manual$ adj2 search$)).tw,sh.
31. (electronic database$ or bibliographic database$ or computeri?ed database$ or online database$).tw,sh.
32. (pooling or pooled or mantel haenszel).tw,sh.
33. (peto or dersimonian or der simonian or fixed effect).tw,sh.
34. or/26-33
35. 25 and 34
36. meta-analysis.pt.
37. meta-analysis.sh.
38. (meta-analys$ or meta analys$ or metaanalys$).tw,sh.
39. (systematic$ adj5 review$).tw,sh.
40. (systematic$ adj5 overview$).tw,sh.
41. (quantitativ$ adj5 review$).tw,sh.
42. (quantitativ$ adj5 overview$).tw,sh.
43. (quantitativ$ adj5 synthesis$).tw,sh.
44. (methodologic$ adj5 review$).tw,sh.
45. (methodologic$ adj5 overview$).tw,sh.
46. (integrative research review$ or research integration).tw.
47. or/36-46
48. 35 or 47
49. 19 or 24 or 48
50. 8 and 49
51. 10 or 11 or 50
52. limit 51 to english language
53. (2013 jul $ or 2013 aug $ or 2013 sep $ or 2013 oct $ or 2013 nov $ or 2013 dec $).dp.
54. (“2013 07 $” or “2013 08 $” or “2013 09 $” or 2013 10 $ or 2013 11 $ or 2013 12 $).dp.
55. 52 and (53 or 54)
56. limit 52 to yr="2014 - 2019"
57. 55 or 56

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Hepatitis B/
2. Hepatitis B virus/
3. (“hepatitis b” or hbv).ti,ab.
4. 1 or 2 or 3
5. (interferon or “alfa 2a” or “alfa 2b” or entecavir or tenofovir or lamivudine or adefovir or telbivudine).ti,ab.
6. 4 and 5
7. limit 6 to english language
8. limit 7 to yr="2013 - 2019"
9. limit 7 to medline records
10. 8 not 9

### Key Question 7

#### Database: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations

1. (“hepatitis b” or hbv).ti,ab,kf.
2. (mortality or cirrhosis or “hepatocellular cancer” or “hepatocellular carcinoma” or “quality of life” or extrahepatic).ti,ab,kf.
3. transmission.ti,ab,kf.
4. 1 and (2 or 3)
5. 4 and (association or relation* or clinical or outcome*).ti,ab,kf.
6. limit 5 to english language
7. (2013 jul $ or 2013 aug $ or 2013 sep $ or 2013 oct $ or 2013 nov $ or 2013 dec $).dp.
8. (“2013 07 $” or “2013 08 $” or “2013 09 $” or 2013 10 $ or 2013 11 $ or 2013 12 $).dp.
9. 6 and (7 or 8)
10. limit 6 to yr="2014 - 2019"
11. 9 or 10

#### Database: Ovid MEDLINE(R)

1. exp Hepatitis B/
2. exp Hepatitis B Antigens/
3. Hepatitis B virus/
4. (“hepatitis b” or hbv).ti,ab,kf.
5. or/1-4
6. disease-free survival/ or treatment outcome/
7. exp survival analysis/
8. (mortality or cirrhosis or “hepatocellular cancer” or “hepatocellular carcinoma” or “quality of life” or extrahepatic).ti,ab,kf,hw.
9. Carcinoma, Hepatocellular/
10. transmission.ti,ab.
11. tm.fs.
12. 5 and (6 or 7)
13. 12 and (8 or 9 or 10 or 11)
14. (2013 jul $ or 2013 aug $ or 2013 sep $ or 2013 oct $ or 2013 nov $ or 2013 dec $).dp.
15. (“2013 07 $” or “2013 08 $” or “2013 09 $” or 2013 10 $ or 2013 11 $ or 2013 12 $).dp.
16. limit 13 to yr="2014 - 2019"
17. 15 or 16
18. limit 17 to english language
19. 18 not (case series or case reports or editorial or comment).pt.

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Hepatitis B/
2. exp Hepatitis B Antigens/
3. Hepatitis B virus/
4. (“hepatitis b” or hbv).ti,ab,kf.
5. or/1-4
6. disease-free survival/ or treatment outcome/
7. exp survival analysis/
8. (mortality or cirrhosis or “hepatocellular cancer” or “hepatocellular carcinoma” or “quality of life” or extrahepatic).ti,ab,kf,hw.
9. Carcinoma, Hepatocellular/
10. transmission.ti,ab.
11. tm.fs.
12. 5 and (6 or 7 or 8 or 9 or 10 or 11)
13. limit 12 to yr="2013 - 2019"
14. limit 12 to medline records
15. 13 not 14

### All Key Questions

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. (“hepatitis b” or hbv).ti.
2. limit 1 to full systematic reviews
3. limit 1 to full systematic reviews

## Appendix A2 Inclusion and Exclusion Criteria

| Included | Excluded
Definition of Disease | Chronic HBV infection, defined as detectable HBsAg in blood for >6 months | Acute HBV infection
Populations | KQs 1–3: Nonpregnant adolescents (ages 13 to <18 years) and adults (age ≥18 years) with no signs or symptoms of HBV infection; KQs 4–7: Nonpregnant adolescents and adults with chronic HBV infection | KQs 1–3: Symptomatic patients, children age <13 years, pregnant women, persons living with HIV or hepatitis C virus infection, persons who have been previously treated for HBV infection, and other special populations (e.g., persons undergoing hemodialysis or an organ transplant)
Interventions | KQs 1–3: Screening, including alternative screening strategies (KQ 3); KQs 4–7: Antiviral treatments approved by the FDA for patients who have never been treated for HBV infection. Therapies will be classified as:; - Preferred: Pegylated interferon (adults), nonpegylated interferon (adolescents ages 13 to 17 years), entecavir, tenofovir disoproxil fumarate, and tenofovir alafenamide; - Nonpreferred: Lamivudine, adefovir, and telbivudine | KQs 4–7: Antiviral treatments not approved by the FDA; combination therapy
Comparators | KQs 1, 2: No screening; KQ 3: One screening strategy vs. an alternative screening strategy; KQs 4–6: No treatment; preferred vs. nonpreferred antiviral therapies; KQ 7: Effects on intermediate outcomes (HBV DNA level, HBeAg status, HBsAg status, alanine aminotransferase level, fibrosis) as a result of antiviral therapy vs. no effects on intermediate outcomes
Outcomes | KQs 1, 5, 7:; - Mortality; - Cirrhosis; - Hepatocellular cancer; - Quality of life; - Disease transmission; - Extrahepatic outcomes (e.g., polyarteritis nodosa, membranous nephropathy, membranoproliferative glomerulonephritis); KQ 2: Labeling, anxiety, and stigma; KQ 3: Yield (number of new diagnoses per number of persons screened) and sensitivity (number of diagnoses of HBV infection per number of total HBV diagnoses); KQ 4:; - Virologic improvement; - Histologic improvement; - HBeAg clearance (loss of HBeAg or acquisition of anti-HBe); - HBsAg clearance (loss of HBsAg or acquisition of anti-HBs); KQ 6:; - Harms of antiviral medications; - Withdrawals due to adverse events; - Serious adverse events | KQ 4: Drug resistance; development of virus mutations or antibodies to drugs
Setting | All KQs: Primary care and primary care–referable settings (e.g., correctional settings, community care settings serving persons who inject drugs, men who have sex with men, or persons with sexually transmitted diseases); KQs 1–3: United States and countries with similar HBV prevalence; KQs 4–7: All countries
Study Designs | KQs 1–3: Randomized, controlled trials; cohort studies; and case-control studies; cross-sectional studies (KQ 3 only); KQs 4–6: Randomized, placebo-controlled trials; head-to-head trials of preferred vs. nonpreferred antiviral therapies approved by the FDA; KQ 5: Cohort studies for long-term (>5 years) clinical outcomes that report adjusted risk estimates; KQ 6: All of the above study designs, plus cohort studies of harms not adequately evaluated in randomized trials; KQ 7: Cohort studies examining the association between intermediate and clinical outcomes after antiviral treatment that report adjusted risk estimates | KQs 1–3: Uncontrolled studies (e.g., case studies, treatment series)

Abbreviations: anti-HBe = antibody to the hepatitis B e-antigen; anti-HBs = hepatitis B surface antibody; DNA = deoxyribonucleic acid; FDA = U.S. Food and Drug Administration; HBeAg = hepatitis B e-antigen; HBsAg = hepatitis B surface antigen; HBV = hepatitis B virus; KQ = key question.

## Appendix A3 Literature Flow Diagram

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows that 6,272 citations were identified and reviewed. Five hundred and six articles were reviewed at the full-text level after excluding 5,766 citations based on review of title and abstract. From the 506 full-text articles reviewed, 17 had been included in the prior report and were subsequently excluded from this update for the following reasons: wrong population, cirrhosis (11), treatment-experienced (3), and poor quality (3). Four hundred and thirty-three were new records excluded for the following reasons: wrong population (162, including 94 for Contextual Question on reactivation), wrong intervention (45), wrong outcome (43), wrong comparator (39), wrong study design for key question (61), not a study (22), not English language but possibly relevant (6), systematic review or meta-analysis used as a source document only to identify individual studies (24), wrong country (18), insufficient duration (7), insufficient sample size (5), cost effectiveness, outdated (1). Two articles were included for a contextual question on modeling and no studies were found to inform the contextual questions on tools or reactivation. Fifty studies in 54 articles were included that provide evidence for Key Questions as follows: no studies for Key Questions 1 or 2, 2 new studies and 1 previously included study for Key Question 3, 9 new trials and 21 previously included trials for Key Question 4, 4 new trials and 7 new cohort studies and 12 previously included trials for Key Question 5, 7 new trials and 1 new cohort study and 17 previously included trials for Key Question 6, and 3 new studies and 6 previously included studies for Key Question 7. Some included studies overlapped among the key questions, and some cohort studies included overlapping populations in the same database.

* Some included studies overlap among the Key Questions.

† Some cohort studies included overlapping populations from the same database.

## Appendix A4 Included Studies

Arends P, Sonneveld MJ, Zoutendijk R, . Entecavir treatment does not eliminate the risk of hepatocellular carcinoma in chronic hepatitis B: limited role for risk scores in Caucasians. Gut. 2015;64(8):1289–95. doi: 10.1136/gutjnl-2014-307023. PMID: 25011935.25011935
Baltayiannis G, Katsanos K, Karayiannis P, . Interferon-α therapy in HBeAg-negative chronic hepatitis B: a long-term prospective study from north-western Greece. Aliment Pharmacol Ther. 2006;24(3):525–33. doi: 10.1111/j.1365-2036.2006.03008.x. PMID: 16886919.16886919
Bottero J, Boyd A, Lemoine M, . Current state of and needs for hepatitis B screening: results of a large screening study in a low-prevalent, metropolitan region. PLoS One. 2014;9(3):e92266. doi: 10.1371/journal.pone.0092266. PMID: 24663387.24663387
Bozkaya H, Yurdaydin C, Idilman R, . Lamivudine treatment in HBeAg-negative chronic hepatitis B patients with low level viraemia. Antivir Ther. 2005;10(2):319–25. PMID: 15865226.15865226
Chan HL, Wang H, Niu J, . Two-year lamivudine treatment for hepatitis B e antigen-negative chronic hepatitis B: a double-blind, placebo-controlled trial. Antivir Ther. 2007;12(3):345–53. PMID: 17591024.17591024
Chang TT, Chao YC, Gorbakov VV, . Results of up to 2 years of entecavir vs lamivudine therapy in nucleoside-naive HBeAg-positive patients with chronic hepatitis B. J Viral Hepat. 2009;16(11):784–9. doi: 10.1111/j.1365-2893.2009.01142.x. PMID: 19457141.19457141
Chang TT, Gish RG, de Man R, . A comparison of entecavir and lamivudine for HBeAg-positive chronic hepatitis B. N Engl J Med. 2006;354(10):1001–10. doi: 10.1056/NEJMoa051285. PMID: 16525137.16525137
Dienstag JL, Schiff ER, Wright TL, . Lamivudine as initial treatment for chronic hepatitis B in the United States. N Engl J Med. 1999;341(17):1256–63. doi: 10.1056/nejm199910213411702. PMID: 10528035.10528035
Gish RG, Lok AS, Chang TT, . Entecavir therapy for up to 96 weeks in patients with HBeAg-positive chronic hepatitis B. Gastroenterology. 2007;133(5):1437–44. doi: 10.1053/j.gastro.2007.08.025. PMID: 17983800.17983800
Gordon SC, Lamerato LE, Rupp LB, . Antiviral therapy for chronic hepatitis B virus infection and development of hepatocellular carcinoma in a US population. Clin Gastroenterol Hepatol. 2014;12(5):885–93. doi: 10.1016/j.cgh.2013.09.062. PMID: 24107395.24107395
Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, . Adefovir dipivoxil for the treatment of hepatitis B e antigen-negative chronic hepatitis B. N Engl J Med. 2003;348(9):800–7. doi: 10.1056/NEJMoa021812. PMID: 12606734.12606734
Hoang JK, Yang HI, Le A, . Lower liver cancer risk with antiviral therapy in chronic hepatitis B patients with normal to minimally elevated ALT and no cirrhosis. Medicine. 2016;95(31):e4433. doi: 10.1097/MD.0000000000004433. PMID: 27495067.27495067
Hosaka T, Suzuki F, Kobayashi M, . Long-term entecavir treatment reduces hepatocellular carcinoma incidence in patients with hepatitis B virus infection. Hepatology. 2013;58(1):98–107. doi: 10.1002/hep.26180. PMID: 23213040.23213040
Hou JL, Gao ZL, Xie Q, . Tenofovir disoproxil fumarate vs adefovir dipivoxil in Chinese patients with chronic hepatitis B after 48 weeks: a randomized controlled trial. J Viral Hepat. 2015;22(2):85–93. doi: 10.1111/jvh.12313. PMID: 25243325.25243325
Hui CK, Leung N, Shek WH, . Changes in liver histology as a “surrogate” end point of antiviral therapy for chronic HBV can predict progression to liver complications. J Clin Gastroenterol. 2008;42(5):533–8. doi: 10.1097/MCG.0b013e31804bbdff. PMID: 18344885.18344885
Lai CL, Chien RN, Leung NW, . A one-year trial of lamivudine for chronic hepatitis B. Asia hepatitis lamivudine study group. N Engl J Med. 1998;339(2):61–8. doi: 10.1056/nejm199807093390201. PMID: 9654535.9654535
Lai CL, Ching CK, Tung AK, . Lamivudine is effective in suppressing hepatitis B virus DNA in Chinese hepatitis B surface antigen carriers: a placebo-controlled trial. Hepatology. 1997;25(1):241–4. PMID: 8985298.8985298
Lai CL, Shouval D, Lok AS, . Entecavir versus lamivudine for patients with HBeAg-negative chronic hepatitis B. N Engl J Med. 2006;354(10):1011–20. doi: 10.1056/NEJMoa051287. PMID: 16525138.16525138
Lai CL, Rosmawati M, Lao J, . Entecavir is superior to lamivudine in reducing hepatitis B virus DNA in patients with chronic hepatitis B infection. Gastroenterology. 2002;123(6):1831–8. PMID: 12454840.12454840
Lampertico P, Del Ninno E, Manzin A, . A randomized, controlled trial of a 24-month course of interferon alfa 2b in patients with chronic hepatitis B who had hepatitis B virus DNA without hepatitis B e antigen in serum. Hepatology. 1997;26(6):1621–5. PMID: 9398007.9398007
Lau DT, Everhart J, Kleiner DE, . Long-term follow-up of patients with chronic hepatitis B treated with interferon alfa. Gastroenterology. 1997;113(5):1660–7. PMID: 9352870.9352870
Lau GK, Piratvisuth T, Luo KX, . Peginterferon Alfa-2a, lamivudine, and the combination for HBeAg-positive chronic hepatitis B. N Engl J Med. 2005;352(26):2682–95. doi: 10.1056/NEJMoa043470. PMID: 15987917.15987917
Lee KS, Kweon YO, Um SH, . Efficacy and safety of entecavir versus lamivudine over 5 years of treatment: a randomized controlled trial in Korean patients with hepatitis B e antigen-negative chronic hepatitis B. Clin Mol Hepatol. 2017;23(4):331–9. doi: 10.3350/cmh.2016.0040. PMID: 28946736.28946736
Lee TY, Hsu YC, Yu SH, . Effect of nucleos(t)ide analogue therapy on risk of intrahepatic cholangiocarcinoma in patients with chronic hepatitis B. Clin Gastroenterol Hepatol. 2018;16(6):947–54.e4. doi: 10.1016/j.cgh.2017.09.031. PMID: 28951229.28951229
Liaw YF, Lin SM, Chen TJ, . Beneficial effect of prednisolone withdrawal followed by human lymphoblastoid interferon on the treatment of chronic type B hepatitis in Asians: a randomized controlled trial. J Hepatol. 1994;20(2):175–80. PMID: 8006397.8006397
Lin SM, Sheen IS, Chien RN, . Long-term beneficial effect of interferon therapy in patients with chronic hepatitis B virus infection. Hepatology. 1999;29(3):971–5. PMID: 10051505.10051505
Lin SM, Yu ML, Lee CM, . Interferon therapy in HBeAg positive chronic hepatitis reduces progression to cirrhosis and hepatocellular carcinoma. J Hepatol. 2007;46(1):45–52. doi: 10.1016/j.jhep.2006.08.021. PMID: 17107734.17107734
Marcellin P, Chang TT, Lim SG, . Adefovir dipivoxil for the treatment of hepatitis B e antigen-positive chronic hepatitis B. N Engl J Med. 2003;348(9):808–16. doi: 10.1056/NEJMoa020681. PMID: 12606735.12606735
Marcellin P, Heathcote EJ, Buti M, . Tenofovir disoproxil fumarate versus adefovir dipivoxil for chronic hepatitis B. N Engl J Med. 2008;359(23):2442–55. doi: 10.1056/NEJMoa0802878. PMID: 19052126.19052126
Matsumoto A, Tanaka E, Rokuhara A, . Efficacy of lamivudine for preventing hepatocellular carcinoma in chronic hepatitis B: a multicenter retrospective study of 2795 patients. Hepatol Res. 2005;32(3):173–84. doi: 10.1016/j.hepres.2005.02.006. PMID: 16024289.16024289
Mazzella G, Saracco G, Festi D, . Long-term results with interferon therapy in chronic type B hepatitis: a prospective randomized trial. Am J Gastroenterol. 1999;94(8):2246–50. PMID: 10445557.10445557
Muller R, Baumgarten R, Markus R, . Treatment of chronic hepatitis B with interferon alfa-2b. J Hepatol. 1990;11(1) PMID: 2079572.2079572
Niederau C, Heintges T, Lange S, . Long-term follow-up of HBeAg-positive patients treated with interferon alfa for chronic hepatitis B. N Engl J Med. 1996;334(22):1422–7. PMID: 8618580.8618580
Papatheodoridis GV, Manesis E, Hadziyannis SJ. The long-term outcome of interferon-alpha treated and untreated patients with HBeAg-negative chronic hepatitis B. J Hepatol. 2001;34(2):306–13. PMID: 11281561.11281561
Papatheodoridis GV, Manolakopoulos S, Touloumi G, . Virological suppression does not prevent the development of hepatocellular carcinoma in HBeAg-negative chronic hepatitis B patients with cirrhosis receiving oral antiviral(s) starting with lamivudine monotherapy: results of the nationwide HEPNET. Greece cohort study. Gut. 2011;60(8):1109–16. doi: 10.1136/gut.2010.221846. PMID: 21270118.21270118
Realdi G, Fattovich G, Pastore G, . Problems in the management of chronic hepatitis B with interferon: experience in a randomized, multicentre study. J Hepatol. 1990;11: Suppl 1:S129–32. PMID: 2079570.2079570
Ren FY, Piao DM, Piao XX. A one-year trial of entecavir treatment in patients with HBeAg-positive chronic hepatitis B. World J Gastroenterol. 2007;13(31):4264–7. PMID: 17696259.17696259
Spenatto N, Boulinguez S, Mularczyk M, . Hepatitis B screening: who to target? A French sexually transmitted infection clinic experience. J Hepatol. 2013;58(4):690–7. doi: 10.1016/j.jhep.2012.11.044. PMID: 23220369.23220369
Suh DJ, Um SH, Herrmann E, . Early viral kinetics of telbivudine and entecavir: results of a 12-week randomized exploratory study with patients with HBeAg-positive chronic hepatitis B. Antimicrob Agents Chemother. 2010;54(3):1242–7. doi: 10.1128/aac.01163-09. PMID: 20028815.20028815
Tassopoulos NC, Volpes R, Pastore G, . Efficacy of lamivudine in patients with hepatitis B e antigen-negative/hepatitis B virus DNA-positive (precore mutant) chronic hepatitis B. Lamivudine Precore Mutant Study Group. Hepatology. 1999;29(3):889–96. doi: 10.1002/hep.510290321. PMID: 10051494.10051494
Thomas HC, Lok AS, Carreno V, . Comparative study of three doses of interferon-alpha 2a in chronic active hepatitis B. The International Hepatitis Trial Group. J Viral Hepat. 1994;1(2):139–48. PMID: 8790569.8790569
Tseng KC, Chen CY, Tsai HW, . Efficacy of entecavir in chronic hepatitis B patients with persistently normal alanine aminotransferase: randomized, double-blind, placebo-controlled study. Antivir Ther. 2014;19(8):755–64. doi: 10.3851/IMP2754. PMID: 24583931.24583931
Wang JP, Kao FY, Wu CY, . Nucleos(t)ide analogues associated with a reduced risk of hepatocellular carcinoma in hepatitis B patients: a population-based cohort study. Cancer. 2015;121(9):1446–55. doi: 10.1002/cncr.29159. PMID: 25537961.25537961
Wei MT, Le AK, Chang MS, . Antiviral therapy and the development of osteopenia/osteoporosis among Asians with chronic hepatitis B. J Med Virol. 2019;91(7):1288–94. doi: 10.1002/jmv.25433. PMID: 30776311.30776311
Wen Z, Zhang H, Zhang M, . Effect of hepatitis B virus genotypes on the efficacy of adefovir dipivoxil antiviral therapy. Hepatology. 2014;14(8):e10813. doi: 10.5812/hepatmon.10813. PMID: 25237370.25237370
Wolffram I, Petroff D, Batz O, . Prevalence of elevated ALT values, HBsAg, and anti-HCV in the primary care setting and evaluation of guideline defined hepatitis risk scenarios. J Hepatol. 2015;62(6):1256–64. doi: 10.1016/j.jhep.2015.01.011. PMID: 25617500.25617500
Wong GH, Chan HY, Chan HY, . Accuracy of risk scores for patients with chronic hepatitis B receiving entecavir treatment. Gastroenterology. 2013;144(5):933–44. PMID: 23405803.23415803
Wu CY, Lin JT, Ho HJ, . Association of nucleos(t)ide analogue therapy with reduced risk of hepatocellular carcinoma in patients with chronic hepatitis B: a nationwide cohort study. Gastroenterology. 2014;147(1):143–51.e5. doi: 10.1053/j.gastro.2014.03.048. PMID: 24704525.24704525
Yalcin K, Degertekin H, Kokoglu OF, . A three-month course of lamivudine therapy in HBeAg-positive hepatitis B patients with normal aminotransferase levels. Turk J Gastroenterol. 2004;15(1):14–20. PMID: 15264116.15264116
Yao G, Chen C, Lu W, . Efficacy and safety of entecavir compared to lamivudine in nucleoside-naive patients with chronic hepatitis B: a randomized double-blind trial in China. Hepatol Int. 2007;1(3):365–72. doi: 10.1007/s12072-007-9009-2. PMID: 19669331.19669331
Yao G, Wang B, Cui Z, . A randomized double-blind placebo-controlled study of lamivudine in the treatment of patients with chronic hepatitis B virus infection. Chin Med J. 1999;112(5):387–91. PMID: 11593504.11593504
Yao GB. Management of hepatitis B in China. J Med Virol. 2000;61(3):392–7. PMID: 10861652.10861652
Yao GB, Zhu M, Cui ZY, . A 7-year study of lamivudine therapy for hepatitis B virus e antigen-positive chronic hepatitis B patients in China. J Dig Dis. 2009;10(2):131–7. PMID: 19426396.19426396
Zheng MH, Shi KQ, Dai ZJ, . A 24-week, parallel-group, open-label, randomized clinical trial comparing the early antiviral efficacy of telbivudine and entecavir in the treatment of hepatitis B e antigen-positive chronic hepatitis B virus infection in adult Chinese patients. Clin Ther. 2010;32(4):649–58. doi: 10.1016/j.clinthera.2010.04.001. PMID: 20435234.20435234

## Appendix A5 Excluded Studies with Reasons for Exclusion

Abdullahi A, Fopoussi OM, Torimiro J, . Hepatitis b virus (HBV) infection and re-activation during nucleos(t)ide reverse transcriptase inhibitor-sparing antiretroviral therapy in a high-HBV endemicity setting. Open Forum Infect Dis. 2018;5(10):ofy251. doi: 10.1093/ofid/ofy251. PMID: 30377627. Excluded: wrong population – excluded for reactivation CQ.30377627
Agarwal K, Fung SK, Nguyen TT, . Twenty-eight day safety, antiviral activity, and pharmacokinetics of tenofovir alafenamide for treatment of chronic hepatitis b infection. J Hepatol. 2015;62(3):533–40. doi: 10.1016/j.jhep.2014.10.035. PMID: 25450717. Excluded: wrong comparator.25450717
Aggeletopoulou I, Davoulou P, Konstantakis C, . Response to hepatitis B vaccination in patients with liver cirrhosis. Rev Med Virol. 2017;27(6):11. doi: 10.1002/rmv.1942. PMID: 28905444. Excluded: wrong intervention: vaccine.28905444
Aghoram R, Cai P, Dickinson JA. Alpha-foetoprotein and/or liver ultrasonography for screening of hepatocellular carcinoma in patients with chronic hepatitis B. Cochrane Database Syst Rev. 2012 (9) PMID: 22972059. Excluded: wrong intervention.22972059
Ajayi T, Luu H, Saberi B, . Role of nucleoside/nucleotide analogues and low-dose hepatitis B immune globulin in prophylaxis of hepatitis B recurrence among cadaveric liver transplant recipients. Turk J Gastroenterol. 2018;29(1):61–6. doi: 10.5152/tjg.2018.17595. PMID: 29391309. Excluded: wrong population – excluded for reactivation CQ.29391309
Akuta N, Suzuki F, Suzuki Y, . Favorable efficacy of long-term lamivudine therapy in patients with chronic hepatitis B: an 8-year follow-up study. J Med Virol. 2005;75(4):491–8. doi: 10.1002/jmv.20305. PMID: 15714490. Excluded: wrong population.15714490
Alavian SM, Haghbin H. Relative importance of hepatitis b and c viruses in hepatocellular carcinoma in EMRO countries and the middle east: a systematic review. Hepat Mon. 2016;16(3):e35106. doi: 10.5812/hepatmon.35106. PMID: 27226803. Excluded: wrong outcome.27226803
Alberer M, Burchard G, Jelinek T, . Immunogenicity and safety of concomitant administration of a combined hepatitis a/b vaccine and a quadrivalent meningococcal conjugate vaccine in healthy adults. J Travel Med. 2015;22(2):105–14. doi: 10.1111/jtm.12180. PMID: 25483566. Excluded: wrong intervention: vaccine.25483566
Ali HY. Trial of lamivudine in hepatitis B surface antigen carriers with persistent hepatitis B core IgM antibody. Saudi Med J. 2003;24(9):996–9. PMID: 19746176. Excluded: poor quality.12973486
Aljumah AA, Bin Selayem NA, Al-Howti SY, . Clinical and virological outcomes of entecavir therapy in patients with chronic hepatitis B: a real life experience. J Infect Chemother. 2019;25(1):12–6. doi: 10.1016/j.jiac.2018.09.014. PMID: 30366861. Excluded: wrong study design for key question.30366861
Aly HH, Suzuki J, Watashi K, . RNA exosome complex regulates stability of the hepatitis B virus X-mRNA transcript in a non-stop-mediated (NSD) RNA quality control mechanism. J Biol Chem. 2016;291(31):15958–74. doi: 10.1074/jbc.M116.724641. PMID: 27281821. Excluded: wrong study design for key question.27281821
An J, Kim JW, Shim JH, . Chronic hepatitis B infection and non-hepatocellular cancers: a hospital registry-based, case-control study. PLoS One. 2018;13(3):e0193232. doi: 10.1371/journal.pone.0193232. PMID: 29543815. Excluded: wrong outcome.29543815
An J, Lim YS, Kim GA, . Telbivudine versus entecavir in patients with undetectable hepatitis B virus DNA: a randomized trial. BMC Gastroenterol. 2017;17(1):15. doi: 10.1186/s12876-017-0572-2. PMID: 28103819. Excluded: wrong population.28103819
An J, Shim JH, Kim SO, . Comprehensive outcomes of on- and off-antiviral prophylaxis in hepatitis B patients undergoing cancer chemotherapy: a competing risks analysis. J Med Virol. 2016;88(9):1576–86. doi: 10.1002/jmv.24512. PMID: 26945543. Excluded: wrong population – excluded for reactivation CQ.26945543
Anderson MG, Harrison TJ, Alexander G, . Randomised controlled trial of lymphoblastoid interferon for chronic active hepatitis B. Gut. 1987;28(5):619–22. PMID: 3297940. Excluded: wrong population.3297940
Andreone P, Gramenzi A, Cursaro C, . High risk of hepatocellular carcinoma in anti-HBe positive liver cirrhosis patients developing lamivudine resistance. J Viral Hepat. 2004;11(5):439–42. PMID: 15357649. Excluded: wrong population – cirrhosis.15357649
Arends P, Rijckborst V, Zondervan PE, . Loss of intrahepatic HBsAg expression predicts sustained response to peginterferon and is reflected by pronounced serum HBsAg decline. J Viral Hepat. 2014;21(12):897–904. doi: 10.1111/jvh.12218. PMID: 24444353. Excluded: wrong outcome.24444353
Armbruster B, Brandeau ML. Cost-effective control of chronic viral diseases: finding the optimal level of screening and contact tracing. Math Biosci. 2010;224(1):35–42. doi: 10.1016/j.mbs.2009.12.006. PMID: 20043926. Excluded: wrong outcome.20043926
Atay K, Hatemi I, Canbakan B, . Five-year results of oral antiviral therapy in HBeAg-negative chronic hepatitis B. Turk J Gastroenterol. 2016;27(3):279–83. doi: 10.5152/tjg.2016.16085. PMID: 27210786. Excluded: wrong study design for key question.27210786
Bakker M, Bunge EM, Marano C, . Immunogenicity, effectiveness and safety of combined hepatitis A and B vaccine: a systematic literature review. Expert Rev Vaccines. 2016;15(7):829–51. doi: 10.1586/14760584.2016.1150182. PMID: 26840060. Excluded: wrong intervention: vaccine.26840060
Barbosa JR, Cortes VF, Portilho MM, . Performance of point of care assays for hepatitis B and C viruses in chronic kidney disease patients. J Clin Pathol. 2018;71(10):879–84. doi: 10.1136/jclinpath-2018-205024. PMID: 29730611. Excluded: wrong intervention.29730611
BarOn ES, Goldberg E, Hellmann S, . Combined DTP-HBV-HIB vaccine versus separately administered DTP-HBV and HIB vaccines for primary prevention of diphtheria, tetanus, pertussis, hepatitis B and Haemophilus influenzae B (HIB). Cochrane Database Syst Rev. 2012 (4)doi: 10.1002/14651858.CD005530.pub3. PMID: 22513932. Excluded: wrong intervention: vaccine.22513932
Bath RM, Doering BE, Nailor MD, . Pharmacotherapy-induced hepatitis B reactivation among patients with prior functional cure: a systematic review. Ann Pharmacother. 2019;53(3):294–310. doi: 10.1177/1060028018800501. PMID: 30203666. Excluded: wrong population – excluded for reactivation CQ.30203666
Bayraktar Y, Uzunalimoglu B, Arslan S, . Effects of recombinant alpha interferon on chronic active hepatitis B: preliminary results. Gut. 1993;34:(2 Suppl):S101. PMID: 8314468. Excluded: poor quality.8314468
Bedre RH, Raj U, Misra SP, . Antiviral therapy with nucleotide/nucleoside analogues in chronic hepatitis B: a meta-analysis of prospective randomized trials. Indian J Gastroenterol. 2016;35(2):75–82. doi: 10.1007/s12664-016-0632-5. PMID: 27083430. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.27083430
Behzadi MA, Ziyaeyan M, Asaei S. Hepatitis B virus DNA level among the seropositive Afghan immigrants, southern Iran. Jundishapur J Microbiol. 2014;7(5):e10127. doi: 10.5812/jjm.10127. PMID: 25147713. Excluded: wrong country.25147713
Beran J, Van Der Meeren O, Leyssen M, . Immunity to hepatitis A and B persists for at least 15 years after immunisation of adolescents with a combined hepatitis A and B vaccine. Vaccine. 2016;34(24):2686–91. doi: 10.1016/j.vaccine.2016.04.033. PMID: 27105563. Excluded: wrong intervention: vaccine.27105563
Berg T, Simon KG, Mauss S, . Long-term response after stopping tenofovir disoproxil fumarate in non-cirrhotic HBeAg-negative patients - FINITE study. J Hepatol. 2017;67(5):918–24. doi: 10.1016/j.jhep.2017.07.012. PMID: 28736139. Excluded: wrong comparator.28736139
Bersoff-Matcha SJ, Cao K, Jason M, . Hepatitis B virus reactivation associated with direct-acting antiviral therapy for chronic hepatitis C virus: a review of cases reported to the U.S. Food and Drug Administration adverse event reporting system. Ann Intern Med. 2017;166(11):792–8. doi: 10.7326/m17-0377. PMID: 28437794. Excluded: wrong study design for key question.28437794
Bloch EM, Shah A, Kaidarova Z, . A pilot external quality assurance study of transfusion screening for HIV, HCV and HBsAG in 12 African countries. Vox Sang. 2014;107(4):333–42. doi: 10.1111/vox.12182. PMID: 25052195. Excluded: wrong country.25052195
Bowden S, Locarnini S, Chang TT, . Covalently closed-circular hepatitis B virus DNA reduction with entecavir or lamivudine. World J Gastroenterol. 2015;21(15):4644–51. doi: 10.3748/wjg.v21.i15.4644. PMID: 25914474. Excluded: wrong outcome.25914474
Brasseur M, Heurgue-Berlot A, Barbe C, . Prevalence of hepatitis B and C and sensibility of a selective screening questionnaire in patients receiving chemotherapy for solid tumors. BMC Cancer. 2015;15:999. doi: 10.1186/s12885-015-2033-z. PMID: 26694960. Excluded: wrong population.26694960
Brunetto MR, Oliveri F, Coco B, . Outcome of anti-HBe positive chronic hepatitis B in alpha-interferon treated and untreated patients: a long term cohort study. J Hepatol. 2002;36(2):263–70. PMID: 11830339. Excluded: sample size for cohort less than 1,000.11830339
Buja A, Martines D, Lobello S, . A cost-consequence analysis of hepatitis B screening in an immigrant population. Ann Ist Super Sanita. 2015;51(4):327–35. doi: 10.4415/ANN_15_04_13. PMID: 26783220. Excluded: wrong country.26783220
Bunchorntavakul C, Taweewattanakitbavorn V, Atsawarungruangkit A. Bone mineral density and renal function in chronic hepatitis B patients receiving nucleotide versus nucleoside analogs: a pilot prospective study. J Med Assoc Thai. 2016;99: Suppl 2:S1–8. PMID: 27266210. Excluded: wrong intervention.27266210
Buti M, Fung S, Gane E, . Long-term clinical outcomes in cirrhotic chronic hepatitis B patients treated with tenofovir disoproxil fumarate for up to 5 years. Hepatol Int. 2015;9(2):243–50. doi: 10.1007/s12072-015-9614-4. PMID: 25788199. Excluded: wrong population – cirrhosis.25788199
Buti M, Gane E, Seto WK, . Tenofovir alafenamide versus tenofovir disoproxil fumarate for the treatment of patients with HBeAg-negative chronic hepatitis B virus infection: a randomised, double-blind, phase 3, non-inferiority trial. Lancet Gastroenterol Hepatol. 2016;1(3):196–206. doi: 10.1016/S2468-1253(16)30107-8. PMID: 28404092. Excluded: wrong comparator.28404092
Buti M, Manzano ML, Morillas RM, . Randomized prospective study evaluating tenofovir disoproxil fumarate prophylaxis against hepatitis B virus reactivation in anti-HBc-positive patients with rituximab-based regimens to treat hematologic malignancies: the Preblin study. PLoS One. 2017;12(9)doi: 10.1371/journal.pone.0184550. PMID: 28898281. Excluded: wrong population – excluded for reactivation CQ.28898281
Buti M, Tsai N, Petersen J, . Seven-year efficacy and safety of treatment with tenofovir disoproxil fumarate for chronic hepatitis B virus infection. Dig Dis Sci. 2015;60(5):1457–64. doi: 10.1007/s10620-014-3486-7. PMID: 25532501. Excluded: wrong comparator.25532501
Byrne R, Carey I, Agarwal K. Tenofovir alafenamide in the treatment of chronic hepatitis B virus infection: rationale and clinical trial evidence. Therap Adv Gastroenterol. 2018;11:1756284818786108. doi: 10.1177/1756284818786108. PMID: 30034532. Excluded: wrong comparator.30034532
Cai Q, Chen K, Chen J, . The effect of prophylactic lamivudine plus adefovir therapy compared with lamivudine alone in preventing hepatitis B reactivation in lymphoma patients with high baseline HBV DNA during chemotherapy. PLoS One. 2016;11(10):e0164210. doi: 10.1371/journal.pone.0164210. PMID: 27711135. Excluded: wrong population – excluded for reactivation CQ.27711135
Cannizzaro MV, Franceschini C, Esposito M, . Hepatitis B reactivation in psoriasis patients treated with anti-TNF agents: prevention and management. Psoriasis (Aukl). 2017;7:35–40. doi: 10.2147/PTT.S108209. PMID: 29387606. Excluded: wrong population – excluded for reactivation CQ.29387606
Cannizzo ES, Tincati C, Binda F, . Unconventional T cells in chronic hepatitis B patients on long-term suppressive therapy with tenofovir followed by a Peg-IFN add-on strategy: a randomized study. J Viral Hepat. 2018;25(4):381–90. doi: 10.1111/jvh.12820. PMID: 29091327. Excluded: wrong intervention.29091327
Cantini F, Boccia S, Goletti D, . HBV reactivation in patients treated with antitumor necrosis factor-alpha (TNF-alpha) agents for rheumatic and dermatologic conditions: a systematic review and meta-analysis. Int J Rheumatol. 2014;2014:926836. doi: 10.1155/2014/926836. PMID: 25114684. Excluded: wrong population – excluded for reactivation CQ.25114684
Carroll MB, Forgione MA. Use of tumor necrosis factor alpha inhibitors in hepatitis B surface antigen-positive patients: a literature review and potential mechanisms of action. Clin Rheumatol. 2010;29(9):1021–9. doi: 10.1007/s10067-010-1523-2. PMID: 20556450. Excluded: wrong population – excluded for reactivation CQ.20556450
Castelli R, Ferraris L, Pantaleo G, . High rate of hepatitis B viral breakthrough in elderly non-Hodgkin lymphomas patients treated with rituximab based chemotherapy. Dig Liver Dis. 2016;48(11):1394–7. doi: 10.1016/j.dld.2016.08.113. PMID: 27590841. Excluded: wrong population – excluded for reactivation CQ.27590841
Caviglia GP, Olivero A, Ngatchou D, . Long-term results of chronic hepatitis B antiviral treatment with nucleos(t)ide analogues: a single center experience. Minerva Gastroenterol Dietol. 2019;65(1):77–8. doi: 10.23736/S1121-421X.18.02517-5. PMID: 30037184. Excluded: wrong study design for key question.30037184
Centers for Disease Control and Prevention. Surveillance for viral hepatitis-United States, 2015. 2015. https://www.cdc.gov/hepatitis/statistics/2015surveillance/Commentary.htm#Ref02. Accessed August 21, 2019. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Chan HL, Chan CK, Hui AJ, . Effects of tenofovir disoproxil fumarate in hepatitis B e antigen-positive patients with normal levels of alanine aminotransferase and high levels of hepatitis B virus DNA. Gastroenterology. 2014;146(5):1240–8. doi: 10.1053/j.gastro.2014.01.044. PMID: 24462735. Excluded: wrong intervention.24462735
Chan HL, Chen YC, Gane EJ, . Randomized clinical trial: efficacy and safety of telbivudine and lamivudine in treatment-naive patients with HBV-related decompensated cirrhosis. J Viral Hepat. 2012;19(10):732–43. doi: 10.1111/j.1365-2893.2012.01600.x. PMID: 22967105. Excluded: wrong comparator.22967105
Chan HL, Fung S, Seto WK, . Tenofovir alafenamide versus tenofovir disoproxil fumarate for the treatment of HBeAg-positive chronic hepatitis B virus infection: a randomised, double-blind, phase 3, non-inferiority trial. Lancet Gastroenterol Hepatol. 2016;1(3):185–95. doi: 10.1016/S2468-1253(16)30024-3. PMID: 28404091. Excluded: wrong comparator.28404091
Chan HL, Shaikh J, Gupta S, . Renal function in nucleos(t)ide analog-treated patients with chronic hepatitis B: a systematic literature review and network meta-analysis. Adv Ther. 2016;33(5):862–75. doi: 10.1007/s12325-016-0337-2. PMID: 27146675. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.27146675
Chan HY, Lim YS, Seto WK, . Three year efficacy and safety of tenofovir alafenamide (TAF) compared to tenofovir disoproxil fumarate (TDF) in HBeAgnegative and HBeAg-positive patients with chronic hepatitis B. Hepatol Int. 2019;13. Excluded: wrong comparator.
Chang JJ, Mohtashemi N, Bhattacharya D. Significance and management of isolated hepatitis B core antibody (Anti-HBc) in HIV and HCV: strategies in the DAA era. Curr HIV/AIDS Rep. 2018;15(2):172–81. doi: 10.1007/s11904-018-0379-y. PMID: 29572624. Excluded: wrong population – excluded for reactivation CQ.29572624
Chang ML, Liaw YF, Hadziyannis SJ. Systematic review: cessation of long-term nucleos(t)ide analogue therapy in patients with hepatitis B e antigen-negative chronic hepatitis B. Aliment Pharmacol Ther. 2015;42(3):243–57. doi: 10.1111/apt.13272. PMID: 26151841. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.26151841
Chang TT, Lai CL, Kew Yoon S, . Entecavir treatment for up to 5 years in patients with hepatitis B e antigen-positive chronic hepatitis B. Hepatology. 2010;51(2):422–30. doi: 10.1002/hep.23327. PMID: 20049753. Excluded: wrong population.20049753
Chang TT, Liaw YF, Wu SS, . Long-term entecavir therapy results in the reversal of fibrosis/cirrhosis and continued histological improvement in patients with chronic hepatitis B. Hepatology. 2010;52(3):886–93. doi: 10.1002/hep.23785. PMID: 20683932. Excluded: wrong study design for key question.20683932
Chang Y, Choe WH, Sinn DH, . Nucleos(t)ide analogue treatment for patients with hepatitis B virus (HBV) e antigen-positive chronic HBV genotype C infection: a nationwide, multicenter, retrospective study. J Infect Dis. 2017;216(11):1407–14. doi: 10.1093/infdis/jix506. PMID: 29029102. Excluded: wrong population.29029102
Charuworn P, Hengen PN, Aguilar Schall R, . Baseline interpatient hepatitis B viral diversity differentiates HBsAg outcomes in patients treated with tenofovir disoproxil fumarate. J Hepatol. 2015;62(5):1033–9. doi: 10.1016/j.jhep.2014.12.008. PMID: 25514556. Excluded: wrong outcome.25514556
Chen CH, Hung CH, Wang JH, . Long-term incidence and predictors of hepatitis B surface antigen loss after discontinuing nucleoside analogues in noncirrhotic chronic hepatitis B patients. Clin Microbiol Infect. 2018;24(9):997–1003. doi: 10.1016/j.cmi.2017.12.013. PMID: 29288020. Excluded: wrong comparator.29288020
Chen G, Liu H, Hu ZQ, . A new scheme with infusion of hepatitis B immunoglobulin combined with entecavir for prophylaxis of hepatitis B virus recurrence among liver transplant recipients. Eur J Gastroenterol Hepatol. 2015;27(8):901–6. doi: 10.1097/MEG.0000000000000388. PMID: 26011237. Excluded: wrong population.26011237
Chen G, Wang C, Chen J, . Hepatitis B reactivation in hepatitis B and C coinfected patients treated with antiviral agents: a systematic review and meta-analysis. Hepatology. 2017;66(1):13–26. doi: 10.1002/hep.29109. PMID: 28195337. Excluded: wrong population - excluded for reactivation CQ.28195337
Chen LF, Mo YQ, Jing J, . Short-course tocilizumab increases risk of hepatitis B virus reactivation in patients with rheumatoid arthritis: a prospective clinical observation. Int J Rheum Dis. 2017;20(7):859–69. doi: 10.1111/1756-185X.13010. PMID: 28160426. Excluded: wrong population – excluded for reactivation CQ.28160426
Chen WC, Cheng JS, Chiang PH, . A comparison of entecavir and lamivudine for the prophylaxis of hepatitis B virus reactivation in solid tumor patients undergoing systemic cytotoxic chemotherapy. PLoS One. 2015;10(6):e0131545. doi: 10.1371/journal.pone.0131545. PMID: 26121480. Excluded: wrong population – excluded for reactivation CQ.26121480
Chen X, Chen X, Chen W, . Extended peginterferon alfa-2a (Pegasys) therapy in Chinese patients with HBeAg-negative chronic hepatitis B. J Med Virol. 2014;86(10):1705–13. doi: 10.1002/jmv.24013. PMID: 24980710. Excluded: wrong comparator.24980710
Cheng J, Hou J, Ding H, . Validation of ten noninvasive diagnostic models for prediction of liver fibrosis in patients with chronic hepatitis B. PLoS One. 2015;10(12)doi: 10.1371/journal.pone.0144425. PMID: 26709706. Excluded: wrong outcome.26709706
Cheng J, Wang Y, Hou J, . Peginterferon alfa-2b in the treatment of Chinese patients with HBeAg-positive chronic hepatitis B: a randomized trial. J Clin Virol. 2014;61(4):509–16. doi: 10.1016/j.jcv.2014.08.008. PMID: 25200354. Excluded: wrong comparator.25200354
Cheng Y, Yan ML, Wang L, . Effect of entecavir and adefovir dipivoxil on thyroid function and liver function in patients with decompensated hepatitis B cirrhosis. World Chin J Dig. 2018;26(5):311–7. doi: 10.11569/wcjd.v26.i5.311. Excluded: not English language but possibly relevant.
Chi H, Hansen BE, Guo S, . Pegylated interferon Alfa-2b add-on treatment in hepatitis B virus envelope antigen-positive chronic hepatitis B patients treated with nucleos(t)ide analogue: a randomized, controlled trial (PEGON). J Infect Dis. 2017;215(7):1085–93. doi: 10.1093/infdis/jix024. PMID: 28329061. Excluded: wrong intervention.28329061
Chiang HH, Lee CM, Hu TH, . A combination of the on-treatment FIB-4 and alpha-foetoprotein predicts clinical outcomes in cirrhotic patients receiving entecavir. Liver Int. 2018;38(11):1997–2005. doi: 10.1111/liv.13889. PMID: 29797410. Excluded: wrong population – cirrhosis.29797410
Chisenga CC, Musukuma K, Chilengi R, . Field performance of the determine HBsAg point-of-care test for diagnosis of hepatitis B virus co-infection among HIV patients in Zambia. J Clin Virol. 2018;98:5–7. doi: 10.1016/j.jcv.2017.11.005. PMID: 29175231. Excluded: wrong population – comorbid HIV or HCV.29175231
Cholongitas E, Haidich AB, Apostolidou-Kiouti F, . Hepatitis B virus reactivation in HBsAg-negative, anti-HBc-positive patients receiving immunosuppressive therapy: a systematic review. Ann Gastroenterol. 2018;31(4):480–90. doi: 10.20524/aog.2018.0266. PMID: 29991894. Excluded: wrong population – excluded for reactivation CQ.29991894
Choudhary NS, Saraf N, Saigal S, . Low-dose short-term hepatitis B immunoglobulin with high genetic barrier antivirals: the ideal post-transplant hepatitis B virus prophylaxis? Transpl Infect Dis. 2015;17(3):329–33. doi: 10.1111/tid.12369. PMID: 25682715. Excluded: wrong population – cirrhosis.25682715
Coluccio C, Begini P, Marzano A, . Hepatitis B in patients with hematological diseases: an update. World J Hepatol. 2017;9(25):1043–53. doi: 10.4254/wjh.v9.i25.1043. PMID: 28951776. Excluded: wrong population – excluded for reactivation CQ.28951776
Crespo J, Esteban R, Torres C, . Cost-effectiveness of a hepatitis B virus screening strategy to prevent reactivation in patients with hematologic neoplasms. Rev Esp Enferm Dig. 2017;109(9):619–26. doi: 10.17235/reed.2017.4693/2016. PMID: 28648087. Excluded: wrong population.28648087
Cruz HM, Scalioni LP, Paula VS, . Poor sensitivity of rapid tests for the detection of antibodies to the hepatitis B virus: implications for field studies. Mem Inst Oswaldo Cruz. 2017;112(3):209–13. doi: 10.1590/0074-02760160394. PMID: 28146158. Excluded: wrong country.28146158
Cunha-Silva M, Marinho FRT, Oliveira PF, . Retrospective analysis of hepatitis B virus chronic infection in 247 patients: clinical stages, response to treatment and poor prognostic factors. Braz J Infect Dis. 2017;21(4):441–7. doi: 10.1016/j.bjid.2017.03.019. PMID: 28554002. Excluded: wrong population – cirrhosis.28554002
Dakin H, Fidler C, Harper C. Mixed treatment comparison meta-analysis evaluating the relative efficacy of nucleos(t)ides for treatment of nucleos(t)ide-naive patients with chronic hepatitis B. Value Health. 2010;13(8):934–45. doi: 10.1111/j.1524-4733.2010.00777.x. PMID: 20825624. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.20825624
Day FL, Karnon J, Rischin D. Cost-effectiveness of universal hepatitis B virus screening in patients beginning chemotherapy for solid tumors. J Clin Oncol. 2011;29(24):3270–7. doi: 10.1200/JCO.2011.35.1635. PMID: 21788556. Excluded: wrong population.21788556
de Man RA, Wolters LM, Nevens F, . Safety and efficacy of oral entecavir given for 28 days in patients with chronic hepatitis B virus infection. Hepatology. 2001;34(3):578–82. doi: 10.1053/jhep.2001.26815. PMID: 11526545. Excluded: wrong population.11526545
de Niet A, Jansen L, Stelma F, . Peg-interferon plus nucleotide analogue treatment versus no treatment in patients with chronic hepatitis B with a low viral load: a randomised controlled, open-label trial. Lancet Gastroenterol Hepatol. 2017;2(8):576–84. doi: 10.1016/S2468-1253(17)30083-3. PMID: 28522204. Excluded: wrong intervention.28522204
Di Marco V, Lo Iacono O, Camma C, . The long-term course of chronic hepatitis B. Hepatology. 1999;30(1):257–64. doi: 10.1002/hep.510300109. PMID: 10385664. Excluded: sample size for cohort less than 1,000.10385664
Di Marco V, Marzano A, Lampertico P, . Clinical outcome of HBeAg-negative chronic hepatitis B in relation to virological response to lamivudine. Hepatology. 2004;40(4):883–91. PMID: 15382125. Excluded: wrong population – cirrhosis.15382125
Ding Y, Lou J, Chen H, . Tolerability, pharmacokinetics and antiviral activity of rHSA/IFNalpha2a for the treatment of chronic hepatitis B infection. Br J Clin Pharmacol. 2017;83(5):1056–71. doi: 10.1111/bcp.13184. PMID: 27862178. Excluded: wrong comparator.27862178
Ding Y, Zhang H, Li X, . Safety, pharmacokinetics and pharmacogenetics of a single ascending dose of pradefovir, a novel liver-targeting, anti-hepatitis B virus drug, in healthy Chinese subjects. Hepatol Int. 2017;11(4):390–400. doi: 10.1007/s12072-017-9797-y. PMID: 28560658. Excluded: wrong intervention.28560658
Dong HJ, Ni LN, Sheng GF, . Risk of hepatitis B virus (HBV) reactivation in non-hodgkin lymphoma patients receiving rituximab-chemotherapy: a meta-analysis. J Clin Virol. 2013;57(3):209–14. doi: 10.1016/j.jcv.2013.03.010. PMID: 23562041. Excluded: wrong population – excluded for reactivation CQ.23562041
Dong J, Wu Y, Zhu H, . A pilot study on screening blood donors with individual-donation nucleic acid testing in China. Blood Transfus. 2014;12(2):172–9. doi: 10.2450/2013.0095-13. PMID: 24333061. Excluded: wrong country.24333061
El Kassas M, Shimakawa Y, Ali-Eldin Z, . Risk of hepatitis B virus reactivation with direct-acting antivirals against hepatitis C virus: a cohort study from Egypt and meta-analysis of published data. Liver Int. 2018;38(12):2159–69. doi: 10.1111/liv.13874. PMID: 29738637. Excluded: wrong population – excluded for reactivation CQ.29738637
Embree J, Law B, Voloshen T, . Immunogenicity, safety, and antibody persistence at 3, 5, and 10 years postvaccination in adolescents randomized to booster immunization with a combined tetanus, diphtheria, 5-component acellular pertussis, and inactivated poliomyelitis vaccine administered with a hepatitis B virus vaccine concurrently or 1 month apart. Clin Vaccine Immunol. 2015;22(3):282–90. doi: 10.1128/CVI.00682-14. PMID: 25540274. Excluded: wrong intervention.25540274
Eun JR, Lee HJ, Lee SH, . The effect of lamivudine and adefovir dipivoxil on preventing hepatocellular carcinoma in hepatitis B virus-related liver cirrhosis. Hepatology. 2007;46(4):664A–5A. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Evens AM, Jovanovic BD, Su YC, . Rituximab-associated hepatitis B virus (HBV) reactivation in lymphoproliferative diseases: meta-analysis and examination of FDA safety reports. Ann Oncol. 2011;22(5):1170–80. doi: 10.1093/annonc/mdq583. PMID: 21115603. Excluded: wrong population – excluded for reactivation CQ.21115603
Fang J, Li W, Tan Z, . Comparison of prednisolone and lamivudine combined therapy with prednisolone monotherapy on carriers of hepatitis B virus with IgA nephropathy: a prospective cohort study. Int Urol Nephrol. 2014;46(1):49–56. doi: 10.1007/s11255-013-0480-5. PMID: 23756850. Excluded: wrong comparator.23756850
Fattovich G, Giustina G, Realdi G, . Long-term outcome of hepatitis B e antigen-positive patients with compensated cirrhosis treated with interferon alfa. European Concerted Action on Viral Hepatitis (EUROHEP). Hepatology. 1997;26(5):1338–42. PMID: 9362381. Excluded: wrong population – cirrhosis.9362381
Feld JJ, Terrault NA, Lin HS, . Entecavir and peginterferon alfa-2a in adults with hepatitis B e antigen-positive immune-tolerant chronic hepatitis B virus infection. Hepatology. 2019;69(6):2338–48. doi: 10.1002/hep.30417. PMID: 30549279. Excluded: wrong intervention: nonFDA approved drug.30549279
Fernandez I, Loinaz C, Hernandez O, . Tenofovir/entecavir monotherapy after hepatitis B immunoglobulin withdrawal is safe and effective in the prevention of hepatitis B in liver transplant recipients. Transpl Infect Dis. 2015;17(5):695–701. doi: 10.1111/tid.12434. PMID: 26257166. Excluded: wrong population.26257166
Flanagan S, Kunkel J, Appleby V, . Case finding and therapy for chronic viral hepatitis in primary care (HepFREE): a cluster-randomised controlled trial. Lancet Gastroenterol Hepatol. 2019;4(1):32–44. doi: 10.1016/S2468-1253(18)30318-2. PMID: 30477810. Excluded: wrong outcome.30477810
Franzeck FC, Ngwale R, Msongole B, . Viral hepatitis and rapid diagnostic test based screening for HBsAg in HIV-infected patients in rural Tanzania. PLoS One. 2013;8(3) PMID: 23469281. Excluded: wrong population – comorbid HIV or HCV.23469281
Fung J, Wong T, Chok K, . Oral nucleos(t)ide analogs alone after liver transplantation in chronic hepatitis B with preexisting rt204 mutation. Transplantation. 2017;101(10):2391–8. doi: 10.1097/TP.0000000000001883. PMID: 28731907. Excluded: wrong population.28731907
Fung S, Gordon SC, Krastev Z, . Tenofovir disoproxil fumarate in Asian or Pacific Islander chronic hepatitis B patients with high viral load (>= 9 log10 copies/ml). Liver Int. 2015;35(2):422–8. doi: 10.1111/liv.12694. PMID: 25277773. Excluded: wrong study design for key question.25277773
Furukawa EN, Yamashita S, Maeyama K, . Clinical course of hepatitis B surface antigen positive subjects following screening: a retrospective observational study from April 2008 to January 2013. Hepatol Res. 2016;46(7):678–85. doi: 10.1111/hepr.12608. PMID: 26492344. Excluded: wrong outcome.26492344
Gaia S, Marzano A, Smedile A, . Four years of treatment with lamivudine: clinical and virological evaluations in HBe antigen-negative chronic hepatitis B. Aliment Pharmacol Ther. 2004;20(3):281–7. doi: 10.1111/j.1365-2036.2004.02073.x. PMID: 15274664. Excluded: wrong comparator.15274664
Gane EJ, Wang Y, Liaw YF, . Efficacy and safety of prolonged 3-year telbivudine treatment in patients with chronic hepatitis B. Liver Int. 2011;31(5):676–84. doi: 10.1111/j.1478-3231.2011.02490.x. PMID: 21457439. Excluded: wrong population.21457439
Gao YJ, Zhang M, Jin B, . Clinical-pathological analysis of hepatitis B virus recurrence after liver transplantation in Chinese patients. J Gastroenterol Hepatol. 2014;29(3):554–60. doi: 10.1111/jgh.12404. PMID: 24117714. Excluded: wrong population.24117714
Garg H, Sarin SK, Kumar M, . Tenofovir improves the outcome in patients with spontaneous reactivation of hepatitis B presenting as acute-on-chronic liver failure. Hepatology. 2011;53(3):774–80. doi: 10.1002/hep.24109. PMID: 21294143. Excluded: wrong population – excluded for reactivation CQ.21294143
Geng L, Lin BY, Shen T, . Anti-virus prophylaxis withdrawal may be feasible in liver transplant recipients whose serum HBeAg and HBV DNA are negative. Hepatobiliary Pancreat Dis Int. 2016;15(3):316–8. PMID: 27298109. Excluded: wrong population.27298109
Gentile G, Andreoni M, Antonelli G, . Screening, monitoring, prevention, prophylaxis and therapy for hepatitis B virus reactivation in patients with haematologic malignancies and patients who underwent haematologic stem cell transplantation: a systematic review. Clin Microbiol Infect. 2017;23(12):916–23. doi: 10.1016/j.cmi.2017.06.024. PMID: 28668465. Excluded: wrong population – excluded for reactivation CQ.28668465
Geue C, Wu O, Xin Y, . Cost-effectiveness of HBV and HCV screening strategies - a systematic review of existing modelling techniques. PLoS One. 2015;10(12):e0145022. doi: 10.1371/journal.pone.0145022. PMID: 26689908. Excluded: wrong outcome.26689908
Gisbert JP, Chaparro M, Esteve M. Review article: prevention and management of hepatitis B and C infection in patients with inflammatory bowel disease. Aliment Pharmacol Ther. 2011;33(6):619–33. PMID: 21416659. Excluded: wrong population – excluded for reactivation CQ.21416659
Gong WF, Zhong JH, Lu SD, . Effects of antiviral therapy on post-hepatectomy HBV reactivation and liver function in HBV DNA-negative patients with HBV-related hepatocellular carcinoma. Oncotarget. 2017;8(9):15047–56. PMID: 28122361. Excluded: wrong population.28122361
Govan L, Wu O, Xin Y, . Comparative effectiveness of antiviral treatment for hepatitis B: a systematic review and Bayesian network meta-analysis. Eur J Gastroenterol Hepatol. 2015;27(8):882–94. doi: 10.1097/MEG.0000000000000376. PMID: 25919772. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.25919772
Guarino M, Picardi M, Vitello A, . Viral outcome in patients with occult HBV infection or HCV-Ab positivity treated for lymphoma. Ann Hepatol. 2017;16(2):198–206. doi: 10.5604/16652681.1231567. PMID: 28233742. Excluded: wrong population – excluded for reactivation CQ.28233742
Guner R, Kocak Tufan Z, Yilmaz GR, . Tenofovir disoproxil fumarate may not cause renal and bone toxicity in chronic hepatitis B patients: a retrospective cross-sectional study. Turk J Med Sci. 2019;49(1):451–2. doi: 10.3906/sag-1805-233. PMID: 30761830. Excluded: wrong study design for key question.30761830
Guzelbulut F, Ovunc AO, Oetinkaya ZA, . Comparison of the efficacy of entecavir and tenofovir in chronic hepatitis B. Hepatogastroenterology. 2012;59(114):477–80. doi: 10.5754/hge11426. PMID: 21940383. Excluded: wrong outcome.21940383
Hadziyannis S, Bramou T, Makris A, . Interferon alfa-2b treatment of HBeAg negative/serum HBV DNA positive chronic active hepatitis type B. J Hepatol. 1990;11: Suppl 1:S133–6. PMID: 2079571. Excluded: wrong population – cirrhosis.2079571
Hadziyannis SJ, Tassopoulos NC, Heathcote EJ, . Long-term therapy with adefovir dipivoxil for HBeAg-negative chronic hepatitis B for up to 5 years. Gastroenterology. 2006;131(6):1743–51. doi: 10.1053/j.gastro.2006.09.020. PMID: 17087951. Excluded: wrong population.17087951
Hahne SJ, Veldhuijzen IK, Wiessing L, . Infection with hepatitis B and C virus in Europe: a systematic review of prevalence and cost-effectiveness of screening. BMC Infect Dis. 2013;13:181. doi: 10.1186/1471-2334-13-181. PMID: 23597411. Excluded: wrong country.23597411
Hakim GD, Akarsu M, Karademir S, . The efficacy and safety of tenofovir in the prevention of hepatitis B virus recurrence following liver transplantation. Turk J Gastroenterol. 2014;25(6):685–9. doi: 10.5152/tjg.2014.5819. PMID: 25599782. Excluded: wrong population.25599782
Han M, Jiang J, Hou J, . Sustained immune control in HBeAg-positive patients who switched from entecavir therapy to pegylated interferon-alpha2a: 1 year follow-up of the OSST study. Antivir Ther. 2016;21(4):337–44. doi: 10.3851/IMP3019. PMID: 26734984. Excluded: wrong comparator.26734984
Han Y, Zeng A, Liao H, . The efficacy and safety comparison between tenofovir and entecavir in treatment of chronic hepatitis B and HBV related cirrhosis: a systematic review and meta-analysis. Int Immunopharmacol. 2017;42:168–75. doi: 10.1016/j.intimp.2016.11.022. PMID: 27915131. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.27915131
Hardtke S, Wedemeyer H, Caruntu FA, . Frequency, severity and impact of Peg-IFNa-associated flares in HDV infection: results from the HIDIT-II study. J Hepatol. 2019;70(1):e466. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Hay AE, Meyer RM. Hepatitis B, rituximab, screening, and prophylaxis: effectiveness and cost effectiveness. J Clin Oncol. 2012;30(26):3155–7. doi: 10.1200/JCO.2012.43.7509. PMID: 22891267. Excluded: not a study (letter, editorial, non-systematic review article, no original data).22891267
He LT, Ye XG, Zhou XY. Effect of switching from treatment with nucleos(t)ide analogs to pegylated interferon alpha-2a on virological and serological responses in chronic hepatitis B patients. World J Gastroenterol. 2016;22(46):10210–8. doi: 10.3748/wjg.v22.i46.10210. PMID: 28028369. Excluded: wrong population.28028369
Heathcote EJ, Marcellin P, Buti M, . Three-year efficacy and safety of tenofovir disoproxil fumarate treatment for chronic hepatitis B. Gastroenterology. 2011;140(1):132–43. doi: 10.1053/j.gastro.2010.10.011. PMID: 20955704. Excluded: wrong study design for key question.20955704
Hepatitis B Foundation. Hepatitis C coinfection. http://www.hepb.org/what-is-hepatitis-b/hepatitis-c-co-infection/. Accessed January 2, 2019. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Hepatitis B Foundation. HIV/AIDS coinfection. http://www.hepb.org/what-is-hepatitis-b/hivaids-co-infection/. Accessed January 2, 2019. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Ho EY, Yau T, Rousseau F, . Preemptive adefovir versus lamivudine for prevention of hepatitis B reactivation in chronic hepatitis B patients undergoing chemotherapy. Hepatol Int. 2015;9(2):224–30. doi: 10.1007/s12072-015-9612-6. PMID: 25788197. Excluded: wrong population – excluded for reactivation CQ.25788197
Hou JL, Zhao W, Lee C, . Outcomes of long-term treatment of chronic HBV infection with entecavir or other agents from a randomized trial in 24 countries. Clin Gastroenterol Hepatol. 2019;12:12. doi: 10.1016/j.cgh.2019.07.010. PMID: 31306800. Excluded: wrong population.31306800
Hsu C, Tsou HH, Lin SJ, . Chemotherapy-induced hepatitis B reactivation in lymphoma patients with resolved HBV infection: a prospective study. Hepatology. 2014;59(6):2092–100. doi: 10.1002/hep.26718. PMID: 24002804. Excluded: wrong population – excluded for reactivation CQ.24002804
Hsu YC, Ho HJ, Lee TY, . Temporal trend and risk determinants of hepatocellular carcinoma in chronic hepatitis B patients on entecavir or tenofovir. J Viral Hepat. 2018;25(5):543–51. doi: 10.1111/jvh.12832. PMID: 29193536. Excluded: wrong population – cirrhosis.29193536
Hu TH, Chen CL, Lin CC, . Section 14. Combination of entecavir plus low-dose on-demand hepatitis B immunoglobulin is effective with very low hepatitis B recurrence after liver transplantation. Transplantation. 2014;97: Suppl 8:S53–9. doi: 10.1097/01.tp.0000446278.43804.f9. PMID: 24849836. Excluded: wrong population.24849836
Huang L, Li J, Yan J, . Antiviral therapy decreases viral reactivation in patients with hepatitis B virus-related hepatocellular carcinoma undergoing hepatectomy: a randomized controlled trial. J Viral Hepat. 2013;20(5):336–42. PMID: 23565616. Excluded: wrong population.23565616
Huang LH, Qiu YW, Hua HY, . The efficacy and safety of entecavir in patients with advanced schistosomiasis co-infected with hepatitis B virus. Int J Infect Dis. 2013;17(8):e606–e9. doi: 10.1016/j.ijid.2013.01.023. PMID: 23490092. Excluded: wrong population.23490092
Huang YH, Hsiao LT, Hong YC, . Randomized controlled trial of entecavir prophylaxis for rituximab-associated hepatitis B virus reactivation in patients with lymphoma and resolved hepatitis B. J Clin Oncol. 2013;31(22):2765–72. doi: 10.1200/JCO.2012.48.5938. PMID: 23775967. Excluded: wrong population – excluded for reactivation CQ.23775967
Huang YW, Takahashi S, Tsuge M, . On-treatment low serum HBV RNA level predicts initial virological response in chronic hepatitis B patients receiving nucleoside analogue therapy. Antivir Ther. 2015;20(4):369–75. doi: 10.3851/IMP2777. PMID: 24739420. Excluded: wrong study design for key question.24739420
Huang Y-W, Chung RT. Management of hepatitis B reactivation in patients receiving cancer chemotherapy. Therap Adv Gastroenterol. 2012;5(5):359. doi: 10.1177/1756283X12450245. PMID: 22973419. Excluded: not a study (letter, editorial, non-systematic review article, no original data).22973419
Hutton DW, Tan D, So SK, . Cost-effectiveness of screening and vaccinating Asian and Pacific Islander adults for hepatitis B. Ann Intern Med. 2007;147(7):460–9. PMID: 17909207. Excluded: old cost effectiveness.17909207
Hwang JP, Huang D, Vierling JM, . Cost-effectiveness analysis of hepatitis B virus screening and management in patients with hematologic or solid malignancies anticipating immunosuppressive cancer therapy. JCO Clin Cancer Inform. 2019;3:1–12. doi: 10.1200/CCI.18.00097. PMID: 30892921. Excluded: wrong population.30892921
Hwang JP, Vierling JM, Zelenetz AD, . Hepatitis B virus management to prevent reactivation after chemotherapy: a review. Support Care Cancer. 2012;20(11):2999–3008. doi: 10.1007/s00520-012-1576-7. PMID: 22933131. Excluded: wrong population – excluded for reactivation CQ.22933131
Ibragimov EK, Abdurakhmanov DT, Rozina TP, . Efficacy and safety of long-term therapy with nucleos(t)ide analogues in chronic hepatitis B. Ter Arkh. 2019;91(2):40–7. doi: 10.26442/00403660.2019.02.000073. PMID: 31094170. Excluded: not English language but possibly relevant.31094170
Idilman R, Akyildiz M, Keskin O, . The long-term efficacy of combining nucleos(t)ide analog and low-dose hepatitis B immunoglobulin on post-transplant hepatitis B virus recurrence. Clin Transplant. 2016;30(10):1216–21. doi: 10.1111/ctr.12804. PMID: 27409074. Excluded: wrong population.27409074
Ismail MH, Wiysonge CS, Ricaforte-Campos JD, . Entecavir for chronic hepatitis B. Cochrane Database Syst Rev. update in process to 2014 report. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.
Jazwa A, Coleman MS, Gazmararian J, . Cost-benefit comparison of two proposed overseas programs for reducing chronic hepatitis B infection among refugees: is screening essential? Vaccine. 2015;33(11):1393–9. doi: 10.1016/j.vaccine.2015.01.010. PMID: 25595868. Excluded: wrong country.25595868
Jia HY, Ding F, Chen JY, . Early kidney injury during long-term adefovir dipivoxil therapy for chronic hepatitis B. World J Gastroenterol. 2015;21(12):3657–62. doi: 10.3748/wjg.v21.i12.3657. PMID: 25834334. Excluded: wrong study design for key question.25834334
Jia J, Hou J, Ding H, . Transient elastography compared to serum markers to predict liver fibrosis in a cohort of Chinese patients with chronic hepatitis B. J Gastroenterol Hepatol. 2015;30(4):756–62. doi: 10.1111/jgh.12840. PMID: 25353058. Excluded: wrong outcome.25353058
Jia J, Tang H, Ning Q, . Real-world evidence for nucleoside/nucleotide analogues in a 5-year multicentre study of antiviral-naive chronic hepatitis B patients in China: 52-week results. Antivir Ther. 2018;23(3):201–9. doi: 10.3851/IMP3205. PMID: 29116050. Excluded: wrong population – cirrhosis.29116050
Jia JD, Hou JL, Yin YK, . Two-year results of a randomized, phase III comparative trial of telbivudine versus lamivudine in Chinese patients. Hepatol Int. 2014;8(1):72–82. doi: 10.1007/s12072-013-9488-2. PMID: 26202408. Excluded: wrong comparator.26202408
Jia W, Qi X, Ji YY, . Low serum hepatitis B surface antigen level predicts compensated cirrhosis caused by chronic hepatitis B in HBeAg positive patients in east China. Hepat Mon. 2015;15(8):e29183. doi: 10.5812/hepatmon.29183. PMID: 26322110. Excluded: wrong outcome.26322110
Jiang L, Yan L, Wen T, . Hepatitis B prophylaxis using lamivudine and individualized low-dose hepatitis B immunoglobulin in living donor liver transplantation. Transplant Proc. 2013;45(6):2326–30. doi: 10.1016/j.transproceed.2013.03.028. PMID: 23953544. Excluded: wrong population.23953544
Jiang XW, Ye JZ, Li YT, . Hepatitis B reactivation in patients receiving direct-acting antiviral therapy or interferon-based therapy for hepatitis C: a systematic review and meta-analysis. World J Gastroenterol. 2018;24(28):3181–91. doi: 10.3748/wjg.v24.i28.3181. PMID: 30065564. Excluded: wrong population – excluded for reactivation CQ.30065564
Jonas MM, Block JM, Haber BA, . Treatment of children with chronic hepatitis B virus infection in the United States: patient selection and therapeutic options. Hepatology. 2010;52(6):2192–205. doi: 10.1002/hep.23934. PMID: 20890947. Excluded: not a study (letter, editorial, non-systematic review article, no original data).20890947
Jonas MM, Chang MH, Sokal E, . Randomized, controlled trial of entecavir versus placebo in children with hepatitis B envelope antigen-positive chronic hepatitis B. Hepatology. 2016;63(2):377–87. doi: 10.1002/hep.28015. PMID: 26223345. Excluded: wrong population.26223345
Jonas MM, Kelly D, Pollack H, . Safety, efficacy, and pharmacokinetics of adefovir dipivoxil in children and adolescents (age 2 to <18 years) with chronic hepatitis B. Hepatology. 2008;47(6):1863–71. PMID: 18433023. Excluded: wrong population.18433023
Jonas MM, Lok AS, McMahon BJ, . Antiviral therapy in management of chronic hepatitis B viral infection in children: a systematic review and meta-analysis. Hepatology. 2016;63(1):307–18. doi: 10.1002/hep.28278. PMID: 26566163. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.26566163
Ju YC, Jun DW, Choi J, . Long term outcome of antiviral therapy in patients with hepatitis B associated decompensated cirrhosis. World J Gastroenterol. 2018;24(40):4606–14. doi: 10.3748/wjg.v24.i40.4606. PMID: 30386110. Excluded: wrong population – cirrhosis.30386110
Jung KS, Park JY, Chon YE, . Clinical outcomes and predictors for relapse after cessation of oral antiviral treatment in chronic hepatitis B patients. J Gastroenterol. 2016;51(8):830–9. doi: 10.1007/s00535-015-1153-1. PMID: 26687058. Excluded: wrong study design for key question.26687058
Kara AV, Yildirim Y, Ozcicek F, . Effects of entecavir, tenofovir and telbivudine treatment on renal functions in chronic hepatitis B patients. Acta Gastroenterol Belg. 2019;82(2):273–7. PMID: 31314188. Excluded: wrong study design for key question.31314188
Karacaer Z, Cakir B, Erdem H, . Quality of life and related factors among chronic hepatitis B-infected patients: a multi-center study, Turkey. Health Qual Life Outcomes. 2016;14(1):153. PMID: 27809934. Excluded: wrong outcome.27809934
Karvellas CJ, Cardoso FS, Gottfried M, . HBV-associated acute liver failure after immunosuppression and risk of death. Clin Gastroenterol Hepatol. 2017;15(1):113–22. PMID: 27311622. Excluded: wrong population.27311622
Katz LH, Fraser A, Gafter-Gvili A, . Lamivudine prevents reactivation of hepatitis B and reduces mortality in immunosuppressed patients: systematic review and meta-analysis. J Viral Hepat. 2008;15(2):89–102. doi: 10.1111/j.1365-2893.2007.00902.x. PMID: 18184191. Excluded: wrong population – excluded for reactivation CQ.18184191
Katz LH, Tur-Kaspa R, Guy DG, . Lamivudine or adefovir dipivoxil alone or combined with immunoglobulin for preventing hepatitis B recurrence after liver transplantation. Cochrane Database Syst Rev. 2010 (7):CD006005. doi: 10.1002/14651858.CD006005.pub2. PMID: 20614442. Excluded: wrong population – excluded for reactivation CQ.20614442
Kawagishi N, Suda G, Onozawa M, . Comparing the risk of hepatitis B virus reactivation between direct-acting antiviral therapies and interferon-based therapies for hepatitis C. J Viral Hepat. 2017;24(12):1098–106. doi: 10.1111/jvh.12737. PMID: 28632923. Excluded: wrong population – excluded for reactivation CQ.28632923
Kawanaka M, Nishino K, Nakamura J, . Quantitative levels of hepatitis B virus DNA and surface antigen and the risk of hepatocellular carcinoma in patients with hepatitis B receiving long-term nucleos(t)ide analogue therapy. Liver Cancer. 2014;3(1):41–52. doi: 10.1159/000343857. PMID: 24804176. Excluded: wrong study design for key question.24804176
Ke W, Liu L, Zhang C, . Comparison of efficacy and safety of tenofovir and entecavir in chronic hepatitis B virus infection: a systematic review and meta-analysis. PLoS One. 2014;9(6):e98865. doi: 10.1371/journal.pone.0098865. PMID: 24905092. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.24905092
Khadse SV, Bajaj G, Vibhakar P, . Evaluation of specificity and sensitivity of oral fluid for diagnosis of hepatitis B. J Clin Diagn Res. 2016;10(1):BC12–4. doi: 10.7860/JCDR/2016/17319.7107. PMID: 26894057. Excluded: wrong country.26894057
Khemichian S, Hsieh MJ, Zhang SR, . Nucleoside-nucleotide analog combination therapy is effective in preventing recurrent hepatitis B after liver transplantation. Dig Dis Sci. 2015;60(9):2807–12. doi: 10.1007/s10620-015-3671-3. PMID: 25939541. Excluded: wrong population.25939541
Kim BG, Park NH, Lee SB, . Mortality, liver transplantation and hepatic complications in patients with treatment-naive chronic hepatitis B treated with entecavir vs tenofovir. J Viral Hepat. 2018;25(12):1565–75. doi: 10.1111/jvh.12971. PMID: 29998592. Excluded: inadequate duration.29998592
Kim DH, Choi JW, Seo JH, . Entecavir to telbivudine switch therapy in entecavir-treated patients with undetectable hepatitis B viral DNA. Yonsei Med J. 2017;58(3):552–6. doi: 10.3349/ymj.2017.58.3.552. PMID: 28332360. Excluded: wrong comparator.28332360
Kim GA, Lim YS, An J, . HBsAg seroclearance after nucleoside analogue therapy in patients with chronic hepatitis B: clinical outcomes and durability. Gut. 2014;63(8):1325–32. doi: 10.1136/gutjnl-2013-305517. PMID: 24162593. Excluded: wrong study design for key question.24162593
Kim HS, Kim BK, Kim SU, . Association between level of fibrosis, rather than antiviral regimen, and outcomes of patients with chronic hepatitis B. Clin Gastroenterol Hepatol. 2016;14(11):1647–56.e6. doi: 10.1016/j.cgh.2016.05.039. PMID: 27305847. Excluded: wrong comparator.27305847
Kim JH, Sinn DH, Kim K, . Lamivudine versus entecavir for newly diagnosed hepatitis B virus-related hepatocellular carcinoma. Gut Liver. 2016;10(6):939–47. doi: 10.5009/gnl15527. PMID: 27282264. Excluded: wrong population.27282264
Kim SS, Ahn EK, Cho SY, . Impact of nucleos(t)ide analog treatment on the development of malignancy in patients with chronic hepatitis B. Medicine. 2018;97(24):e11087. doi: 10.1097/MD.0000000000011087. PMID: 29901622. Excluded: inadequate duration.29901622
Kobashi H, Miyake Y, Ikeda F, . Long-term outcome and hepatocellular carcinoma development in chronic hepatitis B or cirrhosis patients after nucleoside analog treatment with entecavir or lamivudine. Hepatol Res. 2011;41(5):405–16. doi: 10.1111/j.1872-034X.2011.00785.x. PMID: 21435126. Excluded: wrong population.21435126
Kodani M, Mixson-Hayden T, Drobeniuc J, . Rapid and sensitive approach to simultaneous detection of genomes of hepatitis A, B, C, D and E viruses. J Clin Virol. 2014;61(2):260–4. doi: 10.1016/j.jcv.2014.06.027. PMID: 25081939. Excluded: wrong intervention.25081939
Kohli A. The relationship between hepatocellular carcinoma and hepatitis B and C virus. Gastroenterol Hepatol. 2016;12(2):116–8. PMID: 27182212. Excluded: not a study (letter, editorial, non-systematic review article, no original data).27182212
Koike K, Suyama K, Ito H, . Randomized prospective study showing the non-inferiority of tenofovir to entecavir in treatment-naive chronic hepatitis B patients. Hepatol Res. 2018;48(1):59–68. doi: 10.1111/hepr.12902. PMID: 28374496. Excluded: wrong comparator.28374496
Kotake T, Satake H, Okita Y, . Prevalence and risk factors of hepatitis B virus reactivation in patients with solid tumors with resolved HBV infection. Asia Pac J Clin Oncol. 2019;15(1):63–8. doi: 10.1111/ajco.13050. PMID: 29984542. Excluded: wrong outcome.29984542
Krastev Z, Petrova D, Kotzev I, . Telbivudine vs tenofovir in hepatitis B e antigen-negative chronic hepatitis B patients: OPTIMA roadmap study. World J Hepatol. 2016;8(32):1402–13. PMID: 27917266. Excluded: wrong intervention.27917266
Krogsgaard K. The long-term effect of treatment with interferon-alpha 2a in chronic hepatitis B. The Long-Term Follow-up Investigator Group. The European Study Group on Viral Hepatitis (EUROHEP). Executive Team on Anti-Viral Treatment. J Viral Hepat. 1998;5(6):389–97. PMID: 9857348. Excluded: not a study (letter, editorial, non-systematic review article, no original data).9857348
Kuo MT, Hu TH, Hung CH, . Hepatitis B virus relapse rates in chronic hepatitis B patients who discontinue either entecavir or tenofovir. Aliment Pharmacol Ther. 2019;49(2):218–28. doi: 10.1111/apt.15053. PMID: 30484881. Excluded: wrong comparator.30484881
Kuo MT, Tseng PL, Chou YP, . Role of hepatitis B surface antigen in hepatitis B virus relapse after entecavir or tenofovir prophylaxis in patients undergoing cancer chemotherapy. J Gastroenterol Hepatol. 2018;33(10):1766–72. doi: 10.1111/jgh.14142. PMID: 29514418. Excluded: wrong population – excluded for reactivation CQ.29514418
Lai C, Lim SG, Brown NA, . A dose-finding study of once-daily oral telbivudine in HBeAg-positive patients with chronic hepatitis B virus infection. Hepatology. 2004;40(3):719–26. PMID: 15349912. Excluded: poor quality.15349912
Lai CL, Yuen MF. Prevention of hepatitis b virus-related hepatocellular carcinoma with antiviral therapy. Hepatology. 2013;57(1):399–408. PMID: 22806323. Excluded: not a study (letter, editorial, non-systematic review article, no original data).22806323
Lampertico P, Del Ninno E, Vigano M, . Long-term suppression of hepatitis B e antigen-negative chronic hepatitis B by 24-month interferon therapy. Hepatology. 2003;37(4):756–63. doi: 10.1053/jhep.2003.50148. PMID: 12668967. Excluded: wrong population – cirrhosis.12668967
Law MF, Lai HK, Chan HN, . The impact of hepatitis B virus (HBV) infection on clinical outcomes of patients with diffuse large B-cell lymphoma. Eur J Cancer Care. 2015;24(1):117–24. doi: 10.1111/ecc.12166. PMID: 25848698. Excluded: wrong population – excluded for reactivation CQ.25848698
Law ST, Lee MK, Lee AS, . Comparison of clinical efficacy and renal safety of telbivudine and entecavir in chronic hepatitis B patients receiving cytotoxic chemotherapy. J Dig Dis. 2016;17(5):325–33. doi: 10.1111/1751-2980.12349. PMID: 27085094. Excluded: wrong population – excluded for reactivation CQ.27085094
Law ST, Lee MK, Li KK, . Comparison of efficacy and renal safety of telbivudine and entecavir in treatment-naive elderly patients with chronic hepatitis B. Eur J Gastroenterol Hepatol. 2016;28(2):193–8. doi: 10.1097/MEG.0000000000000519. PMID: 26587867. Excluded: wrong population – cirrhosis.26587867
Lee CH, Kim IH, Moon JC, . 3-Dimensional liver volume assessment in patients with hepatitis B virus-related liver cirrhosis during long-term oral nucleos(t)ide analogues therapy. World J Gastroenterol. 2017;23(2):297–305. doi: 10.3748/wjg.v23.i2.297. PMID: 28127203. Excluded: wrong study design for key question.28127203
Lee EC, Kim SH, Lee SD, . High-dose hepatitis B immunoglobulin therapy in hepatocellular carcinoma with hepatitis B virus-DNA/hepatitis B e antigen-positive patients after living donor liver transplantation. World J Gastroenterol. 2016;22(14):3803–12. doi: 10.3748/wjg.v22.i14.3803. PMID: 27076765. Excluded: wrong outcome.27076765
Lee HJ, Kim DY, Keam B, . Lamivudine prophylaxis for hepatitis B virus carrier patients with breast cancer during adjuvant chemotherapy. Breast Cancer. 2014;21(4):387–93. doi: 10.1007/s12282-012-0417-3. PMID: 23073741. Excluded: wrong population – excluded for reactivation CQ.23073741
Lee HY, Oh H, Park CH, . Comparison of renal safety of tenofovir and entecavir in patients with chronic hepatitis B: Systematic review with meta-analysis. World J Gastroenterol. 2019;25(23):2961–72. doi: 10.3748/wjg.v25.i23.2961. PMID: 31249453. Excluded: guidance document/systematic review.31249453
Lee M, Oh S, Lee HJ, . Telbivudine protects renal function in patients with chronic hepatitis B infection in conjunction with adefovir-based combination therapy. J Viral Hepat. 2014;21(12):873–81. doi: 10.1111/jvh.12217. PMID: 24351112. Excluded: wrong intervention.24351112
Lee MH, Yang HI, Liu J, . Prediction models of long-term cirrhosis and hepatocellular carcinoma risk in chronic hepatitis B patients: risk scores integrating host and virus profiles. Hepatology. 2013;58(2):546. doi: 10.1002/hep.26385. PMID: 23504622. Excluded: wrong intervention.23504622
Lee S, Kwon CH, Moon HH, . Antiviral treatment for hepatitis B virus recurrence following liver transplantation. Clin Transplant. 2013;27(5):E597–604. doi: 10.1111/ctr.12212. PMID: 24093615. Excluded: wrong population.24093615
Lee S, Park JY, Song K, . Comparison of the effects of telbivudine and entecavir treatment on estimated glomerular filtration rate in patients with chronic hepatitis B. Gut Liver. 2015;9(6):776–83. doi: 10.5009/gnl14297. PMID: 25963085. Excluded: inadequate duration.25963085
Lee TY, Lin JT, Zeng YS, . Association between nucleos(t)ide analog and tumor recurrence in hepatitis B virus-related hepatocellular carcinoma after radiofrequency ablation. Hepatology. 2016;63(5):1517–27. doi: 10.1002/hep.28266. PMID: 26426978. Excluded: wrong outcome.26426978
Lee YH, Bae SC, Song GG. Hepatitis B virus reactivation in HBsAg-positive patients with rheumatic diseases undergoing anti-tumor necrosis factor therapy or DMARDs. Int J Rheum Dis. 2013;16(5):527–31. doi: 10.1111/1756-185X.12154. PMID: 24164839. Excluded: wrong population – excluded for reactivation CQ.24164839
Lee YH, Bae SC, Song GG. Hepatitis B virus (HBV) reactivation in rheumatic patients with hepatitis core antigen (HBV occult carriers) undergoing anti-tumor necrosis factor therapy. Clin Exp Rheumatol. 2013;31(1):118–21. PMID: 23111095. Excluded: wrong population – excluded for reactivation CQ.23111095
Lens S, Garcia-Eliz M, Fernandez I, . Shorter hepatitis B immunoglobulin administration is not associated to hepatitis B virus recurrence when receiving combined prophylaxis after liver transplantation. Liver Int. 2018;38(11):1940–50. doi: 10.1111/liv.13858. PMID: 29660249. Excluded: wrong population.29660249
Leung NW, Herrmann E, Lau GK, . Early viral kinetics with telbivudine, tenofovir or combination of both in immunotolerant patients with hepatitis B e antigen-positive chronic hepatitis B. Infect Dis Ther. 2014;3(2):191–202. doi: 10.1007/s40121-014-0039-5. PMID: 25228496. Excluded: wrong outcome.25228496
Li CZ, Hu JJ, Xue JY, . Viral infection parameters not nucleoside analogue itself correlates with host immunity in nucleoside analogue therapy for chronic hepatitis B. World J Gastroenterol. 2014;20(28):9486–96. doi: 10.3748/wjg.v20.i28.9486. PMID: 25071343. Excluded: wrong comparator.25071343
Li H, Zhang HM, Chen LF, . Prophylactic lamivudine to improve the outcome of HBsAg-positive lymphoma patients during chemotherapy: a systematic review and meta-analysis. Clin Res Hepatol Gastroenterol. 2015;39(1):80–92. doi: 10.1016/j.clinre.2014.07.010. PMID: 25199680. Excluded: wrong population – excluded for reactivation CQ.25199680
Li J, Huang B, Li Y, . Hepatitis B virus reactivation in patients with multiple myeloma receiving bortezomib-containing regimens followed by autologous stem cell transplant. Leuk Lymphoma. 2015;56(6):1710–7. doi: 10.3109/10428194.2014.941833. PMID: 25098429. Excluded: wrong population – excluded for reactivation CQ.25098429
Li MH, Xie Y, Zhang L, . Hepatitis B surface antigen clearance in inactive hepatitis B surface antigen carriers treated with peginterferon alfa-2a. World J Hepatol. 2016;8(15):637–43. doi: 10.4254/wjh.v8.i15.637. PMID: 27239256. Excluded: sample size for cohort less than 1,000.27239256
Li W, Huang L, Guo H, . Antiviral efficacy analysis of telbivudine concurrent with the first cycle of chemotherapy in HBsAg-positive lymphoma patients. J Clin Virol. 2014;61(2):199–203. doi: 10.1016/j.jcv.2014.07.005. PMID: 25128391. Excluded: wrong population – excluded for reactivation CQ.25128391
Li YC. A clinical study on lamivudine treatment for advanced schistosomisis with chronic B hepatits. Zhongguo Xue Xi Chong Bing Fang Zhi Za Zhi. 2013;25(5):548–9+51. PMID: 24490380. Excluded: not English language but possibly relevant.24490380
Li Z, Lei Z, Xia Y, . Association of preoperative antiviral treatment with incidences of microvascular invasion and early tumor recurrence in hepatitis B virus-related hepatocellular carcinoma. JAMA Surg. 2018;153(10):e182721. doi: 10.1001/jamasurg.2018.2721. PMID: 30073257. Excluded: wrong outcome.30073257
Li Z, Shen C, Wang Y, . Circulating kidney injury molecule-1 is a novel diagnostic biomarker for renal dysfunction during long-term adefovir therapy in chronic hepatitis B. Medicine. 2016;95(44):e5264. PMID: 27858892. Excluded: wrong outcome.27858892
Liang RY, Xu JH, Si CW, . A randomized, double-blind, double-dummy, controlled, multicenter study of Qingzhong (tenofovir disoproxil fumarate) versus viread for the treatment of chronic hepatitis B: first-stage results at week 48. Medicine. 2019;98(33):e16778. doi: 10.1097/MD.0000000000016778. PMID: 31415381. Excluded: wrong comparator.31415381
Liang X, Fan R, Sun J, . Effect of telbivudine versus other nucleos(t)ide analogs on HBeAg seroconversion and other outcomes in patients with chronic hepatitis B: a network meta-analysis. Adv Ther. 2016;33(4):519–31. doi: 10.1007/s12325-016-0305-x. PMID: 26921204. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.26921204
Liao YJ, Li YC, Lee SW, . Lamivudine versus entecavir in the rescue of chemotherapy-induced hepatitis B flare-up. J Chin Med Assoc. 2017;80(12):758–65. doi: 10.1016/j.jcma.2017.07.009. PMID: 28974354. Excluded: wrong outcome.28974354
Liaw YF, Raptopoulou-Gigi M, Cheinquer H, . Efficacy and safety of entecavir versus adefovir in chronic hepatitis B patients with hepatic decompensation: a randomized, open-label study. Hepatology. 2011;54(1):91–100. doi: 10.1002/hep.24361. PMID: 21503940. Excluded: wrong population.21503940
Liaw YF, Sheen IS, Lee CM, . Tenofovir disoproxil fumarate (TDF), emtricitabine/TDF, and entecavir in patients with decompensated chronic hepatitis B liver disease. Hepatology. 2011;53(1):62–72. doi: 10.1002/hep.23952. PMID: 21254162. Excluded: wrong comparator.21254162
Liaw YF, Sung JJ, Chow WC, . Lamivudine for patients with chronic hepatitis B and advanced liver disease. N Engl J Med. 2004;351(15):1521–31. doi: 10.1056/NEJMoa033364. PMID: 15470215. Excluded: wrong population – cirrhosis.15470215
Lim SG, Marcellin P, Tassopoulos N, . Clinical trial: effects of adefovir dipivoxil therapy in Asian and Caucasian patients with chronic hepatitis B. Aliment Pharmacol Ther. 2007;26(10):1419–28. doi: 10.1111/j.1365-2036.2007.03506.x. PMID: 17983369. Excluded: wrong study design for key question.17983369
Lin GN, Peng JW, Xiao JJ, . Hepatitis B virus reactivation in hepatitis B surface antigen seropositive patients with metastatic non-small cell lung cancer receiving cytotoxic chemotherapy: the efficacy of preemptive lamivudine and identification of risk factors. Med Oncol. 2014;31(8):119. doi: 10.1007/s12032-014-0119-0. PMID: 25023055. Excluded: wrong study design for key question.25023055
Lin TC, Yoshida K, Tedeschi SK, . Risk of hepatitis B virus reactivation in patients with inflammatory arthritis receiving disease-modifying antirheumatic drugs: a systematic review and meta-analysis. Arthritis Care Res (Hoboken). 2018;70(5):724–31. doi: 10.1002/acr.23346. PMID: 28834412. Excluded: wrong population – excluded for reactivation CQ.28834412
Lin YS, Shih SC, Wang HY, . Comparison of telbivudine and entecavir on the change of off-treatment eGFR after 3 years of treatment in non-cirrhotic chronic hepatitis B patients. BMC Gastroenterol. 2017;17(1):22. doi: 10.1186/s12876-017-0582-0. PMID: 28137301. Excluded: wrong population.28137301
Liu B, Shen B, Mei M, . Potential effects of telbivudine versus entecavir on renal function in patients with chronic hepatitis B virus receiving glucocorticoids therapy. Ther Apher Dial. 2019;14:14. doi: 10.1111/1744-9987.12839. PMID: 31090170. Excluded: wrong population.31090170
Liu C, Wang L, Xie H, . The relationship between serum hepatitis B virus DNA level and liver histology in patients with chronic HBV infection. PLoS One. 2018;13(11):e0206060. doi: 10.1371/journal.pone.0206060. PMID: 30403735. Excluded: wrong outcome.30403735
Liu H, Wang X, Wan G, . Telbivudine versus entecavir for nucleos(t)ide-naive HBeAg-positive chronic hepatitis B: a meta-analysis. Am J Med Sci. 2014;347(2):131–8. doi: 10.1097/MAJ.0b013e318286878d. PMID: 23563307. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.23563307
Liu JY, Sheng YJ, Ding XC, . The efficacy of lamivudine prophylaxis against hepatitis B reactivation in breast cancer patients undergoing chemotherapy: a meta-analysis. J Formos Med Assoc. 2015;114(2):164–73. doi: 10.1016/j.jfma.2012.10.007. PMID: 25678179. Excluded: wrong population – excluded for reactivation CQ.25678179
Liu S, Zheng H, Huang Y, . The effect of peginterferon alpha-2a vs. interferon alpha-2a on intrahepatic covalently closed circular DNA in HBeAg-positive chronic hepatitis B patients. Clin Res Hepatol Gastroenterol. 2016;40(3):304–8. doi: 10.1016/j.clinre.2015.06.023. PMID: 26382279. Excluded: wrong comparator.26382279
Liu WP, Xiao XB, Xue M, . Prophylactic use of entecavir for lymphoma patients with past hepatitis B virus infection: a randomized controlled trial. Clin Lymphoma Myeloma Leuk. 2018;22:22. doi: 10.1016/j.clml.2018.11.008. PMID: 30581161. Excluded: wrong population – excluded for reactivation CQ.30581161
Liu Y, Corsa AC, Buti M, . No detectable resistance to tenofovir disoproxil fumarate in HBeAg+ and HBeAg-patients with chronic hepatitis B after 8 years of treatment. J Viral Hepat. 2017;24(1):68–74. doi: 10.1111/jvh.12613. PMID: 27658343. Excluded: wrong population – excluded for reactivation CQ.27658343
Liu Z, Jiang L, Liang G, . Hepatitis B virus reactivation in breast cancer patients undergoing chemotherapy: a review and meta-analysis of prophylaxis management. J Viral Hepat. 2017;24(7):561–72. doi: 10.1111/jvh.12672. PMID: 28072494. Excluded: wrong population – excluded for reactivation CQ.28072494
Lok AS, Lai CL, Leung N, . Long-term safety of lamivudine treatment in patients with chronic hepatitis B. Gastroenterology. 2003;125(6):1714–22. doi: 10.1053/j.gastro.2003.09.033. PMID: 14724824. Excluded: wrong outcome.14724824
Lok AS, McMahon BJ, Brown RS, Jr., . Antiviral therapy for chronic hepatitis B viral infection in adults: a systematic review and meta-analysis. Hepatology. 2016;63(1):284–306. doi: 10.1002/hep.28280. PMID: 26566246. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.26566246
Londono MC, Lens S, Marino Z, . Hepatitis B reactivation in patients with chronic hepatitis C undergoing anti-viral therapy with an interferon-free regimen. Aliment Pharmacol Ther. 2017;45(8):1156–61. doi: 10.1111/apt.13985. PMID: 28206681. Excluded: wrong population – excluded for reactivation CQ.28206681
Loomba R, Liang TJ. Hepatitis B reactivation associated with immune suppressive and biological modifier therapies: current concepts, management strategies, and future directions. Gastroenterology. 2017;152(6):1297–309. doi: 10.1053/j.gastro.2017.02.009. PMID: 28219691. Excluded: wrong population – excluded for reactivation CQ.28219691
Loomba R, Rowley A, Wesley R, . Systematic review: the effect of preventive lamivudine on hepatitis B reactivation during chemotherapy. Ann Intern Med. 2008;148(7):519–28. PMID: 18378948. Excluded: wrong population – excluded for reactivation CQ.18378948
Luo Q, Deng Y, Cheng F, . Relationship between nephrotoxicity and long-term adefovir dipivoxil therapy for chronic hepatitis B: a meta-analysis. Medicine. 2016;95(50):e5578. PMID: 27977591. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.27977591
Luo XD, Chen XF, Zhou Y, . Comparison of 208-week sequential therapy with telbivudine and entecavir in HBeAg-positive chronic hepatitis B patients with suboptimal responses to 24 weeks of Peg-IFNalpha-2a therapy: an open-labelled, randomized, controlled, “real-life” trial. J Viral Hepat. 2017;24: Suppl 1:36–42. doi: 10.1111/jvh.12790. PMID: 29082651. Excluded: wrong intervention.29082651
Ma GX, Lee MM, Tan Y, . Efficacy of a community-based participatory and multilevel intervention to enhance hepatitis B virus screening and vaccination in underserved Korean Americans. Cancer. 2018;124(5):973–82. doi: 10.1002/cncr.31134. PMID: 29131316. Excluded: wrong intervention.29131316
Ma H, Yang RF, Li XH, . HBcrAg identifies patients failing to achieve HBeAg seroconversion treated with pegylated interferon Alfa-2b. Chin Med J. 2016;129(18):2212–9. doi: 10.4103/0366-6999.189904. PMID: 27625094. Excluded: wrong comparator.27625094
Maekawa H, Yazawa M, Koitabashi K, . Safety of monitoring viral and liver function markers in patients with prior resolved hepatitis B infection after kidney transplantation. Transplant Proc. 2016;48(6):2046–9. doi: 10.1016/j.transproceed.2016.03.049. PMID: 27569942. Excluded: wrong population.27569942
Mallet V, Schwarzinger M, Vallet-Pichard A, . Effect of nucleoside and nucleotide analogues on renal function in patients with chronic hepatitis B virus monoinfection. Clin Gastroenterol Hepatol. 2015;13(6):1181–8.e1. doi: 10.1016/j.cgh.2014.11.021. PMID: 25460550. Excluded: wrong study design for key question.25460550
Mandala M, Fagiuoli S, Francisci D, . Hepatitis B in immunosuppressed cancer patients: pathogenesis, incidence and prophylaxis. Crit Rev Oncol Hematol. 2013;87(1):12–27. doi: 10.1016/j.critrevonc.2012.12.004. PMID: 23313021. Excluded: wrong population – excluded for reactivation CQ.23313021
Marcellin P, Gane E, Buti M, . Regression of cirrhosis during treatment with tenofovir disoproxil fumarate for chronic hepatitis B: a 5-year open-label follow-up study. Lancet. 2013;381(9865):468–75. doi: 10.1016/s0140-6736(12)61425-1. PMID: 23234725. Excluded: wrong study design for key question.23234725
Marcellin P, Lau GK, Bonino F, . Peginterferon alfa-2a alone, lamivudine alone, and the two in combination in patients with HBeAg-negative chronic hepatitis B. N Engl J Med. 2004;351(12):1206–17. doi: 10.1056/NEJMoa040431. PMID: 15371578. Excluded: wrong population – cirrhosis.15371578
Martyak LA, Taqavi E, Saab S. Lamivudine prophylaxis is effective in reducing hepatitis B reactivation and reactivation-related mortality in chemotherapy patients: a meta-analysis. Liver Int. 2008;28(1):28–38. doi: 10.1111/j.1478-3231.2007.01618.x. PMID: 17976155. Excluded: wrong population – excluded for reactivation CQ.17976155
Masarone M, De Renzo A, La Mura V, . Management of the HBV reactivation in isolated HBcAb positive patients affected with non-Hodgkin lymphoma. BMC Gastroenterol. 2014;14:31. doi: 10.1186/1471-230X-14-31. PMID: 24533834. Excluded: wrong population – excluded for reactivation CQ.24533834
Mealing S, Ghement I, Hawkins N, . The importance of baseline viral load when assessing relative efficacy in treatment-naive HBeAg-positive chronic hepatitis B: a systematic review and network meta-analysis. Syst Rev. 2014;3:21. doi: 10.1186/2046-4053-3-21. PMID: 24602249. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.24602249
Miao B, Lao XM, Lin GL. Post-transplant withdrawal of lamivudine results in fatal hepatitis flares in kidney transplant recipients, under immune suppression, with inactive hepatitis B infection. Afr Health Sci. 2016;16(4):1094–100. doi: 10.4314/ahs.v16i4.27. PMID: 28479903. Excluded: wrong population – excluded for reactivation CQ.28479903
Mikulska M, Lanini S, Gudiol C, . ESCMID Study Group for Infections in Compromised Hosts (ESGICH) consensus document on the safety of targeted and biological therapies: an infectious diseases perspective (agents targeting lymphoid cells surface antigens [I]: CD19, CD20 and CD52). Clin Microbiol Infect. 2018;24: Suppl 2:S71–S82. doi: 10.1016/j.cmi.2018.02.003. PMID: 29447988. Excluded: wrong population – excluded for reactivation CQ.29447988
Mochida S, Nakao M, Nakayama N, . Nationwide prospective and retrospective surveys for hepatitis B virus reactivation during immunosuppressive therapies. J Gastroenterol. 2016;51(10):999–1010. doi: 10.1007/s00535-016-1168-2. PMID: 26831356. Excluded: wrong population – excluded for reactivation CQ.26831356
Moghoofei M, Mostafaei S, Ashraf-Ganjouei A, . HBV reactivation in rheumatic diseases patients under therapy: a meta-analysis. Microbial Pathogenesis. 2018;114:436–43. doi: 10.1016/j.micpath.2017.12.014. PMID: 29223453. Excluded: wrong population – excluded for reactivation CQ.29223453
Mori S, Fujiyama S. Hepatitis B virus reactivation associated with antirheumatic therapy: risk and prophylaxis recommendations. World J Gastroenterol. 2015;21(36):10274–89. doi: 10.3748/wjg.v21.i36.10274. PMID: 26420955. Excluded: wrong population – excluded for reactivation CQ.26420955
Morisco F, Castiglione F, Rispo A, . Hepatitis B virus infection and immunosuppressive therapy in patients with inflammatory bowel disease. Dig Liver Dis. 2011;43: Suppl 1:S40–8. doi: 10.1016/S1590-8658(10)60691-3. PMID: 21195371. Excluded: wrong population – excluded for reactivation CQ.21195371
Morisco F, Guarino M, La Bella S, . Lack of evidence of viral reactivation in HBsAg-negative HBcAb-positive and HCV patients undergoing immunosuppressive therapy for psoriasis. BMC Gastroenterol. 2014;14:214. doi: 10.1186/s12876-014-0214-x. PMID: 25523080. Excluded: wrong population – excluded for reactivation CQ.25523080
Mossner BK, Staugaard B, Jensen J, . Dried blood spots, valid screening for viral hepatitis and human immunodeficiency virus in real-life. World J Gastroenterol. 2016;22(33):7604–12. doi: 10.3748/wjg.v22.i33.7604. PMID: 27672281. Excluded: wrong intervention.27672281
Mozessohn L, Chan KK, Feld JJ, . Hepatitis B reactivation in HBsAg-negative/HBcAb-positive patients receiving rituximab for lymphoma: a meta-analysis. J Viral Hepat. 2015;22(10):842–9. doi: 10.1111/jvh.12402. PMID: 25765930. Excluded: wrong population – excluded for reactivation CQ.25765930
Mucke MM, Backus LI, Mucke VT, . Hepatitis B virus reactivation during direct-acting antiviral therapy for hepatitis C: a systematic review and meta-analysis. Lancet Gastroenterol Hepatol. 2018;3(3):172–80. doi: 10.1016/S2468-1253(18)30002-5. PMID: 29371017. Excluded: wrong population – excluded for reactivation CQ.29371017
Mucke VT, Mucke MM, Peiffer KH, . No evidence of hepatitis B virus reactivation in patients with resolved infection treated with direct-acting antivirals for hepatitis C in a large real-world cohort. Aliment Pharmacol Ther. 2017;46(4):432–9. doi: 10.1111/apt.14177. PMID: 28627791. Excluded: wrong population – excluded for reactivation CQ.28627791
Murray KF, Szenborn L, Wysocki J, . Randomized, placebo-controlled trial of tenofovir disoproxil fumarate in adolescents with chronic hepatitis B. Hepatology. 2012;56(6):2018–26. PMID: 22544804. Excluded: wrong population.22544804
Mutocheluh M, Owusu M, Kwofie TB, . Risk factors associated with hepatitis B exposure and the reliability of five rapid kits commonly used for screening blood donors in Ghana. BMC Res Notes. 2014;7:873. doi: 10.1186/1756-0500-7-873. PMID: 25475050. Excluded: wrong country.25475050
Myran DT, Morton R, Biggs BA, . The effectiveness and cost-effectiveness of screening for and vaccination against hepatitis B virus among migrants in the EU/EEA: a systematic review. Int J Environ Res Public Health. 2018;15(9):01. doi: 10.3390/ijerph15091898. PMID: 30200406. Excluded: wrong country.30200406
Na GH, Kim DG, Han JH, . Prevention and risk factors of hepatitis B recurrence after living donor liver transplantation. J Gastroenterol Hepatol. 2014;29(1):151–6. doi: 10.1111/jgh.12403. PMID: 24117684. Excluded: wrong population.24117684
Naftel J, Khakoo SI, Buchanan R. Treatment outcomes in treatment experienced and treatment naive patients on Tenofovir disoproxil fumarate for chronic hepatitis B. J Infect. 2017;74(1):100–2. doi: 10.1016/j.jinf.2016.10.004. PMID: 27793661. Excluded: wrong study design for key question.27793661
National Academies of Sciences Engineering and Medicine. Eliminating the public health problem of hepatitis B and C in the United States: phase one report: National Academies Press; 2016. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
National Academies of Sciences Engineering and Medicine. Eliminating the public health problem of hepatitis B and C in the United States: phase two report: National Academies Press; 2017. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Nayagam S, Thursz M, Sicuri E, . Requirements for global elimination of hepatitis B: a modelling study. Lancet Infect Dis. 2016;16(12):1399–408. doi: 10.1016/s1473-3099(16)30204-3. PMID: 27638356. Excluded: wrong country.27638356
NCT. Clinical trial of myrcludex B vs entecavir in patients with HBeAg negative chronic hepatitis B. 2016. Excluded: wrong comparator.
Ning Q, Han M, Sun Y, . Switching from entecavir to PegIFN alfa-2a in patients with HBeAg-positive chronic hepatitis B: a randomised open-label trial (OSST trial). J Hepatol. 2014;61(4):777–84. doi: 10.1016/j.jhep.2014.05.044. PMID: 24915612. Excluded: wrong comparator.24915612
Njai HF, Shimakawa Y, Sanneh B, . Validation of rapid point-of-care (POC) tests for detection of hepatitis B surface antigen in field and laboratory settings in the Gambia, Western Africa. J Clin Microbiol. 2015;53(4):1156–63. doi: 10.1128/JCM.02980-14. PMID: 25631805. Excluded: wrong country.25631805
North Carolina Department of Health and Human Services. Hepatitis B, C on rise in N.C.; health officials encourage precautions, testing. Raleigh, North Carolina; 2017. https://www.ncdhhs.gov/news/press-releases/hepatitis-b-c-rise-nc-health-officials-encourage-precautions-testing. Accessed January 15, 2019. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
O’Kelly M, Byrne D, Naughton E, . Opt-out testing for blood-borne viruses in primary care: a multicentre, prospective study. Br J Gen Pract. 2016;66(647):e392–e6. doi: 10.3399/bjgp16X685225. PMID: 27114211. Excluded: wrong study design for key question.27114211
Ozoya OO, Chavez J, Sokol L, . Optimizing antiviral agents for hepatitis B management in malignant lymphomas. Ann Transl Med. 2017;5(3):39. doi: 10.21037/atm.2016.12.25. PMID: 28251118. Excluded: wrong population – excluded for reactivation CQ.28251118
Padovan M, Filippini M, Tincani A, . Safety of abatacept in rheumatoid arthritis with serologic evidence of past or present hepatitis B virus infection. Arthritis Care Res. 2016;68(6):738–43. doi: 10.1002/acr.22786. PMID: 26555747. Excluded: wrong population – excluded for reactivation CQ.26555747
Pan HY, Pan HY, Song WY, . Long-term outcome of telbivudine versus entecavir in treating higher viral load chronic hepatitis B patients without cirrhosis. J Viral Hepat. 2017;24: Suppl 1:29–35. doi: 10.1111/jvh.12794. PMID: 29082652. Excluded: wrong population.29082652
Papadopoulos N, Deutsch M, Manolakopoulos S, . Efficacy of prophylactic antiviral therapy and outcomes in HBsAg-negative, anti-HBc-positive patients receiving chemotherapy: a real-life experience. Eur J Gastroenterol Hepatol. 2017;29(1):56–60. PMID: 27669175. Excluded: wrong population – excluded for reactivation CQ.27669175
Papatheodoridis G, Dalekos G, Sypsa V, . PAGE-B predicts the risk of developing hepatocellular carcinoma in Caucasians with chronic hepatitis B on 5-year antiviral therapy. J Hepatol. 2016;64(4):800–6. doi: 10.1016/j.jhep.2015.11.035. PMID: 26678008. Excluded: wrong comparator.26678008
Papatheodoridis GV, Dimou E, Dimakopoulos K, . Outcome of hepatitis B e antigen-negative chronic hepatitis B on long-term nucleos(t)ide analog therapy starting with lamivudine. Hepatology. 2005;42(1):121–9. doi: 10.1002/hep.20760. PMID: 15962291. Excluded: wrong population.15962291
Park MS, Kim SU, Kim BK, . Prognostic value of the combined use of transient elastography and fibrotest in patients with chronic hepatitis B. Liver Int. 2015;35(2):455–62. doi: 10.1111/liv.12678. PMID: 25183426. Excluded: wrong study design for key question.25183426
Park YH, Kim BK, Kim JK, . Long-term outcomes of chronic hepatitis B virus infection in the era of antiviral therapy in Korea. J Gastroenterol Hepatol. 2014;29(5):1005–11. doi: 10.1111/jgh.12478. PMID: 24325579. Excluded: wrong study design for key question.24325579
Paul S, Dickstein A, Saxena A, . Role of surface antibody in hepatitis B reactivation in patients with resolved infection and hematologic malignancy: a meta-analysis. Hepatology. 2017;66(2):379–88. doi: 10.1002/hep.29082. PMID: 28128861. Excluded: wrong outcome.28128861
Paul S, Saxena A, Terrin N, . Hepatitis B virus reactivation and prophylaxis during solid tumor chemotherapy: a systematic review and meta-analysis. Ann Intern Med. 2016;164(1):30–40. doi: 10.7326/M15-1121. PMID: 26595058. Excluded: wrong population – excluded for reactivation CQ.26595058
Perez V, Tanno H, Villamil F, . Recombinant interferon alfa-2b following prednisone withdrawal in the treatment of chronic type B hepatitis. J Hepatol. 1990;11: Suppl 1:S113–7. PMID: 2079567. Excluded: wrong population – cirrhosis.2079567
Perez-Alvarez R, Diaz-Lagares C, Garcia-Hernandez F, . Hepatitis B virus (HBV) reactivation in patients receiving tumor necrosis factor (TNF)-targeted therapy: analysis of 257 cases. Medicine. 2011;90(6):359–71. doi: 10.1097/MD.0b013e3182380a76. PMID: 22033451. Excluded: wrong population – excluded for reactivation CQ.22033451
Perrillo RP, Gish R, Falck-Ytter YT. American gastroenterological association institute technical review on prevention and treatment of hepatitis B virus reactivation during immunosuppressive drug therapy. Gastroenterology. 2015;148(1):221–44.e3. doi: 10.1053/j.gastro.2014.10.038. PMID: 25447852. Excluded: wrong population – excluded for reactivation CQ.25447852
Perrillo RP, Schiff ER, Davis GL, . A randomized, controlled trial of interferon alfa-2b alone and after prednisone withdrawal for the treatment of chronic hepatitis B. The Hepatitis Interventional Therapy Group. N Engl J Med. 1990;323(5):295–301. PMID: 2195346. Excluded: wrong population – cirrhosis.2195346
Pisaturo M, Di Caprio G, Calo F, . Management of HBV reactivation in non-oncological patients. Expert Rev Anti Infect Ther. 2018;16(8):611–24. doi: 10.1080/14787210.2018.1505501. PMID: 30058401. Excluded: wrong population – excluded for reactivation CQ.30058401
Post SE, Sodhi NK, Peng CH, . A simulation shows that early treatment of chronic hepatitis B infection can cut deaths and be cost-effective. Health Aff (Millwood). 2011;30(2):340–8. doi: 10.1377/hlthaff.2008.0905. PMID: 21289356. Excluded: not a study (letter, editorial, non-systematic review article, no original data).21289356
Preda CM, Popescu CP, Baicus C, . Risk of hepatitis B virus reactivation in hepatitis B virus + hepatitis C virus-co-infected patients with compensated liver cirrhosis treated with ombitasvir, paritaprevir/r + dasabuvir + ribavirin. J Viral Hepat. 2018;25(7):834–41. doi: 10.1111/jvh.12872. PMID: 29397016. Excluded: wrong study design for key question.29397016
Qi X, Wang JY, Mao RC, . Impact of nucleos(t)ide analogues on the estimated glomerular filtration rate in patients with chronic hepatitis B: a prospective cohort study in China. J Viral Hepat. 2015;22(1):46–54. doi: 10.1111/jvh.12229. PMID: 25402626. Excluded: wrong study design for key question.25402626
Qu LS, Liu JX, Zhang HF, . Effect of serum hepatitis B surface antigen levels on predicting the clinical outcomes of chronic hepatitis B infection: A meta-analysis. Hepatol Res. 2015;45(9):1004–13. doi: 10.1111/hepr.12444. PMID: 25355455. Excluded: wrong outcome.25355455
Rapti I, Hadziyannis S. Risk for hepatocellular carcinoma in the course of chronic hepatitis B virus infection and the protective effect of therapy with nucleos(t)ide analogues. World J Hepatol. 2015;7(8):1064–73. doi: 10.4254/wjh.v7.i8.1064. PMID: 26052395. Excluded: wrong study design for key question.26052395
Ray G. Trends of chronic liver disease in a tertiary care referral hospital in Eastern India. Indian J Public Health. 2014;58(3):186–94. doi: 10.4103/0019-557X.138630. PMID: 25116825. Excluded: wrong study design for key question.25116825
Rein DB, Lesesne SB, Smith BD, . Models of community-based hepatitis B surface antigen screening programs in the U.S. and their estimated outcomes and costs. Public Health Rep. 2011;126(4):560–7. PMID: 21800750. Excluded: wrong study design for key question.21800750
Reinwald M, Silva JT, Mueller NJ, . ESCMID Study Group for Infections in Compromised Hosts (ESGICH) consensus document on the safety of targeted and biological therapies: an infectious diseases perspective (intracellular signaling pathways: tyrosine kinase and mTOR inhibitors). Clin Microbiol Infect. 2018;24: Suppl 2:S53–S70. doi: 10.1016/j.cmi.2018.02.009. PMID: 29454849. Excluded: wrong population – excluded for reactivation CQ.29454849
Riedell P, Carson KR. A drug safety evaluation of rituximab and risk of hepatitis B. Expert Opin Drug Saf. 2014;13(7):977–87. doi: 10.1517/14740338.2014.918948. PMID: 24821316. Excluded: wrong population – excluded for reactivation CQ.24821316
Rigopoulou EI, Zachou K, Gatselis NK, . Primary biliary cirrhosis in HBV and HCV patients: clinical characteristics and outcome. World J Hepatol. 2013;5(10):577–83. doi: 10.4254/wjh.v5.i10.577. PMID: 24179617. Excluded: wrong population.24179617
Rocha D, Andrade E, Godoy DT, . The Brazilian experience of nucleic acid testing to detect human immunodeficiency virus, hepatitis C virus, and hepatitis B virus infections in blood donors. Transfusion. 2018;58(4):862–70. doi: 10.1111/trf.14478. PMID: 29383720. Excluded: wrong country.29383720
Rodriguez-Novoa S, Garcia-Samaniego J, Prieto M, . Altered underlying renal tubular function in patients with chronic hepatitis B receiving nucleos(t)ide analogs in a real-world setting: the MENTE study. J Clin Gastroenterol. 2016;50(9):779–89. doi: 10.1097/MCG.0000000000000569. PMID: 27332746. Excluded: wrong study design for key question.27332746
Rossi C, Schwartzman K, Oxlade O, . Hepatitis B screening and vaccination strategies for newly arrived adult Canadian immigrants and refugees: a cost-effectiveness analysis. PLoS One. 2013;8(10):e78548. doi: 10.1371/journal.pone.0078548. PMID: 24205255. Excluded: wrong country.24205255
Ruggeri M, Cicchetti A, Gasbarrini A. The cost-effectiveness of alternative strategies against HBV in Italy. Health Policy. 2011;102(1):72–80. doi: 10.1016/j.healthpol.2010.09.012. PMID: 21035229. Excluded: wrong country.21035229
Ruhi C, Suleymanlar I, Kocak H, . Effect of prophylactic versus preemptive lamivudine treatment and tenofovir on HBsAg+ kidney transplant recipients. Exp Clin Transplant. 2015;13(1):35–40. doi: 10.6002/ect.2013.0280. PMID: 25019317. Excluded: wrong population – excluded for reactivation CQ.25019317
Russo FP, Rodriguez-Castro K, Scribano L, . Role of antiviral therapy in the natural history of hepatitis B virus-related chronic liver disease. World J Hepatol. 2015;7(8):1097–104. doi: 10.4254/wjh.v7.i8.1097. PMID: 26052398. Excluded: wrong study design for key question.26052398
Ryff JC. To treat or not to treat? The judicious use of interferon-alpha-2a for the treatment of chronic hepatitis B. J Hepatol. 1993;17: Suppl 3:S42–6. PMID: 8509638. Excluded: wrong population.8509638
Sagnelli E, Stroffolini T, Sagnelli C, . Epidemiological and clinical scenario of chronic liver diseases in Italy: data from a multicenter nationwide survey. Dig Liver Dis. 2016;48(9):1066–71. PMID: 27291331. Excluded: wrong study design for key question.27291331
Sakamoto K, Beppu T, Hayashi H, . Antiviral therapy and long-term outcome for hepatitis B virus-related hepatocellular carcinoma after curative liver resection in a Japanese cohort. Anticancer Res. 2015;35(3):1647–55. PMID: 25750323. Excluded: wrong study design for key question.25750323
Samonakis DN, Koulentaki M, Coucoutsi C, . Clinical outcomes of compensated and decompensated cirrhosis: a long term study. World J Hepatol. 2014;6(7):504–12. doi: 10.4254/wjh.v6.i7.504. PMID: 25068002. Excluded: wrong population – cirrhosis.25068002
Santos AH, Jr., Casey MJ, Xuerong W, . Association of baseline viral serology and sirolimus regimens with kidney transplant outcomes: a 14-year registry-based cohort study in the United States. Transplantation. 2017;101(2):377–86. doi: 10.1097/TP.0000000000001520. PMID: 28121742. Excluded: wrong population.28121742
Sarin SK, Guptan RC, Thakur V, . Efficacy of low-dose alpha interferon therapy in HBV-related chronic liver disease in Asian Indians: a randomized controlled trial. J Hepatol. 1996;24(4):391–6. PMID: 8738724. Excluded: wrong population – cirrhosis.8738724
Sarmati L, Andreoni M, Antonelli G, . Recommendations for screening, monitoring, prevention, prophylaxis and therapy of hepatitis B virus reactivation in patients with haematologic malignancies and patients who underwent haematologic stem cell transplantation-a position paper. Clin Microbiol Infect. 2017;23(12):935–40. doi: 10.1016/j.cmi.2017.06.023. PMID: 28668466. Excluded: wrong population – excluded for reactivation CQ.28668466
Sawai H, Nishida N, Khor SS, . Genome-wide association study identified new susceptible genetic variants in HLA class I region for hepatitis B virus-related hepatocellular carcinoma. Sci Rep. 2018;8(1):7958. doi: 10.1038/s41598-018-26217-7. PMID: 29784950. Excluded: wrong study design for key question.29784950
Schiller A, Timar R, Siriopol D, . Hepatitis B and C virus infection in the hemodialysis population from three romanian regions. Nephron. 2015;129(3):202–8. doi: 10.1159/000371450. PMID: 25765861. Excluded: wrong population.25765861
Schmidt M, Jimenez A, Muhlbacher A, . Head-to-head comparison between two screening systems for HBsAG, anti-HBc, anti-HCV and HIV combination immunoassays in an international, multicentre evaluation study. Vox Sang. 2015;109(2):114–21. doi: 10.1111/vox.12259. PMID: 25899479. Excluded: wrong intervention.25899479
Seck A, Ndiaye F, Maylin S, . Poor sensitivity of commercial rapid diagnostic tests for hepatitis B e antigen in Senegal, West Africa. Am J Trop Med Hyg. 2018;99(2):428–34. doi: 10.4269/ajtmh.18-0116. PMID: 29869595. Excluded: wrong intervention.29869595
Sehr MA, Joshi KD, Fontanesi JM, . Markov modeling in hepatitis B screening and linkage to care. Theor Biol Med Model. 2017;14(1):11. doi: 10.1186/s12976-017-0057-6. PMID: 28521828. Excluded: wrong study design for key question.28521828
Serper M, Forde KA, Kaplan DE. Rare clinically significant hepatic events and hepatitis B reactivation occur more frequently following rather than during direct-acting antiviral therapy for chronic hepatitis C: data from a national US cohort. J Viral Hepat. 2018;25(2):187–97. doi: 10.1111/jvh.12784. PMID: 28845882. Excluded: wrong population – excluded for reactivation CQ.28845882
Seto WK, Chan TS, Hwang YY, . Hepatitis B reactivation in occult viral carriers undergoing hematopoietic stem cell transplantation: a prospective study. Hepatology. 2017;65(5):1451–61. doi: 10.1002/hep.29022. PMID: 28027590. Excluded: wrong study design for key question.28027590
Seto WK, Chan TS, Hwang YY, . Hepatitis B reactivation in patients with previous hepatitis B virus exposure undergoing rituximab-containing chemotherapy for lymphoma: a prospective study. J Clin Oncol. 2014;32(33):3736–43. doi: 10.1200/JCO.2014.56.7081. PMID: 25287829. Excluded: wrong study design for key question.25287829
Seto WK, Wong DK, Chan TS, . Association of hepatitis B core-related antigen with hepatitis B virus reactivation in occult viral carriers undergoing high-risk immunosuppressive therapy. Am J Gastroenterol. 2016;111(12):1788–95. doi: 10.1038/ajg.2016.436. PMID: 27644733. Excluded: wrong study design for key question.27644733
Shah DP, Grimes CZ, Nguyen AT, . Long-term effectiveness of accelerated hepatitis B vaccination schedule in drug users. Am J Public Health. 2015;105(6):e36–43. doi: 10.2105/AJPH.2014.302487. PMID: 25880946. Excluded: wrong intervention.25880946
Shang J, Wang H, Sun J, . A comparison of lamivudine vs entecavir for prophylaxis of hepatitis B virus reactivation in allogeneic hematopoietic stem cell transplantation recipients: a single-institutional experience. Bone Marrow Transplant. 2016;51(4):581–6. doi: 10.1038/bmt.2015.328. PMID: 26752138. Excluded: wrong population – excluded for reactivation CQ.26752138
Shen J, Yeh CC, Wang Q, . Plasma adiponectin and hepatocellular carcinoma survival among patients without liver transplantation. Anticancer Res. 2016;36(10):5307–14. PMID: 27798893. Excluded: wrong study design for key question.27798893
Shen S, Jiang L, Xiao GQ, . Prophylaxis against hepatitis B virus recurrence after liver transplantation: a registry study. World J Gastroenterol. 2015;21(2):584–92. doi: 10.3748/wjg.v21.i2.584. PMID: 25593480. Excluded: wrong study design for key question.25593480
Sheng J, Zhao Z, Zhang H, . Effect of internet-based follow-up on antiviral treatment compliance and quality of life in discharged patients with chronic hepatitis B. World Chin J Dig. 2017;25(31):2813–8. doi: 10.11569/wcjd.v25.i31.2813. Excluded: not English language but possibly relevant.
Shepherd J, Jones J, Takeda A, . Adefovir dipivoxil and pegylated interferon alfa-2a for the treatment of chronic hepatitis B: a systematic review and economic evaluation. Health Technol Assess. 2006;10(28):iii–iv, xi–xiv, 1–183. PMID: 16904047. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.16904047
Shi GY, Pan YJ, Jiang K, . Efficacy of different antiviral treatments for chronic hepatitis B patients carrying different genotypes of hepatitis B virus. World Chin J Dig. 2016;24(35):4704–9. Excluded: not English language but possibly relevant.
Shi H, Huang M, Lin G, . Efficacy comparison of tenofovir and entecavir in HBeAg-psitive chronic hepatitis B patients with hgh HBV DNA. Biomed Res Int. 2016;2016:6725073. doi: 10.1155/2016/6725073. PMID: 27034945. Excluded: wrong comparator.27034945
Shin JH, Kwon HJ, Jang HR, . Risk factors for renal functional decline in chronic hepatitis B patients receiving oral antiviral agents. Medicine. 2016;95(1):e2400. doi: 10.1097/MD.0000000000002400. PMID: 26735542. Excluded: wrong study design for key question.26735542
Shin JW, Jung SW, Lee SB, . Medication nonadherence increases hepatocellular carcinoma, cirrhotic complications, and mortality in chronic hepatitis B patients treated with entecavir. Am J Gastroenterol. 2018;113(7):998–1008. doi: 10.1038/s41395-018-0093-9. PMID: 29880971. Excluded: wrong outcome.29880971
Shindo M, Chayama K, Mochida S, . Antiviral activity, dose-response relationship, and safety of entecavir following 24-week oral dosing in nucleoside-naive Japanese adult patients with chronic hepatitis B: a randomized, double-blind, phase II clinical trial. Hepatol Int. 2009;3(3):445–52. doi: 10.1007/s12072-009-9135-0. PMID: 19669249. Excluded: wrong study design for key question.19669249
Shouval D, Lai CL, Chang TT, . Relapse of hepatitis B in HBeAg-negative chronic hepatitis B patients who discontinued successful entecavir treatment: the case for continuous antiviral therapy. J Hepatol. 2009;50(2):289–95. doi: 10.1016/j.jhep.2008.10.017. PMID: 19070393. Excluded: wrong intervention.19070393
Simonetti G, Gitto S, Golfieri L, . Quality of life of hepatitis B virus surface antigen-positive patients with suppressed viral replication: comparison between inactive carriers and nucleot(s)ide analog-treated patients. Eur J Gastroenterol Hepatol. 2018;30(1):14–20. doi: 10.1097/MEG.0000000000000999. PMID: 29064847. Excluded: wrong outcome.29064847
Singal AK, Salameh H, Kuo YF, . Meta-analysis: the impact of oral anti-viral agents on the incidence of hepatocellular carcinoma in chronic hepatitis B. Aliment Pharmacol Ther. 2013;38(2):98–106. doi: 10.1111/apt.12344. PMID: 23713520. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.23713520
Singer GA, Zielsdorf S, Fleetwood VA, . Limited hepatitis B immunoglobulin with potent nucleos(t)ide analogue is a cost-effective prophylaxis against hepatitis B virus after liver transplantation. Transplant Proc. 2015;47(2):478–84. doi: 10.1016/j.transproceed.2014.11.029. PMID: 25769595. Excluded: wrong study design for key question.25769595
Sinn DH, Lee J, Goo J, . Hepatocellular carcinoma risk in chronic hepatitis B virus-infected compensated cirrhosis patients with low viral load. Hepatology. 2015;62(3):694–701. doi: 10.1002/hep.27889. PMID: 25963803. Excluded: wrong population – cirrhosis.25963803
Siyahian A, Malik SU, Mushtaq A, . Prophylaxis for hepatitis B virus reactivation after allogeneic stem cell transplantation in the era of drug resistance and newer antivirals: a systematic review and meta-analysis. Biol Blood Marrow Transplant. 2018;24(7):1483–9. doi: 10.1016/j.bbmt.2018.02.027. PMID: 29545185. Excluded: wrong population - excluded for reactivation CQ.29545185
Snast I, Atzmony L, Braun M, . Risk for hepatitis B and C virus reactivation in patients with psoriasis on biologic therapies: a retrospective cohort study and systematic review of the literature. J Am Acad Dermatol. 2017;77(1):88–97.e5. doi: 10.1016/j.jaad.2017.01.037. PMID: 28495497. Excluded: wrong population – excluded for reactivation CQ.28495497
Sohn W, Paik YH, Cho JY, . Influence of hepatitis B virus reactivation on the recurrence of HBV-related hepatocellular carcinoma after curative resection in patients with low viral load. J Viral Hepat. 2015;22(6):539–50. doi: 10.1111/jvh.12356. PMID: 25377516. Excluded: wrong population.25377516
Sommese L, Iannone C, Cacciatore F, . Comparison between screening and confirmatory serological assays in blood donors in a region of South Italy. J Clin Lab Anal. 2014;28(3):198–203. doi: 10.1002/jcla.21666. PMID: 24478048. Excluded: wrong intervention.24478048
Sriprayoon T, Mahidol C, Ungtrakul T, . Efficacy and safety of entecavir versus tenofovir treatment in chronic hepatitis B patients: a randomized controlled trial. Hepatol Res. 2017;47(3):E161–E8. doi: 10.1111/hepr.12743. PMID: 27176630. Excluded: wrong comparator.27176630
Su J, Long L, Zou K. Antiviral prophylaxis for preventing reactivation of hepatitis B virus in rheumatic patients: a systematic review and meta-analysis. Clin Rheumatol. 2018;37(12):3201–14. doi: 10.1007/s10067-018-4096-0. PMID: 29637482. Excluded: wrong study design for key question.29637482
Su MH, Lu AL, Li SH, . Long-term lamivudine for chronic hepatitis B and cirrhosis: a real-life cohort study. World J Gastroenterol. 2015;21(46):13087–94. doi: 10.3748/wjg.v21.i46.13087. PMID: 26673249. Excluded: wrong study design for key question.26673249
Su YC, Lin PC, Yu HC, . Antiviral prophylaxis during chemotherapy or immunosuppressive drug therapy to prevent HBV reactivation in patients with resolved HBV infection: a systematic review and meta-analysis. Eur J Clin Pharmacol. 2018;74(9):1111–9. doi: 10.1007/s00228-018-2487-4. PMID: 29845351. Excluded: wrong population – excluded for reactivation CQ.29845351
Suarez E, Buti M, Rodriguez M, . Hepatitis B surface antigen loss after discontinuing nucleos(t)ide analogue for treatment of chronic hepatitis B patients is persistent in white patients. Eur J Gastroenterol Hepatol. 2019;31(2):267–71. doi: 10.1097/MEG.0000000000001289. PMID: 30576297. Excluded: wrong study design for key question.30576297
Suijkerbuijk AW, van Hoek AJ, Koopsen J, . Cost-effectiveness of screening for chronic hepatitis B and C among migrant populations in a low endemic country. PLoS One. 2018;13(11):e0207037. doi: 10.1371/journal.pone.0207037. PMID: 30408079. Excluded: wrong country.30408079
Sun J, Ding H, Chen G, . Sustained serological and complete responses in HBeAg-positive patients treated with Peginterferon alfa-2b: a 6-year long-term follow-up of a multicenter, randomized, controlled trial in China. BMC Gastroenterology. 2019;19(1):65. doi: 10.1186/s12876-019-0981-5. PMID: 31046700. Excluded: wrong comparator.31046700
Sun J, Ma H, Xie Q, . Response-guided peginterferon therapy in patients with HBeAg-positive chronic hepatitis B: a randomized controlled study. J Hepatol. 2016;65(4):674–82. doi: 10.1016/j.jhep.2016.05.024. PMID: 27238752. Excluded: wrong comparator.27238752
Sun J, Xie Q, Tan D, . The 104-week efficacy and safety of telbivudine-based optimization strategy in chronic hepatitis B patients: a randomized, controlled study. Hepatology. 2014;59(4):1283–92. doi: 10.1002/hep.26885. PMID: 24382690. Excluded: wrong comparator.24382690
Sun LY, Zhu ZJ, Qu W, . Prognosis in liver transplantation recipients after hepatitis B virus recurrence. Hepatogastroenterology. 2014;61(135):2047–51. PMID: 25713909. Excluded: wrong study design for key question.25713909
Sun Y, Wu K, Shen F, . Effects of the combined administration of entecavir and adefovir dipivoxil to improve hepatic fibrosis in hepatitis B patients with interferon resistance. Minerva Med. 2017;108(6):507–12. doi: 10.23736/S0026-4806.17.05222-3. PMID: 28889724. Excluded: wrong population.28889724
Suzuki Y, Maekawa S, Komatsu N, . Hepatitis B virus (HBV)-infected patients with low hepatitis B surface antigen and high hepatitis B core-related antigen titers have a high risk of HBV-related hepatocellular carcinoma. Hepatol Res. 2019;49(1):51–63. doi: 10.1111/hepr.13277. PMID: 30350374. Excluded: wrong study design for key question.30350374
Tada T, Kumada T, Toyoda H, . Long-term natural history of liver disease in patients with chronic hepatitis B virus infection: an analysis using the Markov chain model. J Gastroenterol. 2018;53(11):1196–205. doi: 10.1007/s00535-018-1467-x. PMID: 29675604. Excluded: wrong study design for key question.29675604
Taida T, Arai M, Kanda T, . The prognosis of hepatitis B inactive carriers in Japan: a multicenter prospective study. J Gastroenterol. 2017;52(1):113–22. PMID: 27306374. Excluded: wrong study design for key question.27306374
Tak WY, Yang JM, Kim BI, . A randomized, open-label study comparing low-dose clevudine plus adefovir combination therapy with clevudine monotherapy in naive chronic hepatitis B patients. Hepatol Int. 2014;8(3):375–81. doi: 10.1007/s12072-014-9537-5. PMID: 25101150. Excluded: wrong intervention.25101150
Tamori A, Hino M, Kawamura E, . Prospective long-term study of hepatitis B virus reactivation in patients with hematologic malignancy. J Gastroenterol Hepatol. 2014;29(9):1715–21. doi: 10.1111/jgh.12604. PMID: 24730465. Excluded: wrong study design for key question.24730465
Tan YW, Ge GH, Sun L, . Efficacy of entecavir therapy in elderly patients with chronic hepatitis B infection. Braz J Infect Dis. 2014;18(6):691–2. doi: 10.1016/j.bjid.2014.05.016. PMID: 25179513. Excluded: not a study (letter, editorial, non-systematic review article, no original data).25179513
Tang W, Chen L, Zheng R, . Prophylactic effect of lamivudine for chemotherapy-induced hepatitis B reactivation in breast cancer: a meta-analysis. PLoS One. 2015;10(6):e0128673. doi: 10.1371/journal.pone.0128673. PMID: 26057738. Excluded: wrong population – excluded for reactivation CQ.26057738
Tang Z, Li X, Wu S, . Risk of hepatitis B reactivation in HBsAg-negative/HBcAb-positive patients with undetectable serum HBV DNA after treatment with rituximab for lymphoma: a meta-analysis. Hepatol Int. 2017;11(5):429–33. doi: 10.1007/s12072-017-9817-y. PMID: 28856548. Excluded: wrong population – excluded for reactivation CQ.28856548
Tangkijvanich P, Chittmittraprap S, Poovorawan K, . A randomized clinical trial of peginterferon alpha-2b with or without entecavir in patients with HBeAg-negative chronic hepatitis B: role of host and viral factors associated with treatment response. J Viral Hepat. 2016;23(6):427–38. doi: 10.1111/jvh.12467. PMID: 26387494. Excluded: wrong comparator.26387494
Taplitz RA, Kennedy EB, Bow EJ, . Antimicrobial prophylaxis for adult patients with cancer-related immunosuppression: ASCO and IDSA clinical practice guideline update. J Clin Oncol. 2018;36(30):3043–3054. doi: 10.1200/JCO.18.00374. PMID: 30179565. Excluded: wrong intervention.30179565
Tarakji B, Ashok N, Alakeel R, . Hepatitis B vaccination and associated oral manifestations: a non-systematic review of literature and case reports. Ann Med Health Sci Res. 2014;4(6):829–36. doi: 10.4103/2141-9248.144870. PMID: 25506472. Excluded: wrong intervention.25506472
Tavakolpour S, Alavian SM, Sali S. Hepatitis B reactivation during immunosuppressive therapy or cancer chemotherapy, management, and prevention: a comprehensive review-screened. Hepat Mon. 2016;16(4):e35810. doi: 10.5812/hepatmon.35810. PMID: 27257429. Excluded: wrong population – excluded for reactivation CQ.27257429
Terrault NA, Lok ASF, McMahon BJ, . Update on prevention, diagnosis, and treatment of chronic hepatitis B: AASLD 2018 hepatitis B guidance. Hepatology. 2018;67(4):1560–99. doi: 10.1002/hep.29800. PMID: 29405329. Excluded: wrong population – excluded for reactivation CQ.29405329
Thai KTD, Gotz H, Slingerland B, . An analysis of the predictive value of the HIV Ag/Ab screening assay within the performance characteristics of the DiaSorin LIAISON XL for the detection of blood-borne viruses. J Clin Virol. 2018;102:95–100. doi: 10.1016/j.jcv.2018.02.018. PMID: 29547874. Excluded: wrong intervention.29547874
Thiele M, Gluud LL, Dahl EK, . Antiviral therapy for prevention of hepatocellular carcinoma and mortality in chronic hepatitis B: systematic review and meta-analysis. BMJ Open. 2013;3(8):14. doi: 10.1136/bmjopen-2013-003265. PMID: 23945731. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.23945731
Thu AM, Poovorawan K, Kittitrakul C, . Nephrotoxicity caused by oral antiviral agents in patients with chronic hepatitis B treated in a hospital for tropical diseases in Thailand. BMC Pharmacol Toxicol. 2015;16:38. doi: 10.1186/s40360-015-0037-6. PMID: 26651337. Excluded: inadequate duration.26651337
Tien C, Xu JJ, Chan LS, . Long-term treatment with tenofovir in Asian-American chronic hepatitis B patients is associated with abnormal renal phosphate handling. Dig Dis Sci. 2015;60(2):566–72. doi: 10.1007/s10620-014-3363-4. PMID: 25239496. Excluded: inadequate duration.25239496
Tien PT, Lin CJ, Tsai YY, . Relationship between uveitis, different types of viral hepatitis, and liver cirrhosis: a 12-year nationwide population-based cohort study. Retina. 2016;36(12):2391–8. PMID: 27870801. Excluded: wrong population – cirrhosis.27870801
Tien YC, Yen HH, Chiu YM. Incidence and clinical characteristics of hepatitis B virus reactivation in HBsAg-negative/HBcAb-positive patients receiving rituximab for rheumatoid arthritis. Clin Exp Rheumatol. 2017;35(5):831–6. PMID: 28375829. Excluded: wrong population – excluded for reactivation CQ.28375829
Triantos C, Kalafateli M, Aggeletopoulou I, . Lactate serum concentrations during treatment with nucleos(t)ide analogues in hepatitis B with or without cirrhosis. Eur J Gastroenterol Hepatol. 2017;29(9):998–1003. doi: 10.1097/MEG.0000000000000924. PMID: 28746158. Excluded: wrong study design for key question.28746158
Tsai MC, Chen CH, Hung CH, . A comparison of efficacy and safety of 2-year telbivudine and entecavir treatment in patients with chronic hepatitis B: a match-control study. Clin Microbiol Infect. 2014;20(2):O90–O100. doi: 10.1111/1469-0691.12220. PMID: 23659493. Excluded: wrong study design for key question.23659493
Tsai MC, Chen CH, Tseng PL, . Does nucleos(t)ide analogues treatment affect renal function in chronic hepatitis B patients who have already decreased eGFR? A longitudinal study. PLoS One. 2016;11(3):e0149761. doi: 10.1371/journal.pone.0149761. PMID: 26964034. Excluded: inadequate duration.26964034
Tsai MC, Chen CH, Tseng PL, . Comparison of renal safety and efficacy of telbivudine, entecavir and tenofovir treatment in chronic hepatitis B patients: real world experience. Clin Microbiol Infect. 2016;22(1):95.e1-.e7. doi: 10.1016/j.cmi.2015.05.035. PMID: 26055419. Excluded: wrong outcome.26055419
Tsai NC, Marcellin P, Buti M, . Viral suppression and cirrhosis regression with tenofovir disoproxil fumarate in Asians with chronic hepatitis B. Dig Dis Sci. 2015;60(1):260–8. doi: 10.1007/s10620-014-3336-7. PMID: 25179493. Excluded: not a study (letter, editorial, non-systematic review article, no original data).25179493
Tseng CM, Chen TB, Hsu YC, . Comparative effectiveness of nucleos(t)ide analogues in chronic hepatitis B patients undergoing cytotoxic chemotherapy. Asia Pac J Clin Oncol. 2016;12(4):421–9. doi: 10.1111/ajco.12520. PMID: 27435683. Excluded: wrong study design for key question.27435683
Turan I, Yapali S, Bademkiran F, . Telbivudine in liver transplant recipients: renal protection does not overcome the risk of polyneuropathy and myopathy. Liver Transpl. 2015;21(8):1066–75. doi: 10.1002/lt.24131. PMID: 25845464. Excluded: wrong study design for key question.25845464
Udayakumar VP, Surendran S, Padma UD. Utilization of hepatitis B core antibody positive grafts in living donor liver transplantation. Indian J Gastroenterol. 2018;37(1):39–43. doi: 10.1007/s12664-018-0823-3. PMID: 29450703. Excluded: wrong intervention.29450703
Udompap P, Kim D, Ahmed A, . Longitudinal trends in renal function in chronic hepatitis B patients receiving oral antiviral treatment. Aliment Pharmacol Ther. 2018;48(11-12):1282–9. doi: 10.1111/apt.15020. PMID: 30370967. Excluded: inadequate duration.30370967
Ungtrakul T, Mahidol C, Chun-On P, . Hepatocellular carcinoma screening and surveillance in 2293 chronic hepatitis B patients in an endemic area. World J Gastroenterol. 2016;22(34):7806–12. doi: 10.3748/wjg.v22.i34.7806. PMID: 27678364. Excluded: wrong study design for key question.27678364
van den Ende C, Marano C, van Ahee A, . The immunogenicity of GSK’s recombinant hepatitis B vaccine in children: a systematic review of 30 years of experience. Expert Rev Vaccines. 2017;16(8):789–809. doi: 10.1080/14760584.2017.1338569. PMID: 28586278. Excluded: wrong intervention.28586278
Van Den Ende C, Marano C, Van Ahee A, . The immunogenicity and safety of GSK’s recombinant hepatitis B vaccine in adults: a systematic review of 30 years of experience. Expert Rev Vaccines. 2017;16(8):811–32. doi: 10.1080/14760584.2017.1338568. PMID: 28573913. Excluded: wrong intervention.28573913
Van Der Meeren O, Peterson JT, Dionne M, . Prospective clinical trial of hepatitis B vaccination in adults with and without type-2 diabetes mellitus. Hum Vaccin Immunother. 2016;12(8):2197–203. PMID: 27123743. Excluded: wrong intervention.27123743
van Loo IHM, Dukers-Muijrers N, Heuts R, . Screening for HIV, hepatitis B and syphilis on dried blood spots: a promising method to better reach hidden high-risk populations with self-collected sampling. PLoS One. 2017;12(10):e0186722. doi: 10.1371/journal.pone.0186722. PMID: 29053737. Excluded: wrong intervention.29053737
Varisco V, Vigano M, Batticciotto A, . Low risk of hepatitis B virus reactivation in HBsAg-negative/Anti-HBc-positive carriers receiving rituximab for rheumatoid arthritis: a retrospective multicenter Italian study. J Rheumatol. 2016;43(5):869–74. doi: 10.3899/jrheum.151105. PMID: 26879359. Excluded: wrong intervention.26879359
Varma A, Biritxinaga L, Saliba RM, . Impact of hepatitis B Core antibody seropositivity on the outcome of autologous hematopoietic stem cell transplantation for multiple myeloma. Biol Blood Marrow Transplant. 2017;23(4):581–7. doi: 10.1016/j.bbmt.2017.01.005. PMID: 28063964. Excluded: wrong intervention.28063964
Veldhuijzen IK, Toy M, Hahne SJ, . Screening and early treatment of migrants for chronic hepatitis B virus infection is cost-effective. Gastroenterology. 2010;138(2):522–30. doi: 10.1053/j.gastro.2009.10.039. PMID: 19879275. Excluded: wrong country.19879275
Vet R, de Wit JB, Das E. Factors associated with hepatitis B vaccination among men who have sex with men: a systematic review of published research. Int J STD AIDS. 2017;28(6):534–42. doi: 10.1177/0956462415613726. PMID: 26503555. Excluded: wrong intervention.26503555
Viard JP, Assuied A, Levy Y, . No positive association between vitamin D level and immune responses to hepatitis B and streptococcus pneumoniae vaccination in HIV-infected adults. PLoS One. 2016;11(12):e0168640. doi: 10.1371/journal.pone.0168640. PMID: 27977797. Excluded: wrong intervention.27977797
Voican CS, Mir O, Loulergue P, . Hepatitis B virus reactivation in patients with solid tumors receiving systemic anticancer treatment. Ann Oncol. 2016;27(12):2172–84. doi: 10.1093/annonc/mdw414. PMID: 27803003. Excluded: wrong population – excluded for reactivation CQ.27803003
Vourli G, Papatheodoridis G, Raptopoulou M, . Association of antiviral therapy with reduced disease progression in chronic hepatitis B patients: results from a nation-wide cohort study. Hippokratia. 2016;20(3):214–21. PMID: 29097888. Excluded: wrong study design for key question.29097888
Vu V, Trinh S, Le A, . Hepatitis B and renal function: a matched study comparing non-hepatitis B, untreated, treated and cirrhotic hepatitis patients. Liver Int. 2018;20:20. doi: 10.1111/liv.14009. PMID: 30460749. Excluded: wrong outcome.30460749
Wahle RC, Perez RM, Pereira PF, . Hepatitis B virus reactivation after treatment for hepatitis C in hemodialysis patients with HBV/HCV coinfection. Braz J Infect Dis. 2015;19(5):533–7. doi: 10.1016/j.bjid.2015.04.003. PMID: 25997784. Excluded: wrong study design for key question.25997784
Waked I, Amin M, Abd el Fattah S, . Experience with interferon in chronic hepatitis B in Egypt. J Chemother. 1990;2(5):310–8. PMID: 2090770. Excluded: wrong population – cirrhosis.2090770
Wang C, Teng Z, Zhu Y, . Associations between pre-S deletion mutation of hepatitis B virus and risk of hepatocellular carcinoma in the Asian population: a meta-analysis. Med Sci Monit. 2015;21:1072–7. doi: 10.12659/MSM.894058. PMID: 25868851. Excluded: wrong population.25868851
Wang G, Liu Y, Qiu P, . Cost-effectiveness analysis of lamivudine, telbivudine, and entecavir in treatment of chronic hepatitis B with adefovir dipivoxil resistance. Drug Des Devel Ther. 2015;9:2839–46. doi: 10.2147/DDDT.S73150. PMID: 26082614. Excluded: wrong outcome.26082614
Wang GL, Liu Y, Qiu P, . Cost-effectiveness of lamivudine, telbivudine, adefovir dipivoxil and entecavir on decompensated hepatitis B virus-related cirrhosis. Eur Rev Med Pharmacol Sci. 2016;20(5):866–72. PMID: 27010143. Excluded: wrong outcome.27010143
Wang H, Ji YY, Yao GB, . Two years efficiency of lamivudine and adefovir dipivoxil combined therapy in chronic hepatitis B patients. Eur Rev Med Pharmacol Sci. 2013;17(5):636–43. PMID: 23543447. Excluded: wrong comparator.23543447
Wang X, Liu X, Dang Z, . Nucleos(t)ide analogues for reducing hepatocellular carcinoma in chronic hepatitis B patients: a systematic review and meta-analysis. Gut Liver. 2019;03:03. doi: 10.5009/gnl18546. PMID: 31158948. Excluded: guidance document/systematic review.31158948
Wang Y, Xiang X, Chen L, . Randomized clinical trial: nucleos(t)ide analogues improved survival of CHB-related HCC patients via reducing severity and progression of malignancy. Oncotarget. 2016;7(36):58553–62. doi: 10.18632/oncotarget.10155. PMID: 27329718. Excluded: wrong population.27329718
Wang Z, Sun L, Wu Y, . Extended duration versus standard duration of peginterferon alfa-2a in treatment of chronic hepatitis B: a systematic review and meta-analysis. Clin Res Hepatol Gastroenterol. 2016;40(2):195–202. doi: 10.1016/j.clinre.2015.06.022. PMID: 26299874. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.26299874
Wei L, Kao JH. Benefits of long-term therapy with nucleos(t)ide analogues in treatment-naive patients with chronic hepatitis B. Curr Med Res Opin. 2017;33(3):495–504. doi: 10.1080/03007995.2016.1264932. PMID: 27882776. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.27882776
Wei MJ, Pan XN, Wei KP, . Efficacy of HBV-pulsed DCs in combination with entecavir in patients with chronic hepatitis B infection. Int Immunopharmacol. 2015;27(2):238–43. doi: 10.1016/j.intimp.2015.06.019. PMID: 26118632. Excluded: too small.26118632
Wei Q, Xu X, Ling Q, . Perioperative antiviral therapy for chronic hepatitis B-related hepatocellular carcinoma. Hepatobiliary Pancreat Dis Int. 2013;12(3):251–5. PMID: 23742769. Excluded: wrong population – excluded for reactivation CQ.23742769
Wong D, Littlejohn M, Edwards R, . ALT flares during nucleotide analogue therapy are associated with HBsAg loss in genotype A HBeAg-positive chronic hepatitis B. Liver Int. 2018;38(10):1760–9. doi: 10.1111/liv.13716. PMID: 29427368. Excluded: wrong outcome.29427368
Wong D, Littlejohn M, Yuen L, . HBeAg levels at week 24 predict response to 8 years of tenofovir in HBeAg-positive chronic hepatitis B patients. Aliment Pharmacol Ther. 2018;47(1):114–22. doi: 10.1111/apt.14362. PMID: 29023803. Excluded: wrong outcome.29023803
Wong GL, Chan HL, Mak CW, . Entecavir treatment reduces hepatic events and deaths in chronic hepatitis B patients with liver cirrhosis. Hepatology. 2013;58(5):1537–47. doi: 10.1002/hep.26301. PMID: 23389810. Excluded: wrong population – cirrhosis.23389810
Wong GL, Chan HL, Tse YK, . Chronic kidney disease progression in patients with chronic hepatitis B on tenofovir, entecavir, or no treatment. Aliment Pharmacol Ther. 2018;48(9):984–92. doi: 10.1111/apt.14945. PMID: 30125952. Excluded: wrong outcome.30125952
Wong GL, Tse YK, Yip TC, . Long-term use of oral nucleos(t)ide analogues for chronic hepatitis B does not increase cancer risk - a cohort study of 44,494 subjects. Aliment Pharmacol Ther. 2017;45(9):1213–24. doi: 10.1111/apt.14015. PMID: 28239880. Excluded: wrong outcome.28239880
Wong VW, Wong GL, Yiu KK, . Entecavir treatment in patients with severe acute exacerbation of chronic hepatitis B. J Hepatol. 2011;54(2):236–42. doi: 10.1016/j.jhep.2010.06.043. PMID: 21030105. Excluded: wrong population.21030105
Wong WW, Hicks LK, Tu HA, . Hepatitis B virus screening before adjuvant chemotherapy in patients with early-stage breast cancer: a cost-effectiveness analysis. Breast Cancer Res Treat. 2015;151(3):639–52. doi: 10.1007/s10549-015-3382-7. PMID: 25962692. Excluded: wrong population – excluded for reactivation CQ.25962692
Wong WW, Woo G, Jenny Heathcote E, . Cost effectiveness of screening immigrants for hepatitis B. Liver Int. 2011;31(8):1179–90. doi: 10.1111/j.1478-3231.2011.02559.x. PMID: 21745300. Excluded: wrong country.21745300
World Health Organization. Global Hepatitis Report. 2017. http://apps.who.int/iris/bitstream/handle/10665/255016/9789241565455-eng.pdf;jsessionid=23CD86753C0FA6AE96C26AC476ABACBB?sequence=1. Accessed August 21, 2019. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Wu CS, Zhao Q, Zhang J, . Methylation status of the stimulator of interferon genes promoter in patients with chronic hepatitis B. Medicine. 2018;97(52):e13904. doi: 10.1097/MD.0000000000013904. PMID: 30593207. Excluded: wrong study design for key question.30593207
Wu VC, Chen TH, Wu M, . Comparison of cardiovascular outcomes and all-cause mortality in patients with chronic hepatitis B and C: a 13-year nationwide population-based study in Asia. Atherosclerosis. 2018;269:178–84. doi: 10.1016/j.atherosclerosis.2018.01.007. PMID: 29366991. Excluded: wrong outcome.29366991
Wu X, Cai S, Li Z, . Potential effects of telbivudine and entecavir on renal function: a systematic review and meta-analysis. Virol J. 2016;13:64. doi: 10.1186/s12985-016-0522-6. PMID: 27062520. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.27062520
Wu Y, Jie Y, Li X, . Comprehensive analysis of hospital-based prospective cohort reveals the unique effectiveness and safety for nucleos(t)ide analogues in HBV patients. Clin Res Hepatol Gastroenterol. 2016;40(2):213–20. doi: 10.1016/j.clinre.2015.06.018. PMID: 26598028. Excluded: wrong outcome.26598028
Wu YT, Li X, Liu ZL, . Hepatitis B virus reactivation and antiviral prophylaxis during lung cancer chemotherapy: a systematic review and meta-analysis. PLoS One. 2017;12(6):e0179680. doi: 10.1371/journal.pone.0179680. PMID: 28640902. Excluded: wrong population - excluded for reactivation CQ.28640902
Xie YD, Ma H, Feng B, . Efficacy of real-world entecavir therapy in treatment-naive chronic hepatitis B patients. Chin Med J. 2017;130(18):2190–7. doi: 10.4103/0366-6999.213969. PMID: 28875955. Excluded: wrong outcome.28875955
Xing T, Xu H, Cao L, . HBeAg seroconversion in HBeAg-positive chronic hepatitis B patients receiving long-term nucleos(t)ide analog treatment: a systematic review and network meta-analysis. PLoS One. 2017;12(1):e0169444. doi: 10.1371/journal.pone.0169444. PMID: 28107377. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.28107377
Xu WX, Zhang Q, Zhu X, . 48-week outcome after cessation of nucleos(t)ide analogue treatment in chronic hepatitis B patient and the associated factors with relapse. Can J Gastroenterol Hepatol. 2018:1817680. doi: 10.1155/2018/1817680. PMID: 29862225. Excluded: wrong outcome.29862225
Xu Y, Wang X, Liu Z, . Addition of nucleoside analogues to peg-IFNalpha-2a enhances virological response in chronic hepatitis B patients without early response to peg-IFNalpha-2a: a randomized controlled trial. BMC Gastroenterol. 2017;17(1):102. doi: 10.1186/s12876-017-0657-y. PMID: 28854883. Excluded: wrong intervention.28854883
Xu Z, Dai W, Wu YT, . Prophylactic effect of lamivudine on chemotherapy-induced hepatitis B virus reactivation in patients with solid tumour: a meta-analysis. Eur J Cancer Care. 2018;27(2):e12799. doi: 10.1111/ecc.12799. PMID: 29265535. Excluded: wrong population – excluded for reactivation CQ.29265535
Yan H, Zhang X, Lv Y. The effect of entecavir therapy on immune status in chronic hepatitis B patients. Iran J Immunol. 2019;16(1):84–91. doi: 10.22034/IJI.2019.39409. PMID: 30864558. Excluded: wrong outcome.30864558
Yang C, Qin B, Yuan Z, . Meta-analysis of prophylactic entecavir or lamivudine against hepatitis B virus reactivation. Ann Hepatol. 2016;15(4):501–11. PMID: 27236149. Excluded: wrong population – excluded for reactivation CQ.27236149
Yang HC, Tsou HH, Pei SN, . Quantification of HBV core antibodies may help predict HBV reactivation in patients with lymphoma and resolved HBV infection. J Hepatol. 2018;69(2):286–92. doi: 10.1016/j.jhep.2018.02.033. PMID: 29551710. Excluded: wrong intervention.29551710
Yang PH, Cai ZC, Huang YX. Integrated medicine on the treatment of chronic active hepatitis B with liver fibrosis and early cirrhosis of the liver for 40 cases. Chinese Medicine Modern Distance Education of China. 2015;13(8):65–6. Excluded: not English language but possibly relevant.
Yang Q, Gong ZJ, Hu DF. [A clinical study of adefovir dipivoxil treatment for chronic hepatitis patients with cirrhosis in their decompensation period]. Zhonghua Gan Zang Bing Za Zhi. 2009;17(7):515–9. PMID: 19912686. Excluded: wrong comparator.19912686
Yang S, Tian G, Cui Y, . Factors influencing immunologic response to hepatitis B vaccine in adults. Sci Rep. 2016;6:27251. doi: 10.1038/srep27251. PMID: 27324884. Excluded: wrong intervention.27324884
Yang Y, Ma YP, Chen DP, . A meta-analysis of antiviral therapy for hepatitis B virus-associated membranous nephropathy. PLoS One. 2016;11(9):e0160437. doi: 10.1371/journal.pone.0160437. PMID: 27598699. Excluded: wrong intervention.27598699
Yang YW, Lee CY, Hu RH, . Long-term effects of prophylactic and therapeutic lamivudine treatments in hepatitis B surface antigen-positive renal allograft recipients. Clin Exp Nephrol. 2014;18(1):144–50. doi: 10.1007/s10157-013-0807-7. PMID: 23605388. Excluded: wrong population.23605388
Yao CC, Hung CH, Hu TH, . Incidence and predictors of HBV relapse after cessation of nucleoside analogues in HBeAg-negative patients with HBsAg <= 200 IU/mL. Sci Rep. 2017;7(1):1839. doi: 10.1038/s41598-017-02010-w. PMID: 28500322. Excluded: wrong comparator.28500322
Yapali S, Talaat N, Fontana RJ, . Outcomes of patients with chronic hepatitis B who do not meet criteria for antiviral treatment at presentation. Clin Gastroenterol Hepatol. 2015;13(1):193–201.e1. doi: 10.1016/j.cgh.2014.07.019. PMID: 25041863. Excluded: wrong outcome.25041863
Yasunaka T, Ikeda F, Wada N, . Entecavir reduces hepatocarcinogenesis in chronic hepatitis B patients. Acta Med Okayama. 2016;70(1):1–12. PMID: 26899604. Excluded: wrong study design for key question.26899604
Yeh YC, Liu CJ, Kuo RN, . Association of adjuvant antiviral therapy with risk of cancer progression and deaths in patients with hepatitis-B-virus-related hepatocellular carcinoma following curative treatment: a nationwide cohort study. PLoS One. 2014;9(7):e102051. doi: 10.1371/journal.pone.0102051. PMID: 25025231. Excluded: wrong population.25025231
Yip TC, Chan HL, Tse YK, . On-treatment improvement of MELD score reduces death and hepatic events in patients with hepatitis B-related cirrhosis. Am J Gastroenterol. 2018;113(11):1629–38. doi: 10.1038/s41395-018-0247-9. PMID: 30315283. Excluded: wrong population – cirrhosis.30315283
Yip TC, Chan HL, Wong VW, . Impact of age and gender on risk of hepatocellular carcinoma after hepatitis B surface antigen seroclearance. J Hepatol. 2017;67(5):902–8. doi: 10.1016/j.jhep.2017.06.019. PMID: 28652084. Excluded: wrong outcome.28652084
Yip VS, Cheung TT, Poon RT, . Does hepatitis B seroconversion affect survival outcome in patients with hepatitis B related hepatocellular carcinoma? Transl Gastroenterol Hepatol. 2016;1:51. doi: 10.21037/tgh.2016.05.11. PMID: 28138618. Excluded: wrong population.28138618
Yu S, Luo H, Pan M, . Comparison of entecavir and lamivudine in preventing HBV reactivation in lymphoma patients undergoing chemotherapy: a meta-analysis. Int J Clin Pharm. 2016;38(5):1035–43. doi: 10.1007/s11096-016-0358-6. PMID: 27450506. Excluded: wrong population – excluded for reactivation CQ.27450506
Yu S, Zhou Q, Zhao XM, . Comparison of the antiviral effects of different nucleos(t)ide analogues in Chinese patients with chronic hepatitis B: a head-to-head study. Saudi J Gastroenterol. 2014;20(6):350–5. doi: 10.4103/1319-3767.145320. PMID: 25434315. Excluded: wrong study design for key question.25434315
Yu SJ, Kim YJ. Hepatitis B viral load affects prognosis of hepatocellular carcinoma. World J Gastroenterol. 2014;20(34):12039–44. doi: 10.3748/wjg.v20.i34.12039. PMID: 25232241. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.25232241
Yuen MF, Seto WK, Chow DH, . Long-term lamivudine therapy reduces the risk of long-term complications of chronic hepatitis B infection even in patients without advanced disease. Antivir Ther. 2007;12(8):1295–303. PMID: 18240869. Excluded: sample size for cohort less than 1,000.18240869
Zeng M, Mao Y, Yao G, . A double-blind randomized trial of adefovir dipivoxil in Chinese subjects with HBeAg-positive chronic hepatitis B. Hepatology. 2006;44(1):108–16. doi: 10.1002/hep.21225. PMID: 16799983. Excluded: wrong population.16799983
Zhang D, Zhao G, Li L, . Observation of combined/optimized therapy of lamivudine and adefovir dipivoxyl for hepatitis B-induced decompensated cirrhosis with baseline HBV DNA>1,000 IU/mL. Acta Gastroenterol Belg. 2017;80(1):9–13. PMID: 29364091. Excluded: wrong intervention.29364091
Zhang H, Chen H, Li Q, . Association of pharmacogenomics and pharmacokinetics with antiviral activity of Pradefovir for treatment of chronic hepatitis B infection. J Hepatol. 2019;70(1):e143–e4. Excluded: not a study (letter, editorial, non-systematic review article, no original data).
Zhang K, Cao H, Liang J, . CONSORT: Effects of adding adefovirdipivoxil to peginterferon alfa-2a at different time points on HBeAg-positivepatients: a prospective, randomized study. Medicine (Baltimore). 2016;95(31):e4471. doi: 10.1097/MD.0000000000004471. PMID: 27495085. Excluded: wrong intervention.27495085
Zhang MY, Zhu GQ, Shi KQ, . Systematic review with network meta-analysis: comparative efficacy of oral nucleos(t)ide analogues for the prevention of chemotherapy-induced hepatitis B virus reactivation. Oncotarget. 2016;7(21):30642–58. doi: 10.18632/oncotarget.8907. PMID: 27121321. Excluded: wrong population – excluded for reactivation CQ.27121321
Zhang MY, Zhu GQ, Zheng JN, . Nucleos(t)ide analogues for preventing HBV reactivation in immunosuppressed patients with hematological malignancies: a network meta-analysis. Expert Rev Anti Infect Ther. 2017;15(5):503–13. doi: 10.1080/14787210.2017.1309291. PMID: 28317397. Excluded: wrong population – excluded for reactivation CQ.28317397
Zhang SS, Liu JX, Zhu J, . Effects of TACE and preventive antiviral therapy on HBV reactivation and subsequent hepatitis in hepatocellular carcinoma: a meta-analysis. Jpn J Clin Oncol. 2019;10:10. doi: 10.1093/jjco/hyz046. PMID: 30968933. Excluded: wrong population – excluded for reactivation CQ.30968933
Zhang Y, Hu P, Qi X, . A comparison of telbivudine and entecavir in the treatment of hepatitis B e antigen-positive patients: a prospective cohort study in China. Clin Microbiol Infect. 2016;22(3):287.e1–9. doi: 10.1016/j.cmi.2015.10.024. PMID: 26548508. Excluded: wrong comparator.26548508
Zhang Y, Zhang WL, Pang XW, . Effect of 48-week pegylated interferon alpha-2a or nucleos(t)ide analogue therapy on renal function in Chinese patients with chronic hepatitis B. Virol J. 2017;14(1):49. doi: 10.1186/s12985-017-0712-x. PMID: 28274240. Excluded: wrong outcome.28274240
Zhang Z, Zhou Y, Yang J, . The effectiveness of TDF versus ETV on incidence of HCC in CHB patients: a meta analysis. BMC Cancer. 2019;19(1):511. doi: 10.1186/s12885-019-5735-9. PMID: 31142283. Excluded: guidance document/systematic review.31142283
Zheng Y, Zhang S, Tan Grahn HM, . Prophylactic lamivudine to improve the outcome of breast cancer patients with HBsAg positive during chemotherapy: a meta-analysis. Hepat Mon. 2013;13(4):e6496. doi: 10.5812/hepatmon.6496. PMID: 23805156. Excluded: wrong population – excluded for reactivation CQ.23805156
Zhou J, Wu X, Wei W, . A meta-analysis of the efficacy of interferon monotherapy or combined with different nucleos(t)ide analogues for chronic hepatitis B. Int J Environ Res Public Health. 2016;13(5):21. doi: 10.3390/ijerph13070730. PMID: 27455288. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.27455288
Ziakas PD, Karsaliakos P, Mylonakis E. Effect of prophylactic lamivudine for chemotherapy-associated hepatitis B reactivation in lymphoma: a meta-analysis of published clinical trials and a decision tree addressing prolonged prophylaxis and maintenance. Haematologica. 2009;94(7):998–1005. doi: 10.3324/haematol.2009.005819. PMID: 19454492. Excluded: wrong population – excluded for reactivation CQ.19454492
Zoulim F, Carosi G, Greenbloom S, . Quantification of HBsAg in nucleos(t)ide-naive patients treated for chronic hepatitis B with entecavir with or without tenofovir in the BE-LOW study. J Hepatol. 2015;62(1):56–63. doi: 10.1016/j.jhep.2014.08.031. PMID: 25176615. Excluded: wrong comparator.25176615
Zuo SR, Zuo XC, Wang CJ, . A meta-analysis comparing the efficacy of entecavir and tenofovir for the treatment of chronic hepatitis B infection. J Clin Pharmacol. 2015;55(3):288–97. doi: 10.1002/jcph.409. PMID: 25293471. Excluded: systematic review or meta-analysis used as a source document only to identify individual studies.25293471
Zurawska U, Hicks LK, Woo G, . Hepatitis B virus screening before chemotherapy for lymphoma: a cost-effectiveness analysis. J Clin Oncol. 2012;30(26):3167–73. doi: 10.1200/jco.2011.40.7510. PMID: 22711851. Excluded: wrong population.22711851

## Appendix A6 U.S. Preventive Services Task Force Quality Rating Criteria

### RCTs and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  ○ For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Definition of ratings based on above criteria:

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.

Poor: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of ratings based on above criteria:

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease.

Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.

Poor: Has a fatal flaw, such as: Uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients.

Source: U.S. Preventive Services Task Force Procedure Manual. Accessed at https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes.

## Appendix A7 Expert Reviewers of the Draft Report

❖ Erin Abramsohn, MPH, DrPH, Centers for Disease Control and Prevention
❖ Jennifer Fuld, PhD, Centers for Disease Control and Prevention
❖ David E. Kaplan, MD, MSc, FACP, FAASLD, Perelman School of Medicine, University of Pennsylvania, Department of Medicine, Division of Gastroenterology and Hepatology
❖ Bill G. Kapogiannis, MD, Eunice Kennedy Shriver National Institute of Child Health and Development, National Institutes of Health
❖ Rajen Koshy, PhD, National Institute of Allergy and Infectious Diseases
❖ Rebecca L. Morgan, MPH, PhD, McMaster University
❖ John W. Ward, MD, Coalition for Global Hepatitis Elimination, Task Force for Global Health

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the report findings.