# References

1 Thompson M, Dana T, Bougatsos C, . Screening for hypertension in children and adolescents to prevent cardiovascular disease. Pediatrics. 2013 Mar;131(3):490–525. doi: 10.1542/peds.2012-3523. PMID: 27531686.23439904
2 Flynn JT, Kaelber DC, Baker-Smith CM, . Clinical practice guideline for screening and management of high blood pressure in children and adolescents. Pediatrics. 2017 Sep;140(3) doi: 10.1542/peds.2017-1904. PMID: 28755804.28755804
3 Whelton PK, Carey RM, Aronow WS, . 2017 ACC/AHA/AAPA/ABC/ACPM/AGS/APhA/ASH/ASPC/NMA/PCNA guideline for the prevention, detection, evaluation, and management of high blood pressure in adults: executive summary: a report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Circulation. 2018 Oct 23;138(17):e426–e83. doi: 10.1161/cir.0000000000000597. PMID: 30354655.30354655
4 National High Blood Pressure Education Program Working Group on High Blood Pressure in Children and Adolescents. The fourth report on the diagnosis, evaluation, and treatment of high blood pressure in children and adolescents. Pediatrics. 2004 Aug;114(2 Suppl 4th Report):555–76. PMID: 15286277.15286277
5 Expert panel on integrated guidelines for cardiovascular health and risk reduction in children and adolescents: summary report. Pediatrics. 2011 Dec;128: Suppl 5:S213–56. doi: 10.1542/peds.2009-2107C. PMID: 22084329.22084329
6 Hamdani G, Flynn JT, Becker RC, . Prediction of ambulatory hypertension based on clinic blood pressure percentile in adolescents. Hypertension. 2018 Oct;72(4):955–61. doi: 10.1161/hypertensionaha.118.11530. PMID: 29677048.30354718
7 Du T, Fernandez C, Barshop R, . 2017 pediatric hypertension guidelines improve prediction of adult cardiovascular outcomes. Hypertension. 2019 Jun;73(6):1217–23. doi: 10.1161/hypertensionaha.118.12469. PMID: 31006329.31006329
8 Flynn JT, Pierce CB, Miller ER, . Reliability of resting blood pressure measurement and classification using an oscillometric device in children with chronic kidney disease. J Pediatr. 2012;160(3):434–40.e1.22048052
9 Chen X, Wang Y. Tracking of blood pressure from childhood to adulthood: a systematic review and meta-regression analysis. Circulation. 2008;117(25):3171–80.18559702
10 Sun SS, Grave GD, Siervogel RM, . Systolic blood pressure in childhood predicts hypertension and metabolic syndrome later in life. Pediatrics. 2007 2007/02/01;119(2):237–46. doi: 10.1542/peds.2006-2543.17272612
11 Juhola J, Oikonen M, Magnussen CG, . Childhood physical, environmental, and genetic predictors of adult hypertension: the cardiovascular risk in young Finns study. Circulation. 2012;126(4):402–9.22718800
12 Juhola J, Magnussen CG, Viikari JSA, . Tracking of serum lipid levels, blood pressure, and body mass index from childhood to adulthood: The Cardiovascular Risk in Young Finns Study. J Pediatr. 2011 2011/10;159(4):584–90. doi: 10.1016/j.jpeds.2011.03.021.21514597
13 Kaelber DC, Liu W, Ross M, . Diagnosis and medication treatment of pediatric hypertension: a retrospective cohort study. Pediatrics. 2016 Dec;138(6) doi: 10.1542/peds.2016-2195. PMID: 27255757.27255757
14 Dobson CP, Eide M, Nylund CM. Hypertension prevalence, cardiac complications, and antihypertensive medication use in children. J Pediatr. 2015 Jul;167(1):92–7.e1. doi: 10.1016/j.jpeds.2015.04.016. PMID: 25953004.25957976
15 McNiece KL, Poffenbarger TS, Turner JL, . Prevalence of hypertension and pre-hypertension among adolescents. J Pediatr. 2007 Jun;150(6):640–4, 4.e1. doi: 10.1016/j.jpeds.2007.01.052. PMID: 17517252.17517252
16 Hansen ML, Gunn PW, Kaelber DC. Underdiagnosis of hypertension in children and adolescents. JAMA. 2007 Aug 22;298(8):874–9. doi: 10.1001/jama.298.8.874. PMID: 17712071.17712071
17 Roulet C, Bovet P, Brauchli T, . Secular trends in blood pressure in children: a systematic review. J Clin Hypertens (Greenwich). 2017 May;19(5):488–97. doi: 10.1111/jch.12955. PMID: 28097834.27982505
18 Flynn J, Zhang Y, Solar-Yohay S, . Clinical and demographic characteristics of children with hypertension. Hypertension. 2012 Oct;60(4):1047–54. doi: 10.1161/hypertensionaha.112.197525. PMID: 22892814.22892814
19 Rebholz CM, Friedman EE, Powers LJ, . Dietary protein intake and blood pressure: a meta-analysis of randomized controlled trials. Am J Epidemiol. 2012 Oct 1;176 Suppl 7:S27–43. doi: 10.1093/aje/kws245. PMID: 23640493.23035142
20 Bloomer LD, Nelson CP, Eales J, . Male-specific region of the Y chromosome and cardiovascular risk: phylogenetic analysis and gene expression studies. Arterioscler Thromb Vasc Biol. 2013 Jul;33(7):1722–7. doi: 10.1161/atvbaha.113.301608. PMID: 23411869.23640493
21 Sorof JM, Lai D, Turner J, . Overweight, ethnicity, and the prevalence of hypertension in school-aged children. Pediatrics. 2004 Mar;113(3 Pt 1):475–82. doi: 10.1542/peds.113.3.475. PMID: 14993537.14993537
22 Koebnick C, Black MH, Wu J, . High blood pressure in overweight and obese youth: implications for screening. J Clin Hypertens (Greenwich). 2013 Nov;15(11):793–805. doi: 10.1111/jch.12199. PMID: 24101758.24119024
23 Falkner B, Gidding SS, Ramirez-Garnica G, . The relationship of body mass index and blood pressure in primary care pediatric patients. J Pediatr. 2006 Feb;148(2):195–200. doi: 10.1016/j.jpeds.2005.10.030. PMID: 16492428.16492428
24 Lurbe E, Invitti C, Torro I, . The impact of the degree of obesity on the discrepancies between office and ambulatory blood pressure values in youth. J Hypertens. 2006 Aug;24(8):1557–64. doi: 10.1097/01.hjh.0000239291.32883.e3. PMID: 16877958.16877958
25 Parker ED, Sinaiko AR, Kharbanda EO, . Change in weight status and development of hypertension. Pediatrics. 2016 Mar;137(3):e20151662. doi: 10.1542/peds.2015-1662. PMID: 26908707.26908707
26 Skinner AC, Perrin EM, Moss LA, . Cardiometabolic risks and severity of obesity in children and young adults. N Engl J Med. 2015 Oct;373(14):1307–17. doi: 10.1056/NEJMoa1502821. PMID: 26422721.26422721
27 Javaheri S, Storfer-Isser A, Rosen CL, . Sleep quality and elevated blood pressure in adolescents. Circulation. 2008 Sep 2;118(10):1034–40. doi: 10.1161/circulationaha.108.766410. PMID: 18711015.18711015
28 Li AM, Au CT, Ng C, . A 4-year prospective follow-up study of childhood OSA and its association with BP. Chest. 2014 Jun;145(6):1255–63. doi: 10.1378/chest.13-1333. PMID: 24384690.24384690
29 Flynn JT, Alderman MH. Characteristics of children with primary hypertension seen at a referral center. Pediatr Nephrol. 2005;20(7):961–6. doi: 10.1007/s00467-005-1855-3.15864653
30 Gomes RS, Quirino IG, Pereira RM, . Primary versus secondary hypertension in children followed up at an outpatient tertiary unit. Pediatr Nephrol. 2011 Mar;26(3):441–7. doi: 10.1007/s00467-010-1712-x. PMID: 21174218.21174218
31 Baracco R, Kapur G, Mattoo T, . Prediction of primary vs secondary hypertension in children. J Clin Hypertens (Greenwich). 2012 May;14(5):316–21. doi: 10.1111/j.1751-7176.2012.00603.x. PMID: 22533658.22533658
32 Edvardsson VO, Steinthorsdottir SD, Eliasdottir SB, . Birth weight and childhood blood pressure. Curr Hypertens Rep. 2012 Dec;14(6):596–602. doi: 10.1007/s11906-012-0311-6. PMID: 23054892.23054892
33 Mhanna MJ, Iqbal AM, Kaelber DC. Weight gain and hypertension at three years of age and older in extremely low birth weight infants. J Neonatal Perinatal Med. 2015;8(4):363–9. doi: 10.3233/npm-15814080. PMID: 26836822.26836822
34 Gupta-Malhotra M, Banker A, Shete S, . Essential hypertension vs. secondary hypertension among children. Am J Hypertens. 2015 Jan;28(1):73–80. doi: 10.1093/ajh/hpu083. PMID: 24842390.24842390
35 Silverstein DM, Champoux E, Aviles DH, . Treatment of primary and secondary hypertension in children. Pediatr Nephrol. 2006 Jun;21(6):820–7. PMID: 16703375.16703375
36 Kaelber DC. Unlocking the power of big data. Population health management solutions. Entire populations. Entirely personal. Armonk, NY: IBM; 2017.
37 de Simone G, Devereux RB, Daniels SR, . Effect of growth on variability of left ventricular mass: assessment of allometric signals in adults and children and their capacity to predict cardiovascular risk. J Am Coll Cardiol. 1995;25(5):1056–62.7897116
38 O’Leary DH, Polak JF, Kronmal RA, . Carotid-artery intima and media thickness as a risk factor for myocardial infarction and stroke in older adults. Cardiovascular Health Study Collaborative Research Group. N Engl J Med. 1999;340(1):14–22.9878640
39 Mitchell GF, Hwang S-J, Vasan RS, . Arterial stiffness and cardiovascular events: the Framingham Heart Study. Circulation. 2010;121(4):505–11.20083680
40 Chio S-S, Urbina EM, Lapointe J, . Korotkoff sound versus oscillometric cuff sphygmomanometers: comparison between auscultatory and DynaPulse blood pressure measurements. J Am Soc Hypertens. 2011;5(1):12–20.21269907
41 Green M. Bright futures: Guidelines for health supervision of infants, children, and adolescents: ERIC; 1994.
42 Flynn JT, Daniels SR, Hayman LL, . Update: ambulatory blood pressure monitoring in children and adolescents: a scientific statement from the American Heart Association. Hypertension. 2014 May;63(5):1116–35. doi: 10.1161/hyp.0000000000000007. PMID: 23031153.24591341
43 Dionne JM, Harris KC, Benoit G, . Hypertension Canada’s 2017 guidelines for the diagnosis, assessment, prevention, and treatment of pediatric hypertension. Can J Cardiol. 2017 May;33(5):577–85. doi: 10.1016/j.cjca.2017.03.007. PMID: 28689331.28449829
44 Lurbe E, Agabiti-Rosei E, Cruickshank JK, . 2016 European Society of Hypertension guidelines for the management of high blood pressure in children and adolescents. J Hypertens. 2016 Oct;34(10):1887–920. doi: 10.1097/hjh.0000000000001039. PMID: 29406644.27467768
45 American Academy of Family Physicians. Clinical Preventive Service recommendation: hypertension, children and adolescents. Leawood, KS: American Academy of Family Physicians; 2013. https://www.aafp.org/patient-care/clinical-recommendations/all/hypertension.html. Accessed October 1, 2018.
46 Solutions for Public Health. Screening to prevent adverse outcomes from primary hypertension in children and young people: external review against programme appraisal criteria for the UK National Screening Committee. London, England: Council UNS; 2018. https://legacyscreening.phe.org.uk/hypertension-child
47 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001 Apr;20:(3 Suppl):21–35. PMID: 11306229.11306229
48 West SL, Gartlehner G, Mansfield AJ, . Comparative effectiveness review methods: clinical heterogeneity. 2010.
49 Agency for Healthcare Research and Quality. Methods guide for effectiveness and comparative effectiveness reviews. AHRQ Publication No. 10(14)-EHC063-EF. Bethesda, MD: Agency for Healthcare Research and Quality; January 2014. http://effectivehealthcare.ahrq.gov/
50 U.S. Preventive Services Task Force. Final research plan: high blood pressure in children and adolescents: screening. Rockville, MD: U.S. Preventive Services Task Force; 2018. https://www.uspreventiveservicestaskforce.org/Page/Document/final-research-plan/high-blood-pressure-in-children-and-adolescents-screening1. Accessed July 1, 2019.
51 Fixler DE, Laird WP. Validity of mass blood pressure screening in children. Pediatrics. 1983;72(4):459–63.6889060
52 Stergiou GS, Nasothimiou E, Giovas P, . Diagnosis of hypertension in children and adolescents based on home versus ambulatory blood pressure monitoring. J Hypertens. 2008 2008/08;26(8):1556–62. doi: 10.1097/hjh.0b013e328301c411.18622232
53 Stenn PG, Noce A, Buck C. A study of the labelling phenomenon in school children with elevated blood pressure. Clin Invest Med. 1981;4(3–4):179–81. PMID: 7337989.7337989
54 Gregoski MJ, Barnes VA, Tingen MS, . Breathing awareness meditation and lifeskills training programs influence upon ambulatory blood pressure and sodium excretion among African American adolescents. J Adolesc Health. 2011 2011/01;48(1):59–64. doi: 10.1016/j.jadohealth.2010.05.019.21185525
55 Gillman MW, Cook NR, Rosner B, . Identifying children at high risk for the development of essential hypertension. J Pediatr. 1993 1993/06;122(6):837–46. doi: 10.1016/s0022-3476(09)90005-1.8501557
56 Beckett LA, Rosner B, Roche AF, . Serial changes in blood pressure from adolescence into adulthood. Am J Epidemiol. 1992 1992/05/15;135(10):1166–77. doi: 10.1093/oxfordjournals.aje.a116217.1632426
57 Bao W, Threefoot SA, Srinivasan SR, . Essential hypertension predicted by tracking of elevated blood pressure from childhood to adulthood: The Bogalusa heart study*. Am J Hypertens. 1995 1995/07;8(7):657–65. doi: 10.1016/0895-7061(95)00116-7.7546488
58 Hoq S, Chen W, Srinivasan SR, . Childhood blood pressure predicts adult microalbuminuria in African Americans, but not in whites: the Bogalusa Heart Study. Am J Hypertens. 2002 Dec;15(12):1036–41. PMID: 12460698.12460698
59 Li S, Chen W, Srinivasan SR, . Childhood cardiovascular risk factors and carotid vascular changes in adulthood. JAMA. 2003 2003/11/05;290(17):2271. doi: 10.1001/jama.290.17.2271.14600185
60 Shear CL, Burke GL, Freedman DS, . Designation of children with high blood pressure—considerations on percentile cut points and subsequent high blood pressure: the Bogalusa Heart Study. Am J Epidemiol. 1987 1987/01;125(1):73–84. doi: 10.1093/oxfordjournals.aje.a114513.3788956
61 Xi B, Zhang T, Li S, . Can pediatric hypertension criteria be simplified? A prediction analysis of subclinical cardiovascular outcomes from the Bogalusa Heart Study. Hypertension. 2017 Apr;69(4):691–6. doi: 10.1161/hypertensionaha.116.08782. PMID: 29935098.28223474
62 Lauer RM, Clarke WR. Childhood risk factors for high adult blood pressure: the Muscatine Study. Pediatrics. 1989;84(4):633–41.2780125
63 Lauer RM, Mahoney LT, Clarke WR, . Childhood predictors for high adult blood pressure. Pediatr Clin North Am. 1993 1993/02;40(1):23–40. doi: 10.1016/s0031-3955(16)38478-4.8417407
64 Raitakari OT, Juonala M, Kähönen M, . Cardiovascular risk factors in childhood and carotid artery intima-media thickness in adulthood. JAMA. 2003 2003/11/05;290(17):2277. doi: 10.1001/jama.290.17.2277.14600186
65 Juonala M, Viikari JSA, Hutri-Kahonen N, . The 21-year follow-up of the cardiovascular risk in Young Finns Study: risk factor levels, secular trends and east-west difference. J Intern Med. 2004 2004/04;255(4):457–68. doi: 10.1111/j.1365-2796.2004.01308.x.15049880
66 Oikonen M, Nuotio J, Magnussen CG, . Repeated blood pressure measurements in childhood in prediction of hypertension in adulthood. Hypertension. 2016 Jan;67(1):41–7. doi: 10.1161/hypertensionaha.115.06395. PMID: 26134554.26553229
67 Aatola H, Koivistoinen T, Tuominen H, . Influence of child and adult elevated blood pressure on adult arterial stiffness: the cardiovascular risk in Young Finns Study. Hypertension. 2017 Sep;70(3):531–6. doi: 10.1161/hypertensionaha.117.09444. PMID: 28381095.28674036
68 Theodore RF, Broadbent J, Nagin D, . Childhood to early-midlife systolic blood pressure trajectories: early-life predictors, effect modifiers, and adult cardiovascular outcomes. Hypertension. 2015 Dec;66(6):1108–15. doi: 10.1161/hypertensionaha.115.05831. PMID: 24157221.26558818
69 Juhola J, Magnussen CG, Berenson GS, . Combined effects of child and adult elevated blood pressure on subclinical atherosclerosis: the International Childhood Cardiovascular Cohort Consortium. Circulation. 2013 Jul 16;128(3):217–24. doi: 10.1161/circulationaha.113.001614. PMID: 23637029.23780579
70 Koskinen J, Juonala M, Dwyer T, . Utility of different blood pressure measurement components in childhood to predict adult carotid intima-media thickness. Hypertension. 2019 Feb;73(2):335–41. doi: 10.1161/hypertensionaha.118.12225. PMID: 30580683.30580683
71 Dionne JM. Updated guideline may improve the recognition and diagnosis of hypertension in children and adolescents; review of the 2017 AAP Blood Pressure Clinical Practice Guideline. Curr Hypertens Rep. 2017 Oct 16;19(10):84. doi: 10.1007/s11906-017-0780-8. PMID: 26615340.29035421
72 Chobanian AV, Bakris GL, Black HR, . Seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. Hypertension (Dallas, Tex.: 1979). 2003;42(6):1206–52.
73 James PA, Oparil S, Carter BL, . 2014 evidence-based guideline for the management of high blood pressure in adults: report from the panel members appointed to the Eighth Joint National Committee (JNC 8). JAMA. 2014 Feb 5;311(5):507–20. doi: 10.1001/jama.2013.284427. PMID: 24352797.24352797
74 Duran-Cantolla J, Aizpuru F, Martinez-Null C, . Obstructive sleep apnea/hypopnea and systemic hypertension. Sleep Med Rev. 2009 Oct;13(5):323–31. doi: 10.1016/j.smrv.2008.11.001. PMID: 19515590.19515590
75 Burrello J, Erhardt EM, Saint-Hilary G, . Pharmacological treatment of arterial hypertension in children and adolescents: A network meta-analysis. J Hypertens. 2019;37:e178.
76 Batisky DL, Sorof JM, Sugg J, . Efficacy and safety of extended release metoprolol succinate in hypertensive children 6 to 16 years of age: a clinical trial experience. J Pediatr. 2007 2007/02;150(2):134–9.e1. doi: 10.1016/j.jpeds.2006.09.034.17236889
77 Trachtman H, Hainer JW, Sugg J, . Efficacy, safety, and pharmacokinetics of candesartan cilexetil in hypertensive children aged 6 to 17 years. J Clin Hypertens. 2008 2008/10;10(10):743–50. doi: 10.1111/j.1751-7176.2008.00022.x.
78 Trachtman H, Frank R, Mahan JD, . Clinical trial of extended-release felodipine in pediatric essential hypertension. Pediatr Nephrol. 2003 Jun;18(6):548–53. doi: 10.1007/s00467-003-1134-0. PMID: 12700955.12700955
79 Wells TG, Portman R, Norman P, . Safety, efficacy, and pharmacokinetics of telmisartan in pediatric patients with hypertension. Clin Pediatr (Phila). 2010 2010/08/19;49(10):938–46. doi: 10.1177/0009922810363609.20724342
80 Sorof JM, Cargo P, Graepel J, . β-Blocker/thiazide combination for treatment of hypertensive children: a randomized double-blind, placebo-controlled trial. Pediatr Nephrol. 2002 2002/05/01;17(5):345–50. doi: 10.1007/s00467-002-0851-0.12042891
81 Li JS, Berezny K, Kilaru R, . Is the extrapolated adult dose of fosinopril safe and effective in treating hypertensive children? Hypertension. 2004 2004/09;44(3):289–93. doi: 10.1161/01.hyp.0000138069.68413.f0.15262902
82 Wells T, Frame V, Soffer B, . A double-blind, placebo-controlled, dose-response study of the effectiveness and safety of enalapril for children with hypertension. J Clin Pharmacol. 2002 2002/08;42(8):870–80. doi: 10.1177/009127002401102786.12162469
83 Soffer B, Zhang Z, Miller K, . A double-blind, placebo-controlled, dose-response study of the effectiveness and safety of lisinopril for children with hypertension. Am J Hypertens. 2003 Oct;16(10):795–800. PMID: 14553956.14553956
84 Shahinfar S, Cano F, Soffer B, . A double-blind, dose-response study of losartan in hypertensive children. Am J Hypertens. 2005 2005/02;18(2):183–90. doi: 10.1016/j.amjhyper.2004.09.009.15752945
85 Hazan L, Hernández Rodriguez OA, Bhorat AaE, . A double-blind, dose-response study of the efficacy and safety of olmesartan medoxomil in children and adolescents with hypertension. Hypertension. 2010 2010/06;55(6):1323–30. doi: 10.1161/hypertensionaha.109.147702.20385971
86 Li JS, Flynn JT, Portman R, . The efficacy and safety of the novel aldosterone antagonist eplerenone in children with hypertension: a randomized, double-blind, dose-response study. J Pediatr. 2010 2010/08;157(2):282–7. doi: 10.1016/j.jpeds.2010.02.042.20400095
87 Wells T, Blumer J, Meyers KEC, . Effectiveness and safety of valsartan in children aged 6 to 16years with hypertension. J Clin Hypertens (Greenwich). 2011;13(5):357–65.21545397
88 Flynn JT, Newburger JW, Daniels SR, . A randomized, placebo-controlled trial of amlodipine in children with hypertension. J Pediatr. 2004 2004/09;145(3):353–9. doi: 10.1016/j.jpeds.2004.04.009.15343191
89 Berenson GS, Voors AW, Webber LS, . A model of intervention for prevention of early essential hypertension in the 1980s. Hypertension. 1983 1983/01;5(1):41–54. doi: 10.1161/01.hyp.5.1.41.6848468
90 Couch SC, Saelens BE, Levin L, . The efficacy of a clinic-based behavioral nutrition intervention emphasizing a DASH-type diet for adolescents with elevated blood pressure. J Pediatr. 2008 2008/04;152(4):494–501. doi: 10.1016/j.jpeds.2007.09.022.18346503
91 Son WM, Sung KD, Bharath LP, . Combined exercise training reduces blood pressure, arterial stiffness, and insulin resistance in obese prehypertensive adolescent girls. Clin Exp Hypertens. 2017;39(6):546–52. doi: 10.1080/10641963.2017.1288742. PMID: 28336112.28590143
92 Hansen HS, Froberg K, Hyldebrandt N, . A controlled study of eight months of physical training and reduction of blood pressure in children: the Odense schoolchild study. BMJ. 1991 1991/09/21;303(6804):682–5. doi: 10.1136/bmj.303.6804.682.1912915
93 Howe PRC, Cobiac L, Smith RM. Lack of effect of short-term changes in sodium intake on blood pressure in adolescent schoolchildren. J Hypertens. 1991 1991/02;9(2):181–6. doi: 10.1097/00004872-199102000-00014.1849536
94 Sinaiko AR, Gomez-Marin O, Prineas RJ. Effect of low sodium diet or potassium supplementation on adolescent blood pressure. Hypertension. 1993 1993/06;21(6_pt_2):989–94. doi: 10.1161/01.hyp.21.6.989.8505112
95 Ewart CK, Harris WL, Iwata MM, . Feasibility and effectiveness of school-based relaxation in lowering blood pressure. Health Psychol. 1987;6(5):399–416. doi: 10.1037//0278-6133.6.5.399.3315645
96 Berenson GS, Shear CL, Chiang YK, . Combined low-dose medication and primary intervention over a 30-month period for sustained high blood pressure in childhood. Am J Med Sci. 1990 1990/02;299(2):79–86. doi: 10.1097/00000441-199002000-00001.2301454
97 Pepe MS, Janes H, Longton G, . Limitations of the odds ratio in gauging the performance of a diagnostic, prognostic, or screening marker. Am J Epidemiol. 2004 May 1;159(9):882–90. doi: 10.1093/aje/kwh101. PMID: 15105181.15105181
98 Smith PB, Li JS, Murphy MD, . Safety of placebo controls in pediatric hypertension trials. Hypertension. 2008 2008/04;51(4):829–33. doi: 10.1161/hypertensionaha.107.104950.18285612
99 Baker-Smith CM, Benjamin DK, Califf RM, . Cough in pediatric patients receiving angiotensin-converting enzyme inhibitor therapy or angiotensin receptor blocker therapy in randomized controlled trials. Clin Pharmacol Ther. 2010;87(6):668–71. doi: 10.1038/clpt.2009.231.20130570
100 Group SR. A randomized trial of intensive versus standard blood-pressure control. N Engl J Med. 2015;373(22):2103–16.26551272
101 O’Brien E, Parati G, Stergiou G, . European Society of Hypertension position paper on ambulatory blood pressure monitoring. J Hypertens. 2013 Sep;31(9):1731–68. doi: 10.1097/HJH.0b013e328363e964. PMID: 24029863.24029863
102 National Clinical Guideline Centre. National Institute for Health and Clinical Excellence: guidance. Hypertension: the clinical management of primary hypertension in adults: update of clinical guidelines 18 and 34. London: Royal College of Physicians (UK), National Clinical Guideline Centre; 2011.
103 Wuhl E, Witte K, Soergel M, . Distribution of 24-h ambulatory blood pressure in children: normalized reference values and role of body dimensions. J Hypertens. 2002 Oct;20(10):1995–2007. PMID: 12359978.12359978
104 Soergel M, Kirschstein M, Busch C, . Oscillometric twenty-four-hour ambulatory blood pressure values in healthy children and adolescents: a multicenter trial including 1141 subjects. J Pediatr. 1997;130(2):178–84.9042117
105 Stergiou GS, Karpettas N, Kapoyiannis A, . Home blood pressure monitoring in children and adolescents: a systematic review. J Hypertens. 2009 Oct;27(10):1941–7. doi: 10.1097/HJH.0b013e32832ea93e. PMID: 19542894.19542894
106 Hanevold C, Waller J, Daniels S, . The effects of obesity, gender, and ethnic group on left ventricular hypertrophy and geometry in hypertensive children: a collaborative study of the International Pediatric Hypertension Association. Pediatrics. 2004 Feb;113(2):328–33. PMID: 14754945.14754945
107 Brady TM, Fivush B, Flynn JT, . Ability of blood pressure to predict left ventricular hypertrophy in children with primary hypertension. J Pediatr. 2008;152(1):73–8, 8.e1.18154904
108 Hodis HN, Mack WJ, LaBree L, . The role of carotid arterial intima-media thickness in predicting clinical coronary events. Ann Intern Med. 1998 Feb 15;128(4):262–9. doi: 10.7326/0003-4819-128-4-199802150-00002. PMID: 9471928.9471928
109 Malcolm DD, Burns TL, Mahoney LT, . Factors affecting left ventricular mass in childhood: the Muscatine Study. Pediatrics. 1993 Nov;92(5):703–9. PMID: 8414859.8414859
110 Urbina EM, Khoury PR, McCoy C, . Cardiac and vascular consequences of pre-hypertension in youth. J Clin Hypertens (Greenwich). 2011;13(5):332–42.21545394
111 Stabouli S, Kotsis V, Rizos Z, . Left ventricular mass in normotensive, prehypertensive and hypertensive children and adolescents. Pediatr Nephrol. 2009 Aug;24(8):1545–51. doi: 10.1007/s00467-009-1165-2. PMID: 19444486.19444486
112 Kollias A, Dafni M, Poulidakis E, . Out-of-office blood pressure and target organ damage in children and adolescents: a systematic review and meta-analysis. J Hypertens. 2014 Dec;32(12):2315–31; discussion 31. doi: 10.1097/hjh.0000000000000384. PMID: 24097285.25304469
113 Ayer JG, Harmer JA, Nakhla S, . HDL-cholesterol, blood pressure, and asymmetric dimethylarginine are significantly associated with arterial wall thickness in children. Arterioscler Thromb Vasc Biol. 2009 Jun;29(6):943–9. doi: 10.1161/atvbaha.109.184184. PMID: 19359663.19359663
114 Matteucci MC, Chinali M, Rinelli G, . Change in cardiac geometry and function in CKD children during strict BP control: a randomized study. Clin J Am Soc Nephrol. 2013 Feb;8(2):203–10. doi: 10.2215/cjn.08420811. PMID: 22227459.23124781
115 Litwin M, Niemirska A, Sladowska-Kozlowska J, . Regression of target organ damage in children and adolescents with primary hypertension. Pediatric nephrology (Berlin, Germany). 2010;25(12):2489–99.
116 Sinaiko AR, Jacobs DR, Jr., Woo JG, . The International Childhood Cardiovascular Cohort (i3C) consortium outcomes study of childhood cardiovascular risk factors and adult cardiovascular morbidity and mortality: design and recruitment. Contemp Clin Trials. 2018 Jun;69:55–64. doi: 10.1016/j.cct.2018.04.009. PMID: 29684544.29684544
117 Leiba A, Fishman B, Twig G, . Association of adolescent hypertension with future end-stage renal disease. JAMA Intern Med. 2019 Feb 25 doi: 10.1001/jamainternmed.2018.7632. PMID: 30801616.30801616
118 Leiba A, Twig G, Levine H, . Hypertension in late adolescence and cardiovascular mortality in midlife: a cohort study of 2.3 million 16- to 19-year-old examinees. Pediatr Nephrol. 2016 Mar;31(3):485–92. doi: 10.1007/s00467-015-3240-1. PMID: 26508439.26508439
119 Gray L, Lee IM, Sesso HD, . Blood pressure in early adulthood, hypertension in middle age, and future cardiovascular disease mortality: HAHS (Harvard Alumni Health Study). J Am Coll Cardiol. 2011 Nov 29;58(23):2396–403. doi: 10.1016/j.jacc.2011.07.045. PMID: 22115646.22115646
120 Flynn JT, Meyers KEC, Neto JP, . Efficacy and safety of the angiotensin receptor blocker valsartan in children with hypertension aged 1 to 5 years. Hypertension. 2008;52(2):222–8.18591457
121 Din-Dzietham R, Liu Y, Bielo MV, . High blood pressure trends in children and adolescents in national surveys, 1963 to 2002. Circulation. 2007 Sep 25;116(13):1488–96. doi: 10.1161/circulationaha.106.683243. PMID: 17846287.17846287
122 Freedman DS, Goodman A, Contreras OA, . Secular trends in BMI and blood pressure among children and adolescents: the Bogalusa Heart Study. Pediatrics. 2012 Jul;130(1):e159–66. doi: 10.1542/peds.2011-3302. PMID: 22665416.22665416
123 Khang YH, Lynch JW. Exploring determinants of secular decreases in childhood blood pressure and hypertension. Circulation. 2011 Jul 26;124(4):397–405. doi: 10.1161/circulationaha.110.014399. PMID: 21730305.21730305
124 Lin FH, Chu NF, Hsieh AT. The trend of hypertension and its relationship to the weight status among Taiwanese young adolescents. J Hum Hypertens. 2012 Jan;26(1):48–55. doi: 10.1038/jhh.2010.121. PMID: 21248777.21248777
125 McCrindle BW. Assessment and management of hypertension in children and adolescents. Nat Rev Cardiol. 2010 Mar;7(3):155–63. PMID: 20065950.20065950
126 Xi Y, Jiang X, Li R, . The levels of human milk microRNAs and their association with maternal weight characteristics. Eur J Clin Nutr. 2016 Apr;70(4):445–9. doi: 10.1038/ejcn.2015.168. PMID: 27141061.26486303
127 Feber J, Litwin M. Blood pressure (BP) assessment-from BP level to BP variability. Pediatr Nephrol. 2016 Jul;31(7):1071–9. doi: 10.1007/s00467-015-3161-z. PMID: 28569934.26201477
128 Dwyer T, Sun C, Magnussen CG, . Cohort Profile: the International Childhood Cardiovascular Cohort (i3C) consortium. Int J Epidemiol. 2013 Feb;42(1):86–96. doi: 10.1093/ije/dys004. PMID: 22434861.22434861
129 Ruggenenti P, Cravedi P, Chianca A, . Achieving remission of proteinuria in childhood CKD. Pediatr Nephrol. 2017 Feb;32(2):321–30. doi: 10.1007/s00467-016-3495-1. PMID: 27745591.27704256
130 Chung H, Lee JH, Park E, . Long-term outcomes of pediatric renovascular hypertension. Kidney Blood Press Res. 2017;42(3):617–27. doi: 10.1159/000481549. PMID: 28787728.28950261
131 Alexander A, Richmond L, Geary D, . Outcomes of percutaneous transluminal angioplasty for pediatric renovascular hypertension. J Pediatr Surg. 2017 Mar;52(3):395–9. doi: 10.1016/j.jpedsurg.2016.08.011. PMID: 26895218.27634559
132 Kari JA, Roebuck DJ, McLaren CA, . Angioplasty for renovascular hypertension in 78 children. Arch Dis Child. 2015 May;100(5):474–8. doi: 10.1136/archdischild-2013-305886. PMID: 25743698.25527520
133 Lee Y, Lim YS, Lee ST, . Pediatric renovascular hypertension: treatment outcome according to underlying disease. Pediatr Int. 2018 Mar;60(3):264–9. doi: 10.1111/ped.13491. PMID: 28994226.29281158
134 Padua LM, Garcia LC, Rubira CJ, . Stent placement versus surgery for coarctation of the thoracic aorta. Cochrane Database Syst Rev. 2012 May 16(5):Cd008204. doi: 10.1002/14651858.CD008204.pub2. PMID: 24151290.22592728
135 Lillitos PJ, Nassar MS, Tibby SM, . Is the medical treatment for arterial hypertension after primary aortic coarctation repair related to age at surgery? A retrospective cohort study. Cardiol Young. 2017 Nov;27(9):1701–7. doi: 10.1017/s1047951117001019. PMID: 27521927.28595675
136 Meadows J, Minahan M, McElhinney DB, . Intermediate outcomes in the prospective, multicenter Coarctation of the Aorta Stent Trial (COAST). Circulation. 2015 May 12;131(19):1656–64. doi: 10.1161/circulationaha.114.013937. PMID: 25487173.25869198
137 Morgan GJ, Lee KJ, Chaturvedi R, . Systemic blood pressure after stent management for arch coarctation implications for clinical care. JACC Cardiovasc Interv. 2013 Feb;6(2):192–201. doi: 10.1016/j.jcin.2012.10.009. PMID: 23446318.23428013
138 Rumman RK, Nickel C, Matsuda-Abedini M, . Disease beyond the arch: a systematic review of middle aortic syndrome in childhood. Am J Hypertens. 2015 Jul;28(7):833–46. doi: 10.1093/ajh/hpu296. PMID: 26969751.25631383
139 Porras D, Stein DR, Ferguson MA, . Midaortic syndrome: 30 years of experience with medical, endovascular and surgical management. Pediatr Nephrol. 2013 Oct;28(10):2023–33. doi: 10.1007/s00467-013-2514-8. PMID: 23774056.23775038
140 Romero M, Kapur G, Baracco R, . Treatment of hypertension in children with catecholamine-secreting tumors: a systematic approach. J Clin Hypertens (Greenwich). 2015 Sep;17(9):720–5. doi: 10.1111/jch.12571. PMID: 24345633.26010736
141 Al Khalifah RA, Florez ID, Dennis B, . Metformin or oral contraceptives for adolescents with polycystic ovarian syndrome: a meta-analysis. Pediatrics. 2016 May;137(5) doi: 10.1542/peds.2015-4089. PMID: 23363471.23363471
142 Flynn JT, Newburger JW, Daniels SR, . A randomized, placebo-controlled trial of amlodipine in children with hypertension. J Pediatr. 2004;145(3):353–9.15343191