# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Iris Mabry-Hernandez, MD, MPH, AHRQ Medical Officer; Tracy Wolf, MD, MPH, AHRQ Associate Scientific Director; Quyen Ngo-Metzger, MD, MPH, Professor at Kaiser Permanente School of Medicine; current members of the U.S. Preventive Services Task Force; expert peer reviewers Alex Kemper, MD, MPH, Callie Brown, MD, MPH, and Joseph T. Flynn, MD, MS; three Federal partner reviewers; and RTI International–University of North Carolina EPC staff Carol Woodell, BSPH; B. Lynn Whitener, DrPH; Sharon Barrell, MA; Rachel Clark, MPH; and Loraine Monroe.