# Abbreviations

AAP: American Academy of Pediatrics
ABPM: ambulatory blood pressure monitoring
ACE: angiotensin converting enzyme
ADAPT: Dietary/Exercise Alteration Program Trial
AE: adverse event
AHA: American Heart Association
AHRQ: Agency for Health Research & Quality
ARBs: angiotensin II receptor blockers
AUC: area under curve
B/HT: bisoprolol fumarate/hydrochlorothiazide
BAM: breathing awareness meditation
BMI: body mass index
BP: blood pressure
BPM: beats per minute
CIMT: carotid intima-media thickness
CINCH: Candesartan in Children with Hypertension
CKD: chronic kidney disease
CQ: contextual question
DASH: Dietary Approaches to Stop Hypertension
DBP: diastolic blood pressure
DM: diabetes mellitus
ECG: electrocardiograph
EPC: Evidence-based Practice Center
ER: extended release
FDA: Food and Drug Administration
HR: hazard ratio
IMT: intima media thickness
ITT: intent to treat
KQ: key question
LFT: liver function test
mmHg: millimeters of mercury
NA: not applicable
NR: not reported
PMR: progressive muscle relaxation
PPV: positive predictive value
PWV: pulse wave velocity
RCT: randomized, controlled trial
REF: reference
RR: relative risk
SBP: systolic blood pressure
SD: standard deviation
US: United States
USPSTF: United States Preventive Services Task Force
vs.: versus