# Chapter 4 Discussion

This chapter begins with a summary of review findings for each KQ. Following those sections, we present limitations of the evidence and the review and end with conclusions.

## Summary of Evidence

Table 2 details the summary of the evidence for this update review. Our review did not identify any studies that addressed the overarching question (KQ 1) of whether screening for hypertension in children and adolescents compared with no screening reduces the risk of adverse health outcomes related to hypertension during childhood or adulthood. In addition, we did not find any studies that addressed screening for secondary hypertension in asymptomatic children. For diagnostic test accuracy of blood pressure screening (KQ 2), one fair study (n=247) reported a sensitivity of office-based measurements of 81.6 percent (CI not reported) with a specificity of 70.3 percent (CI not reported) compared with ABPM as a reference standard.

For adverse events of screening (KQ 3), we did not identify any eligible studies.

For the association between abnormal blood pressure in childhood and abnormal blood pressure or intermediate outcomes in adulthood (KQ 4), 20 studies, all observational, provided results from nine databases. The studies were characterized by substantial heterogeneity in the selection of thresholds for childhood and adult hypertension. Despite the heterogeneity, studies generally reported ORs (ranging from 1.1 to 4.5), RRs (ranging from 1.45 to 3.60), and HRs (ranging from 2.8 to 3.2), suggesting an association between childhood hypertension and abnormal blood pressure or intermediate cardiovascular outcomes in adulthood. However, the results were much less consistent and favorable using a different measure of the predictive accuracy such as sensitivity or PPV.^97^ The results suggested sensitivity ranging from 0.0 to 0.89 (with most values below 0.6) and PPVs ranging from 0.05 to 0.97 (again with most values below 0.6). These results suggest low SOE of association between abnormal blood pressure in childhood and abnormal blood pressure in adulthood.

Results for the association between abnormal blood pressure in childhood and intermediate cardiovascular outcomes in adulthood, specifically CIMT, were consistent with an OR of 1.24 (95% CI, 1.13 to 1.37) and HRs ranging from 2.03 to 3.07.

For the effectiveness of treatment of hypertension in children and adolescents (KQ 5), 13 fair-quality placebo-controlled RCTs and one meta-analysis evaluated the efficacy of various pharmacological treatments. All studies reported greater reductions in SBP and DBP measurements in participants who received pharmacological treatments compared with those treated with placebo. The magnitude of reductions, however, varied, and not all differences reached statistical significance. Pooled reductions of SBP were −4.38 mmHg (95% CI, −2.16 to −7.27) for ACE inhibitors, −3.07 mmHg (95% CI, −1.44 to −4.99) for ARBs, −3.20 mmHg (95% CI, +2.23 to −8.69) for beta blockers, −3.10 mmHg (95% CI, +0.45 to −6.52) for calcium channel blockers, and −0.12 mmHg (95% CI, +3.46 to −3.69) for mineralocorticoid receptor antagonists.

The SOE for reduction was moderate; studies, however, were limited to 2 to 4 weeks of followup.^76–80^ A combination of drug treatment and several lifestyle components provided low strength evidence of reduction of blood pressure after 6 months (SBP, −7.6 mmHg; DBP,−6.9 mmHg).^89^ Likewise, two RCTs provided low strength evidence that physical exercise reduces SBP during 3 (−8.3 mmHg) and 8 (−4.9 mmHg) months.^91,^ ^92^ Only a study lasting 8 months reported a significant decrease in DBP (−3.8 mmHg vs. not reported).^92^ Low strength evidence showed that a DASH diet did not provide a lasting reduction of blood pressure.^90^ Two RCTs provided moderate strength evidence that a low-sodium diet did not achieve a reduction of blood pressure in children.^93,^ ^94^ Likewise, low strength evidence indicated that progressive muscle relaxation did not achieve any significant changes in SBP or DBP.^95^

No eligible studies addressed the effectiveness of treating childhood hypertension to reduce blood pressure or other intermediate outcomes (KQ 6) or adverse health outcomes (KQ 7) in adulthood.

For harms of treatment (KQ 8), six fair-quality RCTs^76–81,^ ^89,^ ^96^ reported similar risks of adverse events between various pharmacological treatments (beta blocker, calcium channel blockers, ACE inhibitors, or ARBs) and placebo during 2 to 4 weeks of treatment. We assessed the SOE as low for these outcomes. No long-term studies on risk of harms were available.

A pooled analysis of FDA data did not meet our inclusion criteria because it was not based on a systematic search of the literature but provides an otherwise comprehensive assessment of the risks of harms of pharmacological treatments in children and adolescents.^98^ This study was an individual patient data meta-analysis of 10 RCTs that were submitted to FDA between 1998 and 2005.^98^ Overall, the pooled analysis included data on 1,707 children (6 to 17 years of age; 55% white; 62% male) treated with amlodipine, benazepril, enalapril, felodipine, fosinopril, irbesartan, lisinopril, losartan, quinapril, ramipril, or placebo. All trials excluded children with severe hypertension or renal disease. The placebo-controlled phases of these 10 trials ranged from 2 weeks to 4 weeks. Quinapril and ramipril are currently not FDA approved for use in children.

Authors pooled event rates for all active treatments as a class compared with placebo. Overall, proportions of children with adverse events were similar between active treatments and placebo (39.3% vs. 38.4%; p=0.72). In addition, risks for specific adverse events were similar between active treatments and placebo, including gastrointestinal events (6.9% vs. 6.40%), infections (5.2% vs. 6.0%), respiratory disorders (13.0% vs. 11.1%), or general disorders (11.7% vs. 11.8%).

A subgroup analysis of this study focused on cough in children treated with ACE inhibitors or ARBs.^99^ Based on data of 1, 299 subjects and a followup of 2 to 4 weeks, the risk of cough was similar between children treated with ACE inhibitors (3.2%), ARBs (1.8%), or placebo (2.5%; p=0.86 for active drugs vs. placebo).

## Limitations

The main limitation of the evidence base is the lack of research directly assessing the effectiveness of screening for hypertension to reduce adverse outcomes of hypertension in childhood and adulthood. In addition, the indirect evidence pathway from screening to improvement of health outcomes is scarce, of limited applicability, or entirely missing for some steps of the pathway. In the context of this limited evidence base on the direct and indirect pathway, the evidence on the association between abnormal blood pressure in childhood and outcomes in adulthood takes on greater weight.

We found only one study on the diagnostic test accuracy of blood pressure measurements to detect hypertension, which has some limitations regarding applicability.

Studies reporting on the association between abnormal blood pressure in childhood and abnormal blood pressure or other intermediate outcomes in adulthood were very heterogeneous (although the results were consistent in demonstrating an association with abnormal blood pressure in adulthood). Other limitations included the variations in underlying prevalence and the use of indirect measures of predictive accuracy.

Overall, treatment studies indicate efficacy and good tolerability of pharmacological interventions, but these studies were small, of very short duration (2 to 4 weeks), and mostly limited to participants with primary hypertension. Moreover, none of the drugs were evaluated in more than one study. The magnitude of the antihypertensive effects varied across agents and was not always significantly different from placebo. The mean age of children in these studies ranged from age 12 to 14 years; the generalizability of results to younger children or children with secondary hypertension is unknown.

Because of small sample sizes and short study durations, the available pharmacological treatment studies cannot adequately determine the risks of rare but serious adverse events that are known from adult trials such as angioedema, hyperkalemia, or adverse pregnancy outcomes with ACE inhibitors, interactions with drugs or foods that change cytochrome P 450 metabolism of calcium channel blockers, or bronchoconstriction with beta blockers. We identified no studies reporting on harms associated with lifestyle interventions.

The main limitation of our methodological approach is that we limited literature searches to English-language studies. This strategy might have missed studies in Hispanic children who have a higher risk for obesity and primary hypertension than non-Hispanic White children.

In addition to the dearth of evidence to answer the KQs, this topic poses several other challenges that relate to diagnostic imprecision and the long lead time of adverse health outcomes of hypertension. First, thresholds and classifications of hypertension in children are based on normative values and not on health outcomes like in adults. Although the recent update of the AAP clinical practice guideline revised normative blood pressure values to reflect data of healthy, normal-weight children,^2^ it is still unclear whether such distribution-based thresholds can adequately distinguish between children with and without hypertension. This guideline also modified the classification of hypertension in adolescents to make the recommendations consistent with those of the American College of Cardiology/AHA guidelines for adults.^3^ Recommendations for adults, however, were influenced by the SPRINT (Systolic Blood Pressure Intervention Trial) study, which enrolled participants older than 50 years of age with an increased risk of CVD.^100^ It is unclear how applicable findings of this trial are to adolescents at a much lower cardiovascular risk.

Second, the exact diagnostic workup in children who screen positive is not well established. In adults, ABPM and home monitoring of blood pressure are well-established methods of detecting white-coat hypertension and masked hypertension. These methods of measuring blood pressure have stronger associations with target organ damage and cardiovascular events than office-based measurements.^101,^ ^102^ In children, ABPM is recommended by the AAP to confirm office-based measurements. Normative values and thresholds for hypertension for ABPM, however, are not well established in children and adolescents. Currently, reference values by the German Working Group on Pediatric Hypertension,^103,^ ^104^ which were established on 1,141 children in the late 1990s, are still considered the best available standard. The applicability to a U.S. setting, however, might be limited because the cohort included only Central European white children.

The evidence on the accuracy and reliability of home blood pressure monitoring as an alternative to ABPM in children and adolescents is scarce.^105^ Overall, the varying standards of diagnostic workup to confirm or dismiss hypertension in children who screen positive might lead to additional unnecessary diagnostic procedures such as renal ultrasound, urinalysis, blood lab tests, and others to eventually rule out secondary hypertensions.

Third, although target organ damage because of elevated blood pressure in children is quite common, a causal association with cardiovascular events later in life is difficult to establish.^106,^ ^107^ In adults, target organ damage such as such left ventricular hypertrophy, CIMT, or arterial stiffness has been associated with an increased risk of cardiovascular events.^108^ In children, studies also reported higher risks of left ventricular hypertrophy,^109–111^ CIMT,^112^ arterial wall stiffness,^113^ or urine albumin excretion.^112^ In addition, treatment studies showed the potential of reducing left ventricular mass in hypertensive children.^114,^ ^115^ Nevertheless, the association between these intermediate outcomes and cardiovascular outcomes is not established in children and has to be inferred from indirect evidence in adult populations. Because studies assessing health outcomes in children or adults are challenging because of the long followup periods that are required to reliably assess cardiovascular outcomes, indices of preclinical organ damage are currently still the best available evidence.

The ongoing International Childhood Cardiovascular Cohort Consortium (i3C) Outcomes study might be able to provide more solid and more direct evidence regarding the association between childhood hypertensions and adult cardiovascular events.^116^ This study uses data on risk factors for heart disease from long-term observational studies in school children in the United States (Bogalusa, Muscatine, Cincinnati, Minneapolis), Finland, and Australia. Researchers will contact individuals (n=41,006 in total) who participated in the childhood studies to ask them to complete a heart health survey. The study will then assess whether there is link between certain risk factors for heart disease (overweight and obesity, high blood pressure, high cholesterol, smoking) measured during childhood and adolescence and cardiovascular events (coronary artery disease, myocardial infarction, angina pectoris, heart failure, stroke, transient ischemic attack, and aneurysm) in middle-aged adults.

Large retrospective studies (presented in CQ 3) reported an association between hypertension during adolescence and cerebrovascular mortality^116–119^ and between hypertension during adolescence and end-stage renal disease.^117^

## Future Research Needs

Given the ethical considerations about withholding a screening intervention that is commonly used in clinical practice, an adequately powered RCT or other controlled prospective study that compares long-term health outcomes of screened and unscreened children is unlikely. Future research, therefore, needs to establish a stronger evidence base for intermediate links between screening for hypertension and relevant outcomes during childhood and adulthood. Specifically, it should determine the diagnostic test accuracy of blood pressure measurements with aneroid sphygmomanometers or oscillometric automated devices and establish clear thresholds for hypertension for 24-hour ambulatory monitoring. There is also a pressing need for long-term treatment studies that assess benefits and harms of pharmacological treatments for hypertension in children and adolescents. Such studies should have long-term followup of several months or years for different ages because benefits and harms of treatments may be age dependent and hypertension in children may be self-limiting. Epidemiological research needs to address the long-term natural history of hypertension in children, specifically focused on spontaneous resolution of hypertension. The use of a new threshold for determining abnormal blood pressure in childhood has created some uncertainty related to diagnosis and prognosis. Epidemiological studies could substantially add to the evidence base with relatively low effort by applying new thresholds to existing datasets and testing the validity of these thresholds.

## Conclusions

We identified no direct evidence that compared screening with no screening in asymptomatic children and adolescents. Epidemiological studies indicate an association between hypertension in childhood and adolescence and hypertension in adulthood. Large longitudinal cohort studies also provide evidence that hypertension in adolescents and young adults is associated with end-stage renal disease (ESRD) and mortality from cerebrovascular events during adulthood. Despite the evidence indicating associations between childhood or adolescent hypertension and adult hypertension, intermediate cardiovascular outcomes, or health outcomes, the evidence on other parts of the evidence chain supporting screening in unselected populations is weak. The proportion of spontaneous resolution of hypertension in children and the long-term benefits and harms of treatment, however, remain unclear. The evidence is also inconclusive whether the diagnostic accuracy of blood pressure measurements is adequate for screening asymptomatic children and adolescents in primary care. Short-term pharmacological treatments appear effective and safe but no evidence with a followup of more than 4 weeks is available.

No evidence exists to determine whether screening for hypertension is effective in identifying children with secondary hypertension who are asymptomatic. Most treatment studies excluded children with secondary hypertension.