# Chapter 3 Results

In the following sections, we summarize the evidence by KQ. Appendix D presents quality rating criteria and quality ratings for each eligible study; Appendix E provides detailled evidence tables for each included study. Table 2 summarizes SOE ratings for relevant outcomes and presents a summary of findings.

Table 2 Summary of Evidence for Screening for Hypertension in Children and Adolescents

Key Question | No. of Studies and Design (k);; No. of Participants (N) | Summary of Findings | Consistency/Precision | Other Limitations | EPC Assessment of Strength of Evidence | Applicability
KQ 1 Direct benefits of screening | k=0
KQ 2 Diagnostic test accuracy | k=1 cross-sectional study^6^; N=247 | Sensitivity of office-based BP measurements: 81.6%; Specificity: 70.3% | Consistency unknown (single study body of evidence)/imprecise | Body of evidence limitations: Moderate; Reporting bias: Not detected | LOW for diagnostic test accuracy measures | Limited applicability; only two office-based measurements: population included children with known abnormal blood pressure
KQ 3 Harms of screening | k=0
KQ 4 Association between high BP in children and high BP or intermediate outcomes in adults | k=20 publications^10–12,^ ^55–69^ describing 9 databases, all observational,; N>9,687 | Low to moderate sensitivity and PPV for relationship between childhood and adult abnormal BP; results are consistent despite variable definitions | Consistent/imprecise | Body of evidence limitations: High; Reporting bias: NA | LOW for association between abnormal BP in childhood and abnormal BP in adulthood | Applicability varies because prevalence of HTN is widely variable
| k=7 publications^7,^ ^58,^ ^59,^ ^61,^ ^64,^ ^66,^ ^70^, N>5,925 | ORs for CIMT: 1.24; HRs range from 2.03 to 3.07; Weak correlations between abnormal BP in childhood and CIMT in adulthood (ranging from 0.04 to 0.16) | Consistent/imprecise | Body of evidence limitations: High; Reporting bias: NA | LOW for CIMT | Applicability varies because prevalence of HTN is widely variable
KQ 5 Effectiveness of interventions | k=13 RCTs^76–88^; N=2476 | Pharmacological interventions; Reductions of SBP for ACE inhibitors: −4.38 mmHg; ARBs: −3.07 mmHg; Beta blockers: −3.20 mmHg; Calcium channel blockers: −3.10 mmHg; Mineralocorticoid receptor antagonists: −0.12 mmHg; All comparisons with placebo after 2-4 weeks | Consistent/Imprecise | Body of evidence limitations: Moderate; Reporting bias: Not detected | MODERATE for benefit | Applies to children and adolescents age 6 to 18 years with BP above the 95th percentile; severe hypertension and secondary hypertension were excluded from most studies; study durations up to 4 weeks; no long-term studies
| k=1 RCT^89,^ ^96^; N=141 | Pharmacological + lifestyle intervention; Statistically significant reductions of SBP (−7.6 mmHg) and DBP (−6.9 mmHg) compared with control after 6 months | Consistency unknown (single study body of evidence)/Precise | Body of evidence limitations: High; Reporting bias: Not Detected | LOW for benefit | Applies to children and adolescents age 8 to 18 years with BP above the 90th percentile
| k=2 RCTs^93,^ ^94^; N=313 | Low sodium diet; No clinically relevant differences in DBP or SBP compared with control | Consistent/Imprecise | Body of evidence limitations: Moderate; Reporting bias: Not detected | MODERATE for no benefit | Applies to children and adolescents age 11 to 18 years with BP above the 85th percentile
| k=1 RCT^90^; N=57 | DASH diet; Statistically significant reduction of SBP (−2.2 mmHg; p<0.01) and DBP (−2.8 mmHg; p<0.05) at the end of intervention (3 months) compared with control; At 6-month followup, similar BP measurements between treatment and control group (SBP, 120.1 vs. 120.0; DBP, 75.2 vs. 76.4) | Consistency unknown (single study body of evidence)/Imprecise | Body of evidence limitations: Moderate; Reporting bias: Not detected | LOW for benefit | Applies to children and adolescents age 11 to 18 years with BP above the 90th percentile
| k=2 RCT^91,^ ^92^; N=109 | Physical exercise; Statistically significant reductions in SBP (−4.9 mmHg; p<0.05) and DBP (−3.8 mmHg; p<0.05) in children age 9 to 11 years after 8 months.; Statistically significant reduction in SBP (−8.3 mmHg; p<0.05) but not DBP (data not reported) in obese adolescent girls after 3 months. | Consistent/Imprecise | Body of evidence limitations: Moderate; Reporting bias: Not detected | LOW for benefit | Applies to children age 9 to 11 years with BP above the 95th percentile and obese adolescent girls with elevated BP
| k=1 RCT^95^; N=159 | Progressive muscle relaxation; No clinically relevant differences in SBP or DBP compared with control | Consistency unknown (single study body of evidence)/Imprecise | Body of evidence limitations: Moderate; Reporting bias: Not detected | LOW for no benefit | Applies to children and adolescents age 13 to 17 years with BP above the 85th percentile
KQ 6 Effectiveness of interventions on intermediate outcomes in adulthood | k=0
KQ 7 Effectiveness of interventions on health outcomes in adulthood | k=0
KQ 8 Harms of interventions | 6 RCTs^76–79,^ ^81^; N=909 | Pharmacological interventions; Similar risks of overall adverse events between pharmacological treatments (beta blocker, calcium channel blockers, ACE inhibitors, or ARBs) and placebo over 2 to 4 weeks. | Consistent/Very imprecise | Body of evidence limitations: Moderate | LOW for similar harms | Applies to children and adolescents age 6 to 18 years with BP above the 95th percentile; severe hypertension and secondary hypertension were excluded; study durations up to 4 weeks; no long-term studies
| 1 RCT^89^; N=150 | Pharmacological treatments combined with lifestyle Interventions; Similar risks of overall adverse events between pharmacological treatment (propranolol + chlorothalidone) plus lifestyle interventions and no intervention. | NA/Very imprecise | Body of evidence limitations: Moderate; Indirectness: Propranolol not recommended anymore as first-line treatment | VERY LOW for similar harms | Applies to children and adolescents age 6 to 18 years with BP above the 90th percentile

Abbreviations: ACE=angiotension converting enzyme; ARB=angiotensin receptor blocker; BP=blood pressure; CIMT=carotid intima-media thickness; DASH=Dietary Approaches to Stop Hypertension; DBP=diastolic blood pressure; HR=hazard ratio; HTN=hypertension; k=number of studies; KQ=key question; N=number of participants; NA=not applicable; PPV=; RCT=randomized, controlled trial; SBP=systolic blood pressure; vs.=versus.

We screened 4,588 titles/abstracts and 304 full-text articles and identified 42 studies (43 publications) that met inclusion criteria (Figure 2). We excluded four studies that were in the previous report that did not meet inclusion criteria for this update.^51–54^ Appendix F Table 1 summarizes the reasons why these studies were excluded.

Figure 2 Literature Flow Diagram for Systematic Review of Screening for Hypertension in Children and Adolescents

Abbreviation: KQ=key question.

This figure is a Preferred Reporting of Systematic Reviews and Meta-Analysis (PRISMA) Tree showing the flow of articles through the systematic review process. In the identification section of the PRISMA, it shows that after duplicates were removed, 3,314 records were identified through database searching. After the title and abstract review (screening section), the eligibility section is depicted. There were 304 full-text articles assessed for eligibility. The eligibility section also depicts that 268 full-text articles were excluded. The reason for exclusion and number of articles excluded is as follows: 1. Not original research: 46 2. Ineligible country: 17 3. Ineligible population: 100 4. Ineligible intervention: 37 5. Ineligible comparator: 7 6. Ineligible outcome: 24 7. Ineligible study design: 23 8. Duplicate or superseded: 3 9. Wrong clinical setting: 3 10. Abstract only: 4 11. Non-English full text: 0 12. Other: 4 The figure shows 43 articles were included related to one or more of the following KQs: KQ1: 0 KQ2: 1 article (new: 1) KQ3: 0 KQ4: 20 articles (new: 8) KQ5: 22 articles (new 2) KQ6: 0 KQ7: 0 KQ8: 7 articles (new: 0)

## Benefits of Screening (Key Question 1)

We identified no studies that examined the direct effect of screening for hypertension in children or adolescents in delaying the onset of or reducing adverse health outcomes related to hypertension.

## Diagnostic Test Accuracy (Key Question 2)

### Key Points

- One fair diagnostic test accuracy study (n=247) reported that the sensitivity of six office-based blood pressure measurements, 1 to 2 weeks apart, was 81.6 percent (confidence interval [CI] not reported) with a specificity of 70.3 percent (CI not reported). The reference standard was ABPM.

### Summary of the Evidence

For the diagnostic test accuracy of blood pressure screening (KQ 2), we identified one fair-quality study.^6^ The U.S.-based SHIP AHOY (Study of Hypertension in Pediatric, Adults Hypertension Onset in Youth) study is an ongoing cross-sectional cohort study to determine blood pressure levels and phenotypes that predict blood pressure–related target organ damage in adolescents. In a sample of the first 247 participants of this study, investigators assessed the diagnostic test accuracy of six blood pressure measurements obtained by auscultation over two visits 1 to 2 weeks apart. The study enrolled healthy volunteers or patients referred for abnormal blood pressure ages 11 to 19 years. Exclusion criteria, among others, were stage 2 hypertension, use of antihypertensive medications, and secondary hypertension. The prevalence of hypertension in this population was 29 percent.

Abnormal blood pressure for office-based measurements was defined according to the Fourth Report.^4^ The reference standard was 26-hour ambulatory monitoring at 20-minute intervals. Abnormal blood pressure for the reference standard was defined based on the AHA recommendations for pediatric ABPM.^42^ Using systolic blood pressure (SBP) at the 90th percentile as a threshold, the sensitivity of two office-based blood pressure measurements was 81.6 percent (CI not reported) with a specificity of 70.3 percent (CI not reported) compared with ABPM.

## Harms of Screening (Key Question 3)

We identified no studies that compared harms of screening in a screened versus an unscreened population.

## Association Between High Blood Pressure in Children and Intermediate Outcomes in Adults (Key Question 4)

### Key Points

- Twenty publications,^7,^ ^10–12,^ ^55–70^ drawing from nine data sources, reported on the association between abnormal blood pressure in childhood and abnormal blood pressure or other intermediate outcomes in adulthood.
- Studies presented measures of association such as odds ratios (ORs), relative risks (RRs), and hazard ratios (HRs) and measures of predictive accuracy such as sensitivity and positive predictive value (PPV). Studies focusing on the association between abnormal blood pressure in childhood and abnormal blood pressure in adulthood generally reported ORs (ranging from 1.1 to 4.5), RRs (ranging from 1.45 to 3.60), and HRs (ranging from 2.8 to 3.2, mean duration of followup ranged from 10 to 33 years), suggesting an association between abnormal blood pressure in childhood and abnormal blood pressure in adults. Results for predictive accuracy measures such as sensitivity and PPVs varied significantly, with sensitivity ranging from 0.0 to 0.89 (with most values below 0.6) and PPVs ranging from 0.05 to 0.97 (again with most values below 0.6).
- Studies reported associations between abnormal blood pressure in childhood and CIMT in adulthood (OR, 1.24 [95% CI, 1.13 to 1.37], mean duration of followup was 25 years; HRs ranged from 2.03 to 3.07, duration of followup ranged from 10 to 21 years; correlation coefficients ranged from 0.04 to 0.16, duration of followup ranged from 21 to 31 years).
- Studies also reported associations between abnormal blood pressure during childhood and left ventricular hypertrophy (ORs ranged from 1.30 to 1.59, mean duration of followup was 25 years; HRs ranged from 1.92 to 3.41; duration of followup ranged from 10 to 21 years).
- Limited evidence found increased risk of subclinical CVD in adulthood (HRs ranged from 2.20 to 3.21) for those with a history of childhood prehypertension or hypertension.
- Limited evidence also found increased risk of microalbuminuria in adults for those with a history of elevated blood pressure in childhood. This effect was observed among African American participants (regression coefficients range from 0.016 to 0.315, mean duration of followup was 16.1 years) but not white participants.

### Summary of the Evidence

We identified 20 relevant publications. One publication pooled data from four databases (Bogalusa Heart Study, Muscatine Study, Cardiovascular Risk in Young Finns Study, and the Childhood Determinants of Adult Health study).^69^ A second publication from the i3C Consortium pooled data from six databases (Bogalusa Heart Study, Muscatine Study, Cardiovascular Risk in Young Finns Study, the Childhood Determinants of Adult Health study, the Insulin Study, and the Kaunas Study).^70^ All others were analyses of cohorts drawn from single databases. Specifically, 18 drew from six data sources (4 based in the United States [1 unnamed cohort of school children in Boston, MA,^55^ the Fels Longitudinal Study,^10,^ ^56^ Bogalusa,^7,^ ^57–61^ and Muscatine^62,^ ^63^] 1 based in Finland [Young Finns^11,^ ^12,^ ^64–67^], and 1 based in New Zealand [the Dunedin Multidisciplinary Health and Development Study^68^]).

Ten publications^7,^ ^11,^ ^61,^ ^62,^ ^65–70^ and three (the Childhood Determinants of Adult Health study, the Insulin study, and the Kaunas study) databases are new to this update (Appendix E Tables 1 to 3). The evidence base is marked by substantial heterogeneity across and within data sources; publications even within the same data source do not use consistent criteria for determining hypertension in childhood or adulthood. Participants’ ages vary from 2 to 18 years of age. The duration of followup ranges from 12^55^ to 31 years.^66^ The timing, methods, and thresholds for recording blood pressure and characterizing hypertension also vary in childhood and adulthood. The number of measurements in childhood vary from a single measure (selecting the second of 2 measurements) to a mean of 6; the measurement interval varies from a single time point to a span of 6 months. Most studies used a standard mercury sphygmomanometer; one also used Hawksley random-zero sphygmomanometers.^55^

Although most studies reported on systolic, diastolic, or blood pressures above a prespecified threshold, the definition of hypertension in childhood varied, as did the reference standard. Threshold values for hypertension in childhood ranged from >75th percentile to >99th percentile. The reference standards for the threshold also varied: some were cohort specific, some were based on standardized data, and some were not specified. The timing, methods, and thresholds of outcome measures in adults similarly varied within and across data sources. Measures of association between childhood hypertension measures and adult outcomes varied and included PPV, sensitivity, specificity, or areas under the receiver operating characteristics curve, risk ratios, HRs, regression coefficients, and correlation coefficients. Finally, publications reported on both cohort-wide associations and associations within subgroups defined by age, sex, and race.

As in the previous review, we did not rate the quality of these studies but note that the heterogeneity in the evidence base extends to quality as well. All the sources of heterogeneity described above create challenges in interpreting the results and reduce the certainty that can be attached to any conclusions.

As with the previous review, we present results for the association between (1) abnormal blood pressure (elevated blood pressure or hypertension) in children and adults and (2) abnormal blood pressure in children and intermediate outcomes in adults. Given the significant and recent changes in thresholds for defining abnormal blood pressure in children and adults, the synthesis below focuses attention on the definitions most applicable to current clinical practice. Current definitions rely on data from normal-weight children only.^71^ As a result, studies relying on previous definitions that included overweight and obese children may have been likely to identify more severe cases of hypertension than current standards.

In each category of results, we first present findings from publications that use current criteria or previously established criteria for abnormal blood pressure in children and then summarize results that do not use standard criteria. When possible or relevant, we also structure the results to focus on current or recent standards for abnormal blood pressure in adults first, followed by nonstandard definitions. Table 3 maps the evidence against childhood and adult standards.

Table 3 Evidence Map of Studies Examining the Association Between Childhood and Adult Hypertension

Standard | Current Adult Hypertension Standards^a^ | Prior Adult Hypertension Standards^b^ | Nonstandard Adult Hypertension Definitions
Current childhood hypertension standards ^2^ | 1 publication,^7^ n=3,940; RRs range from 1.45 to 1.66 (all statistically significant) | 1 publication,^7^ n=3,940; RRs range from 1.62 to 1.98 (all statistically significant) | 0 publications
Prior childhood hypertension standards ^4^ | 2 publications;^7,^ ^67,^ ^69^ n>5,480; RRs range from 1.49 to 1.65 (all statistically significant); Sensitivity range: 0.55 to 0.56; Specificity range: 0.63-0.64; PPV range: 0.53-0.73 | 6 publications;^7,^ ^12,^ ^61,^ ^65,^ ^66,^ ^68^ n>4,127; RRs range from 1.53 to 1.95 (all statistically significant); HRs: 2.8 to 3.2 (all statistically significant); PPV range: 0.11 to 0.58; AUC range: 0.60 to 0.63; Sensitivity range: 0.05 to 0.37; Specificity range: 0.87 to 0.99 | 1 publication;^11^ n=2,625; OR: 2.12 (95% CI, 1.82 to 2.61)
Nonstandard childhood hypertension definitions | 0 publications | 0 publications | 7 publications;^10,^ ^55–57,^ ^60,^ ^62,^ ^63^ n=4,790; ORs and RRs range: 1.1 to 9.0, generally excluding the null; Sensitivity: 0 to 0.66; Specificity range: 0.77 to 1.00

a Abnormal BP defined as SBP>120mmHg and DPB>80 mmHg or self-reporting of antihypertensive medication use.^3^

b Hypertension defined as SBP≥140 mmHg or DBP ≥90 mmHg or self-reported antihypertensive medication use.^73^

Abbreviations: AUC=area under the receiver operating characteristic curve; CI=confidence interval; DBP=diastolic blood pressure; HR=hazard ratio; n=number; OR=odds ratio; PPV=positive predictive value; RR=relative risk; SBP=systolic blood pressure.

#### Association Between Abnormal Blood Pressure in Children and Abnormal Blood Pressure in Adults

##### Association Between Abnormal Blood Pressure in Children and Abnormal Blood Pressure in Adults Using Current Definitions of Childhood Hypertension

One publication, drawing from the Bogalusa Heart Study,^7^ followed 3,940 children over 25 years, on average. The publication used the 2017 AAP guidelines^2^ to categorize study participants as having elevated blood pressure, being hypertensive, or being normotensive and assessed the RR of adult hypertension, as defined by the current AHA standards.^3^ The publication reported that children with elevated blood pressure had an adjusted RR of 1.45 (95% CI, 1.30 to 1.61) for developing hypertension as adults. For children with hypertension, the adjusted RR was 1.66 (95% CI, 1.47 to 1.87). The study reported similar results when adult hypertension was defined using the Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure criteria.^72^ Specifically, children with elevated blood pressure had an adjusted RR of 1.62 (95% C1, 1.35 to 1.95) for developing hypertension as adults. For children with hypertension, the adjusted RR was 1.98 (95% CI, 1.45 to 2.39).

##### Association Between Abnormal Blood Pressure in Children and Abnormal Blood Pressure in Adults Using Prior Standardized Definitions of Childhood Hypertension

Nine publications from five data sources (Cardiovascular Risk in Young Finns,^11,^ ^12,^ ^65–67^ Bogalusa Heart Study,^7,^ ^61^ the Dunedin Multidisciplinary Health and Development Study,^68^ and one pooled analysis of the Bogalusa Heart Study, Muscatine Study, Young Finns Study, and the Childhood Determinants of Adult Health study)^69^ relied on prior standards (the Fourth Report)^4^ in reporting on the association between childhood hypertension or prehypertension and adult hypertension.

Among the publications relying on prior standards (the Fourth Report definitions for abnormal childhood blood pressure), publications varied in their definitions of adult hypertension, even when drawing from the same data source.^4^ Adult hypertension was defined using current AHA standards,^3,^ ^7^ prior standards,^73^ and nonstandard definitions.

Overall, we found consistent results for associations between abnormal blood pressure in childhood and abnormal blood pressure in adulthood, regardless of the definition of hypertension and method of measurement. Results from other databases also support a consistent association between abnormal blood pressure in childhood and abnormal blood pressure in adulthood. We present results for current adult hypertension standards, prior standards, and nonstandard definitions below.

Current adult hypertension standards. Three publications used prior childhood standards and current adult standards. One publication of 1,540 adults from the Young Finns Study, followed over 27 years, provided data on blood pressure in children (abnormal blood pressure defined as >90th percentile based the Fourth Report^74^ standards) or adolescents and abnormal blood pressure in adults (abnormal blood pressure defined as SBP>120 mmHg and DBP>80 mmHg or self-reporting of antihypertensive medication use).^67^ This definition of abnormal adult blood pressure corresponds with current adult AHA standards.^3^ Measures of predictive accuracy, specifically, calculated sensitivity (0.55 and 0.56 [i.e., 55 and 56% of adults with abnormal blood pressure had abnormal blood pressure in childhood]) and specificity (0.63 and 0.64 [i.e., 63 to 64% of normotensive adults had normal blood pressure in childhood]) were similar among normal-weight and overweight/obese children, respectively, although the calculated PPV was higher among overweight or obese children (0.73 [i.e., 73% of those with abnormal blood pressure in childhood had abnormal blood pressure in adulthood]) than normal-weight children (0.53 [i.e., 53% of those with abnormal blood pressure in childhood had abnormal blood pressure in adulthood]).

One publication, drawing from the Bogalusa Heart Study,^7^ followed 3,940 children over 25 years, on average. As noted above, this publication presented results using the 2017 standards, but the authors also used the Fourth Report^4,^ ^74^ standards to categorize study participants as prehypertensive, hypertensive, or normotensive and assessed the RR of adult hypertension, as defined by the current AHA standards.^3^ The results are presented here for completeness. The publication reported that children with prehypertension had an adjusted RR of 1.49 (95% C1, 1.34 to 1.65) for developing hypertension as adults. For children with hypertension, the adjusted RR was 1.71 (95% CI, 1.48 to 1.98).

One analysis pooled results from four databases (Bogalusa Heart Study, Muscatine Study, Young Finns Study, and the Childhood Determinants of Adult Health study, and used the Fourth Report to define childhood abnormal blood pressure and standards consistent with current AHA standards for adult abnormal blood pressure.^4,^ ^69^ The PPV was 0.60; in other words, 60 percent of children with abnormal blood pressure had abnormal blood pressure in adulthood.

Prior adult hypertension standards. One publication, drawing from the Bogalusa Heart Study,^7^ followed 3,940 children over 25 years, on average, and as described above, presented results using current adult standards. The publication also used the Fourth Report^4,^ ^74^ standards to categorize study participants as prehypertensive, hypertensive, or normotensive and assessed the RR of adult hypertension, as defined by the Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure criteria.^72^ The publication reported that children with prehypertension had an adjusted RR of 1.53 (95% C1, 1.28 to 1.82) for developing hypertension as adults. For children with hypertension, the adjusted RR was 1.95 (95% CI, 1.55 to 2.46).

One study comprising two publications,^12,^ ^65^ also drawing from the Young Finns Study, enrolled 3,596 children in Finland age 3 to 18 years and provided followup for 2, 204 participants 27 years later. Adult hypertension was defined as SBP≥140 mmHg or DBP ≥90 mmHg or self-reported antihypertensive medication use. This definition is consistent with prior hypertension standards for adults.^73^ The study reported that being prehypertensive or hypertensive (as defined by the Fourth Report^74^ thresholds) as adolescents or children is associated with an OR of adult hypertension ranging from 2.1 to 2.8 (the specific odds vary by age and sex). In other words, the odds of being hypertensive as an adult are more than twice as high for hypertensive than normotensive children. The PPV for age 6 to 18 years is 0.44, with a sensitivity of 0.1 and a specificity of 0.97.^12,^ ^65^ In general, PPVs and sensitivities increase with the age of the child. PPV ranges from a low of 0.11 at age 6 to a peak of 0.58 at age 12.

Another publication from the Young Finns data source^66^ tracking 1,927 participants over an average of 29 years used the Fourth Report^74^ standards for prehypertension or hypertension and prior standards for adult hypertension.^73^ This publication reported similar AUCs (area under curve) regardless of number of observations of abnormal blood pressure in childhood (AUCs range from 0.60 to 0.63).

The results for overall predictive accuracy from the Young Finns Study are consistent with the findings from the Dunedin Multidisciplinary Health and Development Study^68^ and the Bogalusa Heart Study.^61^ The Dunedin sample of 975 participants relied on the Fourth Report^74^ standards for prehypertension (now referred to as “elevated blood pressure”) or hypertension at age 7 and 11 years and prior standards for adults for prehypertension (≥120 mmHg) and hypertension (≥140 mmHg) at age 38. AUCs range from 0.68 to 0.70. Underlying the similarity in AUCs between the two data sources (Young Finns and Dunedin), however, are differences in sensitivity (lower in the Dunedin study, ranging from 0.05 to 0.37) and specificity (higher in the Dunedin study, ranging 0.87 to 0.99) than in the Young Finns Study.

One publication drawing from the Bogalusa Heart Study (n=1, 225 adults, followed over a mean of 27 years) used prior adult standards for hypertension and compared simple and complex definitions of childhood hypertension and prehypertension and their association with adult hypertension (defined as ≥140/90 mmHg or taking antihypertensive medicine).^61^ The authors noted the multiplicity of cutoffs arising from the use of reference standards in the complex definition and the resultant difficulty in interpreting the results. The complex definition of prehypertension used thresholds from ≥90th percentile (or ≥120/80 mmHg) to <95th percentile based on age-, height-, and sex-based blood pressure reference standards of the Fourth Report. The simple definition, by contrast, used a fixed cutoff, modified by age.^a^ The authors reported increased HRs for the presence of adult hypertension (ranging from 2.8 to 3.2, all statistically significant [participants with childhood hypertension were 2.8 times to 3.2 times more likely to develop adult hypertension over the course of the observation period than participants without hypertension]), regardless of how childhood hypertension was defined.

Nonstandard adult hypertension definitions. The odds for adult hypertension when using a nonstandard definition of adult hypertension are similar to the odds for the same outcome when using prior standards. A publication from the Young Finns data source, tracking 2,625 participants over 21 to 27 years for the Fourth Report definition of childhood hypertension and a different threshold for adult hypertension (SBP ≥130 mmHg or DBP ≥85 mmHg or self-reported use of antihypertensive medication), reported an OR of 2.12 (95% confidence interval [CI], 1.82 to 2.61).^11^

##### Association Between Abnormal Blood Pressure in Children and Abnormal Blood Pressure in Adults Using Nonstandardized Definitions of Childhood Hypertension

Despite variations in definitions, all studies were generally consistent in demonstrating an association between abnormal blood pressure in childhood and abnormal blood pressure in adulthood. Seven publications from four data sources reported on the association between childhood hypertension and adult hypertension and used nonstandardized definitions of hypertension, generally relying on a percentile cutoff within their own data source. The data sources included an unnamed cohort of school children in Boston, MA^55^; the Fels longitudinal cohort^10,^ ^56^; the Bogalusa Heart Study^57,^ ^60^; and the Muscatine Study.^62,^ ^63^ One publication using a within-cohort 80th percentile threshold^57^ offered results for multiple thresholds.(75th, 80th, 90th, 95th, or 99th).^55,^ ^60,^ ^62,^ ^63^ Other publications defined abnormal blood pressure as 90th percentile and above in the cohort. Most publications used a within-cohort threshold of 90th percentile to define abnormal blood pressure in adults, with the exception of the two publications from the Fels Study. One Fels publication used a threshold of DBP >90 mmHg,^56^ and the second used a threshold SBP >130 mmHg or DBP >85 mmHg.^10^ Publications reporting associations (ORs and RRs^10,^ ^56,^ ^57,^ ^62,^ ^63^) offered estimates by age of the child, age of the adult, sex, race, and threshold, ranging from 1.1 to 9.0. Although studies did not always report CIs, when reported the intervals generally excluded a null effect. In the case of exceptions (e.g., for boys age 14 to 18 years, OR for hypertension in adulthood; 1.1 [95% CI, 0.5 to 2.4]), it was unclear whether the lack of statistical significance could have been the result of chance or small sample size.^10^

Publications reporting predictive accuracy^55,^ ^60^ reported low sensitivity (0 to 0.66) and relatively high specificity (0.77 to 1.00) by age, sex, and blood pressure threshold value.

#### Association Between Abnormal Blood Pressure in Children and Other Intermediate Outcomes in Adults

Seven publications (6 reported on 2 individual databases [Bogalusa Heart Study^7,^ ^58,^ ^59,^ ^61^ and Cardiovascular Risk in Young Finns Study^64,^ ^66^]; 1 pooled analysis from the iC3 Consortium of 6 databases [Bogalusa Heart Study, Muscatine Study, Cardiovascular Risk in Young Finns Study, the Childhood Determinants of Adult Health study, the Insulin Study, and the Kaunas Study^70^]) examined the relationship between abnormal childhood blood pressure and intermediate outcomes in adults. One publication used current definitions of hypertension in children.^7^ Three publications used the Fourth Report definitions^4,^ ^74^ of hypertension, and the others used other thresholds or did not define the threshold.

##### Association Between Abnormal Blood Pressure in Children and Carotid Intima-Media Thickness in Adults

Six publications assessed CIMT. Two publications, one each from the Bogalusa^61^ and Young Finns databases,^66^ reported on the association between childhood hypertension and adult CIMT using the Fourth Report^4^ thresholds. Additionally, one study presented data pooled across multiple databases^69^ using the Fourth Report^4^ thresholds. Three other publications used other thresholds.^59,^ ^64,^ ^70^ The evidence presentation below first focuses on results using the Fourth Report thresholds, followed by results using other thresholds.

Results using the Fourth Report^74^ thresholds suggest an association between abnormal blood pressure in children and CIMT in adults, although the magnitude is unclear. Specifically, a recent publication from the Bogalusa database (n=1, 225 adults, followed over a mean of 27 years) compared simple and complex definitions (described above) of children with hypertension and prehypertension and their association with adult CIMT.^61^ Both simple and complex definitions suggest a statistically significant association between childhood prehypertension or hypertension and high CIMT in adulthood, with HRs ranging from 2.03 to 3.07.^61^

An exploration of 1,927 participants from the Young Finns Study examined whether the frequency of blood pressure measurement was associated with improved prediction. The authors defined thresholds for abnormal blood pressure (hypertension or prehypertension) based on the Fourth Report.^74^ The authors found weak correlations for the association between childhood SBP and adult CIMT (correlation coefficients ranging from 0.12 to 0.16) for a frequency of one to three measurements of blood pressure; these correlations were statistically significant for all frequencies of blood pressure measurement. Correlation coefficients for childhood DBP and adult CIMT were smaller and ranged from 0.04 to 0.06 for one to three measures; two of the three measures were statistically significant, despite the weak correlation.^66^

One analysis pooled results from four databases (Bogalusa Heart Study, Muscatine Study Young Finns Study, and the Childhood Determinants of Adult Health study) and used the Fourth Report to define childhood abnormal blood pressure and standards consistent with current AHA standards for adult abnormal blood pressure.^69^ The study found that individuals who had elevated blood pressure in both childhood and adulthood had a higher RR of CIMT (RR, 1.76 [95% CI, 1.21 to 2.56]).

Results from publications using thresholds other than the Fourth Report^74^ are inconsistent. One publication pooled results across six databases (n=5,925, mean followup=25.8 years) and used age-, sex-, and study-specific thresholds of 90th percentile to define abnormal blood pressure in children and high CIMT in adults.^70^ For high SBP, the publication reported an OR of 1.24 (95% CI, 1.13 to 1.37). One publication from the Young Finns Study (n=2, 229) found that SBP >80th percentile in adolescence (ages 12 to 18 years) had a small association with the presence of CIMT 21 years later in adulthood (regression coefficient 0.013; p<0.001).^64^ One publication from the Bogalusa database (n=486) found no association between an undefined childhood SBP risk and incidence of CIMT an average of 22 years later in adulthood (highest quartile vs. lower three quartiles, OR, 1 [95% CI, 0.80 to 1.25]).^59^

##### Association Between Abnormal Blood Pressure in Children and Intermediate Outcomes Other Than CIMT in Adults

Three publications from the Bogalusa database^7,^ ^58,^ ^61^ reported on the association between abnormal blood pressure in children and intermediate outcomes other than CIMT in adults. The Bogalusa publications varied in the use of reference standards, size of the sample, and specific outcomes.

One publication, drawing from the Bogalusa database (n=3940),^7^ assessed the association between childhood prehypertension/elevated blood pressure or hypertension and adult hypertension, using the 2017^2^ and the Fourth Report^4^ standards. The publication also reported adjusted RRs for adult left ventricular hypertrophy; these RRs ranged from 1.30 to 1.59, and all results were statistically significant.

One publication drawing from the Bogalusa database (n=1, 225) found significantly higher HRs among children and adolescents with prehypertension or hypertension (using either simple or complex [Fourth Report] definitions) for any subclinical CVD (HRs range from 2.20 to 3.21), left ventricular hypertrophy (HRs range from 1.92 to 3.41), and higher aorta-femoral pulse wave velocity in adulthood (HRs range from 2.22 to 3.51).^61^ Subclinical atherosclerosis was defined as values equal to or greater than the age-, sex-, and race-specific 80th percentile of CIMT.^61^ One publication of 2, 122 children from the Bogalusa Heart Study examined the association of childhood blood pressure (≥90th percentile by age, ethnicity, and sex [assumed to be cohort specific]) with microalbuminuria in adulthood (mean age 26 years).^58^ Among black participants, SBP, DBP, and the annual change in SBP and DBP from childhood to adulthood were independent predictors of development of microalbuminuria (based on regression analysis, regression coefficients range from 0.016 to 0.315). Among white participants, SBP and DBP were not significantly associated with microalbuminuria (regression coefficients range from 0.002 to 0.063).^58^

## Effectiveness of Interventions for Treating High Blood Pressure in Children and Adolescents (Key Question 5)

### Key Points

- Thirteen fair-quality, placebo-controlled, randomized, controlled trials (RCTs) and a meta-analysis^75^ assessing the efficacy of various pharmacological treatments reported greater reductions of SBP and DBP measurements in participants who received pharmacological treatments compared with those treated with placebo.^76–88^ The magnitude of reductions, however, varied, and not all differences reached statistical significance. Pooled reductions in SBP were −4.38 mmHg for angiotensin-converting enzyme (ACE) inhibitors, −3.07 mmHg for angiotensin receptor blockers (ARBs), −3.20 mmHg for beta blockers, −3.10 mmHg for calcium channel blockers, and −0.12 mmHg for mineralocorticoid receptor antagonists. Followup of placebo-controlled periods in these studies was limited to 2 to 4 weeks.
- One fair-quality trial using a combination of a pharmacological treatment with lifestyle interventions reported a statistically significant reduction of SBP (−7.6 mmHg) and DBP (−6.9 mmHg) after 6 months.^89^
- A fair-quality DASH (Dietary Approaches to Stop Hypertension)−type diet (high in fruits, vegetables, and low-fat dairy foods) achieved statistically significant reductions in SBP (−2.2 mmHg) and DBP (−2.8 mmHg) in a completers-only analysis.^90^ The effect, however, did not last beyond the intervention period.
- Two fair-quality RCTs assessing physical exercise reported statistically significant decreases in SBP after 3^91^ and 8 months (−8.3 and −4.9 mmHg, respectively).^92^ Only the study lasting 8 months^92^ reported a significant decrease in DBP (−3.8 mmHg vs. not reported).
- Two fair-quality low-sodium diet^93,^ ^94^ and one fair-quality progressive muscle relaxation^95^ RCTs did not achieve any significant or clinically relevant changes in SBP or DBP.

#### Summary of the Evidence

Twenty RCTs (21 publications) and one meta-analysis assessing treatments for hypertension in children and adolescents met inclusion criteria (Appendix E Tables 4 to 6). Two trials and the meta-analysis are new to this update.^75,^ ^87,^ ^91^ Thirteen trials and the meta-analysis assessed pharmacological treatments,^75–88^ six trials evaluated lifestyle interventions,^90–95^ and one trial assessed a combination of drug treatment and lifestyle intervention.^89,^ ^96^ We did not identify any observational studies that met our inclusion criteria. All trials were of fair methodological quality.

The majority of studies excluded children with known secondary hypertension. Three pharmacological trials^81,^ ^83,^ ^84^ and four trials that assessed different lifestyle interventions^92–95^ included children with hypertension regardless of etiology.^92–95^ Table 4 provides a summary of results for each intervention.

Table 4 Summary of Evidence About Effectiveness of Interventions for Treating High Blood Pressure in Children (KQ 5)

Intervention | No. of Studies and Design (k);; No. of Participants (N) | Duration of Followup | Reductions in Blood Pressure
Pharmacological | k=13 RCTs^76–88^; N>2300 | 2 to 4 weeks | Reductions of SBP were −4.38 mmHg (95% CI, −2.16 to −7.27) for ACE inhibitors, −3.07 mmHg (95% CI, −1.44 to −4.99) for ARBs, −3.2 mmHg (95% CI, +2.23 to −8.69) for beta blockers, −3.1 mmHg (95% CI, +0.45 to −6.52) for calcium channel blockers, and −0.12 mmHg (95% CI, +3.46 to −3.69) for mineralocorticoid receptor antagonists.
Pharmacological + Lifestyle | k=1 RCT.^89^; N=95 | 6 months | Significant reduction of SBP (−7.6 mmHg) and DBP (−6.9 mmHg)
Low-sodium diet | k=2 RCTs^93,^ ^94^; N=313 | 8 weeks and 3 years | No clinically relevant or statistically significant reductions in SBP or DBP
DASH diet | k=1 RCT^90^; N=57 | 3 months | Significant reduction of SBP (−2.2 mmHg) and DBP (−2.8 mmHg) at the end of intervention; No lasting effect 3 months after intervention
Physical exercise | k=2 RCTs^91,^ ^92^; N=109 | 8 months; 3 months | Significant reductions in SBP (−4.9 mmHg) and DBP (−3.8 mmHg); Significant reduction in SBP (−8.3 mmHg) but not DBP (data not reported) in obese adolescent girls
Progressive muscle relaxation | k=1 RCT^95^; N=159 | 9 months | No clinically relevant or statistically significant reductions in SBP or DBP

Abbreviations: ACE=angiotension converting enzyme; ARB=angiotensin receptor blocker; CI=confidence interval; DASH=Dietary Approaches to Stop Hypertension; DBP=diastolic blood pressure; k=number of studies; KQ=key question; N=number of participants; RCT=randomized, controlled trial; SBP=systolic blood pressure.

#### Pharmacological Treatments

##### Study Characteristics

Thirteen RCTs with data on more than 2,300 participants assessed the efficacy of pharmacological interventions, including ACE inhibitors (enalapril,^82^ fosinopril,^81^ lisinopril^83^), ARBs (candesartan,^77^ losartan,^84^ olmisartan,^85^ telmisartan,^79^) beta-blockers (metoprolol succinate ER,^76^ combination of bisoprolol fumarate and hydrochlorothiazide,^80^) calcium channel blockers (amlodipine,^88^ felodipine ER^78^) and mineralocorticoid receptor antagonists (eplerenone^86^). (Appendix E Table 4). Eight RCTs used randomized withdrawal designs;^81–88^ five RCTs employed a concurrent placebo-controlled design.^76–80^ None of the studies provided efficacy outcomes beyond 4 weeks. The number of participants in the studies ranged from 73 to 304; all studies included at least one site in the United States. The majority of participants were male and white. Most studies excluded children or adolescents with severe hypertension (mostly defined as SBP ≥20 mmHg or DBP ≥10 mmHg above the 99^th^ percentile). Only three studies permitted the inclusion of participants with secondary hypertension.^81,^ ^83,^ ^84^ The proportion of children with secondary hypertension in these studies, however, was not reported. Some trials included treatments that are not approved by the Food and Drug Administration (FDA) for the treatment of hypertension in children or used doses that were outside FDA-approved dosing ranges.

##### Results

The meta-analysis included 12 of the 13 RCTs that have been included for this update.^75^ It combined treatment arms of individual drugs regardless of the dose. The study was designed as a network meta-analysis; however, for the purpose of this report we summarize comparisons with placebo only. Because of the star-shaped network, none of these estimates are based on indirect comparisons. Pooled reductions of SBP were −4.38 mmHg (95% CI, −2.16 to −7.27) for ACE inhibitors, −3.07 mmHg (95% CI, −1.44 to −4.99) for ARBs, −3.2 mmHg (95% CI, +2.23 to −8.69) for beta blockers, −3.1 mmHg (95% CI, +0.45 to −6.52) for calcium channel blockers, and −0.12 mmHg (95% CI, +3.46 to −3.69) for mineralocorticoid receptor antagonists. Followup of placebo-controlled periods of all studies was limited to 2 to 4 weeks.

The study that was not included in this meta-analysis assessed candesartan in 240 children and adolescents ages 6 to 17 years.^77^ The followup was 4 weeks. Participants treated with candesartan achieved greater reductions in SBP (−6.56 mmHG [95% CI, not reported]; p<0.001) and DBP (−4.76 mmHG [95% CI, not reported]; p=0.003) than those in the placebo group. More children and adolescents on active treatments achieved blood pressures below the 95th percentile than those on placebo (65% vs. 31%; p=NR).

#### Pharmacological Treatments Combined With Lifestyle Interventions

##### Study Characteristics

One open-label trial (2 publications) with 6 and 30 months followup determined the effectiveness of a combination of a pharmacological treatment with lifestyle interventions compared with no intervention.^89,^ ^96^ The trial (Franklinton Blood Pressure Intervention Study) was conducted from 1979 to 1981 in the United States. It enrolled children and adolescents age 8 to 18 years with blood pressure measurements above the 90^th^ percentile (n=95) who were detected during school-based screening. The intervention consisted of low-dose propranolol/chlorthalidone therapy with an educational program directed toward dietary and exercise modifications for children and parents (i.e., educational materials, cooking classes for parents, individual dietary consultations, pledges, t-shirt rewards).^89^ In addition, the program expanded community availability of low-sodium foods in grocery stores, restaurants, and school lunches and a school-based exercise component.

##### Results

At the 6-month followup, SBP and DBP had decreased significantly (SBP, −7.6 mmHg; p<0.0001; DBP, −6.9 mmHg; p<0.01) compared with the control group. After 30 months of followup, SBP (−3.59 mmHg; p<0.01) and DBP (−1.73 mmHg; p<0.05) were significantly lower in the intervention group compared with the control group. We rated the quality for the 30-month followup as poor because loss to followup was high (40%), and authors conducted an intention-to-treat analysis with last observation carried forward (assuming lasting adherence), which could bias results toward a greater difference between groups.^96^

#### Lifestyle Interventions

##### Study Characteristics

Six RCTs assessed the effectiveness of lifestyle interventions in children and adolescents with elevated blood pressure or hypertension (Appendix E Table 4).^90–95^ Lifestyle interventions included dietary interventions,^90,^ ^93,^ ^94^ progressive muscle relaxation,^95^ and physical exercise.^91,^ ^92^ Studies were conducted in Australia, Denmark, Korea, and the United States and lasted between 8 weeks and 3 years. Four studies were conducted in the 1980s and 1990s.^92–95^ Sample sizes ranged from 40 to 210 participants who were recruited mostly through screening programs at public schools. Blood pressure thresholds to be eligible for enrollment varied between the 80th and 95th percentile adjusted for age, sex, and height.

##### Results

A DASH-type diet (high in fruits, vegetables, and low-fat dairy foods) for mostly overweight adolescents with elevated blood pressure or stage 1 hypertension (n=57) led to a decrease in SBP and DBP measurements compared with a regular hospital-based diet in a completers-only analysis (SBP, −2.2 mmHg; p<0.01; DBP, −2.8 mmHg; p<0.05).^90^ Three months after the intervention, however, average SBP and DBP measurements were similar again between the groups (SBP, 120.1 vs. 120.0; DBP, 75.2 vs. 76.4). Intention-to-treat analyses did not substantially alter results.

Two RCTs that assessed the impact of physical exercise, one from Denmark^92^ and one from Korea,^91^ reported mostly statistically significant decreases in SBP and DBP. The Danish study enrolled children age 9 to 11 years with blood pressure measurements above the 95th percentile (n=69).^92^ The intervention group received three extra lessons a week of the regular school physical education program. Compared with the control group, SBP (−4.9 mmHg p<0.05) and DBP (−3.8 mmHg; p<0.05) decreased significantly after 8 months of the intervention.

The Korean study randomized obese, adolescent girls (n=40) with elevated blood pressure to combined resistance and aerobic exercise for 12 weeks or no exercise.^91^ SBP decreased significantly in the intervention group (−8.3 mmHg; p<0.05), but DBP did not change significantly (data not reported by study).

Low-sodium diet^93,^ ^94^ and progressive muscle relaxation^95^ did not achieve any significant or clinically relevant changes in SBP or DBP.

## Effectiveness of Interventions for Treating High Blood Pressure in Children and Adolescents on High Blood Pressure and Intermediate Outcomes in Adulthood (Key Question 6)

We identified no studies that reported on the effectiveness of treatments for primary childhood hypertension and subsequent reduction of blood pressure or other intermediate outcomes in adulthood.

## Effectiveness of Interventions for Treating High Blood Pressure in Children and Adolsescents on Health Outcomes in Adulthood (Key Question 7)

We identified no studies that reported on the effectiveness of treatments for primary childhood hypertension and subsequent reduction of adverse health outcomes in adulthood.

## Harms of Interventions for Treating High Blood Pressure in Children and Adolescents (Key Question 8)

### Key Points

- Six fair-quality RCTs^76–81^ reported similar risks of adverse events between various pharmacological treatments (beta blocker, calcium channel blockers, ACE, inhibitors or angiotensin receptor blockers [ARBs]) and placebo. The duration of trials, however, was limited to 2 to 4 weeks.
- One fair-quality RCT reported similar risks for adverse events between a combination of pharmacotherapy (low-dose propranolol/chlorthalidone) with lifestyle interventions (dietary and exercise modifications for children and parents) and a control group without treatment over 6 months.^89^

### Summary of the Evidence

Seven RCTs^76–81,^ ^89^ provide results on harms of interventions used to treat children and adolescents with elevated blood pressure or hypertension (Appendix E Table 8). All studies were of fair methodological quality and assessed pharmacological treatments, except one study that assessed pharmacological treatment in combination with lifestyle interventions.^89^ Table 5 provides a summary of results on risk of harms for each intervention.

Table 5 Summary of Evidence About Risk of Harms of Interventions for Treating High Blood Pressure in Children (KQ 8)

Intervention | No. of Studies and Design (k);; No. of Participants (N) | Duration of Followup | Risk of Harms
Pharmacological | k=6 RCTs^76–81^; N=909 | 2 to 4 weeks | Similar risks of overall adverse events between pharmacological treatments (beta blocker, calcium channel blockers, ACE, inhibitors, or ARBs) and placebo over 2 to 4 weeks
Pharmacological + Lifestyle | k=1 RCT^89^; N=95 | 6 months | Similar risks compared with no intervention (no data reported)

Abbreviations: ACE=angiotension converting enzyme; ARB=angiotensin receptor blocker; k=number of included studies; KQ=key question; N=number of participants; RCT=randomized, controlled trial.

#### Pharmacological Treatments

The included RCTs assessed the risk of harms of ER metoprolol succinate,^76^ candesartan,^77^ felodipine ER,^78^ fosinopril,^81^ telmisartan,^79^ and a combination of bisoprolol fumarate and hydrochlorothiazide^80^ based on data for 909 participants. We describe characteristics of these studies in more detail in KQ 5, except for the study by Li et al,^81^ which did not meet eligibility criteria for KQ 5. This dose-ranging RCT allocated 255 children age 6 to 16 years to different doses of lisinopril. Because the treatment phase did not include a placebo arm, the study was not eligible for KQ 5. After 4 weeks of treatment, 221 participants entered a placebo-controlled withdrawal phase that provided data on harms.

Telmisartan and a combination of bisoprolol with hydrochlorthiazide are currently not FDA approved for the treatment of children and adolescents. Some trials included doses that were outside FDA-approved dosing ranges; adverse events, however, were generally reported only for the combined active treatment arms.

Overall, risks of experiencing any adverse event and risks of specific adverse events were similar between active treatments and placebo over 2 to 4 weeks. The only study that reported statistically significant differences in risks of adverse events assessed a combination of bisoprolol with hydrochlorthiazide.^80^ In this study, children in the placebo group had significantly higher risks for adverse events (75% vs. 53%; p=0.047) and serious adverse events (16% vs. 2%; p=0.016) than children on active treatment. This finding is most likely attributable to chance effects because of the small sample size (n=94).

#### Pharmacological Treatments Combined With Lifestyle Interventions

One trial with a 6-month followup of low-dose propranolol/chlorthalidone in combination with an educational program (see more details in KQ 5) compared with no intervention did not report specific data on adverse events.^89^ Authors state that the incidence of adverse events was low in both groups. One participant withdrew from propranolol/chlorthalidone treatment because of nightmares.

#### Lifestyle Interventions

None of the included studies for KQ 5 reported data on adverse events.

a For children (6–11 years), prehypertension was defined as SBP≥110 and/or DBP≥70 mmHg; SBP<120 and DBP<80 mmHg also indicated prehypertension. For adolescents (12–17 years), prehypertension was defined as SBP≥120 and/or DBP≥80 mmHg); SBP<130 and DBP<85 mmHg also indicated prehypertension. Hypertension was defined as SBP≥120 and/or DBP≥80 mmHg for children, and SBP≥130 and/or DBP≥85 mmHg for adolescents.