# Chapter 2 Methods

## Key Questions and Analytic Framework

The EPC investigators, USPSTF members, and AHRQ Medical Officers developed the scope and KQs for this review.

The analytic framework illustrates the KQs that guided the review (Figure 1).

Figure 1 Analytic Framework

*Includes left ventricular hypertrophy, urinary albumin excretion (microalbuminuria), intima media thickness (measured at cartoid and/or femoral arteries), and retinal vascular changes.

Abbreviation: KQ=key question.

This figure is an analytic framework depicting the key questions (KQs) within the context of the populations, interventions, comparisons, outcomes, time frames, and settings (PICOTS) relative to the effectiveness and harms of treatment for depression. The figure illustrates screening of asymptomatic children and adolescents, possible adverse events from screening, detection of elevated blood pressure, diagnostic work up, primary and secondary hypertension, treatments (drug, nondrug, combination, or treatment of underlying condition), adverse events from treatment, blood pressure and other immediate outcomes in childhood, then adulthood, and reduced adverse health outcomes.

1. Does screening for high blood pressure (i.e., persistently elevated blood pressure or hypertension) in children and adolescents delay the onset of or reduce adverse health outcomes related to high blood pressure?
2. What is the diagnostic accuracy of screening tests for high blood pressure in children and adolescents?
3. What are the adverse effects, such as labeling and anxiety, of screening for high blood pressure in children and adolescents?
4. What is the association between high blood pressure in children and adolescents and high blood pressure and other intermediate outcomes in adults?
5. What is the effectiveness of drug, nondrug, and combination interventions for treating high blood pressure in children and adolescents?
6. What is the effectiveness of drug, nondrug, and combination interventions initiated for the treatment of high blood pressure in children and adolescents for reducing blood pressure and improving other intermediate outcomes in adults?
7. What is the effectiveness of drug, nondrug, and combination interventions initiated for the treatment of high blood pressure in children and adolescents for reducing adverse health outcomes related to high blood pressure in adults?
8. What are the adverse effects of drug, nondrug, and combination interventions for treating high blood pressure in children and adolescents?

In addition to our KQs, we also looked for evidence related to four CQs.

1. What is the prevalence of primary and secondary hypertension in asymptomatic children and adolescents in primary care settings?
2. What are the optimal ages at which to start screening for high blood pressure and the optimal time intervals at which to repeat screening in children and adolescents?
3. What are the associations between intermediate outcomes related to high blood pressure in children and adolescents and health outcomes related to high blood pressure in children, adolescents, and adults?
4. What are the effectiveness and adverse effects of drug, nondrug, and combination interventions for treating the underlying conditions of secondary hypertension in children and adolescents?

We do not show these questions in the analytic framework because they were not analyzed using the same systematic review process as the KQs. Findings related to the CQs are summarized in Appendix A.

## Data Sources and Searches

We searched MEDLINE® (via PubMed) for English-language articles published between June 1, 2012, and September 3, 2019, and the Cochrane Library, Embase, and International Pharmaceutical Abstracts for English language articles. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant population, interventions, comparisons, outcomes, timing, and setting elements. Appendix B describes the search strategies in detail. We conducted surveillance of the literature through October 6, 2020.

We conducted targeted searches for unpublished literature by searching Cochrane Reviews, Cochrane Trials, Embase, ClinicalTrials.gov, Health Services Research Projects in Process (HSRProj), and the World Health Organization’s International Clinical Trials Registry Platform. To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies meeting our inclusion criteria and screened all previously unidentified relevant articles. We also manually reviewed all literature suggested by peer reviewers or Federal partners and, if appropriate, incorporate studies into the final review.

Because we extended the population of interest for this update to children and adolescents with secondary hypertension (see below under Study Selection), we rescreened studies that the previous report excluded for “ineligible population” and rescreened articles that a search for “secondary hypertension” in the bibliographic database of the previous report yielded.

## Study Selection

We developed inclusion and exclusion criteria for selecting studies based on populations, interventions, comparators, outcomes, timing, settings, and study designs; these are described in detail in Appendix B Table 3. Based on comments on the 2013 report and discussions with the USPSTF during the scoping phase of this update, we adapted inclusion and exclusion criteria for this update in the following ways:

- We extended the population of interest to children and adolescents with secondary hypertension.
- We excluded pharmacological dose-ranging studies without a placebo control group from the assessment of benefits and harms of treatments (KQ 5 and KQ 8) because assay sensitivity cannot be established without a placebo-controlled design.
- We excluded information from placebo-controlled withdrawal phases of dose-ranging studies for the assessment of harms because participants with serious or intolerable adverse events would have likely dropped out during the prior dose-ranging phase.

Briefly, for this update we included studies of screening for hypertension in asymptomatic children and adolescents. For benefits and harms of treatments or the association between hypertension in children and adolescents and intermediate outcomes in adults we included participants with primary or secondary hypertension or elevated blood pressure. For studies of diagnostic test accuracy, we required a relevant reference standard comparison. For example, we excluded studies that compared single blood pressure measurements with followup measurements after a specific time period. We also excluded studies of interventions for the treatment or prevention of overweight and obesity and interventions for the primary prevention of hypertension. We included intermediate outcomes only if they were closely related to hypertension (e.g., left ventricular hypertrophy, urinary albumin excretion, retinal vascular changes, and CIMT).

We imported all citations identified through searches and other sources into EndNote Version X8 (Clarivate Analytics, Philadelphia).

Two investigators independently reviewed titles and abstracts. We then dually and independently reviewed the full text of all articles that either reviewer marked for potential inclusion at the title/abstract level. We resolved disagreements by discussion and consensus; if necessary, we sought adjudication of conflicts from other experienced members of the review team. Appendix C lists citations and reasons for exclusion for studies that we excluded at the full-text review stage.

In addition to citations from the update literature search, we incorporated citations from studies included in the previous report, which covered the publication period through June 2012.^1^ Using predefined criteria developed by the USPSTF, two investigators independently assessed the quality of each study as good, fair, or poor.^47^ The USPSTF criteria are listed in Appendix D. Disagreements were resolved by discussion and consensus. We rated trials with fatal flaws as poor quality (i.e., high risk of bias).

One team member abstracted pertinent information from each included study including details on study design and the population, interventions, comparisons, outcomes, timing, and setting elements. A second investigator checked all data abstractions for completeness and accuracy. We resolved differences by consensus or adjudication by a third senior investigator. We did not rate the risk of bias of association studies (KQ 4) because risk-of-bias tools are designed to identify potential biases in causal inference.

## Data Synthesis and Analysis

We qualitatively synthesized findings for each KQ by summarizing the characteristics and results of included studies in tabular or narrative format. To determine whether meta-analyses were appropriate, we assessed both the number of trials available and their clinical and methodological heterogeneity following established guidance.^48^ Because of the dearth of data, we were unable to conduct meta-analyses, in addition to the ones that we included from a published systematic review for KQ 5. We assessed the strength of evidence (SOE) based on AHRQ’s Methods Guide for Effectiveness and Comparative Effectiveness Reviews, which specifies the assessment of study limitations, directness, consistency, precision, and reporting bias for each intervention comparison and major outcome of interest.^49^ A senior reviewer initially developed SOE assessments for each relevant outcome. A second senior reviewer checked the SOE ratings; discrepancies were resolved through discussion or the independent assessment of a third senior reviewer. In addition, we assessed the applicability of the evidence for each relevant outcome to a U.S. primary care setting. Although we did not rate the risk of bias of association studies, we used study design criteria to rate the overall body of evidence for these studies.

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF Web site for public comment from June 28, 2018, to July 25, 2018. In response, we revised the inclusion criteria to be more explicit regarding intermediate outcomes, removed a limitation on the sample size of observational studies, and adjusted screening ages to 3 to 18 years to match the AAP’s recommendation. The final version of the research plan was posted on the USPSTF Web site on November 1, 2018.^50^ A draft report was reviewed by three content experts, three representatives of Federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments received. In response to these comments, we included new studies published since the first literature search, included studies with a randomized withdrawal design for assessing the effectiveness of pharmaceutical interventions, and clarified future research needs. The draft evidence report was made available for public comment in April 2020.

## USPSTF Involvement

This review was funded by AHRQ. Staff of AHRQ and members of the USPSTF participated in developing the scope of work and reviewed draft reports, but the authors are solely responsible for the content.