# Chapter 1 Introduction

## Purpose

This report will be used by the United States Preventive Services Task Force (USPSTF) to update its 2013 recommendation on screening for primary hypertension in children and adolescents.^1^ The 2013 recommendation was an update of the 2003 recommendation on this topic and is summarized as follows:

- The USPSTF concluded that the current evidence was insufficient to assess the balance of benefits and harms of screening for primary hypertension in asymptomatic children and adolescents to prevent subsequent cardiovascular disease (CVD) in childhood and adulthood (I statement).

The USPSTF made the 2013 recommendation based on an updated systematic review (search through July 2012) conducted by the Oregon Health & Science University Evidence-based Practice Center (EPC).^1^ The USPSTF issued an I statement because there was no direct evidence available demonstrating that screening for hypertension in children and adolescents reduced adverse health outcomes, and limited evidence existed for assessing the harms of systematic screening. Therefore, the USPSTF could not determine the balance of benefits and harms of screening for hypertension in children and adolescents.

## Condition Definition and Etiology

The newest definitions for abnormal blood pressure for children and adolescents were established by the American Academy of Pediatrics (AAP) in 2017.^2^ For children 1 to 13 years of age, hypertension is defined as three auscultatory blood pressure measurements at three different visits that are above the 95th percentile based on age, height, and sex or above 130/80 mmHg (millimeters of mercury), whichever is lower. AAP defines Stage 1 hypertension as blood pressure between the limits listed above and the limits for Stage 2 hypertension. Stage 2 hypertension for children 1 to 13 years of age is defined as the 95th percentile for children of a given age, height, and sex plus 12 mmHg or 140/90 mmHg, whichever value is lower. AAP defines elevated blood pressure (previously termed “prehypertension”) for children 1 to 13 years as between 90th and 94th percentile for a given age, height, and sex, or 120-129/<80 mmHg, whichever value is lower.^2^

Thresholds for adolescents 13 years of age and older now mirror those guidelines of the 2017 American Heart Association (AHA) and American College of Cardiology for adults regardless of height and sex.^3^ Stage 1 hypertension for children age 13 years or older is 130-139/80-89 mmHg. Stage 2 hypertension for children age 13 years or older is >140/>90 mmHg. Elevated blood pressure for children age 13 years or older is defined as 120 to 129/<80 mmHg. For all age groups, blood pressure should be taken in the right arm with an appropriately sized cuff. The AAP recommends that the diagnosis should be confirmed by ambulatory blood pressure monitoring (ABPM), although it is not required to make a diagnosis. Confirmatory ABPM uses a portable measuring device in the home setting to take blood pressure measurements every 20 to 30 minutes over a designated period of time, often 24 hours. It can be used to rule out white coat hypertension and confirm a diagnosis of hypertension in those that have either had 1 year of elevated blood pressures or three different occasions of elevated blood pressures in the clinical setting.^2^

Table 1 summarizes current blood pressure thresholds for diagnosing abnormal blood pressure in children.

Table 1 Blood Pressure Thresholds^*^ for Diagnosing Hypertension in Children based on the American Academy of Pediatrics^2^

Age | Elevated BP | Stage 1 Hypertension | Stage 2 Hypertension
1-<13 years | 90-94 percentiles; or; Systolic: 120-129 mmHg; Diastolic: <80mmHg (whichever is lower) | 95 percentiles to 95 percentiles +11 mmHg; or; Systolic: 130-139 mmHg; Diastolic: 80-89 mmHg (whichever is lower) | ≥95 percentiles +12 mmHg; or; Systolic: ≥140 mmHg; Diastolic: ≥90 mmHg (whichever is lower)
≥13 years | Systolic: 120-129 mmHg; Diastolic: <80mmHg | Systolic: 130-139 mmHg; Diastolic: 80-89 mmHg | Systolic: ≥140 mmHg; Diastolic: ≥90 mmHg

* All thresholds are defined as at least three independent auscultatory blood pressure readings.

Abbreviation: BP=blood pressure.

Prior to the publication of the 2017 AAP guideline, clinicians followed the 2004 “Fourth Report on Diagnosis, Evaluation, and Treatment of High Blood Pressure in Children and Adolescents” (“Fourth Report”)^4^; the 2011 National Heart, Lung, and Blood Institute’s guidelines used the same diagnostic thresholds and percentile as the Fourth Report.^5^ In contrast to the Fourth Report, the 2017 guideline (1) uses the term “elevated blood pressure” rather than “prehypertension”; (2) uses new normative values for blood pressure by age, height, and sex from only normal-weight individuals rather than including overweight and obese individuals as well; (3) uses absolute blood pressure thresholds rather than percentiles for teenagers; and (4) calls for a greater role for ABPM in diagnosis.^6^ One 2018 study found that in the same adolescent study population, 27 percent would be diagnosed with systolic hypertension by the 2017 guidelines compared with 16 percent based on the Fourth Report.^6^ Another study using data from the Bogalusa Heart Study found that compared with thresholds from the Fourth Report the new reference standard (2017 guidelines) resulted in a reclassification of 8 percent of children to higher blood pressure categories and a reclassification of 1 percent to lower blood pressure categories.^7^ The newly reclassified children with abnormal blood pressure were more likely than their propensity score–matched normotensive counterparts to develop hypertension in adulthood, whereas the children reclassified to lower blood pressure categories had similar adult hypertension outcomes to their propensity score–matched normotensive counterparts.

## Etiology and Natural History

Primary hypertension, by definition, does not have an identifiable cause. Secondary hypertension in children is most commonly caused by renal or renovascular disease; it can also be caused by congenital cardiac abnormalities such as aortic coarctation, endocrine disorders, environmental exposures, medications, neurofibromatosis, and other genetic disorders.^8^

Children with primary hypertension are more likely than normotensive children to develop hypertension in adulthood.^9–12^ They are also more likely to develop intermediate cardiovascular outcomes, such as as increased left ventricular mass, carotid intima-media thickness (CIMT), and increased pulse wave velocity.^9^ The association between intermediate outcomes in childhood and health outcomes in adulthood, however, is unclear. These risks are discussed in greater detail below in Key Question (KQ) 4 and Contextual Question (CQ) 3 (Appendix A).

Untreated secondary hypertension can lead to similar sequelae as those of primary hypertension. In addition, untreated underlying secondary causes of hypertension can lead to serious sequelae related to their etiologies. For example, untreated renal artery stenosis, a leading cause of secondary hypertension, can lead to renal failure.

## Prevalence and Burden of Disease/Illness

The overall reported prevalence of hypertension (both primary and secondary) in children and adolescents ranges in studies from 0.54 percent to 29 percent, with most studies reporting between 3 percent to 4 percent of children having hypertension.^13–17^ These data come from observational studies from a variety of settings, including a primary care network, insurance program, health care system, and schools.

Prevalence is higher in children and adolescents who are overweight and obese. Prevalence is also higher in African American and Hispanic children compared with non-Hispanic white children. One small study suggests that approximately half of children with hypertension have primary hypertension; children age 13 years or older are more likely to have primary hypertension (60%), while those under age 6 years are less likely to have primary hypertension (17%).^18^ Greater detail is provided in Appendix A.

The prevalence cited above may underestimate the actual prevalence for children age 13 years or older because it is based on studies conducted before the adoption of uniform definitions in 2017. The thresholds for high blood pressure with the new uniform definitions are lower than the previous thresholds, which were placed at the 95th percentile for children of a given age, height, and sex. However, the new 2017 uniform definitions result in thresholds that are slightly higher than measurements at the 95th percentile for younger adolescents of a given age and sex at lower heights.

## Risk Factors

Children with family histories of hypertension are 2 to 3 times as likely to develop primary hypertension.^19,^ ^20^ Children with specific chronic conditions are also at higher risk of developing hypertension. Obesity is a common comorbid condition with hypertension in children, with prevalence rates estimated between 3.8 percent and 20.2 percent in children with obesity (body mass index greater [BMI] greater than 95th percentile for age and sex).^21–24^ Children with a BMI at the 95th to 98th percentile are 2 times as likely to develop hypertension as their normal-weight peers.^25^ Rates of hypertension increase in relationship to increasing BMI.^21–24,^ ^26^ Children with sleep-disordered breathing (including snoring, sleep fragmentation, and obstructive sleep apnea) are approximately 3 times as likely to develop hypertension, and a higher severity correlates with higher risk.^9,^ ^27,^ ^28^ Children born prematurely or with low birth weight also have a higher prevalence of hypertension (7.3%) than their term and normal birth weight peers.^29–33^

Chronic kidney disease is the most common cause of secondary hypertension, and it increases the risk of hypertension considerably. Approximately half of children and adolescents with chronic kidney disease are hypertensive, and the proportion is higher for those with end-stage kidney disease. Between 34 percent and 79 percent of patients with secondary hypertension have a structural renal abnormality, while 12 percent to 13 percent have renovascular disease.^31,^ ^34,^ ^35^ Nearly 20 percent of pediatric hypertension may be attributable to chronic kidney disease.^36^ Infants and young children with hypertension are more likely to have an underlying renal etiology, while adolescents with hypertension are more likely to have primary hypertension.

## Rationale for Screening

Some studies have found that children with hypertension have early signs of intermediate cardiac outcomes that have been shown to predict cardiovascular events in adults, such as increased left ventricular mass, CIMT, and pulse wave velocity.^37–39^ Screening for hypertension in childhood may lead to earlier treatment, therefore reducing the risk of adult hypertension as well as cardiovascular complications resulting from hypertension. In addition, given higher rates of secondary hypertension in children than in adults, screening for hypertension in childhood may lead to diagnosis of underlying etiologies that are amenable to treatment, thus preventing nonhypertensive sequelae related to those etiologies.

For the purposes of this report, screening for hypertension involves measuring blood pressure using an oscillometric (automated) or auscultatory (manual) method and is conducted by a qualified health care professional. Diagnosis of hypertension requires confirmation of elevated blood pressure above diagnostic thresholds on three separate occasions by qualified health care professionals because blood pressure can be temporarily elevated at any given time by inappropriate cuff size, patient nervousness (“white coat hypertension”), recent physical activity, recent medications, or pain. To establish a diagnosis, blood pressure should be measured using auscultation because blood pressure norms are based on auscultatory measurement, and oscillometric devices overestimate both SBP and diastolic blood pressure (DBP).^8,^ ^40^

## Treatments/Interventions

Treatments for hypertension in children and adolescents vary depending on severity, associated symptomatology, and comorbidities. It is unknown whether treatment efficacy or harms vary by age. Lifestyle changes, including dietary and physical activity changes, may be effective for patients with asymptomatic, less severe hypertension without evidence of comorbidities (such as diabetes or chronic kidney disease). Studies have supported the effectiveness of the Dietary Approaches to Stop Hypertension (DASH), which emphasizes high intake of fruits, vegetables, whole grains, and lean meats, in addition to low sodium and low sugar intake. Moderate to vigorous physical activity 3 to 5 times each week has been shown to help lower blood pressure. Stress reduction activities can also be effective in decreasing blood pressure.^2^

Children and adolescents with hypertension refractory to lifestyle changes, symptomatic hypertension, or comorbidities may require pharmacologic interventions. Classes of antihypertensives include angiotensin converting enzyme (ACE) inhibitors, angiotensin II receptor blockers (ARBs), beta blockers, central alpha-agonists, diuretics, and vasodilators. Treatment choices are generally guided by response to medications or a patient’s comorbidities.^2^

## Current Clinical Practice

Current screening practices vary. Bright Futures, the AAP’s preventative care guide, has recommended routine blood pressure screening for children 3 years of age or older since its first edition was published in 1994.^41^ This may have led to routine screening as commonplace in many pediatrics offices. Currently, many pediatricians follow the most recent AAP 2017 clinical practice guideline to begin screening all patients for hypertension at least annually and high-risk patients at each visit beginning at 3 years of age.^2^ This guideline recommends ABPM (citing USPSTF’s most recent adult blood pressure recommendations) for the confirmation of hypertension in children and adolescents; however, it is unknown how frequently this is being implemented. The AHA,^42^ National Heart, Lung, and Blood Institute,^5^ National High Blood Pressure Education Program,^4^ Hypertension Canada,^43^ and European Society of Hypertension^44^ recommend routine screening starting at age 3 years. The American Academy of Family Physicians^45^ and UK National Screening Committee^46^ guidelines cite insufficient evidence for or against routine screening. These guidelines were all based on systematic evidence reviews that were reviewed by panels of experts to develop the guidelines.