# Appendix F Summary of Excluded Studies

Appendix F Table 1 Studies Included in 2013 AHRQ Report and Excluded From This Review

Key Question | Author (Year) | Exclusion Reason
KQ 2 (Diagnostic Test Accuracy) | Fixler & Laird (1983)^51^; Stergiou (2008)^52^ | Wrong comparator (two additional hypertension measurements); Poor quality (excluded participants with very high blood pressure during the course of the study)
KQ 3 (Harms of Screening) | Stenn (1981)^53^ | Wrong population (control group was students who were screened but normotensive)
KQ 5 (Effectiveness of Interventions) | Flynn (2004)^142^ Gregoski (2011)^54,^ ^86^ | Wrong population (needed a resting SBP between the 50th and 95th percentiles)
KQ 6 (Intermediate Outcomes) | Li (2010)^86^ | Wrong comparator (dose-ranging studies with no placebo control group)
KQ 8 (Harms of Treatment) | Flynn (2004)^142^; Hazan (2010)^85^; Shahinfar (2005)^84^; Soffer (2003)^83^; Wells (2002)^82^; Li (2010)^86^ | Wrong comparator (dose-ranging studies with no placebo control group); Wrong comparator (dose-ranging studies with no placebo control group); Wrong comparator (dose-ranging studies with no placebo control group); Wrong comparator (dose-ranging studies with no placebo control group); Wrong comparator (dose-ranging studies with no placebo control group); Wrong comparator (dose-ranging studies with no placebo control group)

Abbreviation: KQ=key question; SBP=systolic blood pressure.