# Appendix E Evidence Tables

Appendix E Table 1 Diagnostic Accuracy of Screening for Elevated Blood Pressure in Children and Adolescents (KQ 2)

Appendix E Table 2 Tracking Hypertension and Other Outcomes From Childhood to Adulthood (KQ 4)—Part 1

Appendix E Table 3 Tracking Hypertension and Other Outcomes From Childhood to Adulthood (KQ 4)—Part 2

Appendix E Table 4 Tracking Hypertension and Other Outcomes From Childhood to Adulthood (KQ 4)—Part 3

Appendix E Table 5 Study Characteristics and Results From RCTs Assessing the Effectiveness of Treatment of Abnormal Blood Pressure in Children and Adolescents (KQ 5)—Part 1

Appendix E Table 6 Study Characteristics and Results From RCTs Assessing the Effectiveness of Treatment of Abnormal Blood Pressure in Children and Adolescents (KQ 5)—Part 2

Appendix E Table 7 Study Characteristics and Results From RCTs Assessing the Effectiveness of Treatment of Abnormal Blood Pressure in Children and Adolescents (KQ 5)—Part 3

Appendix E Table 8 Study Characteristics and Results From RCTs Assessing the Adverse Effects of Treatment of Abnormal Blood Pressure in Children and Adolescents (KQ 8)